# Appendixes

Appendix A Technical Experts and Peer Reviewers

Appendix B Hand Searched Journals

Appendix C Detailed Search Strategies

Appendix D List of Excluded Articles

Appendix E Feedback Forms

Appendix F Reviewer Comments

Appendix G Evidence Tables