# Acronyms

ACCE: Analytic validity, Clinical validity, Clinical utility and Ethical, legal and social implications
AHRQ: Agency for Healthcare Research and Quality
APC: Activated protein C
AS-PCR: Allele-specific polymerase chain reaction
CDC: Center for Disease Control and Prevention
CI: Confidence interval
CISMEL: Italian Committee for Standardization of Laboratory Tests
DNA: Deoxyribonucleic acid
DVT: Deep venous thrombosis
EGAPP: Evaluation of Genomic Applications in Practice and Prevention
ELATE: Extended Low-Intensity Anticoagulation for Unprovoked Thromboembolism
ELISA: Enzyme-linked immunosorbent assay
EPC: Evidence-based Practice Center
EPCOT: European Prospective Cohort on Thrombophilia
FDA: Food and Drug Administration
FRET: Fluorescent resonance energy transfer
FVL: Factor V Leiden
GRADE: The Grading of Recommendations Assessment, Development and Evaluation
HR: Hazard ratio
ICER: Incremental cost-effectiveness ratio
INR: International normalized ratio
MeSH: Medical Subject Heading
M-H: Mantel-Haenszel
PCR: Polymerase chain reaction
PCR-RFLP: Polymerase chain reaction and restriction fragment length polymorphism
PE: Pulmonary embolism
PT 20210A: Prothrombin G20210A
QA: Quality assurance
QALY: Quality-adjusted life year
READIT: Reversed Enzyme Activity DNA Interrogation Test
STARD: Standards of Reporting of Diagnostic Accuracy
TEP: Technical Expert Panel
TGCE: Temperature gradient capillary electrophoresis
THRIVE: Thrombin Inhibitor in Venous Thromboembolism
UK NEQAS: United Kingdom National External Quality Assessment Scheme
VTE: Venous thromboembolism