# Acknowledgments

The EPC thanks Renee F. Wilson, Dr. Olaide Odelola, and Ritu Sharma for their assistance with the final assembly and formatting of this report, and Dr. Gurvaneet Randhawa for his valuable insight.