# Evidence Tables

Evidence Table 1: Biologic markers: Fetal fibronectin - Study design

Author (Year) | Research Objective | Study Design & Masking | Definition of Preterm Labor | Patient Inclusion/Exclusion Characteristics | Sample SizeInitial/End | | | Demographic Characteristics | | | Biologic Markers Intervention | Uniform Adjunctive Drug Intervention | Uniform Non-Drug Intervention | Country & Time Period | Quality Scores
Author (Year) | Research Objective | Study Design & Masking | Definition of Preterm Labor | Patient Inclusion/Exclusion Characteristics | Pos | Neg | Cx | Pos | Neg | Cx | Biologic Markers Intervention | Uniform Adjunctive Drug Intervention | Uniform Non-Drug Intervention | Country & Time Period | Quality Scores
Lockwood CJ, Senyei AE, Dische MR, et al. ^101^ | To relate the presence of fFN to the risk of preterm birth | Prospective cohort study; Masking: Subject: dk Physician: yes | No definition provided | EGA: <37 wks Intact membranes Contractions Also no: placenta previa, congenital anomalies, intercourse in last 24 h, previous preterm birth | 117/117 | | | | | | Fetal fibronectin >50 ng/mL | Tocolysis: IV magnesium sulfate, IV, subcutaneous or oral beta-mimetic therapy; Tx at doctor discretion | | Country: United States Time period: dk | M=92% C=54%
  59 | 58
Iams JD, Casal D, McGregor JA, et al. ^103^ | To investigate the utility of cervicovaginal expression of fFN in the diagnosis of PTL | Prospective cohort study; Masking: Subject: dk Physician: yes | Suspected amniorrhexis or uterine activity or abdominal discomfort, or change in vaginal discharge or bleeding or cramping | EGA: 24-34 wks Intact membranes Being seen for unscheduled obstetric care Also no: cerclage, dilation >3 cm, placenta previa, uterine anomaly, abruptio placentae | 45/147 | | | Mean Age (SD) 25 (6) Race White: 48% Black: 16% Hispanic: 31% Other: 5% | | | fFN >50 ng/mL CoT: presentation at unscheduled visit | Tocolysis: AoT: to treat change in cervical dilation & persistent uterine activity | | Country: North America Time Period: dk | M=88% C=76%
Irion O., Matute J, Bischof P ^104^ | To assess the relationship between a positive fFN test & premature birth in women susceptible of preterm birth | Prospective cohort study; Masking: Subject: dk Physician: yes | Contractions: regular & >6/hr | EGA: 24-36 wks Intact membranes Also no: bleeding, dilatation >2 cm, "fetal pain," medically indicated preterm birth, intercourse w/ in 24 h | 70/64 | | | Mean Age (SD) | | | Fetal fibronectin pos cutoff: dk CoT: at hospitalization | Tocolytic: hexoprenaline AoT: to treat persistent uterine activity & modification of the cervix | | Country: dk Time period: 1991-1993 | M=76% C=66%
  26 | 38
  28.1 | 29.6
  (4.3) | (5.6)
Malak TM, Sizmur F, Bell SC, et al. ^105^ | To investigate whether fFN is a predictor for preterm birth | Prospective cohort study; Masking: Subject: dk Physician: dk | Contractions: painful or cramps & pelvic pressure w/backache | EGA: 24-37 wks Intact membranes Also no: bleeding, dilatation >2 cm, placenta previa, intercourse w/ in 24 h | 141/141 (subgroup sampled at 24-34 wks=112) | | | Mean Age (SD) | | | Fetal fibronectin>50 ng/mL | Tocolytic: at physician discretion | | Country: dk Time period: dk | M=70% C=52%
  22 | 119
  22 | 90
  23.7 | 25.9
  (1.5) | (0.6)
Rizzo G, Capponi A, Arduini D, et al. ^113^ | To compare the diagnostic performances of fFN & EVUSD in the prediction of preterm birth in patients presenting w/ PTL | Prospective cohort study; Masking: Subject: dk Physician: yes | Contractions: 4/20 min and unresolved w/bed rest & hydration and Dilation: change from baseline and Effacement | EGA: 24-36 wks Intact membranes Also no: multiple gestations, dilation >3 cm, other maternal or fetal complications at admission or during pregnancy | 108/108 fFN | | | Age (SD) 31.4 (2.7) | | | fFN vaginal >50 ng/mL cervical >60 ng/mL CoT: at study entry EVUSD funneling present cervical length <20 mm cervical index >0.50 CoT: at study entry | | Bed rest, Hydration | Country: Italy Time period: 1993-1995 | M=75% C=50%
  43 | 65
Rozenberg P, Nisand I, Malagrida L, et al. ^106^ | To better understand the relationship between the presence of fFN in cervicovaginal secretions & the risk of preterm birth | Prospective cohort study; Masking: Subject: dk Physician: yes | No definition provided | EGA: 24-34 wks Hospitalization Also no: fetal anomaly, psychiatric pathology | 155/70 (14 of the 70 are excluded from the presented results due to PROM) | | | Mean Age (SD) | | | Fetal fibronectin >50 ng/mL CoT: at hospitalization | Tocolytic, Corticosteroids | | Country: dk Time period: 1993-1994 | M=70% C=22%
  16 | 40
  29.5 | 28.7
  (5.4) | (5.5)
Vetr M, Kudela M, & Prasilova J ^107^ | To determine whether fFN is a disciminator for PTL & early delivery in women who have intact membranes & uterine activity & increased risk of preterm birth | Prospective cohort study; Masking: Subject: dk Physician: dk | No definition provided | EGA: 25-36 wks Intact membranes Also no: bleeding, placenta previa, hypertensive disorders, congenital anomalies, fetal growth retardation & fetal distress, diabetes, "diagnosed & admitted w/ true labor" | 46/46 | | | | | | Fetal fibronectin pos cutoff: dk | Tocolytic IV & oral fenoterol & magnesium lactate tabletsused in the absence of clinical evidence of intra-amniotic infection, fetal distress, or advanced cervical dilatation | | Country: Czech Republic Time period: dk | M=61% C=40%
  16 | 30
  27.1 | 24.7
  (6.1) | (4.7)
Benattar C, Taieb J, Fernandez H, et al. ^108^ | To evaluate the predictive value of a qualitative rapid assay for the detection of fFN in patients w/ PTL to identify those at low risk of delivery w/ in 14 days | Prospective cohort study; Masking: Subject: dk Physician: yes | Contractions: >5/hr and cervical change | EGA: 24-36 wks Intact membranes Also no: bleeding, dilatation >3 cm Pyrrexia >38 degrees w/ intact membranes not excluded | 124/124 | | | | | | Bedside fetal fibronectin | Tocolytic: IV beta-mimetics on admission & oral tocolytics after successful arrest of PTL w/parenteral drugs | | Country: France Time Period: dk | M=65% C=52%
  19 | 105
Inglis SR, Jeremias J, Kuno K, et al. ^102^ | To determine whether tumor necrosis factor-α(TNF-α), interleukin-6 (IL-6), & fFN can be identified in the lower genital tract & whether their occurrence is associated w/preterm birth | Prospective cohort study; Masking: Subject: dk Physician: yes | | EGA: <37 wks Intact membranes Age: 15-40 Also no: multiple gestations, recent antibiotic therapy, hypertensive disorder, placenta previa, congenital anomalies, known genital or urinary tract infection | 111/111 | | | | | | fFN 50 ng/mL CoT: appearing w/ signs and symptoms TNF- α & IL-6 also tested | Erythromycin or amoxicillin AoT: to treat C. trachomatis Clotrimazole or metronidazole AoT: to treat T. vaginalis Tocolysis AoT: discretion of physician | | Country: United States Time Period: dk | M=78% C=42%
Langer B, Boudier E, Schlaeder G ^109^ | To determine whether cervicovaginal fFN could be used to predict which women would deliver preterm | Prospective cohort study; Masking: Subject: yes Physician: yes | Contractions: 4/20 min or 6/60 min, persisting at rest & requiring hospitalization | EGA: 24-34 wks Intact membranes Also no: bleeding, dilatation >2 cm, cervical change, abnormalities of fetal heart rate, intercourse w/ in 24 h. | 61/61 | | | Mean Age (SD) | | | Fetal fibronectin >50 ng/mL | | | Country: dk Time period: 1994-1995 | M=83% C=58%
  18 | 43
  26.7 | 27.4
  (6.0) | (5.0)
Peaceman AM, Andrews WW, Thorp JM, et al. ^46^ | A multicenter study to examine the association between fFN and pregnancy outcomes in a population w/ PTL & no prior tocolytic therapy | Prospective cohort study; Masking: Subject: yes Physician: yes | Symptoms include regular contractions, low abdominal cramping, low back pain, pelvic pressure, vaginal bleeding, & increased vaginal discharge | EGA: 24-34 wks, 6 days Intact membranes Also no: cerclage, placenta previa, dilatation >3 cm, trauma, prior tocolysis | 873/763 | | | Race white 40% | | | Fetal fibronectin >50 ng/mL | Tocolysis &Steroids based on physician judgment | | Country: dk Time period: dk | M=92% C=72%
  150 | 613
Rozenberg P, Goffinet F, Malagrida L, et al. ^114^ | To compare the predictive value of fFN and cervical length, as measured by EVUSD, in patients w/ PTL & whether the combination of the two tests better identified patients at high risk for preterm birth compared w/ either indicator alone | Prospective cohort study; Masking: Subject: dk Physician: none | Contractions: >2/10 min requiring hospitalization and (shortening or dilatation of the cervix) | EGA: 24-<34 wks Intact membranes Also no: cerclage dilatation >2 cm, placenta previa, abruptio placentae, medically indicated delivery | 76/76 | | | | | | Fetal fibronectin >50 ng/mL Cervical length measured through EVUSD >26 mm | | | Country: dk Time period: 1994-1995 | M=52% C=60%
  31 | 45
Chuileannain FN, Bell R, Brennecke S, et al. ^115^ | To determine if the results of the fFN test when used in routine clinical practice would be similar to those found in a previous study | Retrospective cohort study; Masking: no | Regular uterine contractions | EGA: <34 wks Singleton pregnancy Also no: placenta previa, antepartum hemorrhage, cervical cerclage, evidence of fetal abnormality, PROM or dilation >2 cm | 70/70 | | | | | | fFN >50 ng/mL CoT: at study entry | Salbutamol AoT: tocolysis | | Country: Australia Time Period: dk | M=N/A C=N/A
Watson DL, Kim SJ, Humphrey MD ^110^ | To use the strong negative predictive value of fFN to guide management of patients w/ threatened PTL | Case Control: Cases: received fFN test, Historic controls: fFN status unknown Masking: Subject: dk Physician: yes | N/A | EGA: 25-34 wks Intact membrane Also no: contraindications to tocolysis or glucocorticoids, dilation >3 cm, history of vaginal bleeding, sexual intercourse in past 24 h. | 16/16 | | | Age (SD) Race Other | | | fFN >50 ng/mL CoT: at study entry | If cases pos for fFN received: Indocid, salbutamol AoT: tocolysis Betamethasone AoT: glucocorticoid Vitamin K | Routine observation | Country: Australia Time period: 1996-1997 | M=65% C=46%
  3 | 13
  23.34 | 25.88
  (5.98) | (6.63)
  18.8% | 50%

Evidence Table 1: Biologic markers: Fetal fibronectin - Outcomes

Author(Year) | Delivery | | | | | | | | | | | Maternal | | | Infant | | | | | | Other Analyses | Conclusions
Author(Year) | Outcome | Clinical Measurement | Value | | | | | | | | | Morbidity | | | Birth Weight (g) | | | Other Infant Outcomes | | | Other Analyses | Conclusions
Author(Year) | Outcome | Clinical Measurement | Pos/Cases | Controls | Neg | Sig Level | Sens | Spec | PPV | NPV | OR or RR | Pos/Cases | Controls | Neg | Pos/Cases | Controls | Neg | Pos/Cases | Controls | Neg | Other Analyses | Conclusions
Lockwood CJ, Senyei AE, Dische MR, et al. ^101^ | Delivered <37 wks | fFN present/absent | 83% | | 19% | p<0.01 | 82% | 83% | 83% | 81% | | | | | | | | | | | Preterm birth & fFN status & (EGA at delivery, prolongation days birth weight). All sig at p=0.0001 Logit Preterm birth=fFN (OR=4.28)+dilatation (OR=2.93)+contraction frequency at admission (NS)+bleeding (NS)+tocolytic therapy (OR=2.33)+EGA (NS) No correlation found between fFN levels & cervical dilation | Fetal fibronectin effective at predicting preterm birth <37 wks
Iams JD, Casal D, McGregor JA, et al. ^103^ | Mean time to delivery in days Delivered at <37 wks Delivered at <7 days Delivered at < 14 days Delivered at <21 days | fFN present/absent fFN present/absent fFN present/absent fFN present/absent fFN present/absent | 25.3 (24.1) n=27 n=13 n=18 n=26 | | 52.4 (24.8) n=35 n=1 n=8 n=14 | p=.000 p=.000 p=.000 p=.000 p=.000 | 44% 93% 69% 65% | 86% 82% 84% 88% | 60% 29% 40% 58% | 76% 99% 95% 90% | 4.8 (2.4-9.5) p=0.000 59.3 (16.8-209.1) p=0.000 11.6 (5.1-26.1) p=0.000 13.0 (6.3-26.8) p=0.000 | | | | Lower (no data) p=.000 <2000 g Higher (no data) p=.000 | | | | | | Stepwise logit model: Delivery w/ in 7 days = fFN + cervical dilation >1 cm + uterine activity + vaginal bleeding fFN sig: OR=7.45, sens=93%, spec=82%, PPV=29%, NPV=99%; also bleeding sig | fFN is an especially sensitive & specific indicator of delivery w/ in 7 days; superior to contraction frequency & cervical dilation
Irion O, Matute J, Bischof P ^104^ | Delivered at <37 wks Delivered w/ in 7 days | fFN present/absent fFN present/absent | 58% 10 | | 18% 0 | | 68% 100% | 74% 70% | 58% 38% | 82% 100% | | | | | p=.08 | | | Perinatal Deaths p=.89 | | | Pos test stratified by tocolytic use Kaplan-Meier survival analysis difference between fFN pos & neg (p = .005)Mantel-Haenszel test to control for EGA & parity | fFN positively predicts preterm birth
  2875 | | 3005
  (830-3850) | | (1040-4150)
  2 | | 2
Malak TM, Sizmur F, Bell SC, et al. ^105^ | Delivery <37 wks Subsample EGA 24-34 wks at entry: Delivery <37 wks Delivery w/ in 7 days Delivery w/ in 14 days Delivery w/ in 21 days Mean EGA(SD) | fFN present/absent fFN present/absent fFN present/absent fFN present/absent fFN present/absent fFN present/absent | 14 237.3 (6.8) | | 8 274.7 (1.4) | | 64% 63% 80% 81% 86% | 96% 96% 90% 91% 94% | 78% 77% 44% 50% 67% | 92% 92% 98% 98% 98% | | | | | | | | | | | | fFN predicts risk of preterm birth (before 37 wks gestation).
Rizzo G, Capponi A, Arduini D, et al. ^113^ | Delivered at <37 wks Delivered at <37 wks Delivered at <37 wks Delivered at <37 wks Delivered at<37 wks | Vaginal fFN present/absent Cervical fFN present/absent EVUSD Funneling present/absent EVUSD Cervical Length < cutoff/ > cutoff EVUSD Cervical Index cutoff/ < cutoff | | | | | 74% 81% 70% 68% 70% | 87% 84% 67% 79% 80% | 81% 79% 62% 71% 73% | 81% 85% 75% 76% 78% | 1.6 (0.5-3.8) p=NS 21.3 (2.8-42.4) p<0.001 3.4 (0.6-9.4) p=NS 5.2 (0.8-14.9) p=NS 9.9 (1.5-19.7) p<0.005 | | | | | | | | | | ROC curves: Predicting delivered <37 wks, all fFN & USD measurements sig, cervical fFN highest diagnostic index Stepwise logit model: Delivered <37 wks=cervical fFN*+cervical index*+cervical length+funneling+vaginal fFN+EGA at admission *sig Survival analysis: Predicting admission to delivery interval: corr. w/ cervical length p<0.01 | Cervical fFN more accurate than EVUSD in predicting preterm delivery. Combined use of fFN and EVUSD improves diagnostic efficiency & allows prediction of admission to delivery interval.
Rozenberg P, Nisand I, Malagrida L, et al. ^106^ | Mean EGA at delivery (SD) Prolongation days (SD) Delivery <37 wks Delivery <34 wks Delivery <21 days | fFN present/absent fFN present/absent fFN present/absent fFN present/absent fFN present/absent | 34.2 (4) 21.9 (25.3) | | 38.3 (1.9) 54.9 (23) | p=.001 p=.001 | 60% 66.6% 85.7% | 88.9% 78.7% 90.5% | 75% 37.5% 75% | 80% 92.5% 95% | 12 (3.4-42.1) p=0.001 29.9 (13.4-24.3) p=0.001 | | | | | | | | | | | fFN helps distinguish real from false labor of high risk symptomatic patients.
Vetr M, Kudela M, & Prasilova J ^107^ | Mean EGA (SD) Time to delivery Delivery <37 wks Maternal working inability (wk) Birth weight | fFN present/absent fFN present/absent fFN present/absent fFN present/absent fFN present/absent | 37.7 (1.7) 35.1 (26.4) 20.3 (8.6) 300 (579) | | 38.0 (1.8) 52.5 (23.5) 13.9 (9.0) 3031 (541) | p=NS p<0.05 p<.025 p=NS | 56% | 70% | 31% | 87% | 4.81 p<0.05 | Length of Hospital Stay p=NS Working inability in wks p<0.025 | | | p=NS | | | | | | | fFN test negative predictive value effective at predicting low probability of preterm birth
  5.1 | | 5.7
  (2.9) | | (5.1)
  20.3 | | 13.9
  (8.6) | | (9.0)
  3000 | | 3031
  (579) | | (541)
Benattar C, Taieb J, Fernandez H, et al. ^108^ | Delivery <37 wks Delivery <32 wks Delivery w/ in 7 days Delivery w/ in 14 days Delivery w/ in 21 days | fFN present/absent fFN present/absent fFN present/absent fFN present/absent fFN present/absent | 47% | | 15% | p<.001 | 36% 73% 89% 69% 46% | 91% 91% 90% 93% 91% | 50% 55% 42% 57% 58% | 85% 97% 99% 95% 81% | | | | | | | | | | | | Test effective at predicting preterm birth.
Inglis SR, Jeremias J, Kuno K, et al. ^102^ | Mean EGA Time to Delivery in days Delivered at <37 wks | fFN present/absent fFN present/absent fFN present/absent | 32.7 31.2 n=7 | | 37.3 46.8 | p=NS | | | | | 4.8 (1.1-20.2) p<0.05 | Maternal Febrile Morbidity | | | | | | Neonatal Hospital Days p<0.05 Neonatal Deaths Neonatal Sepsis | | | Outcomes also provided for: tumor necrosis factor-α: RR=6.2 (1.5-24.8) p<0.005 interleukin-6: RR=1.8 (0.8-4.2) p=NS | When sampled during PTL, fFN & tumor necrosis factor-α correlated w/subsequent preterm delivery.
  2 | | 4
  5 | | 4
  1 | | 1
  2 | | 4
Langer B, Boudier E, Schlaeder G ^109^ | Mean EGA (SD) Time to delivery Delivered at <37 wks | fFN present/absent fFN present/absent fFN present/absent | 36.4 (2.5) 39.9 (22.8) 10 | | 37.7 (2.3) 58.9 (29.5) 8 | p<0.05 p<0.05 p<0.01 | 56% | 81% | 56% | 81% | RR=3.0 | | | | p<0.05 | | | APGAR at 5 min P=NS | | | | In indications of PTL w/ no modification of the cervix, presence of fFN makes it possible to identify patients at risk of preterm birth.
  2708 | | 3053
  (525) | | (473)
  9.35 | | 9.82
  (1.5) | | (0.6)
Peaceman AM, Andrews WW, Thorp JM, et al. ^46^ | Delivery <7 days Delivery <14 days Delivery <37 wks Singleton pregnancies only Delivery <7 days Delivery <14 days Delivery <37 wks | fFN positive/negative fFN positive/negative fFN positive/negative fFN positive/negative fFN positive/negative fFN positive/negative | 20 25 67 | | 3 5 95 | | 91% 89% 44% | | 13% 16% 43% | 100% 100% 86% | RR=27.1 RR=20.4 RR=2.9 | | | | <1500 g RR=7.5 <2500g RR=3.4 | | | NICU RR=2.6 Sepsis RR=2.3 NRDS RR=3.4 Infant death RR=6.1 | | | Logit (singletons only) Delivery w/ in 7 days= historic risk factors+demographic characteristics+clinical findings. Sig. findings: prior preterm birth (OR=8.3), use of tocolytics (OR=4.1), fFN (OR=48.8) Preterm birth (whole sample)=confounders +fFN (OR=3.6)+ tocolytics (OR=4.5)+ dilatation>1cm (OR=2.9)+prior preterm birth (OR=2.5) Survival analysis: fFN result pos., interval from sampling to delivery shorter (p<0.001) | fFN test, w/ high neg predictive value supporting less intervention for patients w/ this result.
  11 | | 6
  57 | | 69
  44 | | 68
  15 | | 23
  19 | | 23
  6 | | 4
Rozenberg P, Goffinet F, Malagrida L, et al. ^114^ | Delivery <37 wks | fFN present/absent EVUSD Cervical Length <26 mm/>26 mm fFN present or cervical length <26mm or both fFN present & cervical length <26 mm/ | 14 | | 6 | | 70% 75% 90% 55% | 87% 73% 61% 82% | 45% 50% 45% 52% | 87% 89% 94% 84% | OR=5.3 OR=8.2 OR=13.9 OR=5.6 | | | | | | | | | | ROC curve analysis of cervical length for preterm birth risk | Results of the tests considered separately were similar & each has an excellent neg. predictive value (identified a group of patients at low risk for preterm birth). Advantages of performing both test are modest.
Chuileannain FN, Bell R, Brennecke S, et al. ^115^ | Mean EGA at delivery (SD) Mean days to delivery Delivery <34 wks | fFN present/absent fFN present/absent | 34.9 (3.6) 29.3 45% | | 38.2 (2.4) 62.5 2% | p=.001 p<.001 p<.001 | 90% | 82% | 45% | 98% | | Maternal peripartum febrile morbidity p=0.5 | | | Mean (Range) P<0.001 | | | | | | | In routine, unblinded clinical practice, the clinical utility of the fFN test is almost identical in terms of pos & neg predictive values to the findings of the original, blinded research.
  5% | | 2%
  2426 | | 3202
  (1016-3640) | | (1116-3980)
Watson DL, Kim SJ, Humphrey MD ^110^ | Mean EGA Delivered at <34 wks Delivered at <37 wks Delivered within 24 h Delivered within 48 h | Cases: fFN tested vs. historic controls Cases: fFN tested vs. historic controls Cases: fFN tested vs. historic controls Cases: fFN tested vs. historic controls Cases: fFN tested vs. historic controls | 270.7 (19.2) n=2 n=3 n=1 n=1 | 256.3 (28.1) n=8 n=14 n=3 n=4 | | p=NS p=NS p=NS p=NS p=NS | | | | | | Tocolytic Therapy p<0.0001 | | | Mean (SD) | | | NICU Admissions p=NS | | | None | fFN effective in predicting the need for tocolysis
  n=3 | n=30
  3074.4 | 2730.0
  (616.7)
  (843.4)
  n=2 | n=13

Evidence Table 2: Biologic markers: Endovaginal ultrasound-Study design

Author (Year) | Research Objective | Study Design & Masking | Definition of Preterm Labor | Patient Inclusion/Exclusion Characteristics | Sample SizeInitial/End | | | Demographic Characteristics | | | Biologic markers: Intervention | Uniform Adjunctive Drug Intervention | Uniform Nondrug Intervention | Country & Time Period | Quality Scores
Author (Year) | Research Objective | Study Design & Masking | Definition of Preterm Labor | Patient Inclusion/Exclusion Characteristics | Pos | Neg | Cx | Pos | Neg | Cx | Biologic markers: Intervention | Uniform Adjunctive Drug Intervention | Uniform Nondrug Intervention | Country & Time Period | Quality Scores
Crane JM, Van den Hof M, Armson BA, et al. ^112^ | To compare the effectiveness of EVUSD w/ digital exam in predicting preterm delivery in women w/ PTL | Prospective cohort study; Masking: Subject: dk Physician: yes | Contractions: regular and Cervical change: dilation, effacement, or change in consistency | EGA: 23-33 wks Intact membranes Also no: current bleeding, cerclage, dilation >3 cm, multiple gestation >twins, placenta previa | 162/162 | | | Mean Age (SD) Singleton moms 26.7 (6.0) Twin moms 27.9 (3.8) | | | EVUSD length of cervix <30 mm | Tocolysis: not used universally and includes ritodrine, indomethacin, and magnesium sulfate | Bed rest, IV fluids | Country: Canada Time period: 1994-1995 | M=64% C=52%
Iams JD, Paraskos J, Landon MB, et al. ^55^ | To improve the accuracy of the diagnosis of PTL by comparing transvaginal ultrasound to digital assessment of dilatation and effacement | Prospec-tive cohort study; Masking: Subject: dk Physician: dk | Contractions: 4/20 min or 8/hr despite lateral recumbency & IV or oral hydration and Cervical change If dilatation >2cm or effacement >50% then PTL defined solely through contraction status | EGA: 24-34 wks Intact membranes Successful tx w/parenteral tocolysis within 48 h of enrollment Also no: cerclage, multiple gestation >twins, | 60/60 | | | Mean Age (SD) 22.6 (4.8) | | | EVUSD length of cervix <30 mm | Tocolysis: IV magnesium sulfate supplemented by subcutaneous terbutaline, oral terbutaline prescribed after parenteral tocolysis | | | M=72% C=54%
  15 | 45
Rizzo G, Capponi A, Arduini D, et al. ^113^ | To compare the diagnostic performances of fFN & EVUSD in the prediction of preterm birth in patients presenting w/ PTL | Prospec-tive Cohort Study; Masking: Subject: dk Physician: yes | Contractions: 4/20 min and unresolved w/bed rest & hydration and Dilation: change from baseline and Effacement | EGA: 24-36 wks Intact membranes Also no: multiple gestations, dilation >3 cm, other maternal or fetal complications at admission or during pregnancy | 108/108 | | | Age (SD) 31.4 (2.7) | | | fFN vaginal >50 ng/mL cervical >60 ng/mL CoT: at study entry EVUSD funneling present cervical length 20 mm cervical index >0.50 CoT: at study entry | | Bed rest, Hydration | Country: Italy Time period: 1993-1995 | M=75% C=50%
Timor-Tritsch IE, Booz-arjomehi F, Masakowski Y, et al. ^111^ | To test the hypothesis that wedging of the cervical interior os as determined by transvaginal ultrasound is associated w/ PTL & preterm birth | Prospec-tive Cohort Study; Masking: Subjects: dk Physician: yes | Contractions: >6/h and Cervical change | EGA: 20-35 wks Intact membranes: viable fetus Also no: bleeding, multiple gestation, history of DSS exposure or cone biopsy | 70/70 | | | Mean Age (SD) | | | Transvaginal ultrasound wedging or funneling present CoT: at admission, after cervical evaluation | Tocolytic: terbutaline or magnesium sulfate AoT: to treat contractions unresponsive to intravenous hydration | IV fluids if regular contractions >6/h | Country: United States Time period: dk | M=67% C=39%
  32 | 38
  25.9 | 25.1
  (1.1) | (1.0)
Rozenberg P, Goffinet F, Malagrida L, et al. ^114^ | To compare the predictive value of fFN and cervical length, as measured by EVUSD, in patients w/ PTL & whether the combination of the two tests better identified patients at high risk for preterm birth compared to either indicator alone | Prospec-tive cohort study; Masking: Subject: dk Physician: none | Contractions: >2/10 min requiring hospitalization and (shortening or dilatation of the cervix) | EGA: 24<34 wks Intact membrane Also no: cerclage dilatation >2 cm, placenta previa, abruptio placentae, medically indicated delivery | 76/76 | | | | | | Fetal fibronectin>50 ng/mL Cervical length measured though EVUSD >26 mm | | | Country: dk Time period: 1994-1995 | M=52% C=60%
  31 | 45

Evidence Table 2: Biologic markers: Endovaginal ultrasound-Outcomes

Author (Year) | Delivery | | | | | | | | | | | Maternal | | | Infant | | | | | | Other Analyses | Conclusions
Author (Year) | Outcome | Clinical Measurement | Value | | | | | | | | | Morbidity | | | Birth Weight (g) | | | Other Infant Outcomes | | | Other Analyses | Conclusions
Author (Year) | Outcome | Clinical Measurement | Pos/Cases | Controls | Neg | Sig Level | Sens | Spec | PPV | NPV | OR or RR | Pos/Cases | Controls | Neg | Pos/Cases | Controls | Neg | Pos/Cases | Controls | Neg | Other Analyses | Conclusions
Crane JM, Van den Hoff M, Armson BA, et al. ^112^ | Delivery <37 wks Delivery <34 wks | EVUSD cervical length <30mm/>30mm EVUSD funneling Effacement >50%/<50% Dilation >1.5 cm/<1.5 cm EVUSD cervical length <30mm/>30mm EVUSD funneling Effacement >50%/<50% Dilation >1.5 cm/<1.5 cm | | | | | 79% 23% 81% 38% 88% 50% 82% 47% | 61% 90% 40% 94% 56% 57% 36% 85% | 50% 46% 40% 70% 19% 32% 13% 27% | 86% 76% 82% 80% 97% 95% 95% 93% | | | | | | | | | | | ROC and logistic analysis comparing singleton and twin gestations. Endocervical length though EVUSD only sig predictor for singletons at <37 & <34 wks. Same finding in twins only at <34 wks. | Cervical length as measured though EVUSD superior to funneling and digital exam in predicting preterm birth in patients w/PTL.
Iams JD, Paraskos J, Landon MB, et al. ^55^ | Mean EGA Delivery <36 wks Delivery <36 wks Delivery <36 wks | Cervical length <30mm/>30mm Cervical length <30mm/>30mm Dilatation >2 cm/<2cm Effacement >50%/<50% | 34.8 (2.8) 24 | | 38.0 (1.8) 0 | p<.001 | 100% 62% 83% | 44% 39% 39% | 55% 40% 48% | 100% 61% 78% | | | | | | | | | | | Scattergrams and ROC curves correlating delivery <36 wks and (sonographic length, effacement, and dilatation). Sonographic length best predictor. | Cervical length of >30 mm (as determined by ultrasound) predicted a low likelihood of preterm birth for women who have received parenteral tocolysis.
Rizzo G, Capponi A, Arduini D, et al. ^113^ | Delivered at <37 wks Delivered at <37 wks Delivered at <37 wks Delivered at <37 wks Delivered at <37 wks | vaginal fFN present/absent cervical fFN present/absent EVUSD funneling present/absent EVUSD cervical length < cutoff/> cutoff EVUSD cervical index > cutoff/< cutoff | | | | | 74% 81% 70% 68% 70% | 87% 84% 67% 79% 80% | 81% 79% 62% 71% 73% | 81% 85% 75% 76% 78% | 1.6 (0.5-3.8) p=NS 21.3 (2.8-42.4) p0.001 3.4 (0.6-9.4) p=NS 5.2 (0.8-14.9) p=NS 9.9 (1.5-19.7) p0.005 | | | | | | | | | | ROC curves: Predicting delivered <37 wks, all fFN & USD measurements sig, cervical fFN highest diagnostic index Stepwise logit model: Delivered <37 wks=cervical fFN*+cervical index*+cervical length+funneling+vaginal fFN+EGA at admission *sig Survival analysis: Predicting admission to delivery interval: corr. w/ cervical length p<0.01 | Cervical fFN more accurate than EVUSD in predicting preterm delivery. Combined use of fFN and EVUSD improves diagnostic efficiency & allows prediction of admission to delivery interval.
Timor-Tritsch LE, Booz-arjomehi F, Masakowski Y, et al. ^111^ | Prolongation of pregnancy Delivered at <37 wks | EVUSD wedging present/absent EVUSD wedging present/absent | 5.68 (0.69) 19 | | 9.84 (0.54) 0 | p<.001 | 100% | 74% | 59% | 100% | | | | | | | | | | | Wedging found to be significantly related to shorter cervical length (p<0.001). Stepwise logit Preterm Birth=Cervical wedging. Adding other factors did not increase model predictive value. | The presence of wedging and shorter cervical length was suggestive of true PTL requiring aggressive management.
Rozenberg P, Goffinet F, Malagrida L, et al. ^114^ | Delivery <37 wks | fFN present/absent EVUSD cervical length <26 mm/>26 mm fFN present or cervical length <26mm or both fFN present & cervical length <26 mm/ | 14 | | 6 | | 70% 75% 90% 55% | 87% 73% 61% 82% | 45% 50% 45% 52% | 87% 89% 94% 84% | OR=5.3 OR=8.2 OR=13.9 OR=5.6 | | | | | | | | | | ROC curvey analysis of cervical length for preterm birth risk | Results of the tests considered separately were similar & each has an excellent neg. predictive value (identified a group of patients at low risk for preterm birth). Advantages of performing both tests are modest.

Evidence Table 3: Tocolytic first line: Beta-mimetics - Study design

Author (Year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion Exclusion Characteristics | Sample Size Initial/End | | | Demographic Characteristics | | | Tocolytic Intervention | Uniform Adjunctive Drug Intervention | Uniform Nondrug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Author (Year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion Exclusion Characteristics | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tocolytic Intervention | Uniform Adjunctive Drug Intervention | Uniform Nondrug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Castrén O, Gummerus M, Saarikoski ^144^ | To compare two commonly used Beta-mimetics w/ ethanol and placebo treatment | RCT Masking: Subject: none Physician: none Pharm: dk Other care providers: dk | PTL: Contractions: "active" contractions verified by tocography Successful tocolysis: premature contractions arrested and the pregnancy prolonged such that birth weight was >2500 or (PTL postponed for >7 days and pregnancy continued until >37th week) | EGA: 24-36 wks Intact membranes | 194/194 Tx1(n=43) Tx2 (n=60) Tx3 (n=50) Cx (n=41) | | | | | | Tx1 Nylidrin IV 50 mg in 500 mL of 5% glucose, at a rate of 0.2 mg/min CoT: on admission DoT: 1 hr Nylidrin IV 0.1 mg/min CoT: after initial infusion DoT: 5 h Nylidrin intramuscularly 5 mg CoT: immediately following last dose DoT: once Nylidrin intramuscularly 5 mg/3 h CoT: immediately following last dose DoT: 3 times Nylidrin intramuscularly 5 mg/5 h CoT: immediately following last dose DoT: 48 h Nylidrin intramuscularly 6 mg/5 h CoT: immediately following last dose DoT: dk Tx2 Isoxuprine IV 100 mg in 500 mL of 5% glucose, rate of 0.4 mg/min CoT: on admission DoT: 1 hr Isoxuprine IV 25 mg CoT: after initial dose DoT: once Isoxuprine intramuscularly 10 mg/3 h CoT: following last dose DoT: 4 doses Isoxuprine intramuscularly 10 mg/4 h CoT: following last dose DoT: 48 h Isoxuprine intramuscularly 10 mg/4 h CoT: following last dose DoT: continued at home, duration: dk Tx3 Ethanol solution IV 96 mL of 96% ethanol in 1000 mL of 5% glucose, at rate of 0.8 mL/min CoT: on admission DoT: 2 h Ethanol solution IV 0.13 mL/min CoT: following last dose DoT: 4 h Cognac oral 40 mL/6 h CoT: dk DoT: dk Cx Placebo given according to same schedule as Tx1. | | Fetal monitoring, routine observation | Inpatient | Country: Finland Time period: dk | M=50% C=58%

Evidence Table 3: Tocolytic first line: Beta-mimetics - Study design

Author (Year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion Exclusion Characteristics | Sample Size Initial/End | | | Demographic Characteristics | | | Tocolytic Intervention | Uniform Adjunctive Drug Intervention | Uniform Nondrug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Author (Year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion Exclusion Characteristics | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tocolytic Intervention | Uniform Adjunctive Drug Intervention | Uniform Nondrug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Lauersen NH, Merkatz IR, Tejani N, et al. ^117^ | To compare the effectiveness and acceptability of ethanol versus ritodrine in a randomized controlled multicenter study | RCT Masking: none | Contractions: 1/10 min, lasting 30-60 s eachand Cervical effacement and Dilation<4 cm Successful tocolysis: delivery postponed for more than 72 h | EGA: 20-36 wks Estimated fetal Weight <2500g Intact membranes Uterine fundus above the umbilicus Also no: bulging membranes, premature separation of the placenta, preeclampsia, chronic renal disease, chronic hypertension, cardiac disease, diabetes mellitus, other severe maternal diseases, dead or malformed fetus, placenta previa (if bleeding is severe enough to require intervention), maternal or fetal complications that require immediate delivery | 150/135 | | | Mean Age (SD) Race, White Race, Nonwhite | | | Tx1 Ethanol IV 7.5 mL/kg/h (10% in 5% dextrose in water) CoT: after diagnosis and 30 min of observation DoT: 2 h Ethanol IV 1.5 mL/kg/h CoT: after initial dose DoT: 10 h or more Ethanol IV dose: variable, up to 2 additional courses of tx CoT: upon reoccurrence of labor DoT: same as above Tx2 Ritodrine IV 50 µg/min, increasing by 50 µg every 10 min, maximum 350 µg, until uterine relaxation (or decreased if disturbing palpitations or maternal heart rate over 120 beats/min observed) CoT: after diagnosis and 30 min of observation DoT: 12 h Ritodrine oral 10 µg every 2 h CoT: 30 min before end of IV infusion DoT: 24 h Ritodrine oral 20-60 µg daily CoT: after discharge DoT: 4 wks or until 38 wks gestation Ritodrine IV, up to 2 repeat courses CoT: upon reoccurrence of labor while on oral ritodrine DoT: same as above | | Bed rest, uterine monitoring, fetal monitoring | Weekly clinic or physician visits | Country: United States Time period: dk | M=75% C=71%
  67 | 68
  23.6 | 23.9
  (5.8) | (5.2)
  25 | 22
  42 | 46

Evidence Table 3: Tocolytic first line: Beta-mimetics - Study design

Author (Year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion Exclusion Characteristics | Sample Size Initial/End | | | Demographic Characteristics | | | Tocolytic Intervention | Uniform Adjunctive Drug Intervention | Uniform Nondrug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Author (Year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion Exclusion Characteristics | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tocolytic Intervention | Uniform Adjunctive Drug Intervention | Uniform Nondrug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Gamissans O, Cañas E, Cararach J, et al. ^118^ | To compare the efficacy & side effects of ritodrine & placebo versus ritodrine & indomethacin in patients w/ threatened PTL | RCT Masking: Subject: Physician: yes Pharm: other care Providers: dk | PTL: Contractions: (regular or irregular)or (Cervical effacement & Dilation4 cm) or Other: slight bleeding or "showing" Successful tocolysis: not defined | EGA: 20-36 wks Intact membranes Also no: multiple gestation, pre-eclampsia toxemia, Rh immunization | 44/44 | | | Mean Age (SEM) | | | Tx1 Ritodrine hydrochloride, IV in 5% glucose, 200 µg/min CoT: after admission DoT: at least 1h Ritodrine hydrochloride, IV in 5% glucose, adjusted to according to the needs of individual patients CoT: after initial infusion DoT: at least 24 h Ritodrine intramuscularly or orally, 10 mg/4-6 h CoT: after 24 h infusion DoT: up to 38 wks, unless labor occurs* Placebo suppository (identical in appearance to indomethacin suppository) Tx2 Ritodrine hydrochloride, IV in 5% glucose, 200 µg/min CoT: after admission DoT: at least 1 h Ritodrine hydrochloride, IV in 5% glucose, adjusted to according to the needs of individual patients CoT: after initial infusion DoT: at least 24 h Ritodrine intramuscularly or orally, 10 mg/4-6 h CoT: after 24 h infusion DoT: up to 38 wks, unless labor occurs* Indomethacin suppository 50 mg/8 h CoT: dk DoT: for 2 wks unless labor occurs or rectal intolerance occurs *If patients under oral or intramuscular tx present w/ recurrent regular uterine contractions, IV infusion of ritodrine was repeated for at least 24 h. | | Bed rest | Inpatient | Country: dk Time period: dk | M=88% C=71%
  22 | 22
  24.8 | 22.05
  (1.18) | (1.04)

Evidence Table 3: Tocolytic first line: Beta-mimetics - Study design

Author (Year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion Exclusion Characteristics | Sample Size Initial/End | | | Demographic Characteristics | | | Tocolytic Intervention | Uniform Adjunctive Drug Intervention | Uniform Nondrug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Author (Year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion Exclusion Characteristics | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tocolytic Intervention | Uniform Adjunctive Drug Intervention | Uniform Nondrug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Sims CD, Chamberlain GVP, Boyd IE, et al. ^145^ | To compare IV salbutamol & ethanol as treatments for PTL | RCT Masking: Subject: none Physician: dk Pharm: dk Other care providers: dk | PTL: Contractions: history of >6/h Successful tocolysis: stopping contractions | EGA: 27-35 wks Maternal age: >15 yrs Also no: abruptio placentae, fulminating preeclampsia, intrauterine growth retardation, dilation > 4 cm, multiple gestation, placenta previa | 100/88 | | | | | | Tx1 Salbutamol IV 4 mg in 500 mL of 5% dextrose in water, administered at 5 µg/min and increased by 5 µg/10 min CoT: initial tx DoT: until contractions abolished or max of 50µ g/min reached or unacceptable side effects occurred Salbutamol IV, lowest dose from above to stop contractions CoT: after initial treatment DoT: 12 h (or 24 for those w/ PROM, if the cervix showed progressive dilation, or contractions were not abolished) (If contractions reappeared, the treatment was repeated) Tx2 Ethanol IV 10% ethanol in 5% dextrose in water rate of 15 mL/kg of body weight CoT: initial tx DoT: 2 h Ethanol IV 1.5 mL.kg body weight/h CoT: after initial 2 h DoT: 10 h (If contractions reappeared, the treatment was repeated.) | Betamethasone AoT: Patients randomized and either received betamethasone or placebo intramuscularly to determine whether it had any influence on the development of respiratory distress syndrome in preterm infants. | | | Country: England Time period: dk | M=32% C=44%
  42 | 46

Evidence Table 3: Tocolytic first line: Beta-mimetics - Study design

Author (Year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion Exclusion Characteristics | Sample Size Initial/End | | | Demographic Characteristics | | | Tocolytic Intervention | Uniform Adjunctive Drug Intervention | Uniform Nondrug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Author (Year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion Exclusion Characteristics | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tocolytic Intervention | Uniform Adjunctive Drug Intervention | Uniform Nondrug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Hesseldahl H ^157^ | To evaluate (1) if short IV or long IV infusion of ritodrine is preferable, (2) if intramuscular treatment is of similar efficacy as IV treatment, (3) if ritodrine treatment is preferable to standard treatment | RCT Masking: Subject: yes Physician: dk Pharm: dk Other care providers: dk | PTL: Contractions: regular or (Contractions and [Cervical dilation or Cervical effacement]) observed & recorded for >20 min Successful tocolysis: not defined | EGA: 20-37 wks Intact membranes Fetal weight: <2500 g Also no: abruptio placentae, dilation >5 cm, severe uterine hemorrhage, eclampsia or severe preeclamptic toxemia, Rh neg women w/previously infected babies or history of ABO incompatibility, cardiac disease, intrauterine infection, diabetes situations were it was considered undesirable to postpone labor | 199/176 TxA: ritodrine long-infusion, N= 41 TxB: ritodrine short-infusion, N= 46 TxC: ritodrine intra-muscularly, N= 44 Cx: 45 | | | | | | TxA Ritodrine IV, in "increased doses" CoT: initial DoT: until cease of contractions and then continuously for a total of 24 h Ritodrine oral, dose:dk CoT: after IV treatment DoT: until 37th wk TxB Ritodrine IV, in increased doses CoT: initial DoT: until cease of contractions Ritodrine oral, dose: dk CoT: after IV treatment DoT: until 37th wk TxC Ritodrine intramuscularly, dose: dk, every 6-8 h CoT: initial DoT: 24 h Cx Glucose IV 5.5%, dose: dk CoT: initial DoT: 24 h Placebo tablets oral CoT: after ritodrine dose DoT: until 37th wks | | Bed rest, IV fluids | Inpatient: dk Outpatient: dk | Country: Denmark Time period: dk | M=44% C=30%

Evidence Table 3: Tocolytic first line: Beta-mimetics - Study design

Author (Year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion Exclusion Characteristics | Sample Size Initial/End | | | Demographic Characteristics | | | Tocolytic Intervention | Uniform Adjunctive Drug Intervention | Uniform Nondrug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Author (Year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion Exclusion Characteristics | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tocolytic Intervention | Uniform Adjunctive Drug Intervention | Uniform Nondrug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Merkatz IR, Peter JB, Barden TP ^136^ | To evaluate the safety and efficacy of ritodrine compared to either ethanol or a placebo in the treatment of idiopathic PTL occurring in otherwise healthy women. | RCT Masking: dk | PTL: not defined Successful tocolysis: not defined | EGA: 20 to 36 wks Intact membranes Also no: multiple gestations | 366/313 | | | | | | Tx1 Ritodrine hydrochloride IV dose: dk CoT: dk DoT: dk Cx Ethanol or placebo IV | | Bed rest, routine observation | Inpatient | Country: United States Time period: 1972-1977 | M=44% C=54%
  190 | | 123

Evidence Table 3: Tocolytic first line: Beta-mimetics - Study design

Author (Year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion Exclusion Characteristics | Sample Size Initial/End | | | Demographic Characteristics | | | Tocolytic Intervention | Uniform Adjunctive Drug Intervention | Uniform Nondrug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Author (Year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion Exclusion Characteristics | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tocolytic Intervention | Uniform Adjunctive Drug Intervention | Uniform Nondrug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Gummerus M ^158^ | To study the use of salbutamol for the prevention of PTL and to compare it w/ fenoterol and the results achieved w/ different beta-mimetics in the same hospital | RCT Masking: none | PTL: Contraction: regular for 30 minutes Successful tocolysis: not defined | EGA: 24-36 wks Intact membranes | 108/108 | | | | | | Tx1 Fenoterol IV 3-4 µg/min CoT: dk DoT: 12 h after cessation of uterine contractions Fenoterol oral 5 mg CoT: after completion of IV therapy DoT: every 4 h until: dk Tx2 Salbutamol IV 12 µg/min increased by 6 µg/min to maximum dose of 50 µg/min CoT: dk DoT: desired effect achieved Salbutamol IV 12-24 µg/min CoT: after contractions ceased DoT: 12 h Salbutamol oral 4 mg CoT: after completion of IV therapy DoT: every 4 h at least 10 days | | Routine observation | | Country: Finland Time period: 1977-1978 | M=46% C=38%
  54 | 54

Evidence Table 3: Tocolytic first line: Beta-mimetics - Study design

Author (Year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion Exclusion Characteristics | Sample Size Initial/End | | | Demographic Characteristics | | | Tocolytic Intervention | Uniform Adjunctive Drug Intervention | Uniform Nondrug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Author (Year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion Exclusion Characteristics | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tocolytic Intervention | Uniform Adjunctive Drug Intervention | Uniform Nondrug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Caritis SN, Carson D, Greenbon D, et al. ^148^ | To compare terbutaline and ethanol to determine the relative efficacy and safety of these agents in women w/ PTL | RCT Masking: Subject: none Physician: none Pharm: dk Other care providers: dk | Contractions:>1 every 5-7 min as documented by a tocodynamometer, each contraction lasting >30 s for at least 1 h Successful tocolysis: If intact membrane: "Complete success": pregnancy >36 wks, "Partial success": mature lecithin/ sphingomyelin (L/S) ratio obtained or a full course of betamethasone is given If PROM: delayed delivery or 36 h to administer betamethasone | EGA: 20-36 wks or 24-34 wks for PROM Also no: obstetrical or medical contraindications to the inhibition of labor (including maternal hypertension, diabetes mellitus, heart disease, hyperthyroidism), preeclampsia or eclampsia, abruptio placentae, chorioamnionitis, abnormal or dead fetus, cervical dilation >5 cm, other tocolytic use in this pregnancy | 92/85 Intact Membrane PROM | | | | | | Tx1 Terbutaline IV 5 µg/min, increased by 5 µg/min every 20 min to max dose 30 µg/min CoT: dk DoT: 1 h after contractions stop or if side effects Terbutaline IV 5-10 µg/min CoT: after loading dose, for those w/ out side effects DoT: 8 h Terbutaline oral 5 µg/min (intact membranes only) CoT: for those whose labor was successfully inhibited, received drug 30 min before end of IV maintenance infusion DoT: 4 times daily for 5 days Tx2 Ethanol IV 7.5 mL/kg/h of 10% ethanol in 5% dextrose CoT: dk DoT: 2 h Ethanol IV 1.5 mL/kg.hr CoT: after loading dose DoT: 10 h Ethanol IV Reloading dose reduced by 10% for each hour less than 10 elapsing from the end of the previous maintenance infusion CoT: after maintenance infusion if labor reoccurs DoT: dk Magnesium sulfate If ethanol intolerance led to discontinuation of treatment & patient continues to experience labor or if patient refuses to be treated w/ the assigned drug for a recurrent episode of PTL. | Betamethasone AoT: to enhance fetal lung maturation | | Inpatient | Country: United States Time period: 1979-1980 | M=60% C=71%
  28 | 28
  17 | 12

Evidence Table 3: Tocolytic first line: Beta-mimetics - Study design

Author (Year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion Exclusion Characteristics | Sample Size Initial/End | | | Demographic Characteristics | | | Tocolytic Intervention | Uniform Adjunctive Drug Intervention | Uniform Nondrug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Author (Year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion Exclusion Characteristics | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tocolytic Intervention | Uniform Adjunctive Drug Intervention | Uniform Nondrug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Gummerus M ^149^ | To gather clinical experiences w/ the tocolytic agent hexoprenalin and to compare it to salbutamol | RCT Masking: dk | PTL: Contractions: >1/10 min Successful tocolysis: prolongation of pregnancy >7 days after initiation of therapy, birth weight >2500 g, birth >37 wks | EGA: 24-37 wks Intact membranes | 140/140 | | | | | | Tx1 Hexoprenalin IV 0.1 µg/min, increased by 0.05 µg/min/10 min, max dose 0.35 µg/min CoT: dk DoT: until labor suppressed for 12 h Hexoprenalin oral 0.5 mg, 6-8 times daily CoT: 30 min before discontinuation of IV therapy DoT: for 10 days after discharge Tx2 Salbutamol 12 µg/min, increased by 6 µg/min/10 min, max dose 50 µg/min CoT: dk DoT: until labor suppressed for 12 h Salbutamol oral 4 mg, 6-8 times daily CoT: 30 min before discontinuation of IV therapy DoT: for 10 days after discharge | | | Inpatient and outpatient at women's clinic | Country: Germany Time period: 1978-1980 | M=48% C=10%
  72 | 74

Evidence Table 3: Tocolytic first line: Beta-mimetics - Study design

Author (Year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion Exclusion Characteristics | Sample Size Initial/End | | | Demographic Characteristics | | | Tocolytic Intervention | Uniform Adjunctive Drug Intervention | Uniform Nondrug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Author (Year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion Exclusion Characteristics | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tocolytic Intervention | Uniform Adjunctive Drug Intervention | Uniform Nondrug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Caritis SN, Toig G, Heddinger LA, et al. ^137^ | To compare labor-inhibiting properties and side effects of terbutaline and ritodrine | RCT Masking: Subject: yes Physician: yes Other care providers: yes Pharm: dk | PTL: Successful tocolysis: women w/ intact membranes-maintain pregnancy until 32 wks; for all, prevent delivery for at least 36 h | EGA: 23-36 wks | 100/100 | | | | | | Tx1 Ritodrine IV 50 µg/min (incrementally increased every 20 min to maximum dose of 350 µg/min) CoT: initial DoT: until labor stopped or side effects occurred Ritodrine IV at lowest dose to maintain uterine quiescence CoT: after infusion period DoT: 12 h or longer if labor recurred & no PROM Ritodrine oral 20 mg CoT: 30 min before infusion stopped DoT: every 4 h for 5 days Tx2 Terbutaline IV 2.5 µg/min (incrementally increased every 20 min to maximum dose of 17.5 µg/min) CoT: initial DoT: until labor stopped or side effects occurred Terbutaline IV at lowest dose to maintain uterine quiescence CoT: after infusion period DoT: 12 h or longer if labor recurred & no PROM Terbutaline oral 5 mg CoT: 30 min before infusion stopped DoT: every 4 h for 5 days | | Bed rest, fetal monitoring, IV fluids, routine observation, uterine monitoring | | Country: United States Time period: dk | M=58% C=65%
  51 | 49

Evidence Table 3: Tocolytic first line: Beta-mimetics - Study design

Author (Year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion Exclusion Characteristics | Sample Size Initial/End | | | Demographic Characteristics | | | Tocolytic Intervention | Uniform Adjunctive Drug Intervention | Uniform Nondrug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Author (Year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion Exclusion Characteristics | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tocolytic Intervention | Uniform Adjunctive Drug Intervention | Uniform Nondrug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Cotton DB, Strassner HT, Hill LM, et al. ^120^ | To access the efficacy of magnesium sulfate for the inhibition of PTL compared w/ terbutaline and a placebo | RCT Masking: none | PTL: Following hydration (Contractions 3/10 min) and (Dilation progressive over time or Dilation>2 cm or Effacement >80% or Spontaneous PROM) Successful tocolysis: postponement of delivery for >48 h after initiation of treatment | EGA: 26-34 wks Fetal weight: 750-200 gms Also no: Dilation >4 cm, positive Gram stain on amniocentesis, evidence of pulmonary maturity | 54/54 | | | Mean Age (SD) | | | Tx1 Magnesium sulfate IV 4 g CoT: initial DoT: 15 min Magnesium sulfate IV 2 g/h CoT: after initial 15 min infusion DoT: If intact membranes: until no uterine activity for >12 h. If uterine activity reoccurs, agent is readministered. If PROM: At least 48 h after rupture.* Tx2 Terbutaline IV 9.2 µ/min, increasing by approximately 5µ/min to levels as high as 25.3 µ/min dependent on uterine response CoT: initial DoT: If intact membranes: until no uterine activity for >12 h. If uterine activity reoccurs, agent is readministered. If PROM: at least 48 h after rupture.* Cx Dextrose IV 5% in lactated Ringer's solution, 125 mL/h CoT: dk DoT: If intact membranes: until no uterine activity for >12 h. If uterine activity reoccurs, agent is readministered. If PROM: at least 48 h after rupture.* Tx1 & Tx2 * Additional criteria for discontinuing infusions include: progressive cervical dilation >7 cm, evidence of overt amnionitis, fetal distress, maternal heartbeat >150 beats/min, persistent maternal arrhythmia, fetal heart rate >200 beats/min, and maternal respiratory rate < 10 breaths/min. | Steroids AoT: pulmonary maturation | Bed rest, fetal monitoring | Inpatient | Country: dk Time period: dk | M=62% C=88%
  21.8 | 24.3 | 22.6
  (4.6) | (5.9) | (6.4)

Evidence Table 3: Tocolytic first line: Beta-mimetics - Study design

Author (Year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion Exclusion Characteristics | Sample Size Initial/End | | | Demographic Characteristics | | | Tocolytic Intervention | Uniform Adjunctive Drug Intervention | Uniform Nondrug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Author (Year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion Exclusion Characteristics | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tocolytic Intervention | Uniform Adjunctive Drug Intervention | Uniform Nondrug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Tchilinguirian NG, Najem R, Sullivan GB, et al. ^150^ | To obtain information w/ regard to the therapeutic and adverse effects of ritodrine relative to magnesium sulfate | RCT Masking: dk | PTL: Premature Labor Unit (PLU): consisting of: Contractions: 6/h lasting 30 s & amplitude of 20 mmHg above resting uterine tone Successful tocolysis: Arrest labor >48 h , or for long term success, arrest labor >7 days | EGA: 24-36 wks Also no: PROM >24 h before onset of PTL, gravidas suffering from hypertensive disorders or cardiac disease, antepartum hemorrhage, metabolic kidney disease, potentially life-threatening afflictions such as blood dyscrasias and autoimmune diseases, clinically significant Rh or other blood group immunization, obstetric complications that require delivery such as abruption of placentae and prolapse of cord or fetal part. | 67/67 | | | Age= 20 Age 20-30 Age >30 Race, white Race, non-white | | | Tx1 Ritodrine hydrochloride IV, "according to manufacturers' protocol" CoT: initial DoT: after 12 h after the cessation of detectable contractions or until side effects or contraindications to medications occurred Ritodrine oral "according to manufacturers' protocol" CoT: after IV tx DoT: when tx regime was successful, patients were discharged on the 5th day of oral medication Tx2 Magnesium sulfate IV 4 g CoT: initial DoT: 30 min Magnesium sulfate IV 2 g/h CoT: after loading dose DoT: until contractions were reduced to <1 PLU Magnesium sulfate IV 1 g/h CoT: after contractions were reduced to <1 PLU DoT: 12 h after the cessation of detectable contractions or until side effects or contraindications to medications occurred Ritodrine oral, "according to manufacturers' protocol" CoT: after IV treatment DoT: tx regime was successful; patients were discharged on the 5th day of oral medication | | Fetal monitoring, routine observation | Inpatient: dk Outpatient: dk | Country: United States Time period: 1981-1983 | M=65% C=40%
  31 | 36
  5 | 5
  20 | 23
  6 | 8
  24 | 29
  7 | 7

Evidence Table 3: Tocolytic first line: Beta-mimetics - Study design

Author (Year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion Exclusion Characteristics | Sample Size Initial/End | | | Demographic Characteristics | | | Tocolytic Intervention | Uniform Adjunctive Drug Intervention | Uniform Nondrug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Author (Year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion Exclusion Characteristics | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tocolytic Intervention | Uniform Adjunctive Drug Intervention | Uniform Nondrug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Larsen JF, Eldon K, Lange AP, et al. ^121^ | To compare intramuscular ritodrine followed by oral ritodrine treatment and bed rest to placebo and bed rest | RCT Masking: Subject: yes Physician: yes Other care provider: yes Pharm.: dk | Contractions: 1/5 min for 30 min as observed by tocography or 6/30 min observed by tocography or Bishop Score: >4, <9 Successful tocolysis: not defined | EGA: 20-36 wks Intact membranes Singleton preg. Also no: administration of other tocolytic agents before admission, tx w/ beta-blockers, placenta previa, abruptio placentae, vaginal bleeding, severe preeclampsia, Rh or ABO immunization, intrauterine death, fetal malformation, maternal cardiovascular disease, polyhydramnios, history of intrauterine death or serious congenital abnormality, uterine malformation, diabetes, intrauterine infection, need for immediate termination of pregnancy | 125/99 | | | | | | Tx1 Ritodrine intramuscularly 10 mg CoT: dk DoT: one dose Ritodrine intramuscularly 10 mg every 6 h CoT: after initial dose DoT: 24 h Ritodrine oral, lowest possible dosage to inhibit uterine contractions CoT: initiated w/ the last intramuscular injection DoT: until 37 wks Cx Placebo | Betamethasone AOT: fetal lung maturity Indomethacin AoT: given to patients w/ persistent contractions before 30 wks Antibiotics AoT: given to carriers of the group strep to deal w/ the infection | Routine observation, hospitalization for 1 wk | Inpatient: dk Outpatient: dk | Country: Denmark Time period: dk | M=75% C=56%
  49 | | 50

Evidence Table 3: Tocolytic first line: Beta-mimetics - Study design

Author (Year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion Exclusion Characteristics | Sample Size Initial/End | | | Demographic Characteristics | | | Tocolytic Intervention | Uniform Adjunctive Drug Intervention | Uniform Nondrug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Author (Year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion Exclusion Characteristics | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tocolytic Intervention | Uniform Adjunctive Drug Intervention | Uniform Nondrug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Leveno KJ, Guzick DS, Hankins GD, et al. ^151^ | To study the clinical effectiveness of ritodrine treatment as compared to no treatment | RCT Masking: none | PTL: Contractions: regular and Cervical dilation >1 cm Successful tocolysis: failure is defined as: ruptured membranes, dilation progressed >4 cm, contractions for >30 min at max dose w/ continued dilation, or maternal side effects requiring discontinuation | EGA: 24-33 wks Intact membranes Also no: cervical dilation >4 cm, hypertension, diabetes, hyperthyroidism, hemorrhage, cardiac disease, previous caesarian section, chorioamnionitis, fetal growth retardation | 106/106 | | | Mean Age Race, White Race, Black Race, Hispanic | | | Tx1 Ritodrine hydrochloride IV 100 µg/min, increased by 50 µg/min/10 min CoT: dk DoT: until contractions cease or max dose of 350 µg/min reached Ritodrine hydrochloride IV, max dose reached above CoT: after cessation of contractions DoT: 24 h Ritodrine oral 10 mg CoT: 30 min before end of 24 h IV treatment DoT: one dose Ritodrine oral 20 mg/3 h CoT: after initial oral dose DoT: until 36 wks Cx Saline IV 80 mL/hr CoT: dk DoT: 24 h | | Fetal monitoring, routine observation | Inpatient: until 34 wks | Country: United States Time period: 1982-1985 | M=76% C=76%
  54 | | 52
  20.9 | | 20.6
  20 | | 18
  (37%) | | (35%)
  27 | | 28
  (50%) | | (54%)
  7 | | 6
  (13%) | | (12%)

Evidence Table 3: Tocolytic first line: Beta-mimetics - Study design

Author (Year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion Exclusion Characteristics | Sample Size Initial/End | | | Demographic Characteristics | | | Tocolytic Intervention | Uniform Adjunctive Drug Intervention | Uniform Nondrug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Author (Year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion Exclusion Characteristics | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tocolytic Intervention | Uniform Adjunctive Drug Intervention | Uniform Nondrug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Hatjis CG, Swain M, Nelson LH, et al. ^138^ | To determine whether ritodrine alone or ritodrine w/ magnesium sulfate differ w/ respect to their efficacy in controlling PTL or in the incidence of maternal and fetal toxicity | RCT Masking: dk | PTL: not defined, references previous publication Successful tocolysis: Pregnancy prolongation of at least 1 wk from initiation of treatment | EGA: 20-35 wks Also no: abnormal fetus, contraindications to use of IV ritodrine | 74/64 | | | Mean Age (SD) Race, White Race, Other | | | Tx1 Ritodrine IV 50 µg/min, increased by 50 µg/min every 10 min CoT: initial DoT: 8-10 h contractions stopped, max 350 µg/min or unacceptable side effects occurred Ritodrine IV dosage: dk, gradually decreased CoT: after cessation of contractions DoT: dk Ritodrine or Terbutaline oral, dosage: dk CoT: after IV ritodrine dosage was decreased DoT: until 37 wks gestation or until recurrence of labor Magnesium sulfate CoT: unresponsive to IV ritodrine & contractions every 5-7 minutes for at least @@@frac12@@@ h &/or increase in pelvic score Tx2 Magnesium sulfate IV 4 g for 20-30 min, then 2-3 g/h CoT: initial DoT: until reached serum magnesium level of 5-7 mg% Ritodrine IV 50 µg/min, and increased according to protocols outlined in Lipshitz (1981) CoT: after loading dose of magnesium sulfate was completed DoT: until contractions stopped, and then tapered off over next 10-12 h Ritodrine or Terbutaline oral, dosage: dk CoT: after IV ritodrine dosage was tapered off DoT: until 37 wks gestation or until recurrence of labor | | Fetal monitoring, IV fluids, uterine monitoring, vitals signs taken: heart rate, blood pressure respiratory rate, deep tendon reflexes, evidence of fluid overload, ECG | Inpatient | Country: United States Time period: 1982-1984 | M=56% C=31%
  32 | 32
  Group IA: ritodrine alone - success, N= 11;
  Group IB: ritodrine alone - failure, N=5
  Group IC: ritodrine alone, followed by magnesium - success, N=12;
  Group ID: ritodrine alone followed by magnesium - failure, N=4
  Group 2A: ritodrine and magnesium together - success; N=19;
  Group 2B: ritodrine and magnesium together - failure, N=13
  22.31 | 22.63
  (5.20) | (5.10)
  23 | 19
  9 | 13

Evidence Table 3: Tocolytic first line: Beta-mimetics - Study design

Author (Year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion Exclusion Characteristics | Sample Size Initial/End | | | Demographic Characteristics | | | Tocolytic Intervention | Uniform Adjunctive Drug Intervention | Uniform Nondrug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Author (Year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion Exclusion Characteristics | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tocolytic Intervention | Uniform Adjunctive Drug Intervention | Uniform Nondrug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Wilkins IA, Lynch L, Mehalek KE, et al. ^122^ | To examine the efficacy and side effects of ritodrine compared to magnesium sulfate | RCT Masking: Subject: dk Physician: dk Pharm.: dk Other care providers: dk | PTL: Contractions: every 5 min and (Dilation:>2 cm or Effacement:>50% or Other: progressive cervical change while contracting during a period of observation) Successful tocolysis: prolongation of pregnancy for>48 h | EGA: 25-36 wks Intact membranes Also no: sig. bleeding, fetal distress, preeclampsia, fetal anomaly, suspected growth retardation, dilation >4 cm | 120/120 | | | Mean Age (SD) P=NS | | | Tx1 Ritodrine IV 0.1 mg/min (increased by 0.05 mg/min every 15-20 min to a maximum of 0.35 mg/min CoT: initial DoT: 12 h after contractions stopped or maternal pulse 140 beats/min Tx2 Magnesium sulfate IV 4 mg/ over 15 min (followed by 2 gm/h w/rate increased if contractions continued and serum level below 5 to 8 mg/dL, decreased if serum level above 5 to 8 mg/dL) CoT: initial DoT: 24 h after contractions stopped Tx1 & Tx2 Ritodrine oral 20 mg/2 h tapered to every 4 h before discharge CoT: after IV tx DoT: until 37 wks gestation Tx1 & Tx2 Original drug IV followed by second-line therapy CoT: episode of PTL followed by oral tocolytic | | Bed rest, routine observation, uterine monitoring, weekly visits to a high risk clinic w/ weekly exams | Inpatient: dk Oral Outpatient: dk | Country: United States Time period: 1985-1987 | M=76% C=58%
  54 | 66
  23.3 | 23.7
  (4.4) | (4.9)

Evidence Table 3: Tocolytic first line: Beta-mimetics - Study design

Author (Year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion Exclusion Characteristics | Sample Size Initial/End | | | Demographic Characteristics | | | Tocolytic Intervention | Uniform Adjunctive Drug Intervention | Uniform Nondrug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Author (Year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion Exclusion Characteristics | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tocolytic Intervention | Uniform Adjunctive Drug Intervention | Uniform Nondrug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Morales WJ, Smith SG, Angel JL, et al. ^123^ | To compare the relative efficacy and maternal/neonatal effects of indomethacin and ritodrine hydrochloride | RCT Masking: Subject: dk Physician: dk Other care givers: no Pharm.: dk | PTL: Contractions: 4 in 20 min and (Dilation or Effacement) Successful tocolysis: not defined | EGA: 32 wks or less Intact membranes Also no: abnormal fetus, chorioamnionitis, dilation >4 cm, evidence of intra-amniotic infection, pyelonephritis, complications contraindicating tocolysis | 106/106 | | | Mean Age (SD) Black | | | Tx1 Indomethacin rectal suppository 100 mg CoT: initial DoT: once or twice Indomethacin oral 25 mg/4 h CoT: after initial DoT: 48 h Magnesium sulfate IV 5 g CoT: if serious side effects from indomethacin DoT: one dose Magnesium sulfate IV 2-4 g/h CoT: after initial dose of mag sulfate DoT: dk Terbutaline CoT: after first-line tx completed DoT: dk, prophylaxis Tx2 Ritodrine IV 50 µg/min, increasing by 50 µg/min every 20 min CoT: initial DoT: until contraction cease or max dose of 350 µg/min Terbutaline CoT: after first-line tx completed DoT: dk, prophylaxis | | | Inpatient | United States Time period: 1987-1988 | M=60% C=32%
  52 | 54
  21.8 | 20.9
  (3.9) | (4.1)
  39% | 56%

Evidence Table 3: Tocolytic first line: Beta-mimetics - Study design

Author (Year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion Exclusion Characteristics | Sample Size Initial/End | | | Demographic Characteristics | | | Tocolytic Intervention | Uniform Adjunctive Drug Intervention | Uniform Nondrug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Author (Year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion Exclusion Characteristics | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tocolytic Intervention | Uniform Adjunctive Drug Intervention | Uniform Nondrug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Ferguson JE, Dyson DC, Schutz T, et al. ^125^ | To compare tocolysis w/ nifedipine to tocolysis w/ ritodrine | RCT Masking: none | PTL: Contractions: >8/h and (Change in dilation [before 36 wks]) or (Change in effacement[before 36 wks]) Successful tocolysis: defined as delay delivery 48 h if PROM and through 36 completed wks gestation in patients w/ intact membranes | EGA: 20-36 wks Also no: abnormal fetus, dilation >4 cm, fetal distress, multiple gestation, diabetes, hyperthyroidism, cardiac disease, hydramnios, abruptio placentae, dead fetus, intrauterine growth retardation | 66/66 | | | Mean Age (SD) | | | Tx1 Nifedipine sublingually 10 mg (increased to 40 mg) CoT: initial: if contractions persist after 20 min, similar dose until maximum 40 mg during first h DoT: first hour Nifedipine oral 20 mg, typically at 4-6 h intervals CoT: if sublingual stopped contractions, commenced 6 h later DoT: dk Tx2 Ritodrine IV 50 µg/min (increased every 15-30 min by 50 µg) CoT: initial DoT: contractions inhibited, adverse events developed, or 350 mg/min reached Ritodrine IV decreased 50 mg/min CoT: after first ritodrine DoT: 12 h Ritodrine IV decreased 50 µg/min every 2 h COT: after 12 h of tx DOT: 100 µg/min reached Ritodrine oral 10-20 mg CoT: 30 min before discontinuation of IV DoT: every 4-6 h until dk | Hydration Betamethasone AoT: fetal lung maturation | Bed rest, fetal monitoring, IV fluids, uterine monitoring, electrocardiogram | | Country: United States Time period: 1984-1987 | M=60% C=65%
  33 | 33
  26.7 | 25.7
  (5.2) | (4.9)

Evidence Table 3: Tocolytic first line: Beta-mimetics - Study design

Author (Year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion Exclusion Characteristics | Sample Size Initial/End | | | Demographic Characteristics | | | Tocolytic Intervention | Uniform Adjunctive Drug Intervention | Uniform Nondrug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Author (Year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion Exclusion Characteristics | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tocolytic Intervention | Uniform Adjunctive Drug Intervention | Uniform Nondrug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Meyer WR, Randall HW, Graves WL ^126^ | To compare the tocolytic efficacy and safety of nifedipine and ritodrine hydrochloride | RCT Masking: Subject: dk Physician: none Pharm.: dk Other care providers: dk | PTL: (Contractions:>6 within 30 min. or Dilation: change from baseline) and Contractions unresolved w/: bed rest, sedation, hydration IV, & 5 mg oral & 250 µg subcutaneous terbutaline w/ no response Successful tocolysis: delivery deferred for >24 h | EGA: 22-35 wks Intact membranes Also no: current bleeding, multiple gestation, maternal infection, medical contraindication to tocolysis | 58/58 | | | | | | Tx1 Nifedipine oral 30 mg initially CoT: in PTL according to definition DoT: one dose Nifedipine oral 20 mg CoT: after initial dose DoT: every 6 h for 24 h , followed by every 8 h for 24 h Nifedipine oral 10 mg CoT: day 3 DoT: every 8 h until delivery Tx2 Ritodrine IV 50 µg/min w/ 50-µg increments to a maximum of 350 µg/min CoT: in PTL according to definition DoT: every 20 min for 12 h or side effects intolerable Terbutaline 5 mg oral CoT: after ritodrine DoT: every 6 h Tx1 & Tx2 Magnesium sulfate 6 g IV CoT: Nifedipine & Ritodrine failures DoT: 1 dose Magnesium sulfate 2 g/h IV CoT: following dose 1 DoT: dk | | Bed rest, fetal monitoring,rehydration,Doppler ultrasound for 6 subjects who agreed to nifedipine treatment | Inpatient: first 72 h Outpatient: dk | Country: United States Time period: 1986-1987 | M=76% C=40%
  34 | 24

Evidence Table 3: Tocolytic first line: Beta-mimetics - Study design

Author (Year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion Exclusion Characteristics | Sample Size Initial/End | | | Demographic Characteristics | | | Tocolytic Intervention | Uniform Adjunctive Drug Intervention | Uniform Nondrug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Author (Year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion Exclusion Characteristics | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tocolytic Intervention | Uniform Adjunctive Drug Intervention | Uniform Nondrug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Bracero LA, Leikin E, Kirshenbaum N, et al. ^127^ | To compare the efficacy of nifedipine w/ ritodrine in the control of PTL and compare their side effects | RCT Masking: none | PTL: (Dilation: >2 cm or Effacement: >80%) or Contractions: >2/10 min & have not met dilation or effacement criteria, hydrated w/500 cc crystalloid solution but after 1 h contractions every 5 m, in lasting >30 s Successful tocolysis defined as >72 h prolongation | EGA: 20-36 wks Intact membranes Singleton Also: cervix <4 cm dilated, no: contraindications to tocolysis w/ ritodrine or nifedipine | 49/42 | | | Mean Age (SD) p=0.254 | | | Tx1 Ritodrine IV 0.1 mg/min (increased by 0.05 mg/min every 10 min) to a max dose of 0.35 mg/min CoT: initial DoT: 12 h Ritodrine oral 10 mg CoT: 30 min before discontinuation of IV DoT: every 2 h for 24 h Ritodrine oral 10 mg CoT: after 24 h of oral dosing DoT: every 4 h for 24 h Ritodrine oral 10 or 20 mg CoT: after 48 h of oral dosing DoT: every 4-6 h until dk Tx2 Nifedipine oral 30 mg CoT: initial DoT: one dose Nifedipine oral 20 mg CoT: after initial dose DoT: every 6 h for 24 h Nifedipine oral 20 mg CoT: after 24 h of oral dosing DoT: every 8 h for 24 h Nifedipine oral 20 mg CoT: after 24 h of oral dosing DoT: every 8-12 h until dk | | | | Country: dk Time period: 1987-1988 | M=74% C=66%
  19 | 23
  26 | 24
  (4) | (6)

Evidence Table 3: Tocolytic first line: Beta-mimetics - Study design

Author (Year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion Exclusion Characteristics | Sample Size Initial/End | | | Demographic Characteristics | | | Tocolytic Intervention | Uniform Adjunctive Drug Intervention | Uniform Nondrug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Author (Year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion Exclusion Characteristics | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tocolytic Intervention | Uniform Adjunctive Drug Intervention | Uniform Nondrug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Kurki TK, Eronen M, Lumme R, et al. (1991) | To compare the tocolytic effects of indomethacin and nylidrin where the appearance of the treatment was identical to the subjects | RCT Masking: Subject: yes Physician: yes Pharm.: dk Other care providers: dk | PTL: Contractions: painful and >1 every 10 minand Dilation: 2-4 cmand Bishop score: 1-9 Unsuccessful tocolysis: delivery during tocolysis or recurrence of contractions within 48 h after cessation of treatment | EGA: 25-34 wks Intact membranes Also no: abnormal amniotic fluid volume, abnormal fetus, chorioamnionitis, dilation >4 cm, fetal distress, multiple gestation, placenta previa, PROM, fetal growth retardation, previous tocolytics in current pregnancy, illness contraindicating tocolysis | 60/60 | | | Age (SD) | | | Tx1 Indomethacin rectal suppository 100 mg CoT: initial DoT: single dose Indomethacin oral 50 mg CoT: 8 h after initial dose DoT: every 8 h for up to 1 day (2 doses) or until contractions cease Indomethacin oral 50 mg CoT: after day 1 DoT: every 8 h for up to 2 days, or until contractions cease Tx2 Nylidrin IV 50 µg /min CoT: initial DoT: 30 min Nylidrin IV 100-150 µg/min CoT: within 30 min of initial dose DoT: 3 days or until contractions cease | Tx1Saline IV Tx2Placebo rectal suppository & oral capsules | IV fluids, routine observation, uterine monitoring, cervical exam 24 h after initiation of tx | Inpatient | Country: Finland Time period: 1987-1990 | M=79% C=52%
  30 | 30
  29.0 | 29.1
  (1.0) | (1.1)

Evidence Table 3: Tocolytic first line: Beta-mimetics - Study design

Author (Year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion Exclusion Characteristics | Sample Size Initial/End | | | Demographic Characteristics | | | Tocolytic Intervention | Uniform Adjunctive Drug Intervention | Uniform Nondrug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Author (Year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion Exclusion Characteristics | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tocolytic Intervention | Uniform Adjunctive Drug Intervention | Uniform Nondrug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Noblot G, Audra P, Fagur B, et al. ^160^ | To evaluate the efficacy of progesterone prolonged therapy in conjunction w/ IV infusion of ritodrine | RCT Masking: Subject: yes Physician: yes Pharm: none Other care providers: dk | PTL: Contractions: 1/10 min, persisting after 1h restor Cervical change Successful tocolysis: not defined | EGA: 0-35 wks Intact membranes if before wk 32 Also no: cardiopathy, fever, abnormal fetal cardiac rhythm, previous treatment w/ β-mimetics | 44/44 | | | Mean Age | | | Tx1 & Cx Ritodrine IV 0.2 mg/min CoT: upon admission DoT: 1 h Ritodrine IV varied dose (adapted to each individual evolution while trying to administer lowest possible dose capable of maintaining tocolysis and to interrupt IV administration for oral administration as soon as possible) CoT: after initial h DoT: up to 24 h after initiation of tocolysis | Tx1Micronized progesterone oral 400 mg/6 h CoT: w/ initial ritodrine DoT: 24 h Micronized progesterone oral 400 mg/8 h CoT: after initial 24 h DoT: 24 h Micronized progesterone oral 300 mg/6 h CoT: after 48 h DoT: dk CxPlacebo (follows pattern for progesterone) | Uterine monitoring | Inpatient | Country: France Time period: 1987 | M=76% C=71%
  22 | | 22
  22.6 | | 28.6

Evidence Table 3: Tocolytic first line: Beta-mimetics - Study design

Author (Year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion Exclusion Characteristics | Sample Size Initial/End | | | Demographic Characteristics | | | Tocolytic Intervention | Uniform Adjunctive Drug Intervention | Uniform Nondrug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Author (Year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion Exclusion Characteristics | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tocolytic Intervention | Uniform Adjunctive Drug Intervention | Uniform Nondrug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
The Canadian Preterm Labor Investigators Group ^96^ | To assess the effect of ritodrine on perinatal mortality. Secondary objectives included: evaluation of the causes of perinatal death, the extent to which death was delayed w/ ritodrine, effects on birth weight, maternal morbidity, neonatal morbidity, and infant morbidity at 18 months of postnatal age (corrected for preterm delivery). | RCT Masking: Subject: yes Physician: yes Other care providers: yes Pharm.: none | Contractions: 4/20 min or 6/60 minor(Uterine activity and[PROM or Dilation>2 cmor Effacement >50%]) Successful tocolysis: dk | EGA: 20-35 wks Also no: contraindication to the study drug, cardiovascular disease, hyperthyroidism, uncontrolled diabetes, asthma; lethally malformed or dead fetus, fetal distress, serious vaginal bleeding, chorioamnionitis, severe preeclampsia, any other maternal or fetal indication for delivery | 708/708 | | | | | | Tx1 Ritodrine IV 10-70 mL/h, adjusted every 20 min, max dose 0.35 mg/min CoT: dk DoT: until cessation of uterine activity, failure of therapy, or occurrence of unacceptable side effects Ritodrine IV effective dose from treatment #1 CoT: after cessation of contractions DoT: >6 h after cessation of regular uterine contractions, then the dose was progressively decreased until the infusion was ended Ritodrine oral 10 mg CoT: after contractions cease DoT: up to 12 tablets/day for 5 days Cx Dextrose solution IV 10-70 mL/h, adjusted every 20 min CoT: dk DoT: until cessation of uterine activity Placebo oral 10 mg CoT: after contractions cease DoT: up to 12 tablets/day for 5 days | | IV fluids | Inpatient: dk Outpatient: dk | Country: Canada Time period: 1985-1990 | M=82% C=100%
  352 | | 356

Evidence Table 3: Tocolytic first line: Beta-mimetics - Study design

Author (Year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion Exclusion Characteristics | Sample Size Initial/End | | | Demographic Characteristics | | | Tocolytic Intervention | Uniform Adjunctive Drug Intervention | Uniform Nondrug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Author (Year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion Exclusion Characteristics | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tocolytic Intervention | Uniform Adjunctive Drug Intervention | Uniform Nondrug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Kupferminc M, Lessing JB, Yaron Y, et al. ^130^ | To compare the efficacy of tocolysis w/ specific regimens of nifedipine and ritodrine | RCT Masking: dk | PTL: Contractions: > 1/6 min and change in Cervical dilation or Cervical effacement Successful tocolysis: delivery deferred >48 h | EGA: 26-34 wks Intact membranes Also no: cervical dilation >4 cm, polyhydramnios, placental abruption, hypertension, signs of infection, any medical condition which contraindicates use of tocolytic therapy | 71/71 | | | Mean Age (SD) | | | Tx1Nifedipine oral 30 mg CoT: after initial examination DoT: loading dose Nifedipine oral 20 mg CoT: if contractions persist after 90 min DoT: one dose Nifedipine oral 20 mg/8 h CoT: if either or both treatments successfully suppressed contractions DoT: maintenance until uterine quiescence Ritodrine IV dose: dk CoT: if contractions persist more than 60 min after second loading dose, these patients never received the maintenance dose DoT: dk Tx2 Ritodrine IV 50 µg/min, and increased by 15 µg/min/15 min to a max of 300 µg/min CoT: after initial examination DoT: effective dose maintained for 12 h or until contractions stopped, or unacceptable side effects developed Ritodrine oral 10 mg/3 h CoT: after effective dose DoT: until 35 wks | Betamethasone AoT: to enhance fetal lung maturity | Bed rest, fetal monitoring, IV fluids, uterine monitoring, maternal blood pressure and pulse | Inpatient | Country: Israel Time period: 1988-1992 | M=60% C=83%
  36 | 35
  28.4 | 28.6
  (4.1) | (4.3)

Evidence Table 3: Tocolytic first line: Beta-mimetics - Study design

Author (Year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion Exclusion Characteristics | Sample Size Initial/End | | | Demographic Characteristics | | | Tocolytic Intervention | Uniform Adjunctive Drug Intervention | Uniform Nondrug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Author (Year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion Exclusion Characteristics | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tocolytic Intervention | Uniform Adjunctive Drug Intervention | Uniform Nondrug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Eronen M, Pesonen E, Kurki TM, et al. (1994) | To assess the effect on neonatal outcomes of either an inhibitor of prostoglandin synthesis or a β-adrenergic agonist to treat PTL | RCT Masking: Subject: none Physician: none Pharm.: none Other care providers: none | PTL: Contractions: 1 in 10 min or lessand Cervical change (dilation 2-4 cm, softening) Successful tocolysis: not defined | EGA: 24-34 wks Intact membranes Also no: abnormal fetus, suspected chorioamnionitis, fetal distress, vaginal bleeding, pregnancy-induced hypertension, sensitivity to salicylates, history of peptic ulcer | 80/80 | | | Mean Age (SD) | | | Tx1 Placebo IV Indomethacin suppository 100 mg CoT: initial DoT: single dose Indomethacin oral 50 mg every 8 h CoT: after initial dose DoT: until contractions cease or max of 3 days Nylidrin IV dose:dk CoT: if labor reoccurs within 72 h of initial cessation and if before 35 wks DoT: dk Tx2 Nylidrin IV 50 µg/min CoT: initial DoT: <30 min Nylidrin IV 100-150 µg/min CoT: after initial dose DoT: until contractions cease or maximum of 8 days Placebo suppository Nylidrin IV dose: dk CoT: if labor reoccurs within 72 h of initial cessation and if before 35 wks DoT: dk | | Bed rest, routine observation | Inpatient | Country: Finland Time period: 1988-1992 | M=76% C=66%
  40 | 40
  28.2 | | 29.7
  (5.7) | | (5.0)

Evidence Table 3: Tocolytic first line: Beta-mimetics - Study design

Author (Year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion Exclusion Characteristics | Sample Size Initial/End | | | Demographic Characteristics | | | Tocolytic Intervention | Uniform Adjunctive Drug Intervention | Uniform Nondrug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Author (Year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion Exclusion Characteristics | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tocolytic Intervention | Uniform Adjunctive Drug Intervention | Uniform Nondrug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Holleboom CAG, Merkus JMWM, van Elferen, et al. ^131^ | To compare a new loading dose regimen for IV ritodrine administration in PTL w/ the conventional dose regimen | RCT Masking: Subject: no Physician: no Other care provider: no Pharm.: dk | PTL: Contractions: >3 per 15 minand/or Cervical dilation increase Successful tocolysis: arrest of IV treatment in the absence of progressive labor or reaching 34 wks, whichever occurs first | EGA: < 34 wks Intact membranes Normal ECG Also no: abnormal fetus, earlier tocolytic treatment in current pregnancy, intrauterine infection, full dilation before randomization | 203/201 | | | | | | Tx1 Ritodrine IV 200 µg/min, increasing to 400 µg/min & 600 µg/min at 2 h intervals CoT: initial DoT: until tocolysis is achieved or up to 6 h Ritodrine IV, same dose as above CoT: after tocolysis is achieved DoT: 24-48 h after contractions cease Ritodrine IV 50 µg/min CoT: after second treatment ends DoT: 12-24 h Ritodrine or placebo oral, dose: 240 mg daily for ritodrine CoT: after maintenance treatment ends DoT: 7 days Tx2 Ritodrine IV 50 µg/min CoT: initial DoT: one loading dose Ritodrine IV, increase loading dose by 50 µg/min every 15 min CoT: after loading dose DoT: until uterine quiescence or until side effects prohibited further dose increases Ritodrine IV 50 µg/min CoT: after second treatment ends DoT: 12-24 h Ritodrine or placebo oral, dose: 240 mg daily for ritodrine CoT: after maintenance treatment ends DoT: 7 days | | Fetal monitoring, maternal heart rate and blood pressure | Inpatient | Country: Netherlands Time period: dk | M=65% C=80%
  100 | 101

Evidence Table 3: Tocolytic first line: Beta-mimetics - Study design

Author (Year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion Exclusion Characteristics | Sample Size Initial/End | | | Demographic Characteristics | | | Tocolytic Intervention | Uniform Adjunctive Drug Intervention | Uniform Nondrug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Author (Year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion Exclusion Characteristics | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tocolytic Intervention | Uniform Adjunctive Drug Intervention | Uniform Nondrug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Kanayama N, El Maradny E, Yamamoto N, et al. ^132^ | To study and compare the effect of urinary trypsin inhibitor w/ ritodrine in treating PTL | RCT Masking: none | PTL: (History of contractions and Dilation: >2 cm and Effacement: >80% and Nulliparous)or(History of contractions and Dilation: >3 cm and Effacement: >80% and Multiparous)or Contractions: 4/20 min for 1 h Successful tocolysis: not defined | EGA: 22-34 wks Intact membranes Also no: abnormal fetus, chorioamnionitis, dilation >5 cm fetal distress, hypertensive disorders, diabetes mellitus, hyperthyroidism, cardiac diseases, abruptio placentae, renal failure, intrauterine growth retardation, fetal death, hydraminiol, study participants w/ untreatable contractions within 14 days, of discharge | 160/132 | | | Age Primis (SD) Age Multi (SD) | | | Tx1 Urinary trypsin inhibitor vaginal suppository 5000 units CoT: dk DoT: daily for 14 days Tx2 Ritodrine IV 50 µg/min (increased by 50 µg/min every 15 min until a maximum of 300 µg/min or contractions ceased or side effects CoT: dk DoT: 48 h Ritodrine oral 10mg CoT: after IV DoT: every 3 h until 35 wks gestation | None | Bed rest | Hospitalization for 7 days after tocolysis | Country: Japan Time period: 1992-1995 | M=83% C=88%
  66 | 66
  27.7 | 26.6
  (2.76) | (5.77)
  25.6 | 27.0
  (4.61) | (4.81)

Evidence Table 3: Tocolytic first line: Beta-mimetics - Study design

Author (Year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion Exclusion Characteristics | Sample Size Initial/End | | | Demographic Characteristics | | | Tocolytic Intervention | Uniform Adjunctive Drug Intervention | Uniform Nondrug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Author (Year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion Exclusion Characteristics | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tocolytic Intervention | Uniform Adjunctive Drug Intervention | Uniform Nondrug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Guinn DA, Goepfert AR, Owen J, et al. ^133^ | To compare three management strategies in women w/ PTL (observation and bed rest, IV hydration, and terbutaline sulfate) | RCT Masking: none | Contractions: >3/30 minand(Dilation change >1 cmor Effacement >25%) Successful tocolysis: delay in delivery for a min of 48 h after initiation of therapy | EGA: 20-34 wks Intact membranes Singleton gestation, dilation <1 cm, effacement <80% Also no: vaginal bleeding, abnormal fetus incompatible w/ life, chorioamnionitis, placenta previa, oligohydramnios, severe uterine growth restriction, nonreassuring fetal heart rate tracing, known fetal pulmonary maturity, maternal infection, uncontrolled diabetes, diabetic ketoacidosis, preeclampsia cardiac arrhythmias, pulmonary edema, severe hypertension | 179/179 | | | Mean age (SD) p=0.31 Race, Black p=0.45 | | | Tx1 Crystalloid IV 500 mL CoT: dk DoT: once over 20 min Crystalloid IV 200 mL/h CoT: after initial IV DoT: "continuous" Tx2 Terbutaline subcutaneous 0.25 mg CoT: dk DoT: 1 dose Cx Observation and bed rest only (If contractions persisted, all patients eligible for treatment w/ magnesium sulfate.) | | Uterine monitoring, discharge instructions | Inpatient | Country: United States Time period: 1993-1995 | M=66% C=80%
  62 | 61 | 56
  21.6 | 23.2 | 22.6
  (5.3) | (6.6) | (5.3)
  68% | 70% | 79%

Evidence Table 3: Tocolytic first line: Beta-mimetics - Study design

Author (Year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion Exclusion Characteristics | Sample Size Initial/End | | | Demographic Characteristics | | | Tocolytic Intervention | Uniform Adjunctive Drug Intervention | Uniform Nondrug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Author (Year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion Exclusion Characteristics | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tocolytic Intervention | Uniform Adjunctive Drug Intervention | Uniform Nondrug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Jannet D, Abankwa A, Guyard B, et al. ^134^ | To compare the tocolytic action and the side effects of nicardipine to those of salbutamol in patients presenting w/ PTL | RCT Masking: none | | PTL: Contractions: 3/30 minand Dilation:>2 cm Successful tocolysis: defined as delivery at >37 wks | 90/86 | | | Age (SD) | | | Tx1 Nicardipine IV 3 mg/h CoT: after exam DoT: 2 h Nicardipine IV to maximum 6 mg/h CoT: after above DoT: until cessation of uterine activity or troublesome side effects Nicardipine oral 60 mg CoT: after IV DoT: daily until 37 wks gestation Tx2 Salbutamol IV 0.15 mg/h CoT: after exam DoT: 2 h Salbutamol IV to maximum of 0.3 mg/h CoT: after above DoT: until cessation of uterine activity or troublesome side effects Salbutamol oral 8 mg and suppositories 2 mg CoT: after IV DoT: daily until 37 wks gestation | None | Bed rest, IV fluids, routine observation | Regular house calls by midwives and clinic visits twice monthly | Country: France Time period: 1993-1994 | M=80% C=83%
  43 | 43
  29.4 | 28.9
  (5.5) | (6.3)

Evidence Table 3: Tocolytic first line: Beta-mimetics - Study design

Author (Year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion Exclusion Characteristics | Sample Size Initial/End | | | Demographic Characteristics | | | Tocolytic Intervention | Uniform Adjunctive Drug Intervention | Uniform Nondrug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Author (Year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion Exclusion Characteristics | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tocolytic Intervention | Uniform Adjunctive Drug Intervention | Uniform Nondrug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Papatsonis DNM, van Geijn HP, Ader HJ, et al. ^159^ | To compare tocolytic efficacy and perinatal outcomes and to assess maternal side effects | Multicenter RCT Masking: Subject: none Physician: none Pharm.: none Other care providers: dk | PTL: Contractions: 1/10 min, for at least 1 hand/or PROM Successful tocolysis: not defined | EGA: 20-33 4/7 wks Also no: multiple pregnancy, documented intrauterine infection, abnormal fetus, abruptio placentae, fetal growth restrictions, maternal contraindications for beta-adrenergic drugs (diabetes mellitus, cardiovascular disease, hyperthyroidism, server preeclampsia) | 185/173 Intact membranes PROM | | | Mean Age (SD) Intact membranes PROM | | | Tx1 Ritodrine IV fixed loading dose followed by infusion w/ dose decreasing progressively in cases without recurrence of contractions (following protocol of Holleboom, et al.) CoT: initial DoT: at least 3 days Ritodrine oral 40 mg, 3/day (at 2 of 3 sites) CoT: after infusion DoT: until 34 wks Ritodrine IV &/or oral CoT: recurrent contractions DoT: 34 wks Indomethacin 300 mg/day CoT: only in case of ritodrine tocolysis failure DoT: 3 days Tx2 Nifedipine oral 10 mg/15 min CoT: initial DoT: until contraction cessation or max of 4 doses Nifedipine oral 60-160 mg/day CoT: after initial dose DoT: until 34 wks Indomethacin 300 mg/day CoT: only in case of nifedipine tocolysis failure DoT: 3 days | Steroids AoT: fetal lung maturation | Bed rest | Inpatient | Country: Holland Time period: 1992-1995 | M=72% C=100%
  78 | 95
  61 | 68
  29 | 27
  29.8 | 28.7
  (5.0) | (5.8)
  29.3 | 28.3
  (5.6) | (4.6)

Evidence Table 3: Tocolytic first line: Beta-mimetics - Study design

Author (Year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion Exclusion Characteristics | Sample Size Initial/End | | | Demographic Characteristics | | | Tocolytic Intervention | Uniform Adjunctive Drug Intervention | Uniform Nondrug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Author (Year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion Exclusion Characteristics | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tocolytic Intervention | Uniform Adjunctive Drug Intervention | Uniform Nondrug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Garcia-Velasco JA, Gonzalez AG ^153^ | To compare tocolytic efficacy of ritodrine and nifedipine using umbilical pulsed-Doppler ultrasound studies to evaluate fetal blood flow | RCT Masking: dk | PTL: Contractions: minimum of 4 every 30 min, "despite of" cervical changes Successful tocolysis: cessation of uterine activity within 12 h of initiation of tocolytic intervention | EGA: 26-34 wks Intact membranes Also no: multiple gestation, bleeding, dilation >3 cm, previous tocolytic treatment, evidence of maternal infection, any condition that would contraindicate tocolytic therapy | 52/52 | | | Mean Age (SD) | | | Tx1 Ritodrine IV 0.05 mg/min & 0.05 increments every 20 min until contractions ceased or heart rate 120 bpm or higher (max dose was 0.35 mg/min) CoT: dk DoT: 12 h Ritodrine oral 5 mg every 3 h CoT: after IV ritodrine stage complete DoT: up to 12 h, including loading dose Tx2 Nifedipine oral & sublingual initial loading dose 30 mg (20 mg os & 10 mg sublingual) CoT: on uterine activity DoT: one dose Nifedipine oral & sublingual 10-20 mg every 4-6 h, depending on uterine activity CoT: after initial loading DoT: up to 12 h, including loading dose Tx1 & Tx2 Indomethacin rectal 100 mg CoT: 12 h after tocolysis therapy begun and uterine activity still present or prior tocolytic treatment poorly tolerated DoT: single dose Indomethacin oral 25 mg per os CoT: after indomethacin initial dose DoT: every 6 h for up to 3 days | Betamethasone AoT: fetal lung maturation | Bed rest, fetal monitoring, IV fluids, follow-up in high risk clinic | Inpatient | County: dk Time period: 1993-1996 | M=67% C=64%
  26 | 26
  27.62 | 28.76
  (2.01) | (1.52)

Evidence Table 3: Tocolytic first line: Beta-mimetics - Study design

Author (Year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion Exclusion Characteristics | Sample Size Initial/End | | | Demographic Characteristics | | | Tocolytic Intervention | Uniform Adjunctive Drug Intervention | Uniform Nondrug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Author (Year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion Exclusion Characteristics | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tocolytic Intervention | Uniform Adjunctive Drug Intervention | Uniform Nondrug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Koks CAM, Brölmann HAM, de Kleine MJL, et al. ^135^ | To compare the efficacy and safety of nifedipine and ritodrine in preventing preterm labor, and to evaluate maternal side effects and neonatal outcome | RCT Masking: none | PTL: Contractions: 6/h w/ 30 s duration or more and with or without dilatation and effacement Successful tocolysis: not defined | EGA: 24-34 wks Also no: history of any medical condition which would contraindicate the use of either drug, intrauterine infections, irregular fetal heart rate, history of antepartum hemorrhage or polyhydramnios | 102/102 | | | Mean Age (SD) | | | Tx1 Nifedipine sublingual 30 mg (if already on β-mimetics, dose was halved and nifedipine started w/ 20 mg orally, other tocolytic was stopped after 12 h, and the normal nifedipine dosage started) CoT: dk DoT: single dose Nifedipine oral 20 mg, 2-4 times daily (max dose increased to 40 mg every 8 h after 2/93) CoT: after initial dose DoT: until tocolysis achieved Nifedipine oral, dose reduced w/ minimal of 20 mg 3 times daily CoT: dk DoT: after 34 wks or earlier if possible Tx2 Ritodrine IV 200 mcg/min CoT: dk DoT: until tocolysis is achieved (Note: if patient already on β-mimetics, the dose was continued) Ritodrine IV dose decreased as much as possible, max of 400 mcg/min CoT: once tocolysis is achieved DoT: dk Ritodrine oral 80 mg, 3 times daily CoT: dk DoT: after 34 wks or earlier if possible Tx1 & Tx2 Indomethacin dose: dk (given to patients w/ persistent contractions before 30 wks) | Betamethasone AOT: fetal lung maturity Antibiotics AoT: given to carriers of the group β strep to treat the infection | Routine observation, uterine monitoring, fetal monitoring | Inpatient | Country: Netherlands Time period: 1992-1995 | M=63% C=79%
  55 | 47
  29.8 | 29.3
  (4.8) | (4.9)

Evidence Table 3: Tocolytic first line: Beta-mimetics - Study design

Author (Year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion Exclusion Characteristics | Sample Size Initial/End | | | Demographic Characteristics | | | Tocolytic Intervention | Uniform Adjunctive Drug Intervention | Uniform Nondrug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Author (Year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion Exclusion Characteristics | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tocolytic Intervention | Uniform Adjunctive Drug Intervention | Uniform Nondrug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Spearing G ^146^ | To compare various approaches to arresting PTL | Non-random-ized control trial Masking: dk. | PTL: Contractions: >1 per 10 min, regular and painful Successful tocolysis: 48 h free of uterine activity | EGA: 26-35 wks Also no: inadvisable to arrest labor, antepartum hemorrhage, known fetal abnormality, gross hydramnios | 66/62 | | | | | | Tx1 Alcohol IV 10% solution of 5% dextrose, 15 mL/kg CoT: dk DoT: 2 h Alcohol IV 1.5 mL/kg of body weight CoT: after loading dose DoT: dk Tx2 Alcohol (same as Tx1, dose 1) Alcohol (same as Tx1, dose 2) Indomethacin rectal suppository 100 mg/ 12 h CoT: dk DoT: 2 doses Indomethacin oral 25 mg/6 h CoT: after two rectal doses DoT: 48 h after cessation of contractions Tx3 Salbutamol IV (5 mL of salbutamol to 500 mL of 5% dextrose, a concentration of 10 µg/min) infusion rate of 20 drops/min, increased by increments of 10 drops/min every 10 min (max rate 80 drops/min) CoT: dk DoT: until contractions ceased, maternal pulse rate >140 beats/min, or maternal distress due to palpitations or hypertension Salbutamol IV effective dose CoT: after initial dose DoT: 6 h Salbutamol oral 4 mg q.d.s. CoT: after IV doses DoT:>48 h after contractions ceased | | Fetal monitoring, maternal heart rate and blood pressure, uterine monitoring | Inpatient | Country: dk Time period: dk | M=34% C=34%
  22 | 20 | 20
  Tx1: alcohol Tx2: alcohol and indomethacin Tx3: salbutamol

Evidence Table 3: Tocolytic first line: Beta-mimetics - Study design

Author (Year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion Exclusion Characteristics | Sample Size Initial/End | | | Demographic Characteristics | | | Tocolytic Intervention | Uniform Adjunctive Drug Intervention | Uniform Nondrug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Author (Year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion Exclusion Characteristics | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tocolytic Intervention | Uniform Adjunctive Drug Intervention | Uniform Nondrug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Kosasa TS, Nakayama RT, Hale RW, et al. (1985) | To assess the efficacy of ritodrine versus terbutaline in arresting PTL | Non-randomized control trial; Masking: dk | PTL: Cervical dilation: documented progression and/or Cervical effacement: documented progression Successful tocolysis: not defined | EGA: 20-36 wks Intact membranes Normal ECG Also no: dilation >9 cm, cardiovascular or hypertensive disease, diabetes, hyperthyroidism, abnormal vaginal bleeding, fever from chorio-amnionitis or of unknown origin, erythroblastosis fetalis, active thyroid disease | 99/99 | | | | | | Tx1 Terbutaline IV 0.25 mg CoT: initial DoT; 10 min Terbutaline IV 10 µg/min, increased by 5 µg/min, w/ max dose 80 µg/min CoT: after initial bolus DoT: 12 h after contractions arrest Terbutaline IV decreased 17 µg every 2 h CoT: 12 h after contractions arrest Terbutaline oral 5 mg/2 h CoT: w/ IV therapy DoT: 12 h Terbutaline oral 5 mg/4 h CoT: after discontinuation of IV DoT: 48 h Terbutaline oral 5 mg/6 h CoT: at discharge DoT: 38 wks gestation or sooner Tx2 Ritodrine IV 5mg CoT: initial DoT: 10 min Ritodrine IV 100 µg/min, increased by 50 µg/ 10 min, w/ max dose 350 µg/min CoT: after initial bolus DoT: until 12 h after contractions arrest Ritodrine IV decreased 8.3 µg every 2 h CoT: 12 h after contractions arrest Ritodrine oral 10 mg/2 h CoT: w/ IV treatment DoT: 12 h Ritodrine oral 10 mg/4 h CoT: after discontinuation of IV DoT: 48 h , then discharged w/ this dose until 38 wks gestation or sooner | Betamethasone AoT: lung maturation | Bed rest, fetal monitoring, IV fluids, maternal monitoring, cardiac monitoring | Inpatient | Country: dk Time period: dk | M=68% C=42%
  50 | 49

Evidence Table 3: Tocolytic first line: Beta-mimetics - Study design

Author (Year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion Exclusion Characteristics | Sample Size Initial/End | | | Demographic Characteristics | | | Tocolytic Intervention | Uniform Adjunctive Drug Intervention | Uniform Nondrug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Author (Year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion Exclusion Characteristics | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tocolytic Intervention | Uniform Adjunctive Drug Intervention | Uniform Nondrug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Read MD, Wellby DE ^140^ | To compare the efficacy of nifedipine, IV ritodrine, and no treatment controls in suppressing premature uterine activity | Non-randomized control trial: Masking: none | PTL: Contractions: >1/10 min Successful tocolysis: if contractions were abolished and no further cervical dilation occurred during treatment and there was no recurrence of contractions within 48 h of stopping treatment | EGA: 20-35 wks Intact membranes Also no: multiple gestation, dilation >4 cm, history of cervical surgery, polyhydramnios, history of mid-trimester abortion or previous preterm delivery, history of any medical condition which would contraindicate the use of either drug, any evidence of intrauterine infection, irregularity of fetal heart, history of antepartum hemorrhage | 60/60 | | | Mean Age (SD) | | | Tx1 Ritodrine IV 50 µg/min, adjusting by increments of 50 µg up to 300 µg/min CoT: after 30 min of observation DoT: until no contractions for 12 h or no maternal tachycardia (140/min) or fetal tachycardia (180/min), or other intolerable side effects Ritodrine IV 10 mg every 4 h CoT: when there are no contractions for 12 h & infusion discontinued DoT: 48 h Tx2 Nifedipine oral 30 mg CoT: after 30 min of observation DoT: one dose Nifedipine oral 20 mg every 8 h CoT: after loading dose DoT: 3 days Ritodrine IV "standard dose" CoT: if patient shows no benefit after 2 h of receiving nifedipine DoT: dk Cx No treatment | | Observation | Inpatient | Country: England Time period: dk | M=54% C=27%
  20 | 20 | 20
  24.9 | 24.6 | 23.5
  (4.4) | (3.6) | (3.9)

Evidence Table 3: Tocolytic first line: Beta-mimetics - Study design

Author (Year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion Exclusion Characteristics | Sample Size Initial/End | | | Demographic Characteristics | | | Tocolytic Intervention | Uniform Adjunctive Drug Intervention | Uniform Nondrug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Author (Year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion Exclusion Characteristics | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tocolytic Intervention | Uniform Adjunctive Drug Intervention | Uniform Nondrug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Chau AC, Gabert HA, Miller JM ^128^ | To compare the tocolytic efficacy and side effects of IV and oral magnesium and terbutaline | Non-randomized control trial; Masking: Subject: none Physician: none Pharm.: none Other care providers: dk | PTL (Contractions: >3/10 min and Cervical change despite rest, IV hydration, and sedation for 1 h) or (Contractions and Cervical effacement of at least 80% or dilation of >2 cm) Successful tocolysis: delay delivery for 48 h 1 wk, or 37 wks or more gestation | EGA: 23-35 wks Fetal weight: 500-2500 g Intact membranes Also not: multiple gestation, fetal weight <500 g or >2500 g, cardiovascular disease, hepatorenal diseases, chronic hypertension, diabetes mellitus, hyperthyroidism, any history of tocolytic hypersensitivity reaction, obstetric hemorrhage, cervical dilation >4 cm, any other maternal or fetal condition making delivery advisable | 98/98 | | | Mean Age (SD) p=NS Race, White (%) p=NS Race, Black (%) p=NS Race, Asian (%) p=NS | | | Tx1 Magnesium sulfate IV 4g CoT: initial DoT: 30 min Magnesium sulfate IV 2g/h CoT: after initial infusion DoT: at least 24 h or until contractions cease for at least 12 h Magnesium gluconate oral 2-3 g/4-6 h CoT: 30 min before discontinuation of maintenance dose DoT: until failure of tocolysis, delivery, or until 37 wks gestation Tx2 Terbutaline subcutaneous 0.25 mg/30 min CoT: initial DoT: 3 doses/1.5 h Terbutaline subcutaneous 0.25 mg/4 h CoT: after initial 3 doses DoT: at least 24 h or until contractions cease for at least 12 h Terbutaline oral 5 mg/4-6 h CoT: 30 min before discontinuation of maintenance dose DoT: until failure of tocolysis, delivery, or until 37 wks gestation Tx1 & Tx2(If dilation <4 cm and intact membrane) switched to other agent or secondary tx if PTL continued despite max tolerable dose of initial tocolytic | | Bed rest, fetal monitoring, vital signs monitoring | Inpatient: dk Outpatient: dk | Country: United States Time period: 1989-1991 | M=69% C=73%
  46 | 52
  22.5 | 22.6
  (5.3) | (5.8)
  5 | 15
  (11%) | (29%)
  40 | 3
  (87%) | (71%)
  1 | 0
  (2%) | (0%)

Evidence Table 3: Tocolytic first line: Beta-mimetics - Study design

Author (Year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion Exclusion Characteristics | Sample Size Initial/End | | | Demographic Characteristics | | | Tocolytic Intervention | Uniform Adjunctive Drug Intervention | Uniform Nondrug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Author (Year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion Exclusion Characteristics | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tocolytic Intervention | Uniform Adjunctive Drug Intervention | Uniform Nondrug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Kosasa TS, Busse R, Wahl N, et al. ^141^ | To determine whether long-term intravenous tocolysis using combined terbutaline and magnesium sulfate is a safe and effective treatment of PTL. Women w/ intact membranes (Tx1) are distinguished from those w/ PROM (Tx2) | Prospective Cohort Study: Masking: none | PTL: Contractions: painful every 5 min and (Dilation and/or Effacement following admission) Successful tocolysis: is not defined. | EGA: 20-32 wks Also no: documented chorioamnionitis, dilation >7 cm, maternal fever of unknown origin | 1000/1000 | | | Age (Tx1 & TX2) (SD) 25.4 (4.6) | | | Tx1 Intact Membranes Terbutaline subcutaneous 0.25 mg CoT: w/ diagnosis of PTL DoT: one dose Terbutaline IV 1.7 µg/min (increased by 2 µg/min every 10-20 min until 80 µg/min) CoT: after load dose DoT: until delivery, labor stopped, or side effects Magnesium sulfate IV 2 g/h (increased by 0.5 g/h to 4 g/h) CoT: w/ diagnosis of PTL DoT: until stabilized Magnesium sulfate: IV dose adjusted to maintain serum level of 6.5 -7.5 mg/dL CoT: after stabilization DoT: until delivery Tx2 Ruptured MembranesSame treatment as Tx1 | Antibiotics AoT: prophylactic for positive cervical culture Betamethasone to Tx1 w/ EGA (34 wks) AoT: fetal lung maturity Vitamin K AoT: to prevent IVH | Bed rest, fetal monitoring, routine observation, IV fluids, occupational or physical therapy if hospitalized >1 wk | Inpatient | Country: United States Time period: dk | M=29% C=50%
  751 | 249

Evidence Table 3: Tocolytic first line: Beta-mimetics - Study design

Author (Year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion Exclusion Characteristics | Sample Size Initial/End | | | Demographic Characteristics | | | Tocolytic Intervention | Uniform Adjunctive Drug Intervention | Uniform Nondrug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Author (Year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion Exclusion Characteristics | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tocolytic Intervention | Uniform Adjunctive Drug Intervention | Uniform Nondrug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Sciscione AC, Stamilio DM, Manley JS, et al. ^143^ | To determine whether hospital admission and tocolysis of patients w/ PTL resulted in a decrease in the preterm delivery rate | Prospective Cohort Study: Masking: none | PTL: Contractions: >8/h persisting after IV fluid and Dilation: <2 cm and Effacement: <80% and unchanged after 2 h | EGA: 20-37 wks Intact membranes Also no: cerclage, current bleeding, multiple gestations, placenta previa, placental abruption, cervical incompetence, prior tocolytic tx during current pregnancy | 133/133 | | | Mean Age (SD) | | | Tx1 Terbutaline subcutaneous 250 µg every 20 min CoT: initial DoT: <4 contractions/h or adverse reaction Terbutaline subcutaneous 250 µg every 3 h CoT: After adequate tocolysis achieved DoT: at least 12 h or Magnesium sulfate IV 4 g loading dose followed by 2-3g/h & increased every 30 min CoT: initial DoT: until <4 contractions/h or adverse reactions, or max rate of 5 g/h, total tx time at least 12 h Terbutaline oral 5 mg every 4 h CoT: following Successful tocolysis w/either terbutaline or magnesium sulfate DoT: 37 wks gestation Cx No treatment | | Bed rest, abstinence from sexual intercourse, fetal & uterine monitoring, routine observation | weekly follow-up | Country: United States Time period: 1991-1993 | M=N/A C=N/A
  75 | | 81
  27.3 | | 26.5
  (4.5) | | (19.8)

Evidence Table 3: Tocolytic first line: Beta-mimetics - Study design

Author (Year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion Exclusion Characteristics | Sample Size Initial/End | | | Demographic Characteristics | | | Tocolytic Intervention | Uniform Adjunctive Drug Intervention | Uniform Nondrug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Author (Year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion Exclusion Characteristics | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tocolytic Intervention | Uniform Adjunctive Drug Intervention | Uniform Nondrug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Coleman FH ^152^ | To determine the complication rate from using two tocolytics in combination and whether tocolysis can be continued despite complications | Retro-spective Cohort: Masking: none | PTL: Contractions:>1 every 10 min with or without cervical change Successful tocolysis: Delivery after 36 wks gestation | EGA: 24-34 wks Intact membranes Also no: chorioamnionitis, current bleeding, dilation >4 cm, hypertensive disorder, contraindications to tocolysis | 61/61 | | | Mean Age (SD) | | | Tx1 Terbutaline subcutaneous 0.25 mg CoT: at enrollment DoT: every 20 min for up to 3 doses Ritodrine IV 100 µ/min increasing to max of 350 Y/min CoT: after terbutaline DoT: dk Magnesium sulfate IV 2 g/h & increasing try 0.5 gm/h CoT: after ritodrine & with continued contractions or side effects from ritodrine DoT: every 20 min until areflexia, magnesium levels of 8-10 mg/dl or cessation of contractions Ritodrine or terbutaline oral Ritodrine 10 mg terbutaline 2.5 mg CoT: after IV tocolysis DoT: every 2-4 h until 36 wks gestation Tx2Same treatment as for Tx1-dual tocolytics CoT: same as Tx1 DoT: until complications cause discontinuation | | Bed rest, IV fluids, fetal monitoring, reassurance about normal effects of tocolytics | Inpatient: dk Outpatient: dk | Country: United States Time period: 1986-1988 | M=54% C=79%
  41 | 20
  23.8 | 21.2
  (3.3) | (2.5)

Evidence Table 3: Tocolytic first line: Beta-mimetics - Study design

Author (Year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion Exclusion Characteristics | Sample Size Initial/End | | | Demographic Characteristics | | | Tocolytic Intervention | Uniform Adjunctive Drug Intervention | Uniform Nondrug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Author (Year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion Exclusion Characteristics | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tocolytic Intervention | Uniform Adjunctive Drug Intervention | Uniform Nondrug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
de Veciana M, Porto M, Major CA, et al. ^142^ | To evaluate the efficacy of tocolysis in delaying delivery more than 48 h in pregnancy w/ PTL & advanced cervical dilation & to determine the impact of this delay on the incidence of maternal or neonatal morbidity & mortality | Retrospective cohort study: Masking: none | PTL: Contractions: >2 / 10 min, painful, palpable, lasting >1 h and Dilation>3.5 cm Successful tocolysis: ability to delay delivery by more than 48 h after admission | EGA: <36 wks Intact membranes Also: information available on labor course and outcome, no: cerclage, current bleeding/hemorrhage, maternal fever >38°C, positive culture for amniotic fluid, amniocentesis documenting pulmonary maturity, tender uterus between contractions, positive gram stain or culture | 73/73 | | | Mean Age (SD) p=NS | | | Tx1 & Cx terbutaline sulfate subcutaneous CoT: before decision to receive IV tocolysis Tx1 & Cx Terbutaline sulfate oral (18% in Tx1 & 15% in Cx) CoT: before decision to receive IV tocolysis Tx1 Magnesium sulfate IV 4-6 gm CoT: within 1 h of admission DoT: one loading dose Magnesium sulfate IV 2-4 gm/h CoT: after loading dose DoT: until labor stopped or tocolysis failed, 48 h up to 7 days Indomethacin oral or rectal 50 mg (1 dose), then 25 mg (no more than 6 doses) CoT: concurrent w/ magnesium sulfate (29.5% of Tx1) after adequate amniotic fluid volume documented by ultrasound DoT: every 6 h | Dexamethasone, Tx1 group only AoT: fetal lung maturity Antibiotics AoT: prophylactic | Fetal monitoring, routine observation, uterine monitoring | Inpatient | Country: United States Time period: 1985-1991 | M=58% C=52%
  44 | | 29
  22.5 | | 23.1
  (5.1) | | (5.2)

Evidence Table 3: Tocolytic first line: Beta-mimetics - Study design

Author (Year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion Exclusion Characteristics | Sample Size Initial/End | | | Demographic Characteristics | | | Tocolytic Intervention | Uniform Adjunctive Drug Intervention | Uniform Nondrug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Author (Year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion Exclusion Characteristics | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tocolytic Intervention | Uniform Adjunctive Drug Intervention | Uniform Nondrug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
van Dijk KG, Dekkler GA, van Geijn HP ^155^ | To compare treatment of PTL w/ oral nifedipine relative to intravenous ritodrine | Retrospective cohort study: Masking: none | PTL: not defined Successful tocolysis: is defined as stable condition | Also: all patients receiving tocolytic therapy in 1989 and 1990 & referred to hospital because of preterm contractions that could not be halted | 61/61 | | | Mean Age (SD) | | | Tx1 Ritodrine IV 160 mcg/min (increased by 80 mcg/min until contractions stopped or maternal heart rate 140 beats per min) CoT: dk DoT: if stable, tapered after 3 days, if contractions reoccurred, dose increased until effective tocolysis Ritodrine oral dose: dk CoT: after IV DoT: 34 wks gestation Tx2 Nifedipine oral 10-40 mg CoT: first hour after admission DoT: dk Nifedipine oral 60-160 mg CoT: depending on efficacy of drug No. 1 DoT: daily, after 3 days taper to 60 mg until 34 wks gestation, if contractions reoccurred, dose increased until effective tocolysis Tx1 & Tx2 Indomethacin suppositories 100 mg, increased to maximum of 300 mg/day CoT: if labor could not be arrested w/above tx & EGA < 32 wks | Corticosteroids: AoT: fetal lung maturation | | | Country: Holland Time period: 1989-1990 | C=32% M=24%
  32 | 29
  30.3 | 28.3
  (5.4) | (5.1)

Evidence Table 3: Tocolytic first line: Beta-mimetics - Study design

Author (Year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion Exclusion Characteristics | Sample Size Initial/End | | | Demographic Characteristics | | | Tocolytic Intervention | Uniform Adjunctive Drug Intervention | Uniform Nondrug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Author (Year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion Exclusion Characteristics | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tocolytic Intervention | Uniform Adjunctive Drug Intervention | Uniform Nondrug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Hastwell GB, Halloway CP, Taylor TL ^156^ | To demonstrate that oral salbutamol therapy in high doses is an effective, far simpler, and less tedious method of treating premature labor, particularly if prolongation of pregnancy beyond 1 wk is to achieved | Case series: Masking: none | PTL: Contractions:>1 every 10 min and painful Successful tocolysis not defined | EGA: 20-36 wks | 208/208 | | | | | | Tx1 Salbutamol oral 8 mg (or sometimes altered to 4 or 12 mg if no response or side effects) CoT: initial dosing DoT: every 6 h for 1 wk Salbutamol oral 4-8 mg, according to need CoT: after wk 1 DoT: frequency according to need for up to 38 wks gestation | | Bed rest | Inpatient: dk Outpatient: dk | Country: England Time period: dk | M=62% C=10%
  208

Evidence Table 3: Tocolytic first line: Beta-mimetics - Study design

Author (Year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion Exclusion Characteristics | Sample Size Initial/End | | | Demographic Characteristics | | | Tocolytic Intervention | Uniform Adjunctive Drug Intervention | Uniform Nondrug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Author (Year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion Exclusion Characteristics | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tocolytic Intervention | Uniform Adjunctive Drug Intervention | Uniform Nondrug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
TambyRaja RL, Ng SC, & Ratnam SS (1981) | To determine the effectiveness of fenoterol, a selective β_2_ receptor agonist in preventing PTL | Case series: Masking: none | PTL: Contractions: >1/10 min, regular & painful Successful tocolysis: complete success defined as labor postponed >7 days, relative success defined as labor postponed between 24 h and 7 days | EGA: 25 to 35 wks Also no: hypertensive disorders, maternal fever, uterine anomaly, vaginal bleeding from abruptio placentae, diabetes mellitus, thyrotoxicosis, PROM w/ chorio-amnionitis | 90/90 | | | Mean Age (Range) Race, Chinese Race, Malaysian Race, Other | | | Tx1 Fenoterol IV 1 µg/min increased by 1 µg/min every 30 min to maximum dose of 6 µg/min CoT: dk DoT: 6 h then gradually decreased dose over 6 h or stopped due to side effects Fenoterol oral 5 mg CoT: if labor inhibited, 30 min before infusion stopped DoT: every 4 h until 36 wks | | Bed rest, uterine monitoring | Unknown | Country: Singapore Time period: 1975-1979 | C=33% M=43%
  90
  26.5 (19-41)
  69.7%
  24.7%
  5.6%

Evidence Table 3: Tocolytic first line: Beta-mimetics - Study design

Author (Year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion Exclusion Characteristics | Sample Size Initial/End | | | Demographic Characteristics | | | Tocolytic Intervention | Uniform Adjunctive Drug Intervention | Uniform Nondrug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Author (Year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion Exclusion Characteristics | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tocolytic Intervention | Uniform Adjunctive Drug Intervention | Uniform Nondrug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Phuapradit W, Pongthai S, Chaturachinda K ^139^ | To report the result of terbutaline in inhibiting PTL and the use of dexamethasone in the prevention of RDS | Case series: Masking: dk | PTL: Contractions: >1/10 min, regular and painful, observed for at least 30 min and Cervical dilation:<3 cm and Cervical effacement or almost effaced Successful tocolysis: prolongation of pregnancy >7 days after initiation of therapy, birth weight >2500 g, survival time of newborn >7 days | EGA: 28-35 wks Intact membranes Also no: abruptio placentae, placenta previa, maternal arrhythmias, hypertension, hyperthyroidism, diabetes mellitus | 68/68 | | | Mean Age (range) | | | Tx1 Terbutaline IV 0.25 mg CoT: initial DoT: one dose Terbutaline IV 10 µg/min, increased by 5 µg/min/10 min, maximum 25 µg/min CoT: after initial dose DoT: 2 h after contractions ceased Terbutaline subcutaneous injection, 0.25 mg every 4 h CoT: after infusions complete DoT: 24 h Terbutaline oral 10 mg day (2.5 mg/6 h ) CoT: after injection DoT: 36 wks Terbutaline IV CoT: if contractions resumed while on subcutaneous or oral therapy | Dexamethasone AoT: lung maturation | Bed rest, routine observation | Inpatient | Country: India Time period: 1980-1982 | M=44% C=37%
  68
  26 (16-35)

Evidence Table 3: Tocolytic first line: Beta-mimetics - Outcomes

Author (Year) | Delivery | | | | | | | | | Maternal | | | | | | Infant | | | | | | | | | | | | Other Analyses | Conclusions
Author (Year) | Estimated Gestational Age | | | Prolongation of Pregnancy Days | | | Gestational Weeks | | | Length of Hospital Stay | | | Maternal Morbidity | | | Birth Weight (g) | | | APGAR Score | | | Length of Hospital Stay | | | Other Infant Outcomes | | | Other Analyses | Conclusions
Author (Year) | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Other Analyses | Conclusions
Castrén O, Gummerus M, Saarikoski S ^144^ | | | | Postponed >7 days and attained at least 37 wks | | | | | | | | | | | | Birth weight >2500 | | | | | | | | | Neonatal deaths | | | Summarizes success of treatment by week of gestation at onset of tx, showing that results are better the further the gestation had progressed at the time of treatment. | No statistical analysis provided comparing study arms.
  Tx1 | Tx2 | Tx3 | Cx
  33 | 37 | 28 | 30
  (77%) | (62%) | (56%) | (73%)
  Tx1 | Tx2 | Cx | Tx3
  37 | 45 | 29 | 35
  (86%) | (75%) | (71%) | (70%)
  Tx1 | Tx2 | Tx3 | Cx
  5 | 5 | 5 | 3

Evidence Table 3: Tocolytic first line: Beta-mimetics - Outcomes

Author (Year) | Delivery | | | | | | | | | Maternal | | | | | | Infant | | | | | | | | | | | | Other Analyses | Conclusions
Author (Year) | Estimated Gestational Age | | | Prolongation of Pregnancy Days | | | Gestational Weeks | | | Length of Hospital Stay | | | Maternal Morbidity | | | Birth Weight (g) | | | APGAR Score | | | Length of Hospital Stay | | | Other Infant Outcomes | | | Other Analyses | Conclusions
Author (Year) | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Other Analyses | Conclusions
Lauersen NH, Merkatz IR, Tejani N, et al. ^117^ | | | | Mean prolongation days (SD) Singleton births Multiple births Prolonged > 3 days Singleton births: Multiple births: | | | Delivered 29 wks Singleton births: Multiple births: Delivered 30-33 wks Singleton births: Multiple births: Delivered 34-37 wks Singleton births: Multiple births: Delivered >37 wks Singleton births: Multiple births: | | | | | | | | | Birth weight: <1500 Singleton births: Multiple births: 1500-2500 Singleton births: Multiple births: Singleton births: Multiple births: | | | | | | | | | Fetal mortality NRDS | | | Some results are given by center site. | Insufficient statistical analysis provided to compare relative efficacy of treatments.
  26.6 | 46.2
  (3.4) | (4.1)
  30.7 | 22.0
  (9.2) | (6.0)
  41 | 8
  | p<0.05
  56 | 5
  | p>0.05
  6 | 3
  0 | 0
  11 | 6
  2 | 1
  20 | 20
  2 | 3
  21 | 33
  5 | 2
  8 | 3
  3 | 2
  24 | 13
  9 | 9
  | >2500
  26 | 44
  | p<0.01
  6 | 1
  7 | 3
  15 | 6

Evidence Table 3: Tocolytic first line: Beta-mimetics - Outcomes

Author (Year) | Delivery | | | | | | | | | Maternal | | | | | | Infant | | | | | | | | | | | | Other Analyses | Conclusions
Author (Year) | Estimated Gestational Age | | | Prolongation of Pregnancy Days | | | Gestational Weeks | | | Length of Hospital Stay | | | Maternal Morbidity | | | Birth Weight (g) | | | APGAR Score | | | Length of Hospital Stay | | | Other Infant Outcomes | | | Other Analyses | Conclusions
Author (Year) | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Other Analyses | Conclusions
Gamissans O, Cañas E, Cararach J, et al. ^118^ | Mean (SEM) | | | Mean prolongation days Median prolongation days Gain in days 11-30 days 31-60 days >60 days *Difference is between all gain in days categories | | | Delivered <37 wks | | | | | | | | | Mean Median | | | APGAR <7 at 1 min APGAR <7 at 5 min | | | | | | Fetal and postnatal mortality Respiratory distress syndrome | | | Details presented of the cases w/ fetal or neonatal mortality. | Ritodrine & indomethacin showed efficacy over ritodrine & placebo: -delivery <37 wks -birth weight -APGAR <7 at 1 min
  30.54 | 30.63
  (1.04) | (0.96)
  25.93 | 41.34
  20.5 | 33.0
  | < 10 days
  10 | 2
  4 | 7
  5 | 8
  3 | 5
  | p<0.05*
  14 | 7
  | p<0.05
  2367 | 2798
  | p<0.05
  2700 | 3010
  9 | 3
  | p<0.02
  4 | 2
  | p=NS
  4 | 2
  | p=NS
  1 | 1

Evidence Table 3: Tocolytic first line: Beta-mimetics - Outcomes

Author (Year) | Delivery | | | | | | | | | Maternal | | | | | | Infant | | | | | | | | | | | | Other Analyses | Conclusions
Author (Year) | Estimated Gestational Age | | | Prolongation of Pregnancy Days | | | Gestational Weeks | | | Length of Hospital Stay | | | Maternal Morbidity | | | Birth Weight (g) | | | APGAR Score | | | Length of Hospital Stay | | | Other Infant Outcomes | | | Other Analyses | Conclusions
Author (Year) | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Other Analyses | Conclusions
Sims CD, Chamberlain GVP, Boyd IE, et al. ^145^ | | | | Mean prolongation days (SD) Prolongation of delivery: Prolongation index* *Number of days delivery delayed as a percentage of EGA at onset of tx | | | | | | | | | | | | | | | | | | | | | Neonatal deaths | | | Analysis of hours, days, and weeks prolonged by salbutamol and ethanol, w/ and w/ out the use of steroids; delivery delay of women w/intact membranes and dilatation <2 cm. | No statistical analysis provided comparing study arms.
  239 | 244
  (25) | (25)
  15.0 | 20.4
  (24.5) | (24.0)
  | <24 h
  35 | 34
  | >48 h
  20 | 26
  6.9 | 9.4
  (11.5) | (11.3)
  | >37 wks
  10 | 14
  4 | 10

Evidence Table 3: Tocolytic first line: Beta-mimetics - Outcomes

Author (Year) | Delivery | | | | | | | | | Maternal | | | | | | Infant | | | | | | | | | | | | Other Analyses | Conclusions
Author (Year) | Estimated Gestational Age | | | Prolongation of Pregnancy Days | | | Gestational Weeks | | | Length of Hospital Stay | | | Maternal Morbidity | | | Birth Weight (g) | | | APGAR Score | | | Length of Hospital Stay | | | Other Infant Outcomes | | | Other Analyses | Conclusions
Author (Year) | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Other Analyses | Conclusions
Hesseldahl H ^157^ | No data provided p=NS | | | Interval between start of tx & delivery (days) no data provided p=NS Postponement of delivery > 48 h Combined ritodrine groups: 81 Cx: 78 Postponement of delivery 2 wks Combined ritodrine groups: 57% Cx: 67 % | | | Percentage delivered at 40 wks: Intramuscular method was more effective than IV method p=0.05 Ritodrine tx group combined were not better than the Cx group p=0.46 | | | | | | | | | | | | | | | | | | | | | | Data presented was insufficient for comparing the relative efficacy of treatments.

Evidence Table 3: Tocolytic first line: Beta-mimetics - Outcomes

Author (Year) | Delivery | | | | | | | | | Maternal | | | | | | Infant | | | | | | | | | | | | Other Analyses | Conclusions
Author (Year) | Estimated Gestational Age | | | Prolongation of Pregnancy Days | | | Gestational Weeks | | | Length of Hospital Stay | | | Maternal Morbidity | | | Birth Weight (g) | | | APGAR Score | | | Length of Hospital Stay | | | Other Infant Outcomes | | | Other Analyses | Conclusions
Author (Year) | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Other Analyses | Conclusions
Merkatz IR, Peter JB, Barden TP ^136^ | Mean | | | Mean | | | >36 wks (%) | | | | | | | | | >2500 (%) | | | | | | | | | Fetal mortality (%) NRDS/HMD (%) | | | Outcomes also evaluated based on whether or not ritodrine started before or after 33 wks | Ritodrine showed efficacy over placebo/ethanol: -older EGA -greater prolongation -more likely to reach 36 or more gestational weeks -greater birth weight -lower fetal mortality
  34.6 | | 32.5
  | p<0.01
  40.9 | | 24.4
  | p<0.001
  94 | | 45
  (52) | | (38)
  | p<0.05
  110 | | 53
  (58) | | (43)
  | p<0.05
  10 | | 16
  (5) | | (13)
  | p<0.05
  20 | | dk
  (11) | | (20)
  | p<0.05

Evidence Table 3: Tocolytic first line: Beta-mimetics - Outcomes

Author (Year) | Delivery | | | | | | | | | Maternal | | | | | | Infant | | | | | | | | | | | | Other Analyses | Conclusions
Author (Year) | Estimated Gestational Age | | | Prolongation of Pregnancy Days | | | Gestational Weeks | | | Length of Hospital Stay | | | Maternal Morbidity | | | Birth Weight (g) | | | APGAR Score | | | Length of Hospital Stay | | | Other Infant Outcomes | | | Other Analyses | Conclusions
Author (Year) | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Other Analyses | Conclusions
Gummerus M ^158^ | | | | Prolongation >7 days | | | Delivered >37 wks | | | Mean (SD) | | | | | | | | | | | | | | | | | | Compared interventions using Baumgarten's tocolytic index; subanalysis of infants >2500 g; side effects examined | No statistical analysis provided comparing study arms.
  80% | 67%
  70% | 61%
  9 | 7
  (1.3) | (1.5)
  274 | >2500
  78% | 72%

Evidence Table 3: Tocolytic first line: Beta-mimetics - Outcomes

Author (Year) | Delivery | | | | | | | | | Maternal | | | | | | Infant | | | | | | | | | | | | Other Analyses | Conclusions
Author (Year) | Estimated Gestational Age | | | Prolongation of Pregnancy Days | | | Gestational Weeks | | | Length of Hospital Stay | | | Maternal Morbidity | | | Birth Weight (g) | | | APGAR Score | | | Length of Hospital Stay | | | Other Infant Outcomes | | | Other Analyses | Conclusions
Author (Year) | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Other Analyses | Conclusions
Caritis SN, Carson D, Greenbon D, et al. ^148^ | Mean (SD) Intact membranes PROM | | | Mean prolongation days (SD) Intact membranes | | | Delivery at >36 wks intact membranes Delivery as "partial success" intact membranes Delivery as "failure" intact membranes Delivery as "success" PROM | | | | | | | | | Mean (SD) PROM EGA <28 wks at entry Intact membranes EGA >28<32 wks at entry Intact membranes EGA >32 wks at entry Intact membranes | | | <7 at 1 min PROM <7 at 5 min | | | | | | No. of neonatal deaths intact membranes PROM No. of fetal deaths intact membranes PROM Hyaline membrane disease intact membranes PROM | | | Separate analysis for PROM | Terbutaline showed efficacy over ethanol: -mean prolongation days (intact membranes) -delivery as "partial success" (intact membranes) (see definition of successful tocolysis)
  30 | 31
  (3) | (3)
  31 | 31
  (2) | (2)
  15 | 10
  (3.7) | (3.2)
  | (P<0.05)
  5 | 5
  18 | 8
  | (P<0.025)
  5 | 15
  | (p<0.025)
  12 | 7
  (71%) | (58%)
  1,565 | 1,531
  (436) | (487)
  921 | 1,137
  (269) | (602)
  2032 | 1,907
  (612) | (713)
  2,367 | 2,402
  (237) | (766)
  7 | 6
  1 | 3
  6 | 2
  3 | 4
  2 | 1
  0 | 0
  9 | 9
  7 | 7

Evidence Table 3: Tocolytic first line: Beta-mimetics - Outcomes

Author (Year) | Delivery | | | | | | | | | Maternal | | | | | | Infant | | | | | | | | | | | | Other Analyses | Conclusions
Author (Year) | Estimated Gestational Age | | | Prolongation of Pregnancy Days | | | Gestational Weeks | | | Length of Hospital Stay | | | Maternal Morbidity | | | Birth Weight (g) | | | APGAR Score | | | Length of Hospital Stay | | | Other Infant Outcomes | | | Other Analyses | Conclusions
Author (Year) | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Other Analyses | Conclusions
Gummerus M ^149^ | Mean (SD) | | | Mean prolongation weeks (SD) Delivered within 24 h Prolonged >7 days | | | Delivered at >37 wks | | | | | | Adverse drug reactions | | | Mean birth weight (SD) Neonatal births w/birth weight >2500: for all births for EGA 24-28 wks for EGA 29-32 wks for EGA 33-36 wks | | | | | | | | | Fetal mortality NRDS Intraventricular hemorrhage | | | Subanalysis by gestational age | No statistical analysis provided comparing study arms.
  31.9 | 31.5
  (0.4) | (0.4)
  5.0 | 5.5
  (0.5) | (0.4)
  5 | 4
  (7%) | (6%)
  54 | 55
  (77%) | (79%)
  46 | 46
  (66%) | (66%)
  8 | 21
  2923.5 | 2950.4
  (97.8) | (96.8)
  77% | 74%
  9 | 8
  (75%) | (62%)
  18 | 18
  (72%) | (69%)
  27 | 26
  (82%) | (84%)
  0 | 3
  7 | 4
  2 | 0

Evidence Table 3: Tocolytic first line: Beta-mimetics - Outcomes

Author (Year) | Delivery | | | | | | | | | Maternal | | | | | | Infant | | | | | | | | | | | | Other Analyses | Conclusions
Author (Year) | Estimated Gestational Age | | | Prolongation of Pregnancy Days | | | Gestational Weeks | | | Length of Hospital Stay | | | Maternal Morbidity | | | Birth Weight (g) | | | APGAR Score | | | Length of Hospital Stay | | | Other Infant Outcomes | | | Other Analyses | Conclusions
Author (Year) | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Other Analyses | Conclusions
Caritis SN, Toig G, Heddinger LA, et al. ^137^ | | | | Mean days, intact membrane (SD) Mean days, PROM (SD) Prolongation >36 h, intact membrane Prolongation >36 h, PROM | | | Delivery at >37 wks, intact membrane 19% 44% | | | | | | Adverse drug reactions, intact membrane Adverse drug reactions, PROM | | | <1000, intact (%) <1000, ruptured 1000-1750, intact 1000-1750, ruptured 1751-2500, intact 1751-2500, ruptured >2500, intact >2500, ruptured | | | <7 at 1 min, intact (%) <7 at 1 min, ruptured <1 at 5 min, intact <7 at 5 min, ruptured | | | | | | Fetal mortality, intact (%) Fetal mortality, ruptured NRDS, HMD, intact NRDS, HMD, ruptured Necrotizing enterocolitis, intact Necrotizing enterocolitis, ruptured Hyperbilirubinemia, intact Hyperbilirubinemia, ruptured Intermittent positive-pressure ventilation, intact Intermittent positive-pressure ventilation, ruptured | | | Metabolic effects of ritodrine and terbutanol; recurrent labor requiring intravenous treatment and delivery on oral therapy | No statistical analysis provided comparing study arms.
  17 | 30
  (22) | (27)
  4 | 4
  (8) | (5)
  58% | 30%
  65% | 59%
  4 | 3
  1 | 1
  3 | 2
  (0) | (8)
  0% | 9%
  29% | 4%
  43% | 34%
  29% | 31%
  30% | 43%
  32% | 58%
  19% | 9%
  3 | 3
  (10) | (12)
  29% | 26%
  3% | 4%
  19% | 9%
  2 | 3
  (6) | (12)
  14% | 13%
  6% | 19%
  29% | 43%
  3% | 0%
  5% | 4%
  19% | 4%
  30% | 43%
  6% | 12%
  19% | 22%

Evidence Table 3: Tocolytic first line: Beta-mimetics - Outcomes

Author (Year) | Delivery | | | | | | | | | Maternal | | | | | | Infant | | | | | | | | | | | | Other Analyses | Conclusions
Author (Year) | Estimated Gestational Age | | | Prolongation of Pregnancy Days | | | Gestational Weeks | | | Length of Hospital Stay | | | Maternal Morbidity | | | Birth Weight (g) | | | APGAR Score | | | Length of Hospital Stay | | | Other Infant Outcomes | | | Other Analyses | Conclusions
Author (Year) | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Other Analyses | Conclusions
Cotton DB, Strassner HT, Hill LM, et al. ^120^ | Mean (SD) | | | Mean prolongation Days (SD) Delayed >48 h intact membranes Delayed 48 h, PROM Delayed <48 h Delayed 48 hours to 7 days Delayed >7 days | | | | | | | | | Postpartum endometritis Adverse drug reactions Urinary tract infections C-sections due to fetal distress (%) | | | Mean (SD) | | | | | | | | | Neonatal mortality 1/16 1/19 4/19 p=NS Respiratory disease 6 4 6 p=NS Intracranial hemorrhage 0 2 3 p=NS Necrotizing enterocolitis 0 1 1 p=NS Fetal distress 1 1 1 p=NS Infection 2 7 0 p=NS Seizures 1 3 2 p=NS Parent ductus 2 2 0 p=NS Hypoglycemia 1 4 2 p=NS | | | Analysis of neonatal outcome (death vs. survival) by birth weight | No significant difference between magnesium sulfate & terbutaline, placebo
  31.0 | 33.1 | 32.0
  (1.9) | (3.3) | (3.4)
  3.0 | 12.0 | 7.1
  (6.0) | (14.9) | (14.9)
  6 | 10 | 7
  (38%) | (53%) | (37%)
  | p=NS
  3/8 | 3/4 | 2/10
  (38%) | (75%) | (20%)
  | p=NS
  63% | 47% | 63%
  | p=NS
  25% | 26% | 21%
  | p=NS
  12% | 27% | 16%
  | p=NS
  2 | 5 | 1
  | p=NS
  0 | 1 | 0
  1 | 2 | 0
  5 | 4 | 4
  (33%) | (21%) | (21%)
  1651 | 1841 | 1648
  (591) | (678) | (656)
  | p=NS

Evidence Table 3: Tocolytic first line: Beta-mimetics - Outcomes

Author (Year) | Delivery | | | | | | | | | Maternal | | | | | | Infant | | | | | | | | | | | | Other Analyses | Conclusions
Author (Year) | Estimated Gestational Age | | | Prolongation of Pregnancy Days | | | Gestational Weeks | | | Length of Hospital Stay | | | Maternal Morbidity | | | Birth Weight (g) | | | APGAR Score | | | Length of Hospital Stay | | | Other Infant Outcomes | | | Other Analyses | Conclusions
Author (Year) | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Other Analyses | Conclusions
Tchilinguirian NG, Najem R, Sullivan GB, et al. ^150^ | | | | Delivered delayed <48 h Intact membranes: PROM: Delivered delayed >48 h PROM: Delivered delayed 2-7 days Intact membranes: Delivered delayed >7 days Intact membranes: | | | | | | | | | | | | | | | | | | | | | | | | Compares effects of ritodrine vs. magnesium sulfate by cases of intact membranes & PROM by: race, age, parity, number of abortions, gestational age, contraction units, dilation, effacement | Ritodrine & magnesium sulfate showed no differences in efficacy
  3 | 5
  8 | 4
  | p=NS
  2 | 5
  (20%) | (56%)
  | p=NS
  2 | 1
  | p=NS
  16 | 21
  | p=NS

Evidence Table 3: Tocolytic first line: Beta-mimetics - Outcomes

Author (Year) | Delivery | | | | | | | | | Maternal | | | | | | Infant | | | | | | | | | | | | Other Analyses | Conclusions
Author (Year) | Estimated Gestational Age | | | Prolongation of Pregnancy Days | | | Gestational Weeks | | | Length of Hospital Stay | | | Maternal Morbidity | | | Birth Weight (g) | | | APGAR Score | | | Length of Hospital Stay | | | Other Infant Outcomes | | | Other Analyses | Conclusions
Author (Year) | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Other Analyses | Conclusions
Larsen JF, Eldon K, Lange AP, et al. ^121^ | Mean 95% CI: (-0.5 to -2.3) p=0.18 | | | Mean prolongation days 95% CI: (0.7 to 18.3) p=0.034 | | | Delivery: >36 wks 95% CI: (1.3% to 37.9%) p=NS Delivery: >37 wks 95% CI: (-1.9% to 36.7%) p=NS | | | | | | | | | Birth weight 95% CI: (-224 to -418) p=0.55 Birth weight >2500 95% CI: (-10.8% to -25.8%) p=NS | | | APGAR score <7 at 1 min p=NS APGAR score <7 at 5 min p=NS | | | | | | Fetal mortality p=NS RDS p=NS Perinatal asphyxia p=NS | | | | Ritodrine showed efficacy over placebo: -prolongation days.
  37.2 | | 36.3
  33.9 | | 24.4
  79.6% | | 60.0%
  71.4% | | 54.0%
  2845 | | 2748
  73.5% | | 66.0%
  6 | | 5
  0 | | 2
  1 | | 2
  3 | | 6
  6 | | 8

Evidence Table 3: Tocolytic first line: Beta-mimetics - Outcomes

Author (Year) | Delivery | | | | | | | | | Maternal | | | | | | Infant | | | | | | | | | | | | Other Analyses | Conclusions
Author (Year) | Estimated Gestational Age | | | Prolongation of Pregnancy Days | | | Gestational Weeks | | | Length of Hospital Stay | | | Maternal Morbidity | | | Birth Weight (g) | | | APGAR Score | | | Length of Hospital Stay | | | Other Infant Outcomes | | | Other Analyses | Conclusions
Author (Year) | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Other Analyses | Conclusions
Leveno KJ, Guzick DS, Hankins GD, et al. ^151^ | Mean p=NS | | | Mean prolongation days p=NS Days gained: 1 day or less p<0.02 2-7 days p=NS 8-28 days p=NS 28 or more days p=NS | | | Delivered at 24-26 wks p=NS Delivered at 27-29 wks p=NS Delivered at 30-32 wks p=NS Delivered at 33-35 wks p=NS Delivered at >36 wks p=NS | | | Antepartum length of stay (days) p=NS C-sections p=NS | | | | | | Mean p=NS | | | Mean APGAR at 5 min p=NS | | | Mean neonatal hospital days p=NS Mean NICU days p=NS | | | Mean neonatal deaths p=NS Respiratory distress: In need of halo In need of ventilator p=NS Intraventricular hemorrhage p=NS Necrotizing enterocolitis p=NS Hyperbilirubinemia | | | | Ritodrine showed efficacy over no treatment: -prolongation of 1 day or less
  32.8 | | 32.6
  19.8 | | 15.1
  15 | | 25
  (28%) | | (48%)
  9 | | 7
  (17%) | | (14%)
  11 | | 6
  (20%) | | (12%)
  19 | | 14
  (35%) | | (27%)
  4 | | 2
  (7%) | | (4%)
  9 | | 8
  (17%) | | (15%)
  14 | | 17
  (26%) | | (33%)
  9 | | 14
  (17%) | | (27%)
  18 | | 11
  (33%) | | (21%)
  8.9 | | 4.8
  10 | | 8
  (19%) | | (15%)
  2039 | | 1920
  7.9 | | 7.8
  24.5 | | 24.8
  14.3 | | 12.4
  2 | | 4
  (4%) | | (7%)
  12 | | 7
  (21%) | | (13%)
  13 | | 17
  (23%) | | (31%)
  2 | | 4
  (4%) | | (7%)
  0 | | 2
  | | (4%)
  25 | | 25
  (45%) | | (46%)

Evidence Table 3: Tocolytic first line: Beta-mimetics - Outcomes

Author (Year) | Delivery | | | | | | | | | Maternal | | | | | | Infant | | | | | | | | | | | | Other Analyses | Conclusions
Author (Year) | Estimated Gestational Age | | | Prolongation of Pregnancy Days | | | Gestational Weeks | | | Length of Hospital Stay | | | Maternal Morbidity | | | Birth Weight (g) | | | APGAR Score | | | Length of Hospital Stay | | | Other Infant Outcomes | | | Other Analyses | Conclusions
Author (Year) | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Other Analyses | Conclusions
Hatjis CG, Swain M, Nelson LH, et al. ^138^ | | | | Days from tx to delivery or recurrent labor (SD) Prolongation >1 wk | | | | | | | | | | | | Mean birth weight (SD) p<0.001 Mean birth weight >2500 | | | <7 at 5 min | | | | | | NRDS | | | | Ritodrine plus magnesium sulfate showed efficacy over ritodrine alone: -prolongation of pregnancy >1 wk
  Group IA: | 51.14 (29.52)
  Group IC: | 32.75 (27.81)
  Group 2A: | 38.05 (22.59)
  34% | 59%
  | p<0.05
  Group IA: | 2843.647
  | (786.00)
  Group IB: | 1122.67
  | (599.78)
  Group IC: | 2242.57
  | (787.43)
  Group ID: | 1828.25
  | (613.20)
  Group 2A: | 2472.14
  | (841.95)
  Group 2B: | 1456.86
  | (455.66)
  12 | 11
  3 | 3
  Group IA: 0 Group IB: 2 Group IC: 1 Group ID: 0 Group 2A: 2 Group 2B: 1
  6 | 10
  Group IA: 0 Group IB: 2 Group IC: 3 Group ID: 1 Group 2A: 3 Group 2B: 7 Neonatal deaths 3 2 Group IA: 0 Group IB: 2 Group IC: 1 Group ID: 0 Group 2A: 0 Group 2B: 2

Evidence Table 3: Tocolytic first line: Beta-mimetics - Outcomes

Author (Year) | Delivery | | | | | | | | | Maternal | | | | | | Infant | | | | | | | | | | | | Other Analyses | Conclusions
Author (Year) | Estimated Gestational Age | | | Prolongation of Pregnancy Days | | | Gestational Weeks | | | Length of Hospital Stay | | | Maternal Morbidity | | | Birth Weight (g) | | | APGAR Score | | | Length of Hospital Stay | | | Other Infant Outcomes | | | Other Analyses | Conclusions
Author (Year) | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Other Analyses | Conclusions
Wilkins IA, Lynch L, Mehalek KE, et al. ^122^ | | | | Delayed >48 h (%) Delayed >7 days (%) | | | Delivery at >37 wks (%) | | | | | | | | | | | | | | | | | | | | | Patients w/ another episode of PTL initially were given original tocolytic agent but randomized to second line therapy if contractions continued, some description of patients receiving both agents. | No differences in effectiveness shown between ritodrine & magnesium sulfate.
  52 | 61
  (96.3) | (92.3)
  | p=NS
  45 | 53
  (83.3) | (80.3)
  | p=ns
  25 | 31
  (46.3) | (47)
  | p=ns

Evidence Table 3: Tocolytic first line: Beta-mimetics - Outcomes

Author (Year) | Delivery | | | | | | | | | Maternal | | | | | | Infant | | | | | | | | | | | | Other Analyses | Conclusions
Author (Year) | Estimated Gestational Age | | | Prolongation of Pregnancy Days | | | Gestational Weeks | | | Length of Hospital Stay | | | Maternal Morbidity | | | Birth Weight (g) | | | APGAR Score | | | Length of Hospital Stay | | | Other Infant Outcomes | | | Other Analyses | Conclusions
Author (Year) | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Other Analyses | Conclusions
Morales WJ, Smith SG, Angel JL, et al. ^123^ | | | | Mean days p=NS >2 days p=NS >7 days p=NS | | | | | | | | | | | | Mean p=NS | | | 1 min p=NS | | | | | | Neonatal deaths p=NS | | | | Indomethacin & ritodrine did not show differences in efficacy.
  30.6 | 24.6
  94% | 83%
  75% | 70%
  2001 | 2178
  6.9 | 7.3
  3 | 3

Evidence Table 3: Tocolytic first line: Beta-mimetics - Outcomes

Author (Year) | Delivery | | | | | | | | | Maternal | | | | | | Infant | | | | | | | | | | | | Other Analyses | Conclusions
Author (Year) | Estimated Gestational Age | | | Prolongation of Pregnancy Days | | | Gestational Weeks | | | Length of Hospital Stay | | | Maternal Morbidity | | | Birth Weight (g) | | | APGAR Score | | | Length of Hospital Stay | | | Other Infant Outcomes | | | Other Analyses | Conclusions
Author (Year) | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Other Analyses | Conclusions
Ferguson JE, Dyson DC, Schutz T, et al. ^125^ | | | | Prolongation >48 h (%) Prolongation >7 days (%) | | | Delivery at >36 wks (%) | | | | | | Adverse drug reactions 5 18 | | | Mean (SD) | | | <7 at 1 min 5 8 <7 at 5 min | | | | | | Neonatal deaths NRDS or HMD Intraventricular hemorrhage | | | 10 crossover patients: 6/10 delayed >48 h | No statistical analysis provided comparing study arms.
  27 | 23
  (84) | (72)
  16 | 17
  (70) | (63)
  9 | 14
  (41) | (52)
  2228 | 2467
  (880) | (901)
  2 | 3
  2 | 0
  4 | 2
  2 | 1

Evidence Table 3: Tocolytic first line: Beta-mimetics - Outcomes

Author (Year) | Delivery | | | | | | | | | Maternal | | | | | | Infant | | | | | | | | | | | | Other Analyses | Conclusions
Author (Year) | Estimated Gestational Age | | | Prolongation of Pregnancy Days | | | Gestational Weeks | | | Length of Hospital Stay | | | Maternal Morbidity | | | Birth Weight (g) | | | APGAR Score | | | Length of Hospital Stay | | | Other Infant Outcomes | | | Other Analyses | Conclusions
Author (Year) | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Other Analyses | Conclusions
Meyer WR, Randall HW, Graves WL ^126^ | | | | Mean p=0.685 | | | Percent: >36 wks p=0.767 | | | | | | Chorioamnionitis or abruptio placentae | | | Mean (SD) p=0.815 Percent >2500 | | | Mean at 1 min (SD) p=0.815 Mean at 5 min p=0.919 | | | | | | No. of neonatal deaths Meconium stained fluid p=NS | | | | Nifedipine & ritodrine did not show differences in relative efficacy.
  21.3 | 24.4
  42.9% | 34.8%
  1 | 1
  2606.8 | 2281.3
  (776.5)
  (858.0)
  67.6% | 30.4%
  7.0 | 7.1
  (2.1) | (1.9)
  8.6 | 8.6
  (0.8) | (0.8)
  0 | 0
  17% | 8%

Evidence Table 3: Tocolytic first line: Beta-mimetics - Outcomes

Author (Year) | Delivery | | | | | | | | | Maternal | | | | | | Infant | | | | | | | | | | | | Other Analyses | Conclusions
Author (Year) | Estimated Gestational Age | | | Prolongation of Pregnancy Days | | | Gestational Weeks | | | Length of Hospital Stay | | | Maternal Morbidity | | | Birth Weight (g) | | | APGAR Score | | | Length of Hospital Stay | | | Other Infant Outcomes | | | Other Analyses | Conclusions
Author (Year) | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Other Analyses | Conclusions
Bracero LA, Leikin E, Kirshenbaum N, et al. ^127^ | Mean (SD) p=0.184 | | | Prolongation index (SD) p=0.520 Tocolysis to delivery wks p=0.481 Prolongation >72 h p=NS | | | | | | | | | Chorioamnionitis histologic Chorioamnionitis suspected | | | Mean (SD) p=0.048 | | | Score at 1 min (SD) p=0.773 Score at 5 min (SD) p=0.771 | | | Mean NICU days (SD) NICU admissions p=0.037 | | | Neonatal deaths p=ns % NRDS, HMD p=0.043 % Necrotizing enterocolitis p=0.923 % Sepsis p=0.386 % Hyperbilirubinemia p=0.060 | | | | Ritodrine & nifedipine showed no difference in efficacy for delivery outcomes. Nifedipine showed relative efficacy in infant birth weight & NICU admissions.
  35 | 36
  (4) | (3)
  9 | 11
  (11) | (12)
  3 | 4
  (3) | (3)
  68.4% | 69.6%
  5 | 4
  0 | 2
  2336 | 2823
  (781) | (763)
  7 | 8
  (2) | (2)
  8 | 9
  (2) | (2)
  6.8 | 0.9
  (11) | (3)
  57.9% | 26.1%
  0 | 4.3
  26.3 | 4.3
  5.3 | 0
  10.5 | 0
  31.6 | 8.7

Evidence Table 3: Tocolytic first line: Beta-mimetics - Outcomes

Author (Year) | Delivery | | | | | | | | | Maternal | | | | | | Infant | | | | | | | | | | | | Other Analyses | Conclusions
Author (Year) | Estimated Gestational Age | | | Prolongation of Pregnancy Days | | | Gestational Weeks | | | Length of Hospital Stay | | | Maternal Morbidity | | | Birth Weight (g) | | | APGAR Score | | | Length of Hospital Stay | | | Other Infant Outcomes | | | Other Analyses | Conclusions
Author (Year) | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Other Analyses | Conclusions
Kurki T, Eronen M, Lumme R, et al. (1991) | Mean (SD) p=NS | | | Mean (SD) 65.0 55.9 (4.7) (4.1) p=NS Labor delayed <24 h 100% 100% p=NS Labor delayed 24-48 h 96% 76% p<0.05 Labor delayed 48-72 h 90% 73% p=NS | | | Delivery at >37 wks 70% 43% p<0.05 | | | | | | Reported side effects p<0.001 | | | Mean (SD) p=NS | | | <6 at 1 min p=NS <6 at 5 min p=NS | | | | | | Neonatal deaths p=NS NRDS p=NS Intraventricular hemorrhage p=NS Neonatal sepsis p=NS Necrotizing enterocolitis p=NS Respirator treatment p=NS Symptomatic ductal patency p=NS | | | Gestational outcomes by tocolytic & baby born <30 wks vs. >30 wks. Neonatal outcomes by tocolytic & baby born during tocolysis vs. born after tocolysis. | Indomethacin showed efficacy over nylidrine: -labor delayed 24-48 h -delivery >37 wks -fewer maternal side effects.
  36.7 | 35.2
  (0.8) | (0.8)
  20% | 83%
  2892.0 | 2558.3
  (173.9) | (152.3)
  4 | 4
  1 | 0
  1 | 0
  3 | 2
  2 | 0
  1 | 1
  1 | 0
  6 | 4
  2 | 2

Evidence Table 3: Tocolytic first line: Beta-mimetics - Outcomes

Author (Year) | Delivery | | | | | | | | | Maternal | | | | | | Infant | | | | | | | | | | | | Other Analyses | Conclusions
Author (Year) | Estimated Gestational Age | | | Prolongation of Pregnancy Days | | | Gestational Weeks | | | Length of Hospital Stay | | | Maternal Morbidity | | | Birth Weight (g) | | | APGAR Score | | | Length of Hospital Stay | | | Other Infant Outcomes | | | Other Analyses | Conclusions
Author (Year) | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Other Analyses | Conclusions
Noblot G, Audra P, Fagur B, et al. ^160^ | | | | Mean prolongation weeks p=NS | | | Before 37th wk | | | Length of stay days p<0.05 | | | | | | Mean Singleton births p=NS | | | Mean score at 1 min, Singleton births p=NS Mean score at 5 min, Singleton births p=NS Mean score at 10 min, Singleton births p=NS | | | | | | | | | | Ritodrine & progesterone showed efficacy over ritodrine alone: -length of maternal hospital stay.
  6.4 | 6.0
  8 | 6
  17.8 | 13.6
  2832 | 3077
  7.7 | 8.7
  9.3 | 9.7
  9.8 | 9.7

Evidence Table 3: Tocolytic first line: Beta-mimetics - Outcomes

Author (Year) | Delivery | | | | | | | | | Maternal | | | | | | Infant | | | | | | | | | | | | Other Analyses | Conclusions
Author (Year) | Estimated Gestational Age | | | Prolongation of Pregnancy Days | | | Gestational Weeks | | | Length of Hospital Stay | | | Maternal Morbidity | | | Birth Weight (g) | | | APGAR Score | | | Length of Hospital Stay | | | Other Infant Outcomes | | | Other Analyses | Conclusions
Author (Year) | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Other Analyses | Conclusions
The Canadian Preterm Labor Investigators Group ^96^ | Mean (SE) | | | Prolonged delivery in days (SE) Randomization to delivery interval <24 h p<0.001 <48 h p<0.001 <7 days p=NS | | | Delivery <32 wks p=NS Prolonged delivery <37 wks p=NS | | | | | | Maternal deaths | | | Mean (SD) Birth weight <2500 | | | | | | Rehospitalization | | | Neonatal deaths p=NS Fetal mortality p=NS Postnatal deaths p=NS HMD Intraventricular hemorrhage Neonatal infection Respiratory disorders Resuscitation in delivery room Patent ductus arteriosis Seizures Hypotension Hypoglycemia | | | | Ritodrine showed efficacy over placebo: -delivery <24 h -delivery <48 h -delivery <7 days.
  34 | | 33.4
  (1.7) | | (1.8)
  27.8 | | 24.5
  (1.6) | | (1.6)
  7.1% | | 19.7%
  21.4% | | 35.4%
  38.2% | | 47.2%
  48.8% | | 58.0%
  68.2% | | 68.8%
  0 | | 0
  2317 | | 2200
  (48) | | (49)
  55.9% | | 61.8%
  33.6% | | 25.6%
  12 | | 12
  10 | | 11
  1 | | 2
  18.6% | | 23.7%
  5.7% | | 8.2%
  10.3% | | 10.5%
  33.2% | | 37.1%
  43.0% | | 50.3%
  8.1% | | 11.3%
  1.1% | | 1.1%
  11.1% | | 11.3%
  9.5% | | 7.1%

Evidence Table 3: Tocolytic first line: Beta-mimetics - Outcomes

Author (Year) | Delivery | | | | | | | | | Maternal | | | | | | Infant | | | | | | | | | | | | Other Analyses | Conclusions
Author (Year) | Estimated Gestational Age | | | Prolongation of Pregnancy Days | | | Gestational Weeks | | | Length of Hospital Stay | | | Maternal Morbidity | | | Birth Weight (g) | | | APGAR Score | | | Length of Hospital Stay | | | Other Infant Outcomes | | | Other Analyses | Conclusions
Author (Year) | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Other Analyses | Conclusions
Kupferminc M, Lessing JB, Yaron Y, et al. ^130^ | | | | Singleton gestations: Successfully delayed >48 h p=NS Successfully delayed 7 days p=NS Successfully delayed >36 wks p=NS Multiple gestations: Successfully delayed >48 h Successfully delayed 7 days Successfully delayed >36 wks | | | | | | | | | Adverse drug reactions p<0.001 | | | Mean Singleton births (SD) | | | Singleton births: APGAR <7 at 1 min p=NS APGAR <7 at 5 min p=NS Multiple births: APGAR <7 at 1 min APGAR <7 at 5 min | | | | | | Mean neonatal deaths Singleton births: Multiple births: | | | | Nifedipine & ritodrine showed no difference in efficacy.
  25 | 23
  (83%) | (77%)
  20 | 19
  (67%) | (63%)
  15 | 13
  (50%) | (43%)
  5/6 | 3/5
  4/6
  3/6
  8/30 | 23/30
  N=30 | N=30
  2392 | 2471
  (721) | (738)
  3 | 4
  2 | 2
  0 | 0
  0 | 0
  0 | 1
  0 | 0

Evidence Table 3: Tocolytic first line: Beta-mimetics - Outcomes

Author (Year) | Delivery | | | | | | | | | Maternal | | | | | | Infant | | | | | | | | | | | | Other Analyses | Conclusions
Author (Year) | Estimated Gestational Age | | | Prolongation of Pregnancy Days | | | Gestational Weeks | | | Length of Hospital Stay | | | Maternal Morbidity | | | Birth Weight (g) | | | APGAR Score | | | Length of Hospital Stay | | | Other Infant Outcomes | | | Other Analyses | Conclusions
Author (Year) | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Other Analyses | Conclusions
Eronen M, Pesonen E, Kurki TM, et al. (1994) | Mean (SD) p=0.049 | | | Mean prolongation weeks p=0.4 | | | | | | | | | | | | Mean (SD) p=0.2 | | | APGAR <7 at 1 min p=0.9 APGAR <7 at 5 min p=0.5 | | | Median days (SD) p=0.56 | | | Neonatal deaths p=0.5 Respiratory distress syndrome p=0.2 Bronchiopulmonary dysplasia p=0.02 Survival w/ serious morbidity p=0.01 | | | | Indomethacin showed efficacy over nylidrin: -greater EGA at birth -lower rate of bronchiopulminary dysplasia -infant survival w/ serious morbidity.
  35.6 | 34.1
  (5.4) | (4.3)
  6.6 | 4.5
  2570 | | 2289
  (1191) | | (847)
  15 | 15
  9 | 6
  13.7 | 12.4
  1 | 1
  26% | 13%
  24% | 5%
  11 | 2

Evidence Table 3: Tocolytic first line: Beta-mimetics - Outcomes

Author (Year) | Delivery | | | | | | | | | Maternal | | | | | | Infant | | | | | | | | | | | | Other Analyses | Conclusions
Author (Year) | Estimated Gestational Age | | | Prolongation of Pregnancy Days | | | Gestational Weeks | | | Length of Hospital Stay | | | Maternal Morbidity | | | Birth Weight (g) | | | APGAR Score | | | Length of Hospital Stay | | | Other Infant Outcomes | | | Other Analyses | Conclusions
Author (Year) | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Other Analyses | Conclusions
Holleboom CAG, Merkus JMWM, van Elferen, et al. ^131^ | Mean (SEM) p=0.59 | | | Delivered within 12 h p=0.43 Delivered 12-24 h p=0.37 Delivered 24-28 h p=0.77 | | | Delivered at <32 wks p=0.89 Delivered at 32-33 wks p=0.85 Delivered at 34-36 wks p=0.11 | | | | | | Adverse drug reactions Maternal deaths | | | Mean birth weight (SD) | | | | | | NICU admissions p=NS | | | NRDS p=NS Mean neonatal and fetal deaths p=NS Intraventricular hemorrhage p=0.05 Pulmonary edema Hyperbilirubinemia p=NS Patent ductus arteriosis p=NS | | | | The two ritodrine treatment regimens did not show differences in efficacy.
  248 | 250
  (2.7) | (2.7)
  9 | 6
  4 | 7
  6 | 5
  20 | 21
  17 | 16
  24 | 16
  34 | 57
  0 | 0
  2421 | 2570
  (784) | (879)
  65 | 60
  12 | 17
  1 | 4
  4 | 15
  0 | 0
  32 | 28
  1 | 6

Evidence Table 3: Tocolytic first line: Beta-mimetics - Outcomes

Author (Year) | Delivery | | | | | | | | | Maternal | | | | | | Infant | | | | | | | | | | | | Other Analyses | Conclusions
Author (Year) | Estimated Gestational Age | | | Prolongation of Pregnancy Days | | | Gestational Weeks | | | Length of Hospital Stay | | | Maternal Morbidity | | | Birth Weight (g) | | | APGAR Score | | | Length of Hospital Stay | | | Other Infant Outcomes | | | Other Analyses | Conclusions
Author (Year) | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Other Analyses | Conclusions
Kanayama N, Maradny E, Yamamoto N, et al. ^132^ | Mean primi (SD) Mean multi (SD) | | | Weeks, primi p<0.02 Weeks, multi p<0.09 | | | Delivery>36 wks, primi Delivery >36 wks, multi | | | | | | Hours to stop contractions, primi (SD) p<0.01 Hours to stop contractions, multi (SD) p<0.01 Recurrent contractions, primi p<0.009 Recurrent contractions, multi p<0.005 C-section p=ns | | | All patients p=ns | | | All patients at 5 min p=ns | | | | | | Neonatal deaths p=ns | | | | Urinary trypsin inhibitor showed efficacy over ritodrine: -prolongation of pregnancy weeks.
  37.9 | 36.7
  (1.38) | (3.01)
  38.6 | 35.7
  (1.2) | (3.75)
  7.3 | 6.2
  9.2 | 6.9
  24 | 19
  32 | 20
  3.2 | 1.4
  (2.75) | (1.41)
  6.1 | 1.5
  (3.68) | (1.45)
  4 | 13
  16 | 6
  8% | 12%
  2900.53 | 2495.15
  8.2 | 7.8
  1% | 3%

Evidence Table 3: Tocolytic first line: Beta-mimetics - Outcomes

Author (Year) | Delivery | | | | | | | | | Maternal | | | | | | Infant | | | | | | | | | | | | Other Analyses | Conclusions
Author (Year) | Estimated Gestational Age | | | Prolongation of Pregnancy Days | | | Gestational Weeks | | | Length of Hospital Stay | | | Maternal Morbidity | | | Birth Weight (g) | | | APGAR Score | | | Length of Hospital Stay | | | Other Infant Outcomes | | | Other Analyses | Conclusions
Author (Year) | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Other Analyses | Conclusions
Guinn DA, Goepfert AR, Owen J, et al. ^133^ | Mean (SD) p=0.99 | | | Mean prolongation days (SD) p=0.69 | | | Delivered at <34 wks (%) p=0.88 Delivered at <37 wks (%) p=0.18 | | | | | | | | | | | | | | | NICU admissions p=0.89 | | | | | | Tx costs and charges for women discharged <24 h | Terbutaline did not show efficacy over observation and bed rest or hydration.
  38.1 | 38.2 | 38.2
  (2.8) | (2.4) | (2.5)
  55.7 | 59.6 | 60.0
  (26.9) | (25.9) | (24.7)
  4 | 4 | 5
  (6) | (7) | (9)
  19 | 10 | 13
  (31) | (16) | (23)
  18 | 15 | 17

Evidence Table 3: Tocolytic first line: Beta-mimetics - Outcomes

Author (Year) | Delivery | | | | | | | | | Maternal | | | | | | Infant | | | | | | | | | | | | Other Analyses | Conclusions
Author (Year) | Estimated Gestational Age | | | Prolongation of Pregnancy Days | | | Gestational Weeks | | | Length of Hospital Stay | | | Maternal Morbidity | | | Birth Weight (g) | | | APGAR Score | | | Length of Hospital Stay | | | Other Infant Outcomes | | | Other Analyses | Conclusions
Author (Year) | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Other Analyses | Conclusions
Jannet D, Abankwa A, Guyard B, et al. ^134^ | Mean (SD) p<0.05 | | | | | | Delivery <34 wks Delivery at term p<0.05 | | | | | | C-sections | | | Mean (SD) p=ns | | | Mean at 1 min (SD) p=ns Mean at 5 min (SD) p=ns | | | | | | pH <7.25 p=ns Transfer in NICU p=ns | | | Premature infants had comparable outcomes. | Nicardiprine showed efficacy over salbutamol: -EGA at delivery -delivery at term.
  38.4 | | 37.6
  (1.7) | | (2.1)
  1 | 2
  90.7% | 72.1%
  5 | 5
  3131 | | 3019
  (488) | | (494)
  8.7 | | 8.4
  (1.3) | | (1.8)
  9.8 | | 9.5
  (0.5) | | (1.5)
  2 | 4
  5 | 7

Evidence Table 3: Tocolytic first line: Beta-mimetics - Outcomes

Author (Year) | Delivery | | | | | | | | | Maternal | | | | | | Infant | | | | | | | | | | | | Other Analyses | Conclusions
Author (Year) | Estimated Gestational Age | | | Prolongation of Pregnancy Days | | | Gestational Weeks | | | Length of Hospital Stay | | | Maternal Morbidity | | | Birth Weight (g) | | | APGAR Score | | | Length of Hospital Stay | | | Other Infant Outcomes | | | Other Analyses | Conclusions
Author (Year) | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Other Analyses | Conclusions
Papatsonis DNM, van Geijn HP, Ader HJ, et al. ^159^ | Mean (SD) p=0.046 | | | Mean prolongation days (CI) Intact membranes p=0.003 PROM P=0.056 Delivered within 24 h p=0.006 Intact membranes p=0.003 PROM p=0.57 Delivered within 48 h Intact membranes p=0.03 PROM p=0.55 Delivered within 1 wk Intact membranes p=0.01 PROM p=0.35 Delivered within 2 wks Intact membranes p=0.008 PROM p=0.27 | | | Delivered <34 wks Intact membranes p=0.04 PROM p=0.35 Delivered <37 wks Intact membranes p=0.055 PROM p=1.00 | | | | | | | | | Mean (SD) p=.07 | | | | | | | | | Neonatal mortality p=NS NRDS p=0.03 NICU admission p=0.04 Umbilical artery pH (SD) p=NS Umbilical vein pH (SD) p=NS | | | Intact membranes & PROM were analyzed separately. Survival analysis curve of delivery delay until end of week 1. | Nifedipine showed efficacy over ritodrine: -EGA at delivery -delivery at >34 wks -delivery >37 wks -RDS -NICU admissions.
  32.1 | 33.4
  (4.1) | (4.5)
  39.2 | 22.1
  (30.7- 47.6) | (14.9- 29.3)
  7.2 | 15.1
  (3.2- 11.2) | (7.9- 22.3)
  22 | 11
  17 | 7
  5 | 4
  29 | 21
  20 | 13
  9 | 8
  45 | 36
  27 | 19
  18 | 17
  32 | 24
  20 | 19
  35 | 30
  23 | 23
  40 | 39
  24 | 27
  1870 | 2120
  (847) | (920)
  6 | 7
  31 | 23
  64 | 65
  7.23 | 7.26
  (0.13) | (0.08)
  7.30 | 7.32
  (0.10) | (0.07)

Evidence Table 3: Tocolytic first line: Beta-mimetics - Outcomes

Author (Year) | Delivery | | | | | | | | | Maternal | | | | | | Infant | | | | | | | | | | | | Other Analyses | Conclusions
Author (Year) | Estimated Gestational Age | | | Prolongation of Pregnancy Days | | | Gestational Weeks | | | Length of Hospital Stay | | | Maternal Morbidity | | | Birth Weight (g) | | | APGAR Score | | | Length of Hospital Stay | | | Other Infant Outcomes | | | Other Analyses | Conclusions
Author (Year) | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Other Analyses | Conclusions
Garcia-Velasco JA, Gonzalez AG ^153^ | | | | Mean prolongation days (SD) p=NS Prolongation >48 h p=NS | | | Delivery at >36 wks p=NS | | | Length of admission days (SD) | | | | | | Mean (SD) p=NS <2500 g | | | APGAR <7 | | | | | | Neonatal mortality | | | | No significant differences were found between ritodrine & nifedipine.
  43.71 | 64.00
  (4.23) | (7.21)
  88.46% | 93.31%
  84.61% | 89.92%
  3.87 | 3.69
  (0.51) | (0.36)
  2654.28 | 3100.00
  (185.08) | (136.18)
  11.53% | 7.69%
  0 | 0
  0 | 0

Evidence Table 3: Tocolytic first line: Beta-mimetics - Outcomes

Author (Year) | Delivery | | | | | | | | | Maternal | | | | | | Infant | | | | | | | | | | | | Other Analyses | Conclusions
Author (Year) | Estimated Gestational Age | | | Prolongation of Pregnancy Days | | | Gestational Weeks | | | Length of Hospital Stay | | | Maternal Morbidity | | | Birth Weight (g) | | | APGAR Score | | | Length of Hospital Stay | | | Other Infant Outcomes | | | Other Analyses | Conclusions
Author (Year) | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Other Analyses | Conclusions
Koks CAM, Brölmann HAM, de Kleine MJL, et al. ^135^ | Mean (SD) Singleton births p=0.143 Multiple births p=0.675 | | | Prolonged delivery >48 h p=NS Prolonged delivery >7 days p=NS | | | Prolonged delivery >34 wks p=NS | | | | | | | | | Mean birth weight (SD) Singleton births p=0.185 Multiple births p=0.158 | | | APGAR at 1 min Singleton births p=0.002 Multiple births p=0.001 APGAR at 5 min Singleton births p=0.202 Multiple births p=0.077 | | | | | | | | | | No significant differences were shown between nifedipine & ritodrine.
  n=43 | n=35
  33.3 | 31.8
  (4.4) | (4.5)
  n=24 | n=24
  32.1 | 31.6
  (4.1) | (2.9)
  60% | 66%
  47% | 45%
  38% | 23%
  2112 | 1856
  (821) | (855)
  1697 | 1463
  (701) | (373)
  8.5 | 7
  7 | 6
  10 | 9
  9 | 8.5

Evidence Table 3: Tocolytic first line: Beta-mimetics - Outcomes

Author (Year) | Delivery | | | | | | | | | Maternal | | | | | | Infant | | | | | | | | | | | | Other Analyses | Conclusions
Author (Year) | Estimated Gestational Age | | | Prolongation of Pregnancy Days | | | Gestational Weeks | | | Length of Hospital Stay | | | Maternal Morbidity | | | Birth Weight (g) | | | APGAR Score | | | Length of Hospital Stay | | | Other Infant Outcomes | | | Other Analyses | Conclusions
Author (Year) | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Other Analyses | Conclusions
Spearing G ^146^ | | | | Delivery delayed < 48 h p=NS Delivery delayed 48 h - 14 days p=NS Delivery delayed >14 days p=NS | | | | | | | | | Failed to inhibit contractions Relapse <48 h Relapse >48 h No relapse (p<0.05 for Tx1 vs. Tx2) (p=NS for Tx1 vs. Tx3) | | | Mean birth weight: <1500 g 1500-2000 g 2001-2500 g 2501-3000 g >3000 g | | | | | | Mean stay (days) | | | Mean neonatal deaths | | | Table 5 shows distribution of ruptured membranes. | Unresolved due to discontinuation to study. Insufficient statistical analysis to compare study arms.
  10 | 4 | 5
  4 | 6 | 3
  8 | 10 | 12
  11 | 5 | 5
  4 | 1 | 3
  3 | 7 | 4
  4 | 7 | 8
  5 | 3 | 3
  4 | 3 | 4
  4 | 4 | 3
  3 | 4 | 5
  7 | 6 | 10
  5 | 2 | 1
  0 | 3 | 1

Evidence Table 3: Tocolytic first line: Beta-mimetics - Outcomes

Author (Year) | Delivery | | | | | | | | | Maternal | | | | | | Infant | | | | | | | | | | | | Other Analyses | Conclusions
Author (Year) | Estimated Gestational Age | | | Prolongation of Pregnancy Days | | | Gestational Weeks | | | Length of Hospital Stay | | | Maternal Morbidity | | | Birth Weight (g) | | | APGAR Score | | | Length of Hospital Stay | | | Other Infant Outcomes | | | Other Analyses | Conclusions
Author (Year) | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Other Analyses | Conclusions
Kosasa TS, Nakayama RT, Hale RW, et al. (1985) | Mean (SD) p<0.01 Birth age in weeks for admission EGA of <33 wks (SD) p<0.01 Birth age in weeks for admission EGA of >33 wks (SD) p=NS | | | Mean prolongation days (SD) p<0.001 Days gained from admission EGA of <33 wks (SD) p<0.001 Days gained from admission EGA of >33 wks (SD) p<0.001 | | | Number of patients achieving 36 wks gestation p<0.03 | | | | | | | | | Mean birth weight p<0.05 Birth weights <2500 p=NS | | | | | | | | | Respiratory distress | | | | Terbutaline showed efficacy over ritodrine: -EGA at birth -prolongation of pregnancy -achieving 36 wks gestation -birth weight.
  36.5 | 34.5
  (3.99) | (4.99)
  33.7 | 31.6
  (3.87) | (4.32)
  37.6 | 36.0
  (4.28) | (3.72)
  25.8 | 13.0
  (21.4) | (17.4)
  26.3 | 12.6
  (22.8) | (13.2)
  24.7 | 13.8
  (23.2) | (15.6)
  30 | 19
  (60%) | (39%)
  2588 | 2392
  12% | 18%
  6 | 9

Evidence Table 3: Tocolytic first line: Beta-mimetics - Outcomes

Author (Year) | Delivery | | | | | | | | | Maternal | | | | | | Infant | | | | | | | | | | | | Other Analyses | Conclusions
Author (Year) | Estimated Gestational Age | | | Prolongation of Pregnancy Days | | | Gestational Weeks | | | Length of Hospital Stay | | | Maternal Morbidity | | | Birth Weight (g) | | | APGAR Score | | | Length of Hospital Stay | | | Other Infant Outcomes | | | Other Analyses | Conclusions
Author (Year) | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Other Analyses | Conclusions
Read MD, Wellby DE ^140^ | | | | Mean prolongation days p<0.001* *Tx2 compared to Tx1 & Cx | | | | | | | | | Adverse drug reactions | | | Mean | | | | | | | | | Fetal mortality | | | | Nifedipine showed efficacy over ritodrine and control: -prolongation days.
  25.1 | 36.3 | 19.3
  (5.7) | (5.1) | (6.1)
  13 | 18 | 0
  3020 | 3225 | 2860
  (326) | (432) | (258)
  0 | 0 | 0

Evidence Table 3: Tocolytic first line: Beta-mimetics - Outcomes

Author (Year) | Delivery | | | | | | | | | Maternal | | | | | | Infant | | | | | | | | | | | | Other Analyses | Conclusions
Author (Year) | Estimated Gestational Age | | | Prolongation of Pregnancy Days | | | Gestational Weeks | | | Length of Hospital Stay | | | Maternal Morbidity | | | Birth Weight (g) | | | APGAR Score | | | Length of Hospital Stay | | | Other Infant Outcomes | | | Other Analyses | Conclusions
Author (Year) | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Other Analyses | Conclusions
Chau AC, Gabert HA, Miller JM ^128^ | | | | Mean prolongation weeks (SD) p<0.005 Median prolongation weeks Delivery delayed >48 h p=NS Delivery at <7 days p=NS | | | Delivered at term (%) p<0.05 | | | | | | Idiopathic premature labor p=NS Severe preeclampsia p=NS Chorioamnionitis p=NS | | | Mean (SD) p<0.05 | | | APGAR at 1 min p=NS APGAR at 5 min p=NS | | | | | | | | | Discusses subjects who crossed over to the other treatment group due to failure of their initial method. | Magnesium sulfate showed effectiveness over terbutaline: -mean prolongation wks -delivery at term -mean birth weight.
  7.1 | 5.0
  (3.9) | (3.2)
  6.3 | 5.0
  44 | 48
  2 | 7
  34 | 27
  (73.9) | (51.9)
  10.9% | 21.2%
  4 | 3
  2 | 5
  2821 | 2536
  (640) | (759)

Evidence Table 3: Tocolytic first line: Beta-mimetics - Outcomes

Author (Year) | Delivery | | | | | | | | | Maternal | | | | | | Infant | | | | | | | | | | | | Other Analyses | Conclusions
Author (Year) | Estimated Gestational Age | | | Prolongation of Pregnancy Days | | | Gestational Weeks | | | Length of Hospital Stay | | | Maternal Morbidity | | | Birth Weight (g) | | | APGAR Score | | | Length of Hospital Stay | | | Other Infant Outcomes | | | Other Analyses | Conclusions
Author (Year) | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Other Analyses | Conclusions
Kosasa TS, Busse R, Wahl N, et al. ^141^ | | | | Mean days (SD) Delay >72 h | | | | | | | | | Side effects | | | | | | | | | | | | Fetal mortality | | | Side effects detailed: outcomes for placenta previa and abruption (no statistical analyses). | No statistical analysis provided comparing study results.
  61 | 20.5
  (23.6) | (17.4)
  84% | 64%
  44.3% | 59%
  0 | 0

Evidence Table 3: Tocolytic first line: Beta-mimetics - Outcomes

Author (Year) | Delivery | | | | | | | | | Maternal | | | | | | Infant | | | | | | | | | | | | Other Analyses | Conclusions
Author (Year) | Estimated Gestational Age | | | Prolongation of Pregnancy Days | | | Gestational Weeks | | | Length of Hospital Stay | | | Maternal Morbidity | | | Birth Weight (g) | | | APGAR Score | | | Length of Hospital Stay | | | Other Infant Outcomes | | | Other Analyses | Conclusions
Author (Year) | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Other Analyses | Conclusions
Sciscione AC, Stamilio DM, Manley JS, et al. ^143^ | Mean (SD) p=0.14 | | | | | | <37 wks p=0.07 <35 wks p=0.72 <32 wks p=0.25 | | | | | | | | | Mean (SD) | | | | | | NICU admissions p=0.35 | | | | | | | No significant differences were found between tx and control group.
  38.0 | | 38.5
  (2.5) | | (1.8)
  21% | | 10%
  7% | | 4%
  4% | | 0%
  3231 | | 3204
  (703) | | (491)
  11% | | 5%

Evidence Table 3: Tocolytic first line: Beta-mimetics - Outcomes

Author (Year) | Delivery | | | | | | | | | Maternal | | | | | | Infant | | | | | | | | | | | | Other Analyses | Conclusions
Author (Year) | Estimated Gestational Age | | | Prolongation of Pregnancy Days | | | Gestational Weeks | | | Length of Hospital Stay | | | Maternal Morbidity | | | Birth Weight (g) | | | APGAR Score | | | Length of Hospital Stay | | | Other Infant Outcomes | | | Other Analyses | Conclusions
Author (Year) | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Other Analyses | Conclusions
Coleman FH ^152^ | | | | | | | Delivery <36 wks p=0.017 | | | | | | | | | Median (Range) p=NS | | | | | | Median (Range) p=0.017 | | | Neonatal morbidity rate p=NS | | | | Dual tocolysis continued despite complications effectively: -increased delivery >36 wks -decreased Median infant length of hospital stay.
  19.5% | 50%
  3115 | 2449
  (1430- 4139) | (1370- 3621)
  3 | 15.5
  (2-67) | (2-72)
  41.5% | 60%

Evidence Table 3: Tocolytic first line: Beta-mimetics - Outcomes

Author (Year) | Delivery | | | | | | | | | Maternal | | | | | | Infant | | | | | | | | | | | | Other Analyses | Conclusions
Author (Year) | Estimated Gestational Age | | | Prolongation of Pregnancy Days | | | Gestational Weeks | | | Length of Hospital Stay | | | Maternal Morbidity | | | Birth Weight (g) | | | APGAR Score | | | Length of Hospital Stay | | | Other Infant Outcomes | | | Other Analyses | Conclusions
Author (Year) | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Other Analyses | Conclusions
de Veciana M, Porto M, Major CA, et al. ^142^ | Mean (SD) p=ns | | | Mean hours (SD) p=ns | | | Delivery >48 h (%) | | | | | | | | | Mean (SD) p=ns | | | APGAR <7 at 5 min (%) p=ns | | | Mean (SD) p=ns | | | Neonatal deaths p=ns Mild NRDS p=ns Severe NRDS p=.04 Intraventricular hemorrhage p=ns Necrotizing enterocolitis p=ns Mean days incubated (SD) p=NS | | | Decreased incidence of severe respiratory distress syndrome | Combined treatment w/ terbutaline, magnesium sulfate, & indomethacin showed no significant difference over terbutaline alone.
  31.1 | | 32.6
  (3.5) | | (3.5)
  102.9 | | 45.2
  (145.6) | | (146.2)
  21 | | 3
  (48) | | (10)
  1778 | | 2346
  (705) | | (782)
  1 | | 2
  (2.1) | | (6.3)
  22.4 | | 11.5
  (28.6) | | (22.7)
  8.3% | | 9.4%
  23% | | 31.3%
  8.3% | | 28.1%
  4% | | 9.1%
  0% | | 3%
  4.02 | | 12.5
  (2.8) | | (8.5)

Evidence Table 3: Tocolytic first line: Beta-mimetics - Outcomes

Author (Year) | Delivery | | | | | | | | | Maternal | | | | | | Infant | | | | | | | | | | | | Other Analyses | Conclusions
Author (Year) | Estimated Gestational Age | | | Prolongation of Pregnancy Days | | | Gestational Weeks | | | Length of Hospital Stay | | | Maternal Morbidity | | | Birth Weight (g) | | | APGAR Score | | | Length of Hospital Stay | | | Other Infant Outcomes | | | Other Analyses | Conclusions
Author (Year) | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Other Analyses | Conclusions
van Dijk KG, Dekker GA, van Geijn HP ^155^ | Median (Range) | | | Median (Range) | | | Delivery <34 wks (%) | | | Median (Range) | | | Adverse drug reactions (%) p=NS | | | Mean (SD) p=0.001 | | | | | | | | | Neonatal deaths NICU admissions Neonatal patent ductus Mean umbilical artery pH (SD) p=0.36 Mean umbilical vein pH (SD) p=0.89 | | | | Ritodrine showed effectiveness over nifedipine: birth weight.
  30 | 32
  (24-34) | (22-42)
  3 | 10
  (1-53) | (1-135)
  32 | 21
  (100) | (73)
  23 | 59
  (1-45) | (12-130)
  13 | 7
  (74) | (24)
  1430 | 1892
  (569) | (822)
  22% | 14%
  97% | 81%
  50% | 19%
  7.24 | 7.29
  (0.12) | (0.08)
  7.33 | 7.35
  (0.10) | (0.06)

Evidence Table 3: Tocolytic first line: Beta-mimetics - Outcomes

Author (Year) | Delivery | | | | | | | | | Maternal | | | | | | Infant | | | | | | | | | | | | Other Analyses | Conclusions
Author (Year) | Estimated Gestational Age | | | Prolongation of Pregnancy Days | | | Gestational Weeks | | | Length of Hospital Stay | | | Maternal Morbidity | | | Birth Weight (g) | | | APGAR Score | | | Length of Hospital Stay | | | Other Infant Outcomes | | | Other Analyses | Conclusions
Author (Year) | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Other Analyses | Conclusions
Hastwell GB, Halloway CP, Taylor TL ^156^ | | | | >24 h >2 days >1 wk >2 wks >4 wks >24 h >2 days >1wk >2 wks >4 wks | | | 28-31 wks 32-33 wks 34-35 wks 36 or more wks | | | | | | | | | 1-1.4 kg 1.5-1.9 kg 2.0-2.4 kg 2.5+ kg | | | Mean at 1 min Mean at 5 min | | | | | | Fetal mortality NRDS Perinatal mortality Hypothermia | | | Prolongation by level of dilatation and state of membrane | No statistical analysis provided comparing study arms.
  91.8%
  89.4%
  75.5%
  66.8%
  8.0%
  PTL only, no dilation >4 cm or PROM (n=136)
  96.3%
  92.6%
  78.7%
  69.1%
  56.6%
  20
  1
  41
  141
  12
  23
  58
  130
  6.5
  8.2
  8
  4.1%
  13
  12

Evidence Table 3: Tocolytic first line: Beta-mimetics - Outcomes

Author (Year) | Delivery | | | | | | | | | Maternal | | | | | | Infant | | | | | | | | | | | | Other Analyses | Conclusions
Author (Year) | Estimated Gestational Age | | | Prolongation of Pregnancy Days | | | Gestational Weeks | | | Length of Hospital Stay | | | Maternal Morbidity | | | Birth Weight (g) | | | APGAR Score | | | Length of Hospital Stay | | | Other Infant Outcomes | | | Other Analyses | Conclusions
Author (Year) | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Other Analyses | Conclusions
TambyRaja RL, Ng SC, Ratnam SS (1981) | | | | Delayed <24 h Delayed 24 h-7 days Delayed >7 days | | | | | | | | | Adverse drug reactions Post partum hemorrhage | | | | | | | | | | | | Neonatal deaths Serious congenital anomaly Stillbirths | | | Subanalysis of patients w/ intact membranes vs. PROM & dilation >2, =2,<2 cm; twins. | No statistical analysis provided since no comparison group.
  11.1%
  21.1%
  67.8%
  32.6%
  2
  5
  1
  0

Evidence Table 3: Tocolytic first line: Beta-mimetics - Outcomes

Author (Year) | Delivery | | | | | | | | | Maternal | | | | | | Infant | | | | | | | | | | | | Other Analyses | Conclusions
Author (Year) | Estimated Gestational Age | | | Prolongation of Pregnancy Days | | | Gestational Weeks | | | Length of Hospital Stay | | | Maternal Morbidity | | | Birth Weight (g) | | | APGAR Score | | | Length of Hospital Stay | | | Other Infant Outcomes | | | Other Analyses | Conclusions
Author (Year) | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Other Analyses | Conclusions
Phuapradit W, Pongthai S, Chaturachinda K ^139^ | | | | Delayed 72 h to 7 days Delayed >7 days | | | Delivered at >36 wks | | | | | | | | | Mean birth weight Birth weight: >2500 2000-2499 1500-1999 1000-1499 500-1000 | | | | | | | | | Mean neonatal deaths NRDS Jaundice Transient hypoglycemia | | | | No statistical analysis provided since no comparison group.
  57 (78%)
  46 (68%)
  40 (59%)
  2408
  36
  24
  12
  2
  2
  2
  2
  7
  2

Evidence Table 4: Tocolytic first line: Calcium channel blockers - Study design

Author(year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion/Exclusion Characteristics | Sample SizeInitial/End | | | Demographic Characteristics | | | TocolyticIntervention | Uniform Adjunctive Drug Intervention | Uniform Non-Drug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Author(year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion/Exclusion Characteristics | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | TocolyticIntervention | Uniform Adjunctive Drug Intervention | Uniform Non-Drug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Ferguson JE, Dyson DC, Schutz T, et al. ^125^ | To compare tocolysis with nifedipine to tocolysis with ritodrine | RCT; Masking: none | PTL: Contractions: >8/hr and (Change in dilation [before 36 wks]) or Change in effacement [before 36 wks]) Successful tocolysis defined as delay delivery 48 hrs if PROM and through 36 completed wks gestation in patients with intact membranes | EGA: 20-36 wks Also no: abnormal fetus, dilation >4 cm, fetal distress, multiple gestation, diabetes, hyperthyroidism, cardiac disease, hydramnios, abruptio placentae, dead fetus, intrauterine growth retardation | 66/66 | | | Mean Age (SD) | | | Tx1 Nifedipine sublingually 10 mg (increased to 40 mg) CoT: inital: if contractions persist after 20 min, similar dose until maximum 40 mg during first hr DoT: first hour Nifedipine oral 20 mg, typically at 4-6 hr intervals CoT: if sublingual stopped contractions, commenced 6 hrs later DoT: dk Tx2 Ritodrine IV 50 µg/min (increased every 15-30 min by 50 µg) CoT: initial DoT: contractions inhibited, adverse events developed, or 350 mg/min reached Ritodrine IV decreased 50 mg/min CoT: after first ritodrine DoT: 12 hrs Ritodrine IV decreased 50 g/min every 2 hrs COT: after 12 hrs of tx DOT: 100 µg/min reached Ritodrine oral 10-20 mg CoT: 30 min before discontinuation of IV DoT: every 4-6 hrs until dk | Hydration Betamethasone AoT: fetal lung maturation | Bedrest, fetal monitoring, IV fluids, uterine monitoring, electrocardiogram | | Country: United States Time period: 1984-1987 | M=60% C=65%
  33 | 33
  26.7 | 25.7
  (5.2) | (4.9)

Evidence Table 4: Tocolytic first line: Calcium channel blockers - Study design

Author(year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion/Exclusion Characteristics | Sample SizeInitial/End | | | Demographic Characteristics | | | TocolyticIntervention | Uniform Adjunctive Drug Intervention | Uniform Non-Drug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Author(year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion/Exclusion Characteristics | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | TocolyticIntervention | Uniform Adjunctive Drug Intervention | Uniform Non-Drug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Meyer WR, Randall HW, Graves WL ^126^ | To compare the tocolytic efficacy and safety of nifedipine and ritodrine hydrochloride | RCT; Masking: Subject: dk Physician: none Pharm., other care providers: dk | PTL: (Contractions:>6 within 30 min.or Dilation: change from baseline) and Contractions unresolved w/: bed rest, sedation, hydration IV, & 5 mg oral & 250 µg subcutaneous terbutaline w/ no response Successful tocolysis: delivery deferred for >24 hours | EGA: 22-35 wks Intact membranes Also no: current bleeding, multiple gestation, maternal infection, medical contraindication to tocolysis | 58/58 | | | | | | Tx1 Nifedipine oral 30 mg initially CoT: in PTL according to definition DoT: one dose Nifedipine oral 20 mg CoT: after initial dose DoT: every 6 hrs for 24 hrs, followed by every 8 hrs for 24 hrs Nifedipine oral 10 mg CoT: day 3 DoT: every 8 hrs until delivery Tx2 Ritodrine IV 50 µg/min w/ 50-µg increments to a maximum of 350 µg/min CoT: in PTL according to definition DoT: every 20 min for 12 hrs or side effects intolerable Terbutaline 5 mg oral CoT: after Ritodrine DoT: every 6 hrs Tx1 & Tx2 Magnesium sulfate 6 g IV CoT: Nifedipine & Ritodrine failures DoT: 1 dose Magnesium sulfate 2 g/hr IV CoT: following dose 1 DoT: dk | | Bedrest,Fetal monitoring,Rehydration,Doppler ultrasound for 6 subjects who agreed to nifedipine treatment | Inpatient: first 72 hrs Outpatient: dk | Country: United States Time period: 1986-1987 | M=76% C=40%
  34 | 24

Evidence Table 4: Tocolytic first line: Calcium channel blockers - Study design

Author(year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion/Exclusion Characteristics | Sample SizeInitial/End | | | Demographic Characteristics | | | TocolyticIntervention | Uniform Adjunctive Drug Intervention | Uniform Non-Drug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Author(year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion/Exclusion Characteristics | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | TocolyticIntervention | Uniform Adjunctive Drug Intervention | Uniform Non-Drug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Bracero LA, Leikin E, Kirshenbaum N, et al. ^127^ | To compare the efficacy of nifedipine with ritodrine in the control of PTL and compare their side effects | RCT; Masking: none | PTL: (Dilation:>2 cmor Effacement:>80%) or Contractions:>2/10 min & have not met dilation or effacement criteria, hydrated w/500 cc crystalloid solution but after 1 hr contractions every 5 m,in lasting >30 sec Successful tocolysis: defined as >72 hrs prolongation | EGA: 20-36 wks Intact Membranes Singleton Also: cervix <4 cm dilated, no: contraindications to tocolysis with ritodrine or nifedipine | 49/42 | | | Mean Age (SD) p=.254 | | | Tx1 Ritodrine IV 0.1 mg/min (increased by .05 mg/min every 10 min) to a max dose of .35 mg/min CoT: initial DoT: 12 hours Ritodrine oral 10 mg CoT: 30 min prior to discontinuaiton of IV DoT: every 2 hrs for 24 hrs Ritodrine oral 10 mg CoT: after 24 hrs of oral dosing DoT: every 4 hrs for 24 hrs Ritodrine oral 10 or 20 mg CoT: after 48 hrs of oral dosing DoT: every 4-6 hrs until dk Tx2 Nifedipine oral 30 mg CoT: initial DoT: one dose Nifedipine oral 20 mg CoT: after initial dose DoT: every 6 hrs for 24 hrs Nifedipine oral 20 mg CoT: after 24 hrs of oral dosing DoT: every 8 hrs for 24 hrs Nifedipine oral 20 mg CoT: after 24 hrs of oral dosing DoT: every 8-12 hrs until dk | | | | Country: dk Time period: 1987-1988 | M=74% C=66%
  19 | 23
  26 | 24
  (4) | (6)

Evidence Table 4: Tocolytic first line: Calcium channel blockers - Study design

Author(year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion/Exclusion Characteristics | Sample SizeInitial/End | | | Demographic Characteristics | | | TocolyticIntervention | Uniform Adjunctive Drug Intervention | Uniform Non-Drug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Author(year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion/Exclusion Characteristics | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | TocolyticIntervention | Uniform Adjunctive Drug Intervention | Uniform Non-Drug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Glock JL, Morales WJ ^162^ | To establish efficacy and safety of nifedipine versus magnesium sulfate in arresting PTL & preventing recurrent labor. | RCT; Masking: Subject, physician: none Pharm., other care providers: dk | PTL: Contractions: regular, <10 min apart and (Cervical change or dilation:>2 cm) Successful Tocolysis: Delay of delivery at least 2 days | EGA: 20-34 wks Intact membranes Also no: multiple gestation, dilation >4cm, known tocolytic exposure during study pregnancy, diabetes, hyperthyriodism, cardiac disease, preeclampsia, abruptio placentae, chorioamnionitis, hydramnios, renal failure, fetal distress, severe intrauterine growth retardation, and fetal anomalies incompatible with life. | 100/80 | | | Mean Age (SD) p=NS Race, Black p=NS | | | Tx1 Nifedipine sublingual 10 mg CoT: initial DoT: one dose Nifedipine sublingual 10 mg/20 min CoT: if contractions persist after intial dose DoT: up to 40 mg for first hour Nifedipine oral 20 mg/4 hr CoT: if sublingual treatment stopped uterine activity DoT: 48 hrs Nifedipine oral 10 mg/8 hr CoT: after last 48 hr dose DoT: until 34 wks completed Tx2 Magnesium sulfate IV 6 gm CoT: initial DoT: 30 min Magnesium sulfate IV 2 gm/hr, to max. 4 g/hr CoT: after 1^st^ 30 min treatment DoT: 24 hr Magnesium sulfate route unknown, 0.5 g/4-6 hr CoT: after uterine contractions arrested for 24 hrs DoT: dk Terbutaline oral 5 mg/6 hr CoT: when last magnesium sulfate rate reached 0.5 gm/hr DoT: until 34 wks completed Tx1 & Tx2 Ritodrine hydrochloride IV 50 µg/min, increasing by 50 g/min every 20 min AoT: for those who demonstrated persistent contractions and progressive cervical dilation or serious side effects. If successful, maintained for 12 hrs. Patients returned to oral regimen after ritodrine. Recurrent PTL >34 wks:IV magnesium followed by oral terbutaline to 36 wks | Ampicillin AoT: given to all patients, and after testing for Neisseria gonorrhoeae, group B streptococci, Chlamydia trachomatis, continued only with patients with positive tests. Betamethasone AoT: for fetal lung maturation in gestations >24 wks | Bedrest, Fetal monitoring, IV fluids, Uterine monitoring, Blood pressure monitoring | Inpatient | Country: United States Time period: 1991-1992 | M=65% C=80%
  39 | 41
  21.4 | 20.5
  (4.7) | (4.8)
  20 | 22
  (51%) | (54%)

Evidence Table 4: Tocolytic first line: Calcium channel blockers - Study design

Author(year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion/Exclusion Characteristics | Sample SizeInitial/End | | | Demographic Characteristics | | | TocolyticIntervention | Uniform Adjunctive Drug Intervention | Uniform Non-Drug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Author(year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion/Exclusion Characteristics | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | TocolyticIntervention | Uniform Adjunctive Drug Intervention | Uniform Non-Drug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Kupferminc M, Lessing JB, Yaron Y, et al. ^130^ | To compare the efficacy of tocolysis with specific regimens of nifedipine and ritodrine. | RCT; Masking: dk | PTL: Contractions: > 1/6 min and change in Cervical dilation or Cervical effacement Successful Tocolysis: Delivery deferred >48 hrs | EGA: 26-34 wks Intact membranes Also no: cervical dilation >4 cm, polyhydramnios, placental abruption, hypertension, signs of infection, any medical condition which contraindicates use of tocolytic therapy | 71/71 | | | Mean Age (SD) | | | Tx1 Nifedipine oral 30 mg CoT: after initial examination DoT: loading dose Nifedipine oral 20 mg CoT: if contractions persist after 90 min DoT: one dose Nifedipine oral 20 mg/8 hrs CoT: if either or both treatments successfully suppressed contractions DoT: maintenance until uterine quiescence Ritodrine IV dose: dk CoT: if contractions persist more than 60 min after second loading dose, these patients never received the maintenance dose DoT: dk Tx2 Ritodrine IV 50 µg/min, and increased by 15 µg/min/15 min to a max of 300 µg/min CoT: after initial examination DoT: effective dose maintained for 12 hrs or until contractions stopped, or unacceptable side effects developed Ritodrine oral 10 mg/3 hrs CoT: after effective dose DoT: until 35 wks | Betamethasone AoT: to enhance fetal lung maturity | Bedrest, Fetal monitoring, IV fluids, Uterine monitoring, Maternal blood pressure and pulse | Inpatient | Country: Israel Time period: 1988-1992 | M=60% C=83%
  36 | 35
  28.4 | 28.6
  (4.1) | (4.3)

Evidence Table 4: Tocolytic first line: Calcium channel blockers - Study design

Author(year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion/Exclusion Characteristics | Sample SizeInitial/End | | | Demographic Characteristics | | | TocolyticIntervention | Uniform Adjunctive Drug Intervention | Uniform Non-Drug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Author(year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion/Exclusion Characteristics | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | TocolyticIntervention | Uniform Adjunctive Drug Intervention | Uniform Non-Drug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Smith CS, Woodland MB ^154^ | To compare oral nifedipine with subcutaneous terbutaline for reducing premature uterine irritability & contractions Uterine irritability is defined as uterine contractions w/out cervical change | RCT; Masking: dk | PTL: Contractions and Cervical change Successful tocolysis: contractions completely stopping within the 2 hr study interval | EGA: 20-35 wks Also no: chorioamnionitis, fetal distress, hypertensive disorders, seizure disorder, tachycardia, acute asthma | 52/dk | | | Mean Age 24 26 Race, White Race, Black Race, Hispanic | | | Tx1 Nifedipine oral 30 mg CoT: initial DoT: one dose Tx2 Terbutaline subcutaneous 0.25 mg CoT: initial DOT: every 20 minutes for 2 hrs Terbutaline IV dose: dk CoT: if contractions did not abate after oral terbutaline DoT: dk | | Further therapy (e.g. medication type, hospitalization) at discretion of the attending physician | | Country: United States Time period: 1989 | M=70% C=33%
  28 | 24
  5 | 5
  21 | 18
  2 | 1

Evidence Table 4: Tocolytic first line: Calcium channel blockers - Study design

Author(year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion/Exclusion Characteristics | Sample SizeInitial/End | | | Demographic Characteristics | | | TocolyticIntervention | Uniform Adjunctive Drug Intervention | Uniform Non-Drug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Author(year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion/Exclusion Characteristics | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | TocolyticIntervention | Uniform Adjunctive Drug Intervention | Uniform Non-Drug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Floyd RC, McLaughlin BN, Perry Jr KG, et al. ^163^ | To compare IV and subsequent oral magnesium with the oral administration of nifedipine as initial and long-term tocolytic agents in women w/ PTL. | RCT; Masking: dk | PTL: Contractions: regular, persistent, demonstrable, >1/10 min. and (Cervical change in dilation, effacement, position, station, and/or consistency from a previous examination or Cervix 2 cm dilated) Successful Tocolysis: not defined | EGA: 20-34 wks Intact membranes Maternal age: >15 yrs Also no: tocolytic medications during the current pregnancy, no allergies to either study drug, serious medical or obstetric complications that precluded tx w/ either drug or continuation of pregnancy, multiple gestation, chorioamnionitis. | 90/85 | | | Mean Age (SD) Race, White Race, Black Race, American Indian | | | Tx1 Magnesium sulfate IV 4g CoT: initial DoT: 20 min Magnesium sulfate IV 4-6 g/hr CoT: after initial dose DoT: until uterine quiescence achieved Magnesium gluconate oral 2 g/4 hr CoT: after uterine quiescence maintained for 6 hrs DoT: until 37 wks Tx2 Nifedipine oral 30 mg CoT: inital DoT: one dose Nifedipine oral 20 mg/ 8 hrs CoT: after initial dose DoT: until uterine quiescence achieved Nifedipine oral 20 mg/ 8 hrs CoT: after uterine quiescence maintained for 6 hrs DoT: until 37 wks | | Blood pressure Ultrasounds | | Country: United States Time period: dk(18 month period) | M=75% C=65%
  40 | 50
  25.6 | 23.9
  (4.2) | (5.1)
  17 | 16
  22 | 33
  1 | 1

Evidence Table 4: Tocolytic first line: Calcium channel blockers - Study design

Author(year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion/Exclusion Characteristics | Sample SizeInitial/End | | | Demographic Characteristics | | | TocolyticIntervention | Uniform Adjunctive Drug Intervention | Uniform Non-Drug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Author(year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion/Exclusion Characteristics | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | TocolyticIntervention | Uniform Adjunctive Drug Intervention | Uniform Non-Drug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Jannet D, Abankwa A, Guyard B, et al. ^134^ | To compare the tocolytic action and the side effects of nicardipine to those of salbutamol in patients presenting with PTL | RCT; Masking: none | PTL: Contractions: 3/30 min and Dilation:>2 cm Successful tocolysis: defined as delivery at 37 wks | EGA: 25 to 35.5 wks Intact membranes Also informed consent; no: multiple gestation, maternal or fetal contraindications to tocolytic or beta-mimetic therapy | 90/86 | | | Age (SD) | | | Tx1 Nicardipine IV 3 mg/hr CoT: after exam DoT: 2 hr Nicardipine IV to maximum 6 mg/hr CoT: after above DoT: until cessation of uterine activity or troublesome side effects Nicardipine oral 60 mg CoT: after IV DoT: daily until 37 wks gestation Tx2 Salbutamol IV 0.15 mg/hr CoT: after exam DoT: 2 hr Salbutamol IV to maximum of 0.3 mg/hr CoT: after above DoT: until cessation of uterine activity or troublesome side effects Salbutamol oral 8mg and suppositories 2mg CoT: after IV DoT: daily until 37 wks gestation | | Bedrest, IV fluids, routine observation | Regular housecalls by midwives andclinic visits twice monthly | Country: France Time period: 1993-1994 | M=80% C=83%
  43 | 43
  29.4 | 28.9
  (5.5) | (6.3)

Evidence Table 4: Tocolytic first line: Calcium channel blockers - Study design

Author(year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion/Exclusion Characteristics | Sample SizeInitial/End | | | Demographic Characteristics | | | TocolyticIntervention | Uniform Adjunctive Drug Intervention | Uniform Non-Drug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Author(year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion/Exclusion Characteristics | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | TocolyticIntervention | Uniform Adjunctive Drug Intervention | Uniform Non-Drug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Papatsonis DNM, Van Geijn HP, Ader HJ, et al. ^159^ | To compare tocolytic efficacy and perinatal outcomes and to assess maternal side effects | Multi-center RCT; Masking: Subject, physician, pharm.: none Other care providers: dk | PTL: Contractions: 1/10 min, for at least 1 hr and/or PROM Successful Tocolysis: not defined | EGA: 20-33 4/7 wks Also no: multiple pregnancy, documented intrauterine infection, abnormal fetus, abruptio placentae, fetal growth restrictions, maternal contraindications for beta-adrenergic drugs (diabetes mellitus, cardiovascular disease, hyperthyroidism, server preeclampsia) | 185/173 Intact membranes PROM | | | Mean Age (SD) Intact membranes PROM | | | Tx1 Ritodrine IV fixed loading dose followed by infusion w/ dose decreasing progressively in cases w/out recurrence of contractions (following protocol of Holleboom et al.) CoT: initial DoT: at least 3 days Ritodrine oral 40 mg, 3/day (at 2 of 3 sites) CoT: after infusion DoT: until 34 wks Ritodrine IV &/or oral CoT: recurrent contractions DoT: 34 wks Indomethacin 300 mg/day CoT: only in case of ritodrine tocolysis failure DoT: 3 days Tx2 Nifedipine oral 10 mg/15 min CoT: initial DoT: until contraction cessation or max of 4 doses Nifedipine oral 60-160 mg/day CoT: after initial dose DoT: until 34 wks Indomethacin 300 mg/day CoT: only in case of nifedipine tocolysis failure DoT: 3 days | Steroids AoT: fetal lung maturation | Bedrest | Inpatient | Country: Holland Time period: 1992-1995 | M=72% C=100%
  78 | 95
  61 | 68
  29 | 27
  29.8 | 28.7
  (5.0) | (5.8)
  29.3 | 28.3
  (5.6) | (4.6)

Evidence Table 4: Tocolytic first line: Calcium channel blockers - Study design

Author(year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion/Exclusion Characteristics | Sample SizeInitial/End | | | Demographic Characteristics | | | TocolyticIntervention | Uniform Adjunctive Drug Intervention | Uniform Non-Drug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Author(year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion/Exclusion Characteristics | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | TocolyticIntervention | Uniform Adjunctive Drug Intervention | Uniform Non-Drug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Garcia-Velasco JA, Gonzalez AG ^153^ | To compare tocolytic efficacy of ritodrine and nifedipine using umbilical pulsed-Doppler ultrasound studies to evaluate fetal blood flow. | RCT; Masking: dk | PTL: Contractions: minimum of 4 every 30 min, "despite of" cervical changes Successful Tocolysis: Cessation of uterine activity within 12 hrs of initiation of tocolytic intervention | EGA: 26-34 wks Intact membranes Also no: multiple gestation, bleeding, dilation >3 cm, previous tocolytic treatment, evidence of maternal infection, any condition that would contraindicate tocolytic therapy | 52/52 | | | Mean Age (SD) | | | Tx1 Ritodrine IV .05 mg/min & .05 increments every 20 min until contractions ceased or heart rate 120 bpm or higher. (max dose was .35 mg/min) CoT: dk DoT: 12 hrs Ritodrine Oral 5 mg every 3 hours CoT: after IV Ritodrine stage complete DoT: up to 12 hrs including loading dose Tx2 Nifedipine Oral & sublingualInitial loading dose 30 mg (20 mg os & 10 mg sublingual) CoT: on uterine activity DoT: one dose Nifedipine Oral & sublingual10-20 mg every 4-6 hrs, depending on uterine activity CoT: after initial loading DoT: up to 12 hrs including loading dose Tx1 & Tx2 Indomethacin rectal 100 mg CoT: 12 hrs after tocolysis therapy begun and uterine activity still present or prior tocolytic treatment poorly tolerated DoT: single dose Indomethacin oral 25 mg per os CoT: after indomethacin initial dose DoT: every 6 hrs for up to 3 days | Beta-metasone AoT: fetal lung maturation | Bedrest, Fetal monitoring, IV fluids, Follow-up in high risk clinic | Inpatient | County: dk Time period: 1993-1996 | M=67% C=64%
  26 | 26
  27.62 | 28.76
  (2.01) | (1.52)

Evidence Table 4: Tocolytic first line: Calcium channel blockers - Study design

Author(year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion/Exclusion Characteristics | Sample SizeInitial/End | | | Demographic Characteristics | | | TocolyticIntervention | Uniform Adjunctive Drug Intervention | Uniform Non-Drug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Author(year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion/Exclusion Characteristics | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | TocolyticIntervention | Uniform Adjunctive Drug Intervention | Uniform Non-Drug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Koks CAM, Brölmann HAM, de Kleine MJK et al. ^135^ | To compare the efficacy and safety of nifedipine and ritodrine in preventing preterm labor, and to evaluate maternal side effects and neonatal outcome. | RCT; Masking: none | PTL: Contractions: 6/hr w/ 30 sec duration or more and w/ or w/out dilatation and effacement Successful Tocolysis: not defined | EGA: 24-34 wks Also no: history of any medical condition which would contraindicate the use of either drug, intrauterine infections, irregular fetal heart rate, history of antepartum hemorrhage or polyhydramnios | 102/102 | | | Mean Age (SD) | | | Tx1 Nifedipine sublingual 30 mg (if already on β-mimetics, dose was halved and nifedipine started with 20 mg orally, other tocolytic was stopped after 12 hrs, and the normal nifedipine dosage started) CoT: dk DoT: single dose Nifedipine oral 20 mg, 2-4 times daily (max dose increased to 40 mg every 8 hrs after 2/93) CoT: after initial dose DoT: until tocolysis achieved Nifedipine oral, dose reduced with minimal of 20 mg 3 times daily CoT: dk DoT: after 34 wks or earlier if possible Tx2 Ritodrine IV 200 mcg/min CoT: dk DoT: until tocolysis is achieved (Note: if patient already on β-mimetics, the dose was continued) Ritodrine IV dose decreased as much as possible, max of 400 mcg/min CoT: once tocolysis is achieved DoT: dk Ritodrine oral 80 mg, 3 times daily CoT: dk DoT: after 34 wks or earlier if possible Tx1 & Tx2 Indomethacin dose: dk (given to patients w/ persistent contractions before 30 wks) | Betamethasone AOT: fetal lung maturity Antibiotics AoT: given to carriers of the group β strep to treat the infection | Routine observation, Uterine monitoring, Fetal monitoring | Inpatient | Country: Nether-lands Time period: 1992-1995 | M=63% C=79%
  55 | 47
  29.8 | 29.3
  (4.8) | (4.9)

Evidence Table 4: Tocolytic first line: Calcium channel blockers - Study design

Author(year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion/Exclusion Characteristics | Sample SizeInitial/End | | | Demographic Characteristics | | | TocolyticIntervention | Uniform Adjunctive Drug Intervention | Uniform Non-Drug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Author(year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion/Exclusion Characteristics | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | TocolyticIntervention | Uniform Adjunctive Drug Intervention | Uniform Non-Drug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Read MD, Wellby DE ^140^ | To compare the efficacy of nifedipine, IV ritodrine, and no treatment controls in suppressing premature uterine activity | Non-random-ized control trial; Masking: none | PTL: Contractions:> 1/10 min Successful Tocolysis: if contractions were abolished and no further cervical dilation occurred during treatment and there was no recurrence of contractions within 48 hrs of stopping treatment | EGA: 20-35 wks Intact membranes Also no: multiple gestation, dilation >4 cm, history of cervical surgery, polyhydramnios, history of mid-trimester abortion or previous preterm delivery, history of any medical condition which would contraindicate the use of either drug, any evidence of intrauterine infection, irregularity of fetal heart, history of antepartum hemorrhage | 60/60 | | | Mean Age (SD) | | | Tx1 Ritodrine IV 50 µg/min, adjusting by increments of 50 µg up to 300 g/min CoT: after 30 min of observation DoT: until no contractions for 12 hrs or no maternal tachycardia (140/min) or fetal tachycardia (180/min), or other intolerable side effects Ritodrine IV 10 mg every 4 hrs CoT: when there are no contractions for 12hrs & infusion discontinued DoT: 48 hrs Tx2 Nifedipine oral 30 mg CoT: after 30 min of observation DoT: one dose Nifedipine oral 20 mg every 8 hrs CoT: after loading dose DoT: 3 days Ritodrine IV "standard dose" CoT: if patient shows no benefit after 2 hrs of receiving Nifedipine DoT: dk Cx No Treatment | | Observation | Inpatient | Country: England Time period: dk | M=54% C=27%
  20 | 20 | 20
  24.9 | 24.6 | 23.5
  (4.4) | (3.6) | (3.9)

Evidence Table 4: Tocolytic first line: Calcium channel blockers - Study design

Author(year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion/Exclusion Characteristics | Sample SizeInitial/End | | | Demographic Characteristics | | | TocolyticIntervention | Uniform Adjunctive Drug Intervention | Uniform Non-Drug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Author(year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion/Exclusion Characteristics | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | TocolyticIntervention | Uniform Adjunctive Drug Intervention | Uniform Non-Drug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
van Dijk KG, Dekkler GA, van Geijn HP ^155^ | To compare treatment of PTL with oral nifedipine relative to intravenous ritodrine | Retrospective cohort study; Masking: none | PTL not defined Successful tocolysis is defined as stable condition | Also: all patients receiving tocolytic therapy in 1989 and 1990 & referred to hospital because of preterm contractions that could not be halted | 61/61 | | | Mean Age (SD) | | | Tx1 Ritodrine IV 160 mcg/min (increased by 80 mcg/min until contractions stopped or maternal heart rate 140 beats per min) CoT: dk DoT: if stable, tapered after 3 days, if contractions reoccurred, dose increased until effective tocolysis Ritodrine oral dose:dk CoT: after IV DoT: 34 wks gestation Tx2 Nifedipine oral 10-40 mg CoT: first hour after admission DoT: dk Nifedipine oral 60-160 mg CoT: depending on efficacy of drug 1 DoT: daily, after 3 days taper to 60 mg until 34 wks gestation, if contractions reoccurred, dose increased until effective tocolysis Tx1 & Tx2 Indomethacin suppositories 100 mg, increased to maximum of 300 mg/day CoT: if labor could not be arrested w/above tx & EGA < 32 wks | Corticosteroids AoT: fetal lung maturation | | | Country: Holland Time period: 1989-1990 | C=32% M=24%
  32 | 29
  30.3 | 28.3
  (5.4) | (5.1)

Evidence Table 4: Tocolytic first line: Calcium channel blockers - Study design

Author(year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion/Exclusion Characteristics | Sample SizeInitial/End | | | Demographic Characteristics | | | TocolyticIntervention | Uniform Adjunctive Drug Intervention | Uniform Non-Drug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Author(year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion/Exclusion Characteristics | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | TocolyticIntervention | Uniform Adjunctive Drug Intervention | Uniform Non-Drug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Murray C, Haverkamp AD, Orleans M, et al. (1992) | To ascertain whether adverse effects occurred among mothers &/or fetuses treated w/ nifedipine and to assess nifedipine's usefulness in treating women in PTL who were intolerant of other tocolytics | Case series; Masking: none | PTL: Contractions:>6 per hr and admitted to the hospital Successful tocolysis not defined | Chart review of women admitted to antepartum ward for tocolysis w/diagnosis of PTL | 102/102 | | | Mean Age | | | Tx1 Nifedipine dose & route: dk CoT: dk DoT: dk | | Fetal monitoring, Ultrasound | Inpatient | Country: United States Time period: 1988-1989 | M=38% C=19%
  102
  28

Evidence Table 4: Tocolytic first line: Calcium channel blockers - Outcomes

Author (year) | Delivery | | | | | | | | | Maternal | | | | | | Infant | | | | | | | | | | | | Other Analyses | Conclusions
Author (year) | Estimated Gestational Age | | | Prolongation of Pregnancy Days | | | Gestational Weeks | | | Length of Hospital Stay | | | Maternal Morbidity | | | Birth Weight (g) | | | APGAR Score | | | Length of Hospital Stay | | | Other Infant Outcomes | | | Other Analyses | Conclusions
Author (year) | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Other Analyses | Conclusions
Ferguson JE, Dyson DC, Schutz T, et al. ^125^ | | | | Prolongation >48 hrs (%) Prolongation >7 days (%) | | | Delivery at > 36 wks (%) | | | | | | Adverse Drug Reactions | | | Mean (SD) | | | <7 at 1 min <7 at 5 min | | | | | | Neonatal Deaths NRDS or HMD Intraventricular Hemorrhage | | | 10 crossover patients: 6/10 delayed >48 hrs | No statistical analysis provided comparing study arms.
  27 | 23
  (84) | (72)
  16 | 17
  (70) | (63)
  9 | 14
  (41) | (52)
  5 | 18
  2228 | 2467
  (880) | (901)
  5 | 8
  2 | 3
  2 | 0
  4 | 2
  2 | 1

Evidence Table 4: Tocolytic first line: Calcium channel blockers - Outcomes

Author (year) | Delivery | | | | | | | | | Maternal | | | | | | Infant | | | | | | | | | | | | Other Analyses | Conclusions
Author (year) | Estimated Gestational Age | | | Prolongation of Pregnancy Days | | | Gestational Weeks | | | Length of Hospital Stay | | | Maternal Morbidity | | | Birth Weight (g) | | | APGAR Score | | | Length of Hospital Stay | | | Other Infant Outcomes | | | Other Analyses | Conclusions
Author (year) | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Other Analyses | Conclusions
Meyer WR, Randall HW, Graves WL ^126^ | | | | Mean p=.685 | | | Percent: >36 wks p=.767 | | | | | | Chorioamnionitis or abruptio placenta | | | Mean (SD) p=.815 Percent >2500 g | | | Mean at 1 min (SD) p=.815 Mean at 5 min p=.919 | | | | | | # of Neonatal Deaths Meconium stained fluid p=NS | | | | Nifedipine & Ritodrine did not show differences in relative efficacy.
  21.3 | 24.4
  42.9% | 34.8%
  1 | 1
  2606.8 | 2281.3
  (776.5) | (858.0)
  67.6% | 30.4%
  7.0 | 7.1
  (2.1) | (1.9)
  8.6 | 8.6
  (0.8) | (0.8)
  0 | 0
  17% | 8%

Evidence Table 4: Tocolytic first line: Calcium channel blockers - Outcomes

Author (year) | Delivery | | | | | | | | | Maternal | | | | | | Infant | | | | | | | | | | | | Other Analyses | Conclusions
Author (year) | Estimated Gestational Age | | | Prolongation of Pregnancy Days | | | Gestational Weeks | | | Length of Hospital Stay | | | Maternal Morbidity | | | Birth Weight (g) | | | APGAR Score | | | Length of Hospital Stay | | | Other Infant Outcomes | | | Other Analyses | Conclusions
Author (year) | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Other Analyses | Conclusions
Bracero LA, Leikin E, Kirshenbaum N, et al. ^ 127^ | Mean (SD) p=.184 | | | Prolongation Index (SD) p=.520 Tocolysis to delivery wks p=.481 Prolongation >72 hrs p=NS | | | | | | | | | Chorioamnionitis Histologic Chorioamnionitis Suspected | | | Mean (SD) p=.048 | | | Score at 1 min (SD) p=.773 Score at 5 min (SD) p=.771 | | | Mean NICU days (SD) NICU Admissions p=.037 | | | Neonatal Deaths p=ns % NRDS, HMD p=.043 % Necrotizing Entercolitis p=.923 % Sepsis p=.386 % Hyperbilirubenemia p=.060 | | | | Ritodrine & nifedipine showed no difference in efficacy for delivery outcomes. Nifedipine showed relative efficacy in infant birth weight & NICU admissions.
  35 | 36
  (4) | (3)
  9 | 11
  (11) | (12)
  3 | 4
  (3) | (3)
  68.4% | 69.6%
  5 | 4
  0 | 2
  2336 | 2823
  (781) | (763)
  7 | 8
  (2) | (2)
  8 | 9
  (2) | (2)
  6.8 | 0.9
  (11) | (3)
  57.9% | 26.1%
  0 | 4.3
  26.3 | 4.3
  5.3 | 0
  10.5 | 0
  31.6 | 8.7

Evidence Table 4: Tocolytic first line: Calcium channel blockers - Outcomes

Author (year) | Delivery | | | | | | | | | Maternal | | | | | | Infant | | | | | | | | | | | | Other Analyses | Conclusions
Author (year) | Estimated Gestational Age | | | Prolongation of Pregnancy Days | | | Gestational Weeks | | | Length of Hospital Stay | | | Maternal Morbidity | | | Birth Weight (g) | | | APGAR Score | | | Length of Hospital Stay | | | Other Infant Outcomes | | | Other Analyses | Conclusions
Author (year) | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Other Analyses | Conclusions
Glock JL, Morales WJ ^162^ | Mean (SD) p=NS | | | Prolonged >2 days p=NS | | | Delivery at >37 wks p=NS Delivery at >34 wks p=NS | | | Readmission for recurrent labor | | | Adverse Drug Reactions | | | Mean (SD) p=NS | | | APGAR at 1 min (SD) p=NS APGAR at 5 min (SD) p=NS | | | | | | Neonatal Mortality Fetal Mortality | | | | No significant difference shown between the efficacy of nifedipine & magnesium sulfate.
  34.5 | 35.2
  (2.8) | (3.1)
  92% | 93%
  16 | 17
  (41%) | (41%)
  24 | 28
  (62%) | (68%)
  10 | 10
  (26%) | (24%) p=NS
  16 | 13
  2434 | 2508
  (716) | (693)
  7.3 | 7.1
  (1.7) | (1.6)
  8.4 | 8.4
  (2.0) | (1.9)
  2 | 0
  (5%)
  0 | 0

Evidence Table 4: Tocolytic first line: Calcium channel blockers - Outcomes

Author (year) | Delivery | | | | | | | | | Maternal | | | | | | Infant | | | | | | | | | | | | Other Analyses | Conclusions
Author (year) | Estimated Gestational Age | | | Prolongation of Pregnancy Days | | | Gestational Weeks | | | Length of Hospital Stay | | | Maternal Morbidity | | | Birth Weight (g) | | | APGAR Score | | | Length of Hospital Stay | | | Other Infant Outcomes | | | Other Analyses | Conclusions
Author (year) | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Other Analyses | Conclusions
Kupferminc M, Lessing JB, Yaron Y, et al. ^130^ | | | | Singleton gestations: Successfully delayed >48 hrs p=NS Successfully delayed 7 days p=NS Successfully delayed >36 wks p=NS Multiple gestations: Successfully delayed > 48 hrs Successfully delayed 7 days Successfully delayed >36 wks | | | | | | | | | Adverse Drug Reactions p<0.001 | | | Mean singleton births (SD) | | | singleton births: APGAR <7 at 1 min p=NS APGAR <7 at 5 min p=NS multiple births: APGAR <7 at 1 min APGAR <7 at 5 min | | | | | | Mean neonatal deaths singleton births: multiple births: | | | | Nifedipine & ritodrine showed no difference in efficacy.
  25 | 23
  (83%) | (77%)
  20 | 19
  (67%) | (63%)
  15 | 13
  (50%) | (43%)
  5/6 | 3/5
  4/6
  3/6
  8/30 | 23/30
  N=30 | N=30
  2392 | 2471
  (721) | (738)
  3 | 4
  2 | 2
  0 | 0
  0 | 0
  0 | 1
  0 | 0

Evidence Table 4: Tocolytic first line: Calcium channel blockers - Outcomes

Author (year) | Delivery | | | | | | | | | Maternal | | | | | | Infant | | | | | | | | | | | | Other Analyses | Conclusions
Author (year) | Estimated Gestational Age | | | Prolongation of Pregnancy Days | | | Gestational Weeks | | | Length of Hospital Stay | | | Maternal Morbidity | | | Birth Weight (g) | | | APGAR Score | | | Length of Hospital Stay | | | Other Infant Outcomes | | | Other Analyses | Conclusions
Author (year) | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Other Analyses | Conclusions
Smith CS, Woodland MB ^154^ | Mean (Range) p=ns | | | | | | Preterm Delivery Rate | | | | | | Mean Stopping time of contractions (Range) p=ns Total side effects (%) p=ns Tocolytic Success Rate p=ns | | | | | | Mean at 1 min (Range) p=ns Mean at 5 min (Range) p=ns | | | | | | Fetal mortality | | | Patients who demonstrated cervical change at tocolysis initiation with non-significant difference in successful tocolysis; side effects described. | No significant difference shown between nifedipine & terbutaline.
  36.8 | 35
  (29-41) | (24-40)
  36% | 50%
  40 | 41
  (30-90) | (30-60)
  9 | 13
  (32) | (54)
  68% | 71%
  7 | 8.4
  (2-9) | (4-9)
  6.7 | 8.3
  (1-9) | (4-9)
  0 | 0

Evidence Table 4: Tocolytic first line: Calcium channel blockers - Outcomes

Author (year) | Delivery | | | | | | | | | Maternal | | | | | | Infant | | | | | | | | | | | | Other Analyses | Conclusions
Author (year) | Estimated Gestational Age | | | Prolongation of Pregnancy Days | | | Gestational Weeks | | | Length of Hospital Stay | | | Maternal Morbidity | | | Birth Weight (g) | | | APGAR Score | | | Length of Hospital Stay | | | Other Infant Outcomes | | | Other Analyses | Conclusions
Author (year) | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Other Analyses | Conclusions
Floyd RC, McLaughlin BN, Perry Jr KG, et al. ^163^ | | | | Mean Prolongation Days (SD) p=NS | | | Delivery at<34 wks Delivery at 34-37 wks Delivery at >37 wks p=0.58 | | | | | | Estimated blood loss (SD) | | | Birth weight <1500 g p=.08 Birth weight 1500-2500 g Birth weight >2500 g | | | APGAR score <7 at 5 min p=0.89 | | | | | | Mean neonatal deaths Fetal mortality NRDS Transient tachypnea | | | | No significant difference shown between magnesium sulfate & nifedipine.
  43.3 | 37.5
  (34.1) | (26.0)
  8 | 10
  10 | 8
  22 | 32
  355 | 351
  (171) | (154)
  2 | 3
  17 | 11
  21 | 36
  6 | 7
  0 | 0
  0 | 1
  4 | 5
  2 | 0

Evidence Table 4: Tocolytic first line: Calcium channel blockers - Outcomes

Author (year) | Delivery | | | | | | | | | Maternal | | | | | | Infant | | | | | | | | | | | | Other Analyses | Conclusions
Author (year) | Estimated Gestational Age | | | Prolongation of Pregnancy Days | | | Gestational Weeks | | | Length of Hospital Stay | | | Maternal Morbidity | | | Birth Weight (g) | | | APGAR Score | | | Length of Hospital Stay | | | Other Infant Outcomes | | | Other Analyses | Conclusions
Author (year) | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Other Analyses | Conclusions
Jannet D, Abankwa A, Guyard B, et al. ^134^ | Mean (SD) p<.05 | | | | | | Delivery <34 wks Delivery at Term p<.05 | | | | | | C-sections | | | Mean (SD) p=ns | | | Mean at 1 min (SD) p=ns Mean at 5 min (SD) p=ns | | | | | | pH <7.25 p=ns Transfer in NICU p=ns | | | Premature infants had comparable outcomes. | Nicardiprine showed efficacy over salbutanol: - EGA at delivery - delivery at term
  38.4 | | 37.6
  (1.7) | | (2.1)
  1 | 2
  90.7% | 72.1%
  5 | 5
  3131 | | 3019
  (488) | | (494)
  8.7 | | 8.4
  (1.3) | | (1.8)
  9.8 | | 9.5
  (0.5) | | (1.5)
  2 | 4
  5 | 7

Evidence Table 4: Tocolytic first line: Calcium channel blockers - Outcomes

Author (year) | Delivery | | | | | | | | | Maternal | | | | | | Infant | | | | | | | | | | | | Other Analyses | Conclusions
Author (year) | Estimated Gestational Age | | | Prolongation of Pregnancy Days | | | Gestational Weeks | | | Length of Hospital Stay | | | Maternal Morbidity | | | Birth Weight (g) | | | APGAR Score | | | Length of Hospital Stay | | | Other Infant Outcomes | | | Other Analyses | Conclusions
Author (year) | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Other Analyses | Conclusions
Papatsonis DNM, Van Geijn HP, Ader HJ, et al. ^159^ | Mean (SD) p=0.046 | | | Mean Prolongation Days (CI) Intact membranes p=0.003 PROM P=0.056 Delivered w/in 24 hrs p=.006 Intact membranes p=0.003 PROM p=0.57 Delivered w/in 48 hrs Intact Membranes p=0.03 PROM p=0.55 Delivered w/in 1 wk Intact Membranes p=0.01 PROM p=0.35 Delivered w/in 2 wks Intact Membranes p=0.008 PROM p=0.27 | | | Delivered <34 wks Intact Membranes p=0.04 PROM p=0.35 Delivered <37 wks Intact Membranes p=0.055 PROM p=1.00 | | | | | | | | | Mean (SD) p=.07 | | | | | | | | | Neonatal Mortality p=NS NRDS p=0.03 NICU admission p=0.04 Umbilical artery pH (SD) p=NS Umbilical vein pH (SD) p=NS | | | Intact membranes & PROM were analyzed separately. Survival analysis curve of delivery delay until end of wk 1. | Nifedipine showed efficacy over ritodrine: - EGA at delivery - delivery at 34 wks - delivery 37 wks - NRDS - NICU admissions
  32.1 | 33.4
  (4.1) | (4.5)
  39.2 | 22.1
  (30.7- 47.6) | (14.9- 29.3)
  7.2 | 15.1
  (3.2- 11.2) | (7.9- 22.3)
  22 | 11
  17 | 7
  5 | 4
  29 | 21
  20 | 13
  9 | 8
  45 | 36
  27 | 19
  18 | 17
  32 | 24
  20 | 19
  35 | 30
  23 | 23
  40 | 39
  24 | 27
  1870 | 2120
  (847) | (920)
  6 | 7
  31 | 23
  64 | 65
  7.23 | 7.26
  (0.13) | (0.08)
  7.30 | 7.32
  (0.10) | (0.07)

Evidence Table 4: Tocolytic first line: Calcium channel blockers - Outcomes

Author (year) | Delivery | | | | | | | | | Maternal | | | | | | Infant | | | | | | | | | | | | Other Analyses | Conclusions
Author (year) | Estimated Gestational Age | | | Prolongation of Pregnancy Days | | | Gestational Weeks | | | Length of Hospital Stay | | | Maternal Morbidity | | | Birth Weight (g) | | | APGAR Score | | | Length of Hospital Stay | | | Other Infant Outcomes | | | Other Analyses | Conclusions
Author (year) | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Other Analyses | Conclusions
Garcia-Velasco JA, Gonzalez AG ^153^ | | | | Mean Prolongation Days (SD) p=NS Prolongation >48 hrs p=NS | | | Delivery at >36 wks p=NS | | | Length of Admission Days (SD) p=NS | | | | | | Mean (SD) p=NS <2500 g | | | APGAR <7 | | | | | | Neonatal Mortality | | | | No significant differences were found between ritodrine & nifedipine.
  43.71 | 64.00
  (4.23) | (7.21)
  88.46% | 93.31%
  84.61% | 89.92%
  3.87 | 3.69
  (0.51) | (0.36)
  2654.28 | 3100.00
  (185.08) | (136.18)
  11.53% | 7.69%
  0 | 0
  0 | 0

Evidence Table 4: Tocolytic first line: Calcium channel blockers - Outcomes

Author (year) | Delivery | | | | | | | | | Maternal | | | | | | Infant | | | | | | | | | | | | Other Analyses | Conclusions
Author (year) | Estimated Gestational Age | | | Prolongation of Pregnancy Days | | | Gestational Weeks | | | Length of Hospital Stay | | | Maternal Morbidity | | | Birth Weight (g) | | | APGAR Score | | | Length of Hospital Stay | | | Other Infant Outcomes | | | Other Analyses | Conclusions
Author (year) | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Other Analyses | Conclusions
Koks CAM, Brölmann HAM, de Kleine MJL, et al. ^135^ | Mean (SD) singleton births p=0.143 multiple births p=0.675 | | | Prolonged Delivery >48 hrs p=NS Prolonged Delivery >7 days p=NS | | | Prolonged Delivery >34wks p=NS | | | | | | | | | Mean birth weight (SD) singleton births p=0.185 multiple births p=0.158 | | | APGAR at 1 min singleton births p=0.002 multiple births p=0.001 APGAR at 5 min singleton births p=0.202 multiple births p=0.077 | | | | | | | | | | No significant differences were shown between nifedipine & ritodrine.
  n=43 | n=35
  33.3 | 31.8
  (4.4) | (4.5)
  n=24 | n=24
  32.1 | 31.6
  (4.1) | (2.9)
  60% | 66%
  47% | 45%
  38% | 23%
  2112 | 1856
  (821) | (855)
  1697 | 1463
  (701) | (373)
  8.5 | 7
  7 | 6
  10 | 9
  9 | 8.5

Evidence Table 4: Tocolytic first line: Calcium channel blockers - Outcomes

Author (year) | Delivery | | | | | | | | | Maternal | | | | | | Infant | | | | | | | | | | | | Other Analyses | Conclusions
Author (year) | Estimated Gestational Age | | | Prolongation of Pregnancy Days | | | Gestational Weeks | | | Length of Hospital Stay | | | Maternal Morbidity | | | Birth Weight (g) | | | APGAR Score | | | Length of Hospital Stay | | | Other Infant Outcomes | | | Other Analyses | Conclusions
Author (year) | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Other Analyses | Conclusions
Read MD,Wellby DE ^140^ | | | | Mean Prolongation Days p<0.001* *Tx2 compared to Tx1 & Cx | | | | | | | | | Adverse Drug Reactions | | | Mean | | | | | | | | | Fetal Mortality | | | | Nifedipine showed efficacy over ritodrine and control: - prolongation days
  25.1 | 36.3 | 19.3
  (5.7) | (5.1) | (6.1)
  13 | 18 | 0
  3020 | 3225 | 2860
  (326) | (432) | (258)
  0 | 0 | 0

Evidence Table 4: Tocolytic first line: Calcium channel blockers - Outcomes

Author (year) | Delivery | | | | | | | | | Maternal | | | | | | Infant | | | | | | | | | | | | Other Analyses | Conclusions
Author (year) | Estimated Gestational Age | | | Prolongation of Pregnancy Days | | | Gestational Weeks | | | Length of Hospital Stay | | | Maternal Morbidity | | | Birth Weight (g) | | | APGAR Score | | | Length of Hospital Stay | | | Other Infant Outcomes | | | Other Analyses | Conclusions
Author (year) | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Other Analyses | Conclusions
van Dijk KG, Dekker GA, van Geijn HP ^155^ | Median (Range) | | | Median (Range) | | | Delivery <34 wks (%) | | | Median (Range) | | | Adverse Drug Reactions (%) p=NS | | | Mean (SD) p=0.001 | | | | | | | | | Neonatal Deaths NICU Admissions Neonatal Patent Ductus Mean Umbilical artery pH (SD) p=.36 Mean Umbilical vein pH (SD) p=.89 | | | | Insufficient statistical analysis to compare the relative effectiveness of treatments.
  30 | 32
  (24-34) | (22-42)
  3 | 10
  (1-53) | (1-135)
  32 | 21
  (100) | (73)
  23 | 59
  (1-45) | (12-130)
  13 | 7
  (74) | (24)
  1430 | 1892
  (569) | (822)
  22% | 14%
  97% | 81%
  50% | 19%
  7.24 | 7.29
  (.12) | (.08)
  7.33 | 7.35
  (.10) | (.06)

Evidence Table 4: Tocolytic first line: Calcium channel blockers - Outcomes

Author (year) | Delivery | | | | | | | | | Maternal | | | | | | Infant | | | | | | | | | | | | Other Analyses | Conclusions
Author (year) | Estimated Gestational Age | | | Prolongation of Pregnancy Days | | | Gestational Weeks | | | Length of Hospital Stay | | | Maternal Morbidity | | | Birth Weight (g) | | | APGAR Score | | | Length of Hospital Stay | | | Other Infant Outcomes | | | Other Analyses | Conclusions
Author (year) | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Other Analyses | Conclusions
Murray C, Haverkamp AD, Orleans M, et al. (1992) | Mean (SD) | | | Prolongation wks | | | Delivery at >37 wks | | | | | | C-section rate | | | Mean (SD) | | | <7 at 5 min | | | | | | Neonatal deaths Assisted ventilation NICU Venous cord pH <7.20 IUGR 5% | | | Side effect results grouped by terbutaline & nifedipine. | No statistical analysis provided since no comparison group.
  36.8 (2.7)
  4.9
  56.9%
  26.5%
  2582 (512)
  4.2%
  1
  10.8%
  45%
  1

Evidence Table 5: Tocolytic first line: Magnesium sulfate - Study design

Author (year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion/Exclusion Characteristics | Sample Size Initial/End | | | Demographic Characteristics | | | Tocolytic Intervention | Uniform Adjunctive Drug Intervention | Uniform Non-Drug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Author (year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion/Exclusion Characteristics | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tocolytic Intervention | Uniform Adjunctive Drug Intervention | Uniform Non-Drug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Cotton DB, Strassner HT, Hill LM, et al. ^120^ | To access the efficacy of Magnesium sulfate for the inhibition of PTL compared with terbutaline and a placebo | RCT; Masking: none | PTL: Following hydration (Contractions 3/10 min) and (Dilation progressive over time or Dilation>2 cmor Effacement >80% or Spontaneous PROM) Successful Tocolysis: postponement of delivery for >48 hrs after initiation of treatment | EGA: 26-34 wks Fetal weight: 750-200 gms Also no: Dilation >4 cm, positive Gram stain on amniocentesis, evidence of pulmonary maturity | 54/54 | | | Mean Age (SD) | | | Tx1 Magnesium sulfate IV 4g CoT: initial DoT: 15 min Magnesium sulfate IV 2g/hr CoT: after initial 15 min infusion DoT: If intact membranes: until no uterine activity for >12 hrs. If uterine activity reoccurs, agent is readministered. If PROM: At least 48 hrs after rupture.* Tx2 Terbutaline IV 9.2 µ/min, increasing by approximately 5µ/min to levels as high as 25.3 µ/min dependent on uterine response CoT: initial DoT: If intact membranes: until no uterine activity for >12 hrs. If uterine activity reoccurs, agent is readministered. If PROM: At least 48 hrs after rupture.* Cx Dextrose IV 5% in lactated Ringer's solution, 125 ml/hr CoT: dk DoT: If intact membranes: until no uterine activity for >12 hrs. If uterine activity reoccurs, agent is readministered. If PROM: At least 48 hrs after rupture.* Tx1 & Tx2 * Additional criteria for discontinuing infusions include: progressive cervical dilation >7 cm, evidence of overt amnionitis, fetal distress, maternal heartbeat >150 beats/min, persistent maternal arrhythmia, fetal heart rate > 200 beats/min, and maternal respiratory rate < 10 breaths/min | Steroids AoT: pulmonary maturation | Bedrest, Fetal Monitoring | Inpatient | Country: dk Time period: dk | M=62% C=88%
  21.8 | 24.3 | 22.6
  (4.6) | (5.9) | (6.4)

Evidence Table 5: Tocolytic first line: Magnesium sulfate - Study design

Author (year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion/Exclusion Characteristics | Sample Size Initial/End | | | Demographic Characteristics | | | Tocolytic Intervention | Uniform Adjunctive Drug Intervention | Uniform Non-Drug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Author (year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion/Exclusion Characteristics | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tocolytic Intervention | Uniform Adjunctive Drug Intervention | Uniform Non-Drug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Tchilinguirian NG, Najem R, Sullivan GB, et al. ^150^ | To obtain information with regard to the therapeutic and adverse effects of ritodrine relative to Magnesium sulfate. | RCT; Masking: dk | PTL: Premature Labor Unit (PLU): consisting of: Contractions: 6/hr lasting 30 sec & amplitude of 20 mmHg above resting uterine tone Successful Tocolysis: Arrest labor >48 hrs, or for long term success, arrest labor >7 days | EGA: 24-36 wks Also no: PROM >24 hrs before onset of PTL, gravidas suffering from hypertensive disorders or cardiac disease, antepartum hemorrage, metabolic kidney disease, potentially life-threatening afflictions such as blood dyscrasias and autoimmune diseases, clinically significant Rh or other blood group immunization, obstetric complications that require delivery such as abruption of placentae and prolapse of cord or fetal part. | 67/67 | | | Age= 20 Age 20-30 Age >30 Race, white Race, non-white | | | Tx1 Ritodrine hydrochloride IV, "according to manufacturers' protocol" CoT: initial DoT: after 12 hrs after the cessation of detectable contractions or until side effects or contraindications to medications occurred Ritodrine oral "according to manufacturers' protocol" CoT: after IV tx DoT: when tx regime was successful, patients were discharged on the 5^th^ day of oral medication Tx2 Magnesium sulfate IV 4 g CoT: initial DoT: 30 min Magnesium sulfate IV 2 g/h CoT: after loading dose DoT: until contractions were reduced to <1 PLU Magnesium sulfate IV 1 g/h CoT: after contractions were reduced to <1 PLU DoT: 12 hrs after the cessation of detectable contractions or until side effects or contraindications to medications occurred Ritodrine oral, "according to manufacturers' protocol" CoT: after IV treatment DoT: tx regime was successful, patients were discharged on the 5^th^ day of oral medication | | Fetal monitoring, Routine observation | Inpatient, Outpatient: dk | Country: United States Time period: 1981-1983 | M=65% C=40%
  31 | 36
  5 | 5
  20 | 23
  6 | 8
  24 | 29
  7 | 7

Evidence Table 5: Tocolytic first line: Magnesium sulfate - Study design

Author (year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion/Exclusion Characteristics | Sample Size Initial/End | | | Demographic Characteristics | | | Tocolytic Intervention | Uniform Adjunctive Drug Intervention | Uniform Non-Drug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Author (year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion/Exclusion Characteristics | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tocolytic Intervention | Uniform Adjunctive Drug Intervention | Uniform Non-Drug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Hatjis CG, Swain M, Nelson LH, et al. ^138^ | To determine whether ritodrine alone or ritodrine with Magnesium sulfate differ with respect to their efficacy in controlling PTL or in the incidence of maternal and fetal toxicity | RCT; Masking: dk | PTL: not defined, references previous publication Successful Tocolysis: Pregnancy prolongation of at least 1 wk from initiation of treatment | EGA: 20-35 wks Also no: abnormal fetus, contraindications to use of IV ritodrine | 74/64 Group IA: ritodrine alone - success, N= 11; Group IB: ritodrine alone - failure, N=5, Group IC: ritordrine alone, followed by magnesium - success, N=12; Group ID: ritodrine alone followed by magnesium - failure, N=4. Group 2A: ritodrine and magnesium together - success; N=19; Group 2B: ritodrine and magnesium together - failure, N=13 | | | Mean Age (SD) Race, White Race, Other | | | Tx1 Ritodrine IV 50 µg/min, increased by 50 µg/min every 10 min CoT: initial DoT: 8-10 hrs contractions stopped, max 350 g/min or unacceptable side effects occurred Ritodrine IV dosage: dk, gradually decreased CoT: after cessation of contractions DoT: dk Ritodrine or Terbutaline oral, dosage: dk CoT: after IV ritodrine dosage was decreased DoT: until 37 wks gestation or until recurrence of labor Magnesium sulfate CoT: unresponsive to IV ritodrine & contractions every 5-7 minutes for at least 1/2 hr &/or increase in pelvic score Tx2 Magnesium sulfate IV 4g for 20-30 min, then 2-3 g/h CoT: initial DoT: until reached serum magnesium level of 5-7 mg% Ritodrine IV 50 g/min, and increased according to protocols outlined in Lipshitz (1981) CoT: after loading dose of Magnesium sulfate was completed DoT: until contractions stopped, and then tapered off over next 10-12 hrs Ritodrine or Terbutaline oral, dosage: dk CoT: after IV ritodrine dosage was tapered off DoT: until 37 wks gestation or until recurrence of labor | | Fetal monitoring, IV fluids, Uterine monitoring, Vitals signs taken: heart rate, blood pressure respiratory rate, Deep tendon reflexes, Evidence of fluid overload, ECG | Inpatient | Country: United States Time period: 1982-1984 | M=56% C=31%
  32 | 32
  22.31 | 22.63
  (5.20) | (5.10)
  23 | 19
  9 | 13

Evidence Table 5: Tocolytic first line: Magnesium sulfate - Study design

Author (year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion/Exclusion Characteristics | Sample Size Initial/End | | | Demographic Characteristics | | | Tocolytic Intervention | Uniform Adjunctive Drug Intervention | Uniform Non-Drug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Author (year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion/Exclusion Characteristics | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tocolytic Intervention | Uniform Adjunctive Drug Intervention | Uniform Non-Drug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Wilkins IA, Lynch L, Mehalek KE, et al. ^122^ | To examine the efficacy and side effects of ritodrine compared to Magnesium sulfate | RCT; Masking: Subject, physician, pharm., other care providers: dk | PTL: Contractions: every 5 minutes and (Dilation:>2 cm or Effacement:>50% or Other: progressive cervical change while contracting during a period of observation) Successful tocolysis: prolongation of pregnancy for >48 hrs | EGA: 25-36 wks Intact Membranes Also no: sig. bleeding, fetal distress, preeclampsia, fetal anomaly, suspected growth retardation, dilation >4 cm | 120/120 | | | Mean Age (SD) P=NS | | | Tx1 Ritodrine IV 0.1 mg/min (increased by .05 mg/min every 15-20 min to a maximum of .35 mg/min CoT: initial DoT: 12 hrs after contractions stopped or maternal pulse 140 beats/min Tx2 Magnesium sulfate IV 4 mg/ over 15 min (followed by 2 gm/hr w/rate increased if contractions continued and serum level below 5 to 8 mg/dl, decreased if serum level above 5 to 8 mg/dl) CoT: initial DoT: 24 hrs after contractions stopped Tx1 & Tx2 Ritodrine oral 20 mg/2 hrs tapered to every 4 hrs before discharge CoT: after IV tx DoT: until 37 wks gestation Tx1 & Tx2 Original drug IV followed by second-line therapy CoT: episode of PTL followed by oral tocolytic | | Bedrest, routine observation, uterine monitoring, weekly visits to a high risk clinic with weekly exams | Inpatient, Oral Outpatient: dk | Country: United States Time period: 1985-1987 | M=76% C=58%
  54 | 66
  23.3 | 23.7
  (4.4) | (4.9)

Evidence Table 5: Tocolytic first line: Magnesium sulfate - Study design

Author (year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion/Exclusion Characteristics | Sample Size Initial/End | | | Demographic Characteristics | | | Tocolytic Intervention | Uniform Adjunctive Drug Intervention | Uniform Non-Drug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Author (year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion/Exclusion Characteristics | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tocolytic Intervention | Uniform Adjunctive Drug Intervention | Uniform Non-Drug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Cox SM, Sherman ML, Leveno KJ ^124^ | To determine if clinically safe magnesium concentrations (i.e., those <8 m Eq/L, at which level skeletal muscle paralysis occurs) were effective in preventing preterm birth when compared w/ untreated controls. | RCT: Masking: dk | PTL: Contractions: regularand Dilation: <5 cm and >1 cm Unsuccessful tocolysis: ruptured membranes, dilation progression to >4 cm, contractions for >30 min or maternal side effects necessitating discontinuation | EGA: 24-34 wks Intact membranes Also no: maternal or fetal complications necessitating delivery | 156/156 | | | Mean Age (SEM) Black 57% 43% White Hispanic | | | Tx1 Magnesium sulfate IV 4g CoT: initial DoT: one dose Magnesium sulfate IV 2g/hr, increased to 3g/hr if contractions persisted after first hr CoT: after initial DoT: 24 hrs Cx Placebo IV saline CoT: initial DoT: 24 hrs | | Fetal heart rate monitoring, routine observation | | United States Time Period: 1987-1989 | M=N/A C=N/A
  76 | | 80
  20.6 | | 21.3
  (0.5) | | (0.5)
  24% | | 30%
  18% | | 23%

Evidence Table 5: Tocolytic first line: Magnesium sulfate - Study design

Author (year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion/Exclusion Characteristics | Sample Size Initial/End | | | Demographic Characteristics | | | Tocolytic Intervention | Uniform Adjunctive Drug Intervention | Uniform Non-Drug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Author (year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion/Exclusion Characteristics | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tocolytic Intervention | Uniform Adjunctive Drug Intervention | Uniform Non-Drug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Noblot G, Audra P, Dargent D, et al. ^160^ | To evaluate the efficacy of progesterone prolonged therapy in conjunction with IV infusion of ritodrine | RCT; Masking: Subject, physician: yes Pharm.: none Other care providers: dk | PTL: Contractions: 1/10 min, persisting after 1 hr restor Cervical change Successful Tocolysis: not defined | EGA: 0-35 wks Intact membranes if before wk 32 Also no: cardiac pathology, fever, abnormal fetal cardiac rhythm, previous treatment w/β -mimetics | 44/44 | | | Mean Age | | | Tx1 & Cx Ritodrine IV 0.2 mg/min CoT: upon admission DoT: 1 hr Ritodrine IV varied dose (adapted to each individual evolution whilst trying to administer lowest possible dose capable of maintaining tocolysis and to interrupt IV administration for oral administration as soon as possible) CoT: after initial hr DoT: up to 24 hrs after initiation of tocolysis | Tx1 Micronized Progestrone oral 400 mg/6 hr CoT: w/ initial ritodrine DoT: 24 hrs Micronized Progestrone oral 400 mg/8 hr CoT: after initial 24 hrs DoT: 24 hrs Micronized Progestrone oral 300 mg/6 hr CoT: after 48 hrs DoT: dk Cx Placebo (follows pattern for Progesterone) | Uterine monitoring | Inpatient | Country: France Time period: 1987 | M=76% C=71%
  22 | | 22
  22.6 | | 28.6

Evidence Table 5: Tocolytic first line: Magnesium sulfate - Study design

Author (year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion/Exclusion Characteristics | Sample Size Initial/End | | | Demographic Characteristics | | | Tocolytic Intervention | Uniform Adjunctive Drug Intervention | Uniform Non-Drug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Author (year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion/Exclusion Characteristics | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tocolytic Intervention | Uniform Adjunctive Drug Intervention | Uniform Non-Drug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Morales WJ, Madhav H ^167^ | To compare the efficacy of indomethacin and Magnesium sulfate in pregnancies <32 wks gestation. | RCT; Masking: Subject, physician, other direct care givers: no | Contractions: 4 in 20 minand Dilation (>2 cm) or Effacement Successful tocolysis: not defined | EGA:<32 wks Intact membranes Also no: Abnormal fetus, dilation >4 cm, congenital anomalies, growth retardation | 114/101 | | | Mean Age (SD) | | | Tx1 Indomethacin rectal suppository 100 mg CoT: initial DoT: one dose Indomethacin oral 25 mg/4 hr CoT: after initial DoT: 48 hrs Tx2 Magnesium sulfate IV 6g CoT: initial CoT: 30 min Magnesium sulfate IV 2g/hr increasing by 1g/h CoT: after initial DoT: Max of 5g/hr | | Routine Observation | None | United States Time Period: 1988-1989 | M=83% C=36%
  49 | 52
  24.6 | 22.9
  (4.3) | (4.1)

Evidence Table 5: Tocolytic first line: Magnesium sulfate - Study design

Author (year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion/Exclusion Characteristics | Sample Size Initial/End | | | Demographic Characteristics | | | Tocolytic Intervention | Uniform Adjunctive Drug Intervention | Uniform Non-Drug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Author (year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion/Exclusion Characteristics | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tocolytic Intervention | Uniform Adjunctive Drug Intervention | Uniform Non-Drug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Fox MD, Allbert JR, McCaul JF, et al. ^166^ | To assess the benefits and risks of tocolysis versus allowing spontaneous delivery in pregnancies between 34 and 37 wks gestation complicated by PTL | RCT; Masking: Subject: dk Physician: none Pharm., other care providers: dk | PTL: Contractions and Cervical change (dilation, effacement, softening, position) unresolved after hydration and sedation during continued observation Successful Tocolysis: not defined | EGA: 34-37 wks Maternal age: 15-45 Intact Membranes Also no: cervical dilation >3 cm, abnormal fetus, unknown gestational dates, medical or obstetric contraindications necessitating delivery (pregnancy-induced hypertension, cardiac disease, fetal distress, hemorrhage), maternal allergy to Magnesium sulfate | 90/90 | | | Mean Age (SD) | | | Tx1 Magnesium sulfate IV 4 mg bolus CoT: dk DoT: single bolus Magnesium sulfate IV 2-4 g/hr CoT: after initial bolus as maintenance therapy DoT: until uterine quiescence Magnesium gluconate oral, dose: dk CoT: after successful tocolysis DoT: until documented uterine quiescence Magnesium oral, dose: dk CoT: after discharge DoT: until 37 wks Cx Conservative management: no medication or placebo | | Bedrest, Routine observation, IV fluids, Sedation | | Country: dk Time period: dk | M=80% C=81%
  45 | 45
  23.0 | | 21.9
  (4.4) | | (536)

Evidence Table 5: Tocolytic first line: Magnesium sulfate - Study design

Author (year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion/Exclusion Characteristics | Sample Size Initial/End | | | Demographic Characteristics | | | Tocolytic Intervention | Uniform Adjunctive Drug Intervention | Uniform Non-Drug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Author (year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion/Exclusion Characteristics | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tocolytic Intervention | Uniform Adjunctive Drug Intervention | Uniform Non-Drug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Glock JL, Morales WJ ^162^ | To establish efficacy and safety of nifedipine versus Magnesium sulfate in arresting PTL & preventing recurrent labor. | RCT; Masking: Subject, physician: none Pharm., other care providers: dk | PTL: Contractions: regular, <10 min apartand(Cervical changeor dilation:>2 cm) Successful Tocolysis:Delay of delivery at least 2 days | EGA: 20-34 wks Intact membranes Also no: multiple gestation, dilation >4cm, known tocolytic exposure during study pregnancy, diabetes, hyperthyriodism, cardiac disease, preeclampsia, abruption placentae, chorioamnionitis, hydramnios, renal failure, fetal distress, severe intrauterine growth retardation, and fetal anomalies incompatible with life. | 100/80 | | | Mean Age (SD) p=NS Race, Black p=NS | | | Tx1 Nifedipine sublingual 10 mg CoT: initial DoT: one dose Nifedipine sublingual 10 mg/20 min CoT: if contractions persist after intial dose DoT: up to 40 mg for first hour Nifedipine oral 20 mg/4 hr CoT: if sublingual treatment stopped uterine activity DoT: 48 hrs Nifedipine oral 10 mg/8 hr CoT: after last 48 hr dose DoT: until 34 wks completed Tx2 Magnesium sulfate IV 6 gm CoT: initial DoT: 30 min Magnesium sulfate IV 2 gm/hr, to max. 4 g/hr CoT: after 1^st^ 30 min treatment DoT: 24 hr Magnesium sulfate route unknown, 0.5 g/4-6 hr CoT: after uterine contractions arrested for 24 hrs DoT: dk Terbutaline oral 5 mg/6 hr CoT: when last Magnesium sulfate rate reached 0.5 gm/hr DoT: until 34 wks completed Tx1 & Tx2 Ritodrine hydrochloride IV 50 g/min, increasing by 50 g/min every 20 min AoT: for those who demonstrated persistent contractions and progressive cervical dilation or serious side effects. If successful, maintained for 12 hrs. Patients returned to oral regimen after ritodrine. Recurrent PTL >34 wks: IV magnesium followed by oral terbutaline to 36 wks | Ampicillin AoT: given to all patients, and after testing for Neisseria gonorrhoeae, group B streptococci, Chlamydia trachomatis, continued only with patients with positive tests. Betamethasone AoT: for fetal lung maturation in gestations >24 wks | Bedrest, Fetal monitoring, IV fluids, Uterine monitoring, Blood pressure monitoring | Inpatient | Country: United States Time period: 1991-1992 | M=65% C=80%
  39 | 41
  21.4 | 20.5
  (4.7) | (4.8)
  20 | 22
  (51%) | (54%)

Evidence Table 5: Tocolytic first line: Magnesium sulfate - Study design

Author (year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion/Exclusion Characteristics | Sample Size Initial/End | | | Demographic Characteristics | | | Tocolytic Intervention | Uniform Adjunctive Drug Intervention | Uniform Non-Drug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Author (year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion/Exclusion Characteristics | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tocolytic Intervention | Uniform Adjunctive Drug Intervention | Uniform Non-Drug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Smith CS, Woodland MB ^154^ | To compare oral nifedipine with subcutaneous terbutaline for reducing premature uterine irritability & contractions Uterine irritability is defined as uterine contractions w/out cervical change | RCT; Masking: dk | PTL: Contractions and Cervical change Successful tocolysis: contractions completely stopping within the 2 hr study interval | EGA: 20-35 wks Also no: chorioamnionitis, fetal distress, hypertensive disorders, seizure disorder, tachycardia, acute asthma | 52/dk | | | Mean Age Race, White Race, Black Race, Hispanic | | | Tx1 Nifedipine oral 30 mg CoT: initial DoT: one dose Tx2 Terbutaline subcutaneous 0.25 mg CoT: initial DOT: every 20 minutes for 2 hrs Terbutaline IV dose: dk CoT: if contractions did not abate after oral terbutaline DoT: dk | | Further therapy (e.g. medication type, hospitalization) at discretion of the attending physician | | Country: United States Time period: 1989 | M=70% C=33%
  28 | 24
  24 | 26
  5 | 5
  21 | 18
  2 | 1

Evidence Table 5: Tocolytic first line: Magnesium sulfate - Study design

Author (year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion/Exclusion Characteristics | Sample Size Initial/End | | | Demographic Characteristics | | | Tocolytic Intervention | Uniform Adjunctive Drug Intervention | Uniform Non-Drug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Author (year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion/Exclusion Characteristics | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tocolytic Intervention | Uniform Adjunctive Drug Intervention | Uniform Non-Drug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Floyd RC, McLaughlin BN, Perry Jr KG, et al. ^163^ | To compare IV and subsequent oral magnesium with the oral administration of nifedipine as initial and long-term tocolytic agents in women w/ PTL. | RCT; Masking: dk | PTL: Contractions: regular, persistent, demonstrable, >1/10 min. and (Cervical change in dilation, effacement, position, station, and/or consistency from a previous examination or Cervix 2 cm dilated) Successful Tocolysis: not defined | EGA: 20-34 wks Intact membranes Maternal age: >15 yrs Also no: tocolytic medications during the current pregnancy, no allergies to either study drug, serious medical or obstetric complications that precluded tx w/either drug or continuation of pregnancy, multiple gestation, chorioamnionitis. | 90/85 | | | Mean Age (SD) Race, White Race, Black Race, American Indian | | | Tx1 Magnesium sulfate IV 4g CoT: initial DoT: 20 min Magnesium sulfate IV 4-6 g/hr CoT: after initial dose DoT: until uterine quiescence achieved Magnesium gluconate oral 2 g/4 hr CoT: after uterine quiescence maintained for 6 hrs DoT: until 37 wks Tx2 Nifedipine oral 30 mg CoT: inital DoT: one dose Nifedipine oral 20 mg/ 8 hrs CoT: after initial dose DoT: until uterine quiescence achieved Nifedipine oral 20 mg/ 8 hrs CoT: after uterine quiescence maintained for 6 hrs DoT: until 37 wks | | Blood pressure monitored, Ultrasounds | | Country: United States Time period: (18 month period) | M=75% C=65%
  40 | 50
  25.6 | 23.9
  (4.2) | (5.1)
  17 | 16
  22 | 33
  1 | 1

Evidence Table 5: Tocolytic first line: Magnesium sulfate - Study design

Author (year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion/Exclusion Characteristics | Sample Size Initial/End | | | Demographic Characteristics | | | Tocolytic Intervention | Uniform Adjunctive Drug Intervention | Uniform Non-Drug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Author (year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion/Exclusion Characteristics | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tocolytic Intervention | Uniform Adjunctive Drug Intervention | Uniform Non-Drug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Chau AC, Gabert HA, Miller JM ^128^ | To compare the tocolytic efficacy and side effects of IV and oral magnesium and terbutaline | Non-randomized control trial; Masking: Subject, physician, pharm.: none Other care providers: dk | PTL: (Contractions: >3/10 min and Cervical change despite rest, IV hydration, and sedation for 1 hr) or (Contractions and Cervical effacement of at least 80% or dilation of >2 cm) Successful Tocolysis: delay delivery for 48 hrs 1 wk, or 37 wks or more gestation | EGA: 23-35 wks Fetal weight: 500-2500 g Intact membranes Also not: multiple gestation, fetal weight <500 g or >2500 g, cardiovascular disease, hepatorenal diseases, chronic hypertension, diabetes mellitus, hyperthyriodism, any history of tocolytic hypersensitivity reaction, obstetric hemorrhage, cervical dilation >4 cm, any other maternal or fetal condition making delivery advisable | 98/98 | | | Mean Age (SD) p=NS Race, White (%) p=NS Race, Black (%) p=NS Race, Asian (%) p=NS | | | Tx1 Magnesium sulfate IV 4g CoT: initial DoT: 30 min Magnesium sulfate IV 2g/hr CoT: after initial infusion DoT: at least 24 hrs or until contractions cease for at least 12 hrs Magnesium gluconate oral 2-3 g/4-6 hrs CoT: 30 min before discontinuation of maintenance dose DoT: until failure of tocolysis, delivery, or until 37 wks gestation Tx2 Terbutaline subcutaneous 0.25 mg/30 min CoT: initial DoT: 3 doses/1.5 hr Terbutaline subcutaneous 0.25 mg/4 hr CoT: after initial 3 doses DoT: at least 24 hrs or until contractions cease for at least 12 hrs Terbutaline oral 5 mg/4-6 hrs CoT: 30 min before discontinuation of maintenance dose DoT: until failure of tocolysis, delivery, or until 37 wks gestation Tx1 & Tx2 (if dilation <4 cm and intact membrane) switched to other agent or secondary tx if PTL continued despite max tolerable dose of initial tocolytic | | Bedrest, Fetal monitoring, Vital signs monitoring | Inpatient Outpatient: dk | Country: United States Time period: 1989-1991 | M=69% C=73%
  46 | 52
  22.5 | 22.6
  (5.3) | (5.8)
  5 | 15
  (11%) | (29%)
  40 | 3
  (87%) | (71%)
  1 | 0
  (2%) | (0%)

Evidence Table 5: Tocolytic first line: Magnesium sulfate - Study design

Author (year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion/Exclusion Characteristics | Sample Size Initial/End | | | Demographic Characteristics | | | Tocolytic Intervention | Uniform Adjunctive Drug Intervention | Uniform Non-Drug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Author (year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion/Exclusion Characteristics | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tocolytic Intervention | Uniform Adjunctive Drug Intervention | Uniform Non-Drug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Kosasa R, Busse R, Wahl N, et al. ^141^ | To determine whether long-term intravenous tocolysis using combined terbutaline and Magnesium sulfate is a safe and effective treatment of PTL. Women w/intact membranes (Tx1) are distinguished from those w/PROM (Tx2) | Prospective Cohort Study; Masking: none | PTL: Contractions: painful every 5 min and (Dilation and/or Effacement following admission) Successful tocolysis is not defined. | EGA: 20-32 wks Also no: documented chorioamnionitis, dilation >7cm, maternal fever of unknown origin | 1000/1000 | | | Age (Tx1 & TX2) (SD) 25.4 (4.6) | | | Tx1 Intact Membranes Terbutaline subcutaneous 0.25 mg CoT: w/diagnosis of PTL DoT: one dose Terbutaline IV 1.7 µg/min (increased by 2 µg/min every 10-20 min until 80 µg/min) CoT: after load dose DoT: until delivery, labor stopped, or side effects Magnesium sulfate IV 2 g/hr (increased by 0.5 g/hr to 4 g/hr) CoT: w/diagnosis of PTL DoT: until stabilized Magnesium sulfate: IV dose adjusted to maintain serum level of 6.5 -7.5 mg/dL CoT: after stabilization DoT: until delivery Tx2 Ruptured Membranes same treatment as Tx1 | Antibiotics AoT: prophylactic for positive cervical culture Betamethasone to Tx1 w/EGA (34 wks) AoT: fetal lung maturity Vitamin K AoT: to prevent IVH | Bedrest, fetal monitoring, routine observation, IV fluids, occupational or physical therapy if hospitalized > 1 wk | Inpatient | Country: United States Time period: dk | M=29% C=50%
  751 | 249

Evidence Table 5: Tocolytic first line: Magnesium sulfate - Study design

Author (year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion/Exclusion Characteristics | Sample Size Initial/End | | | Demographic Characteristics | | | Tocolytic Intervention | Uniform Adjunctive Drug Intervention | Uniform Non-Drug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Author (year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion/Exclusion Characteristics | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tocolytic Intervention | Uniform Adjunctive Drug Intervention | Uniform Non-Drug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Sciscione AC, Stamilio DM, Manley JS, et al. ^143^ | To determine whether hospital admission and tocolysis of patients with ptl resulted in a decrease in the preterm delivery rate. | Prospective Cohort Study; Masking: none | PTL Contractions:>8/hr persisting after i.v. fluid and Dilation: <2 cm and Effacement: <80% and unchanged after 2 hrs | EGA: 20-37 wks Intact membranes Also no: cerclage, current bleeding, multiple gestations, placenta previa, placental abruption, cervical incompetence, prior tocolytic tx during current pregnancy | 133/133 | | | Mean Age (SD) | | | Tx1 Terbutaline subcutaneous 250 µg every 20min CoT: initial DoT: <4 contractions/hr or adverse reaction Terbutaline subcutaneous 250 µg every 3hrs CoT: After adequate tocolysis achieved DoT: at least 12 hrs or Magnesium sulfate IV 4g loading dose followed by 2-3g/hr & increased every 30min CoT: initial DoT: until <4 contractions/hr or adverse reactions, or max rate of 5 g/hr, total tx time at least 12 hrs Terbutaline oral 5 mg every 4 hrs CoT: following successful tocolysis w/either terbutaline or mag sulfate DoT: 37 wks gestation Cx No treatment | | Bedrest, abstinence from sexual intercourse, fetal & uterine monitoring, routine observation | weekly follow-up | Country: United States Time Period: 1991-1993 | M=N/A C=N/A
  75 | | 81
  27.3 | | 26.5
  (4.5) | | (19.8)

Evidence Table 5: Tocolytic first line: Magnesium sulfate - Study design

Author (year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion/Exclusion Characteristics | Sample Size Initial/End | | | Demographic Characteristics | | | Tocolytic Intervention | Uniform Adjunctive Drug Intervention | Uniform Non-Drug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Author (year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion/Exclusion Characteristics | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tocolytic Intervention | Uniform Adjunctive Drug Intervention | Uniform Non-Drug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Elliott JP ^164^ | To analyze the use of Magnesium sulfate as a tocolytic agent in a large referral population | Retrospec-tive cohort study; Masking: dk | PTL: Contractions: painful, palpable, >2/10 min for > 1 hr or (Cervical dilation and/or Cervical effacement (in the presence of uterine contractions at any frequency)) Successful Tocolysis: for all-prevention of delivery for at least 48 hrs or for intact membrane only-prevention of delivery until term, 37 wks or more (for patients with minimally dilated cervices) Failure of tocolysis: delivery for any cause < 48 hrs after initiation of therapy | EGA: 25-35 wks Also not: if need cerclage | 355/355 4 groups: Tx1 singleton gestations with intact membranes n=274 Tx2 singleton gestations w/PROM n=38 Tx3 multiple gestations w/intact mem-branes n=35 Tx4 multiple gestations w/PROM n=8 | | | | | | All groups Magnesium sulfate bolus 4g CoT: after diagnosis of premature labor was confirmed DoT: dk Magnesium sulfate IV 2g/hr (increased or decreased according to patients' response) CoT: after initial bolus DoT: 48 hrs if PROM or successful tocolysis for others Terbutaline or Ritodribe oral CoT: if Magnesium sulfate treatments were successful DoT: dk (If labor recurred, a decision to retreat with Magnesium sulfate was based on the patient's clinical condition and the gestational age of the fetus) | Corticosteroid therapy | Patient placed in left lateral decubitus position | Treatment in perinatal center | United States Time period: 1978-1982 | M=56% C=43%

Evidence Table 5: Tocolytic first line: Magnesium sulfate - Study design

Author (year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion/Exclusion Characteristics | Sample Size Initial/End | | | Demographic Characteristics | | | Tocolytic Intervention | Uniform Adjunctive Drug Intervention | Uniform Non-Drug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Author (year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion/Exclusion Characteristics | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tocolytic Intervention | Uniform Adjunctive Drug Intervention | Uniform Non-Drug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Dudley D, Gagnon D, Varner M (1989) | A retrospective review of experience w/Magnesium sulfate tocolysis Tx groups are distinguished by length of Magnesium sulfate treatment Tx1: <3 days Tx2: 3-10 days Tx3: >10 days | Retro-spective Cohort Study; Masking: Subjects: dk Other care providers: none | PTL: Contractions: 1> every 10 min, w/ or w/out (Effacement: change and/or Dilation: change from baseline) Unsuccessful tocolysis defined as persistence of regular contractions (at least 1 every 10 min) after maximum dosage of a beta-mimetic for at least 1hr | EGA: 20-34 wks, Also no: renal disease, neonatal data, suspected or proved preclampsia | 111/111 | | | Race White n=106 Black n=3 Asian n=2 | | | Tx1, Tx2, & Tx3 Beta-mimeta (usually Ritodrine or Terbutaline) IV, dose: dk CoT: initial DoT: 2-24 hrs Magnesium sulfate IV 4 g CoT: when beta-mimetic unsuccessful or contraindication for use, loading dose DoT: 5-15 min Tx1 Magnesium sulfate IV 1-4 g/hr CoT: after loading dose DoT: <3 days Tx2 Magnesium sulfate IV 1-4 g/hr CoT: after loading dose DoT: 3-10 days Tx3 Magnesium sulfate IV 1-4 g/hr CoT: after loading dose DoT: >10 days Tx1, Tx2, & Tx3 Ritodrine or Terbutaline oral, dose: dk CoT: w/Magnesium sulfate DoT: until delivery or 36 wks gestation | | Fetal monitoring, Routine Observation, Uterine Monitoring | Inpatient | Country: United States Time period: 1983-1986 | M=58% C=25%
  60 | 29 | 22

Evidence Table 5: Tocolytic first line: Magnesium sulfate - Study design

Author (year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion/Exclusion Characteristics | Sample Size Initial/End | | | Demographic Characteristics | | | Tocolytic Intervention | Uniform Adjunctive Drug Intervention | Uniform Non-Drug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Author (year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion/Exclusion Characteristics | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tocolytic Intervention | Uniform Adjunctive Drug Intervention | Uniform Non-Drug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Coleman FH ^152^ | To determine the complication rate from using 2 tocolytics in combination and whether tocolysis can be continued despite complications. | Retro-spective Cohort; Masking: none | PTL: Contractions: >1 every 10 min w/or w/out cervical change Successful Tocolysis: Delivery after 36wks gestation | EGA: 24-34 wks Intact membranes Also no: chorioamnionitis, current bleeding, dilation >4 cm, hypertensive disorder, contraindications to tocolysis | 61/61 | | | Mean Age (SD) | | | Tx1 Terbutaline subcutaneous .25 mg CoT: at enrollment DoT: every 20 min for up to 3 doses Ritodrine IV 100 µ/min increasing to max of 350 Y/min CoT: after terbutaline DoT: dk Magnesium sulfate IV 2 g/hr & increasing try 0.5 gm/hr CoT: after ritodrine & w/ continued contractions or side effects from Ritodrine DoT: every 20 min until areflexia, magnesium levels of 8-10 mg/dl or cessation of contractions Ritodrine or Terbutaline oral Ritodrine 10 mg Terbutaline 2.5 mg CoT: after IV tocolysis DoT: every 2-4 hrs until 36 wks gestation Tx2same treatment as for Tx1-dual tocolytics CoT: same as Tx1 DoT: until complications cause discontinuation | | Bedrest, IV fluids, Fetal monitoring, Reassurance about normal effects of tocolytics | Inpatient, Outpatient: dk | Country: United States Time period: 1986-1988 | M=54% C=79%
  41 | 20
  23.8 | 21.2
  (3.3) | (2.5)

Evidence Table 5: Tocolytic first line: Magnesium sulfate - Study design

Author (year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion/Exclusion Characteristics | Sample Size Initial/End | | | Demographic Characteristics | | | Tocolytic Intervention | Uniform Adjunctive Drug Intervention | Uniform Non-Drug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Author (year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion/Exclusion Characteristics | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tocolytic Intervention | Uniform Adjunctive Drug Intervention | Uniform Non-Drug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Lewis DF, Grimshaw A, Brooks G, et al. ^165^ | To compare the combination of Magnesium sulfate and indomethacin with Magnesium sulfate alone in patients with cervical dilation of at least 3 cm and to assess the safety and efficacy of this combination | Retrospective cohort study; Masking: none | PTL: (Dilation or Effacement) and regular contractions Successful tocolysis is delay of delivery >48 hrs | EGA: 24-34 wks Dilation>3 cm Also no: chorioamnionitis, current bleeding /hemorrhage, dilation >6 cm, fetal distress, fetal or maternal indications for delivery | 82/44 | | | Mean Age (SD) Race White Race Black | | | Tx1 Magnesium sulfate IV 6 g/ 30 min CoT: dk DoT: 30 min Magnesium sulfate intravenous 2.0-3.5 g/hr CoT: after first 30 min DoT: until contractions stopped or side effects representing toxicity occurred Indomethacin rectal 50 g CoT: dk DoT: one loading dose Indomethacin oral 25 mg CoT: after loading dose DoT: every 6 hrs until <72 hrs of continuous treatment or 72 hrs with EGA <32 wks Terbutaline oral dose: dk CoT: when patient stabilized & primary tocolytic stopped DoT: dk Tx2 Magnesium sulfate IV 6 g/ 30 min CoT: dk DoT: 30 min Magnesium sulfate IV 2.0-3.5 g/hr CoT: after first 30 min DoT: until contractions stopped or side effects representing toxicity occurredTerbutaline oral dose: dk CoT: when patient stabilized & primary tocolytic stopped DoT: dk | Ampicillin AoT: group B streptococci prophylaxis Antibiotic AoT: if group B streptococci culture positive | bedrest, routine monitoring | Inpatient | Country: United States Time period: 1990-1992 | C=56% M=33%
  21 | 23
  22.2 | 21.4
  (5.5) | (4.6)
  5 | 3
  16 | 20

Evidence Table 5: Tocolytic first line: Magnesium sulfate - Study design

Author (year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion/Exclusion Characteristics | Sample Size Initial/End | | | Demographic Characteristics | | | Tocolytic Intervention | Uniform Adjunctive Drug Intervention | Uniform Non-Drug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Author (year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion/Exclusion Characteristics | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tocolytic Intervention | Uniform Adjunctive Drug Intervention | Uniform Non-Drug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
de Veciana M, Porto M, Major CA et al. ^142^ | To evaluate the efficacy of tocolysis in delaying delivery more than 48 hrs in pregnancy w/PTL & advanced cervical dilation & to determine the impact of this delay on the incidence of maternal or neonatal morbidity & mortality | Retrospective cohort study; Masking: none | PTL: Contractions: >2/10 min, painful, palpable, lasting >1 hr and Dilation>3.5 cm Successful tocolysis: ability to delay delivery by more than 48 hrs after admission | EGA: <36 wks Intact Membranes Also: information available on labor course and outcome, no: cerclage, current bleeding/hemorrhage, maternal fever >38°C, positive culture for amniotic fluid, amniocentisis documenting pulmonary maturity, tender uterus between contractions, positive gram stain or culture | 73/73 | | | Mean Age (SD) p=NS | | | Tx1 & Cx Terbutaline sulfate subcutaneous CoT: before decision to receive IV tocolysis Tx1 & Cx Terbutaline sulfate oral (18% in Tx1 & 15% in Cx) CoT: before decision to receive IV tocolysis Tx1 Magnesium sulfate IV 4-6 gm CoT: within 1 hr of admission DoT: one loading dose Magnesium sulfate IV 2-4 gm/hr CoT: after loading dose DoT: until labor stopped or tocolysis failed, 48 hrs up to 7 days Indomethacin oral or rectal 50 mg (1 dose), then 25 mg (no more than 6 doses) CoT: concurrent w/ Magnesium sulfate (29.5% of Tx1) after adequate amniotic fluid volume documented by ultrasound DoT: every 6 hrs | Dexamethasone, Tx1 group only AoT: fetal lung maturity Antibiotics AoT: prophylactic | Fetal monitoring, Routine observation, Uterine monitoring | Inpatient | Country: United States Time period: 1985-1991 | M=58% C=52%
  44 | | 29
  22.5 | | 23.1
  (5.1) | | (5.2)

Evidence Table 5: Tocolytic first line: Magnesium sulfate - Study design

Author (year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion/Exclusion Characteristics | Sample Size Initial/End | | | Demographic Characteristics | | | Tocolytic Intervention | Uniform Adjunctive Drug Intervention | Uniform Non-Drug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Author (year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion/Exclusion Characteristics | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tocolytic Intervention | Uniform Adjunctive Drug Intervention | Uniform Non-Drug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Hales KA, Matthews JP, Rayburn WF, et al.(1995) | To determine the efficacy and safety of IV Magnesium sulfate tocolysis in twin gestations (Tx1) using dosing regimens reported for singletons (Tx2) | Retrospective cohort study; Masking: none | Contractions: 8/hr and (Cervical change or Effacement: 80% or Dilation:>2cm) Successful tocolysis is not defined | EGA: 25-33 wks Intact Membranes Also: dilation <4 cm, no: contraindications to therapy, abnormal fetus, current bleeding/hemorrhage, hypertensive disorders, maternal fever, multiple gestation >3, rupture of membranes, heart disease, liver disease, diabetes, hyperthyroidism, abnormal fetal heart rate pattern, one twin still born, evidence of fetal lung maturity | 72/72 | | | Mean Age (SD) p=ns Race, White p=ns | | | Tx1 (Twins) Magnesium sulfate IV 4-6 g/20 min CoT: initial DoT: one loading dose Magnesium sulfate intravenous 1-3 g/hr CoT: after loading dose DoT: until 24 hrs of inhibited labor Magnesium sulfate IV tapered by 0.5 g/hr CoT: after 24 hrs of inhibiting labor DoT: until no dose Terbutaline oral 5 mg CoT: within an hr before ending intravenous MgSO_4_ DoT: dk Tx2 (Singletons) Same as above, singletons | Betamethasone AoT: fetal lung development | Fetal monitoring, routine observation, various cultures and amniocentisis | | Country: Country: dk Time period: 1989-1992 | M=76% C=26%
  24 | 48
  25.0 | 20.5
  (5.0) | (3.6)
  66.7% | 60.4%

Evidence Table 5: Tocolytic first line: Magnesium sulfate - Outcomes

Author (year) | Delivery | | | | | | | | | Maternal | | | | | | Infant | | | | | | | | | | | | Other Analyses | Conclusions
Author (year) | Estimated Gestational Age | | | Prolongation of Pregnancy Days | | | Gestational Weeks | | | Length of Hospital Stay | | | Maternal Morbidity | | | Birth Weight (g) | | | Apgar Score | | | Length of Hospital Stay | | | Other Infant Outcomes | | | Other Analyses | Conclusions
Author (year) | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Other Analyses | Conclusions
Cotton DB, Strassner HT, Hill LM, et al. ^120^ | Mean (SD) | | | Mean Prolongation Days (SD) Delayed >48 hrs Intact Membranes p=NS Delayed 48 hrs, PROM p=NS Delayed <48 hrs p=NS Delayed 48 hrs-7 days p=NS Delayed >7 days p=NS | | | | | | | | | Postpartum endometritis p=NS Adverse drug reactions Urinary tract infections C-sections due to fetal distress (%) | | | Mean (SD) p=NS | | | | | | | | | Neonatal Mortality p=NS Respiratory disease p=NS Intracranial hemorrhage p=NS Necrotizing enterocolitis p=NS Fetal distress p=NS Infection p=NS Seizures p=NS Parent ductus p=NS Hypoglycemia p=NS | | | Analysis of neonatal outcome (death vs. survival) by birth weight. | No significant difference between Magnesium sulfate & terbutaline, placebo.
  31.0 | 33.1 | 32.0
  (1.9) | (3.3) | (3.4)
  3.0 | 12.0 | 7.1
  (6.0) | (14.9) | (14.9)
  6 | 10 | 7
  (38%) | (53%) | (37%)
  3/8 | 3/4 | 2/10
  (38%) | (75%) | (20%)
  63% | 47% | 63%
  25% | 26% | 21%
  12% | 27% | 16%
  2 | 5 | 1
  0 | 1 | 0
  1 | 2 | 0
  5 | 4 | 4
  (33%) | (21%) | (21%)
  1651 | 1841 | 1648
  (591) | (678) | (656)
  1/16 | 1/19 | 4/19
  6 | 4 | 6
  0 | 2 | 3
  0 | 1 | 1
  1 | 1 | 1
  2 | 7 | 0
  1 | 3 | 2
  2 | 2 | 0
  1 | 4 | 2

Evidence Table 5: Tocolytic first line: Magnesium sulfate - Outcomes

Author (year) | Delivery | | | | | | | | | Maternal | | | | | | Infant | | | | | | | | | | | | Other Analyses | Conclusions
Author (year) | Estimated Gestational Age | | | Prolongation of Pregnancy Days | | | Gestational Weeks | | | Length of Hospital Stay | | | Maternal Morbidity | | | Birth Weight (g) | | | Apgar Score | | | Length of Hospital Stay | | | Other Infant Outcomes | | | Other Analyses | Conclusions
Author (year) | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Other Analyses | Conclusions
Tchilinguirian NG, Najem R, Sullivan GB, et al. ^150^ | | | | Delivered delayed < 48 hrs Intact membranes: PROM: p=NS Delivered delayed > 48 hrs PROM: p=NS Delivered delayed 2-7 days Intact membranes: p=NS Delivered delayed >7 days Intact membranes: p=NS | | | | | | | | | | | | | | | | | | | | | | | | Compares effects of ritodrine vs. Magnesium sulfate by cases of intact membranes & PROM by: race, age, parity, number of abortions, gestational age, contraction units, dilation, effacement. | Ritodrine & Magnesium sulfate showed no differences in efficacy.
  3 | 5
  8 | 4
  2 | 5
  (20%) | (56%)
  2 | 1
  16 | 21

Evidence Table 5: Tocolytic first line: Magnesium sulfate - Outcomes

Author (year) | Delivery | | | | | | | | | Maternal | | | | | | Infant | | | | | | | | | | | | Other Analyses | Conclusions
Author (year) | Estimated Gestational Age | | | Prolongation of Pregnancy Days | | | Gestational Weeks | | | Length of Hospital Stay | | | Maternal Morbidity | | | Birth Weight (g) | | | Apgar Score | | | Length of Hospital Stay | | | Other Infant Outcomes | | | Other Analyses | Conclusions
Author (year) | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Other Analyses | Conclusions
Hatjis CG, Swain M, Nelson LH, et al. ^138^ | | | | Days from tx to delivery or recurrent labor (SD) Prolongation >1 wk p<.05 | | | | | | | | | | | | Mean birth weight (SD) p<.001 Mean birth weight >2500g | | | <7 at 5 min | | | | | | NRDS | | | | Ritodrine plus Magnesium sulfate showed efficacy over ritodrine alone: -prolongation of pregnancy >1 wk
  Group IA: | 51.14 (29.52)
  Group IC: | 32.75 (27.81)
  Group 2A: | 38.05 (22.59)
  34% | 59%
  Group IA: | 2843.647 (786.00)
  Group IB: | 1122.67 (599.78)
  Group IC: | 2242.57 (787.43)
  Group ID: | 1828.25 (613.20)
  Group 2A: | 2472.14 (841.95)
  Group 2B: | 1456.86 (455.66)
  12 | 11
  3 | 3
  Group IA: 0
  Group IB: 2
  Group IC: 1
  Group ID: 0
  Group 2A: 2
  Group 2B: 1
  6 | 10
  Group IA: 0
  Group IB: 2
  Group IC: 3
  Group ID: 1
  Group 2A: 3
  Group 2B: 7
  Neontal Deaths
  3 | 2
  Group IA: 0
  Group IB: 2
  Group IC: 1
  Group ID: 0
  Group 2A: 0
  Group 2B: 2

Evidence Table 5: Tocolytic first line: Magnesium sulfate - Outcomes

Author (year) | Delivery | | | | | | | | | Maternal | | | | | | Infant | | | | | | | | | | | | Other Analyses | Conclusions
Author (year) | Estimated Gestational Age | | | Prolongation of Pregnancy Days | | | Gestational Weeks | | | Length of Hospital Stay | | | Maternal Morbidity | | | Birth Weight (g) | | | Apgar Score | | | Length of Hospital Stay | | | Other Infant Outcomes | | | Other Analyses | Conclusions
Author (year) | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Other Analyses | Conclusions
Wilkins IA, Lynch L, Mehalek KE et al. ^122^ | | | | Delayed >48 hrs (%) p=ns Delayed >7 days (%) p=ns | | | Delivery at >37 wks (%) p=ns | | | | | | | | | | | | | | | | | | | | | Patients with another episode of PTL were initially given original tocolytic agent but randomized to second line therapy if contractions continued, some description of patients receiving both agents. | No differences in effectiveness shown between ritodrine & Magnesium sulfate.
  52 | 61
  (96.3) | (92.3)
  45 | 53
  (83.3) | (80.3)
  25 | 31
  (46.3) | (47)

Evidence Table 5: Tocolytic first line: Magnesium sulfate - Outcomes

Author (year) | Delivery | | | | | | | | | Maternal | | | | | | Infant | | | | | | | | | | | | Other Analyses | Conclusions
Author (year) | Estimated Gestational Age | | | Prolongation of Pregnancy Days | | | Gestational Weeks | | | Length of Hospital Stay | | | Maternal Morbidity | | | Birth Weight (g) | | | Apgar Score | | | Length of Hospital Stay | | | Other Infant Outcomes | | | Other Analyses | Conclusions
Author (year) | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Other Analyses | Conclusions
Cox SM, Sherman ML, Leveno KJ ^124^ | Mean (SEM) p=NS | | | Mean days (SEM) p=NS | | | Delivery 33-35 wks p=.02 Delivery >36 wks p=NS | | | | | | | | | Mean (SEM) p=NS | | | Mean at 5 min p=NS | | | Mean days (SEM) p=NS | | | Infant death p=NS | | | | No significant differences between Magnesium sulfate infusions resulting in maximum concentrations of 5.5 mEq/L and placebo.
  33.8 | | 33.0
  (0.5) | | (0.5)
  26.6 | | 22.4
  (3.0) | | (2.5)
  20% | | 38%
  39% | | 26%
  2264 | | 2204
  (93) | | (77)
  8 | | 8
  (0.2) | | (0.2)
  13.8 | | 19.7
  (1.9) | | (3.1)
  1 | | 1

Evidence Table 5: Tocolytic first line: Magnesium sulfate - Outcomes

Author (year) | Delivery | | | | | | | | | Maternal | | | | | | Infant | | | | | | | | | | | | Other Analyses | Conclusions
Author (year) | Estimated Gestational Age | | | Prolongation of Pregnancy Days | | | Gestational Weeks | | | Length of Hospital Stay | | | Maternal Morbidity | | | Birth Weight (g) | | | Apgar Score | | | Length of Hospital Stay | | | Other Infant Outcomes | | | Other Analyses | Conclusions
Author (year) | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Other Analyses | Conclusions
Noblot G, Audra P, Dargent D, et al. ^160^ | | | | Mean Prolongation weeks p=NS | | | Before 37^th^wk | | | Length of stay days p<0.05 | | | | | | Mean singleton births p=NS | | | Mean score at 1 min, singleton births p=NS Mean score at 5 min, singleton births p=NS Mean score at 10 min, singleton births p=NS | | | | | | | | | | Ritodrine & progesterone showed efficacy over ritodrine alone: -length of maternal hospital stay
  6.4 | | 6.0
  8 | | 6
  17.8 | | 13.6
  2832 | 3077
  7.7 | 8.7
  9.3 | 9.7
  9.8 | 9.7

Evidence Table 5: Tocolytic first line: Magnesium sulfate - Outcomes

Author (year) | Delivery | | | | | | | | | Maternal | | | | | | Infant | | | | | | | | | | | | Other Analyses | Conclusions
Author (year) | Estimated Gestational Age | | | Prolongation of Pregnancy Days | | | Gestational Weeks | | | Length of Hospital Stay | | | Maternal Morbidity | | | Birth Weight (g) | | | Apgar Score | | | Length of Hospital Stay | | | Other Infant Outcomes | | | Other Analyses | Conclusions
Author (year) | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Other Analyses | Conclusions
Morales WJ, Madhav H ^167^ | Mean (SD) p=NS | | | Mean (SD) p=NS | | | | | | | | | | | | Mean (SD) p=NS | | | | | | | | | | | | | No significant difference between tx w/ indomethacin & tx w/ Magnesium sulfate
  28.0 | 29.1
  (2.7) | (2.5)
  22.9 | 22.7
  (11.5) | (13.4)
  1808 | 2030
  (390) | (627)

Evidence Table 5: Tocolytic first line: Magnesium sulfate - Outcomes

Author (year) | Delivery | | | | | | | | | Maternal | | | | | | Infant | | | | | | | | | | | | Other Analyses | Conclusions
Author (year) | Estimated Gestational Age | | | Prolongation of Pregnancy Days | | | Gestational Weeks | | | Length of Hospital Stay | | | Maternal Morbidity | | | Birth Weight (g) | | | Apgar Score | | | Length of Hospital Stay | | | Other Infant Outcomes | | | Other Analyses | Conclusions
Author (year) | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Other Analyses | Conclusions
Fox MD, Allbert JR, McCaul JF, et al. ^166^ | Mean (SD) P<0.05 | | | Mean Prolongation Days (SD) p=0.9 Delivered at <48 hrs p=0.04 | | | | | | | | | | | | Mean (SD) p=0.86 | | | | | | Mean Hospital Days (SD) p=NS | | | Neonatal Deaths p=NS Respiratory distress syndrome p=NS Intraventricular hemorrhage p=NS Necrotizing enterocolitis p=NS Transient tachypnea p=NS Hyperbilirabenia p=NS | | | Morbidity outcomes by completed wks of gestation | Magnesium sulfate showed efficacy over placebo: -less likely to deliver <48 hrs Placebo showed efficacy over Magnesium sulfate: -greater EGA at birth
  36.5 | | 37.7
  (1.7) | | (1.9)
  15.7 | | 15.4
  (12.5) | | (13.5)
  19 | | 29
  2741 | | 2761
  (495) | | (585)
  2.5 | | 2.1
  (1.7) | | (1.4)
  0 | | 0
  1 | | 1
  0 | | 0
  0 | | 0
  3 | | 3
  2 | | 1

Evidence Table 5: Tocolytic first line: Magnesium sulfate - Outcomes

Author (year) | Delivery | | | | | | | | | Maternal | | | | | | Infant | | | | | | | | | | | | Other Analyses | Conclusions
Author (year) | Estimated Gestational Age | | | Prolongation of Pregnancy Days | | | Gestational Weeks | | | Length of Hospital Stay | | | Maternal Morbidity | | | Birth Weight (g) | | | Apgar Score | | | Length of Hospital Stay | | | Other Infant Outcomes | | | Other Analyses | Conclusions
Author (year) | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Other Analyses | Conclusions
Glock JL, Morales WJ ^162^ | Mean (SD) p=NS | | | Prolonged >2 days p=NS | | | Delivery at >37 wks p=NS Delivery at >34 wks p=NS | | | Readmission for recurrent labor p=NS | | | Adverse Drug Reactions | | | Mean (SD) p=NS | | | Apgar at 1 min (SD) p=NS Apgar at 5 min (SD) p=NS | | | | | | Neonatal Mortality Fetal Mortality | | | | No significant difference shown between the efficacy of nifedipine & Magnesium sulfate.
  34.5 | 35.2
  (2.8) | (3.1)
  92% | 93%
  16 | 17
  (41%) | (41%)
  24 | 28
  (62%) | (68%)
  10 | 10
  (26%) | (24%)
  16 | 13
  2434 | 2508
  (716) | (693)
  7.3 | 7.1
  (1.7) | (1.6)
  8.4 | 8.4
  (2.0) | (1.9)
  2 | 0
  (5%)
  0 | 0

Evidence Table 5: Tocolytic first line: Magnesium sulfate - Outcomes

Author (year) | Delivery | | | | | | | | | Maternal | | | | | | Infant | | | | | | | | | | | | Other Analyses | Conclusions
Author (year) | Estimated Gestational Age | | | Prolongation of Pregnancy Days | | | Gestational Weeks | | | Length of Hospital Stay | | | Maternal Morbidity | | | Birth Weight (g) | | | Apgar Score | | | Length of Hospital Stay | | | Other Infant Outcomes | | | Other Analyses | Conclusions
Author (year) | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Other Analyses | Conclusions
Smith CS, Woodland MB ^154^ | Mean (Range) p=ns | | | | | | Preterm Delivery Rate | | | | | | Mean Stopping time of contractions (Range) p=ns Total side effects (%) p=ns Tocolytic Success Rate p=ns | | | | | | Mean at 1 min (Range) p=ns Mean at 5 min (Range) p=ns | | | | | | Fetal mortality | | | Patients who demonstrated cervical change at tocolysis initiation with non-significant difference in successful tocolysis; side effects described. | No significant difference shown between nifedipine & terbutaline.
  36.8 | 35
  (29-41) | (24-40)
  36% | 50%
  40 | 41
  (30-90) | (30-60)
  9 | 13
  (32) | (54)
  68% | 71%
  7 | 8.4
  (2-9) | (4-9)
  6.7 | 8.3
  (1-9) | (4-9)
  0 | 0

Evidence Table 5: Tocolytic first line: Magnesium sulfate - Outcomes

Author (year) | Delivery | | | | | | | | | Maternal | | | | | | Infant | | | | | | | | | | | | Other Analyses | Conclusions
Author (year) | Estimated Gestational Age | | | Prolongation of Pregnancy Days | | | Gestational Weeks | | | Length of Hospital Stay | | | Maternal Morbidity | | | Birth Weight (g) | | | Apgar Score | | | Length of Hospital Stay | | | Other Infant Outcomes | | | Other Analyses | Conclusions
Author (year) | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Other Analyses | Conclusions
Floyd RC, McLaughlin BN, Perry Jr KG, et al. ^163^ | | | | Mean Prolongation Days (SD) p=NS | | | Delivery at<34 wks Delivery at 34-37 wks Delivery at >37 wks p=0.58 | | | | | | Estimated blood loss (SD) | | | Birth weight <1500 g p=.08 Birth weight 1500-2500 g Birth weight >2500 g | | | Apgar score <7 at 5 min p=0.89 | | | | | | Mean neonatal deaths Fetal mortality NRDS Transient tachypnea | | | | No significant difference shown between Magnesium sulfate & nifedipine.
  43.3 | 37.5
  (34.1) | (26.0)
  8 | 10
  10 | 8
  22 | 32
  355 | 351
  (171) | (154)
  2 | 3
  17 | 11
  21 | 36
  6 | 7
  0 | 0
  0 | 1
  4 | 5
  2 | 0

Evidence Table 5: Tocolytic first line: Magnesium sulfate - Outcomes

Author (year) | Delivery | | | | | | | | | Maternal | | | | | | Infant | | | | | | | | | | | | Other Analyses | Conclusions
Author (year) | Estimated Gestational Age | | | Prolongation of Pregnancy Days | | | Gestational Weeks | | | Length of Hospital Stay | | | Maternal Morbidity | | | Birth Weight (g) | | | Apgar Score | | | Length of Hospital Stay | | | Other Infant Outcomes | | | Other Analyses | Conclusions
Author (year) | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Other Analyses | Conclusions
Chau AC, Gabert HA, Miller JM ^128^ | | | | Mean Prolongation Weeks (SD) p<0.005 Median Prolongation Weeks Delivery delayed >48 hrs p=NS Delivery at <7 days 27 p=NS | | | Delivered at term (%) p<0.05 | | | | | | Idiopathic premature labor p=NS Severe preeclampsia p=NS Chorioamnionitis p=NS | | | Mean (SD) p<0.05 | | | Apgar at 1 min p=NS Apgar at 5 min p=NS | | | | | | | | | Discusses subjects who crossed over to the other treatment group due to failure of their initial method. | Magnesium sulfate showed effectiveness over terbutaline: -mean prolongation wks -delivery at term -mean birth weight
  7.1 | 5.0
  (3.9) | (3.2)
  6.3 | 5.0
  44 | 48
  34 | 27
  (73.9) | (51.9)
  10.9% | 21.2%
  4 | 3
  2 | 5
  2821 | 2536
  (640) | (759)

Evidence Table 5: Tocolytic first line: Magnesium sulfate - Outcomes

Author (year) | Delivery | | | | | | | | | Maternal | | | | | | Infant | | | | | | | | | | | | Other Analyses | Conclusions
Author (year) | Estimated Gestational Age | | | Prolongation of Pregnancy Days | | | Gestational Weeks | | | Length of Hospital Stay | | | Maternal Morbidity | | | Birth Weight (g) | | | Apgar Score | | | Length of Hospital Stay | | | Other Infant Outcomes | | | Other Analyses | Conclusions
Author (year) | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Other Analyses | Conclusions
Kosasa TS, Busse R, Wahl N, et al. ^141^ | | | | Mean days (SD) Delay >72 hrs | | | | | | | | | Side Effects | | | | | | | | | | | | Fetal Mortality | | | Side effects detailed;Outcomes for placenta previa and abruption (no statistical analyses). | No statistical analysis provided comparing study results.
  61 | 20.5
  (23.6) | (17.4)
  84% | 64%
  44.3% | 59%
  0 | 0

Evidence Table 5: Tocolytic first line: Magnesium sulfate - Outcomes

Author (year) | Delivery | | | | | | | | | Maternal | | | | | | Infant | | | | | | | | | | | | Other Analyses | Conclusions
Author (year) | Estimated Gestational Age | | | Prolongation of Pregnancy Days | | | Gestational Weeks | | | Length of Hospital Stay | | | Maternal Morbidity | | | Birth Weight (g) | | | Apgar Score | | | Length of Hospital Stay | | | Other Infant Outcomes | | | Other Analyses | Conclusions
Author (year) | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Other Analyses | Conclusions
Sciscione AC, Stamilio DM, Manley JS et al. ^143^ | Mean (SD) p=.14 | | | | | | <37 wks p=.07 <35 wks p=.72 <32 wks p=.25 | | | | | | | | | Mean (SD) | | | | | | NICU Admissions p=.35 | | | | | | | No significant differences were found between tx and control group.
  38.0 | | 38.5
  (2.5) | | (1.8)
  21% | | 10%
  7% | | 4%
  4% | | 0%
  3231 | | 3204
  (703) | | (491)
  11% | | 5%

Evidence Table 5: Tocolytic first line: Magnesium sulfate - Outcomes

Author (year) | Delivery | | | | | | | | | Maternal | | | | | | Infant | | | | | | | | | | | | Other Analyses | Conclusions
Author (year) | Estimated Gestational Age | | | Prolongation of Pregnancy Days | | | Gestational Weeks | | | Length of Hospital Stay | | | Maternal Morbidity | | | Birth Weight (g) | | | Apgar Score | | | Length of Hospital Stay | | | Other Infant Outcomes | | | Other Analyses | Conclusions
Author (year) | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Other Analyses | Conclusions
Elliott JP ^164^ | | | | Mean Prolongation of Delivery 24 hrs 48 hrs 72 hrs >7 days | | | Delivered "at term" | | | | | | Chorioamnionitis | | | | | | | | | | | | | | | Results of prolongation of pregnancy by dilation, Results of length of time to delivery for patients w/ PTL & significant vaginal bleeding, Comparison of magnesium to ritodrine in time gained in pregnancy. | No statistical analysis provided comparing groups.
  Tx1 | Tx2 | Tx3 | Tx4
  214 | 30 | 28 | 3
  (78%) | (79%) | (80%) | (27%)
  208 | 25 | 24 | 2
  (76%) | (64%) | (69%) | (25%)
  191 | N/A | 20 | N/A
  (70%) | | (57%)
  140 | N/A | 13 | N/A
  (51%) | | (37%)
  Tx1 | Tx2 | Tx3 | Tx4
  106 | N/A | 8 | N/A
  (39%) | | (23%)
  Tx1 15 (29%)

Evidence Table 5: Tocolytic first line: Magnesium sulfate - Outcomes

Author (year) | Delivery | | | | | | | | | Maternal | | | | | | Infant | | | | | | | | | | | | Other Analyses | Conclusions
Author (year) | Estimated Gestational Age | | | Prolongation of Pregnancy Days | | | Gestational Weeks | | | Length of Hospital Stay | | | Maternal Morbidity | | | Birth Weight (g) | | | Apgar Score | | | Length of Hospital Stay | | | Other Infant Outcomes | | | Other Analyses | Conclusions
Author (year) | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Other Analyses | Conclusions
Dudley D, Gagnon D, Varner M (1989) | | | | | | | >36 wks | | | | | | | | | | | | | | | | | | Neonatal Deaths NRDS BPD Necrotizing Enterocolitis | | | | No statistical analysis provided comparing study arms.
  11% | 33% | 33%
  22% | 8% | 12%
  62% | 31% | 32%
  22% | 6% combined Tx2 & Tx3
  20% | 8% combined Tx2 & Tx3

Evidence Table 5: Tocolytic first line: Magnesium sulfate - Outcomes

Author (year) | Delivery | | | | | | | | | Maternal | | | | | | Infant | | | | | | | | | | | | Other Analyses | Conclusions
Author (year) | Estimated Gestational Age | | | Prolongation of Pregnancy Days | | | Gestational Weeks | | | Length of Hospital Stay | | | Maternal Morbidity | | | Birth Weight (g) | | | Apgar Score | | | Length of Hospital Stay | | | Other Infant Outcomes | | | Other Analyses | Conclusions
Author (year) | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Other Analyses | Conclusions
Coleman FH ^152^ | | | | | | | Delivery <36 wks p=.017 | | | | | | | | | Median (Range) p=NS | | | | | | Median (Range) p=.017 | | | Neonatal Morbidity Rate p=NS | | | | Dual tocolysis continued despite complications effectively: -increased delivery >36 wks -decreased median infant length of hospital stay
  19.5% | 50%
  3115 | 2449
  (1430- 4139) | (1370- 3621)
  3 | 15.5
  (2-67) | (2-72)
  41.5% | 60%

Evidence Table 5: Tocolytic first line: Magnesium sulfate - Outcomes

Author (year) | Delivery | | | | | | | | | Maternal | | | | | | Infant | | | | | | | | | | | | Other Analyses | Conclusions
Author (year) | Estimated Gestational Age | | | Prolongation of Pregnancy Days | | | Gestational Weeks | | | Length of Hospital Stay | | | Maternal Morbidity | | | Birth Weight (g) | | | Apgar Score | | | Length of Hospital Stay | | | Other Infant Outcomes | | | Other Analyses | Conclusions
Author (year) | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Other Analyses | Conclusions
Lewis DF, Grimshaw A, Brooks G, et al. ^165^ | | | | Mean Days p<.001 Delayed >48 hrs p<.09 | | | | | | | | | Maternal Complications | | | | | | Apgar <7 at 5 min | | | | | | | | | | Tocolysis w/ Magnesium sulfate, indomethacin showed relative effectiveness over Magnesium sulfate: -prolongation of pregnancy days
  15.4 | 2.9
  17 | 12
  0 | 0
  3 | 3

Evidence Table 5: Tocolytic first line: Magnesium sulfate - Outcomes

Author (year) | Delivery | | | | | | | | | Maternal | | | | | | Infant | | | | | | | | | | | | Other Analyses | Conclusions
Author (year) | Estimated Gestational Age | | | Prolongation of Pregnancy Days | | | Gestational Weeks | | | Length of Hospital Stay | | | Maternal Morbidity | | | Birth Weight (g) | | | Apgar Score | | | Length of Hospital Stay | | | Other Infant Outcomes | | | Other Analyses | Conclusions
Author (year) | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Other Analyses | Conclusions
de Veciana M, Porto M, Major CA, et al. ^142^ | Mean (SD) p=ns | | | Mean Hours (SD) p=ns | | | Delivery >48 hr (%) | | | | | | | | | Mean (SD) p=ns | | | Apgar <7 at 5 min (%) p=ns | | | Mean (SD) p=ns | | | Neonatal Deaths p=ns Mild NRDS p=ns Severe NRDS p=.04 Intraventricular Hemorrhage p=ns Necrotizing Enterocolitis p=ns Mean Days Incubated (SD) p=ns | | | decreased incidence of severe respiratory distress syndrome | Combined treatment w/ terbutaline, Magnesium sulfate, & indomethacin showed no significant difference over terbutaline alone.
  31.1 | | 32.6
  (3.5) | | (3.5)
  102.9 | | 45.2
  (145.6) | | (146.2)
  21 | | 3
  (48) | | (10)
  1778 | | 2346
  (705) | | (782)
  1 | | 2
  (2.1) | | (6.3)
  22.4 | | 11.5
  (28.6) | | (22.7)
  8.3% | | 9.4%
  23% | | 31.3%
  8.3% | | 9.4%
  4% | | 9.1%
  0% | | 3%
  4.02 | | 12.5
  (2.8) | | (8.5)

Evidence Table 5: Tocolytic first line: Magnesium sulfate - Outcomes

Author (year) | Delivery | | | | | | | | | Maternal | | | | | | Infant | | | | | | | | | | | | Other Analyses | Conclusions
Author (year) | Estimated Gestational Age | | | Prolongation of Pregnancy Days | | | Gestational Weeks | | | Length of Hospital Stay | | | Maternal Morbidity | | | Birth Weight (g) | | | Apgar Score | | | Length of Hospital Stay | | | Other Infant Outcomes | | | Other Analyses | Conclusions
Author (year) | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Other Analyses | Conclusions
Hales KA, Matthews JP, Rayburn WF, et al. (1995) | Mean (SD) p=ns | | | Mean (SD) p=ns | | | Delivery at >34 wks (%) p=ns Delivery at >36 wks (%) p=ns | | | | | | | | | Mean (SD) | | | | | | | | | | | | | Magnesium sulfate doses yield similar effectiveness for delivery delay and side effects when given to twin pregnancies as compared to singleton pregnancies.
  30.9 | 33.7
  (3.3) | (4.1)
  33.9 | 20.9
  (23.0) | (20.1)
  10 | 25
  (41.7) | (52.1)
  3 | 14
  (12.5) | (29.2)
  1827 | 2208
  (611) | (842)
  1791 | (second twin)
  (600)

Evidence Table 6: Tocolytic first line: Nonsteroidal Anti-inflammatory agents - Study design

Author (year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion/Exclusion Characteristics | Sample Size Initial/End | | | Demographic Characteristics | | | Tocolytic Intervention | Uniform Adjunctive Drug Intervention | Uniform Non-Drug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Author (year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion/Exclusion Characteristics | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tocolytic Intervention | Uniform Adjunctive Drug Intervention | Uniform Non-Drug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Gamissans O, Cañas E, Cararach J, et al. ^118^ | To compare the efficacy & side effects of ritodrine & placebo versus ritodrine & indomethacin in patients with threatened PTL | RCT; Masking: Subject, physician: yes Pharm., other care providers: dk | PTL: (Contractions regular or irregular)or(Cervical effacement & Dilation<4 cm)or Other: slight bleeding or "showing" Successful Tocolysis: not defined | EGA: 20-36 wks Intact Membranes Also no: multiple gestation, Pre-eclampsia toxemia, Rh immunization. | 44/44 | | | Mean Age (SEM) | | | Tx1 Ritodrine hydrochloride, IV in 5% glucose, 200 µg/min CoT: after admission DoT: at least 1hr Ritodrine hydrochloride, IV in 5% glucose, adjusted to according to the needs of individual patients CoT: after initial infusion DoT: at least 24 hrs Ritodrine intramuscularly or orally, 10 mg/4-6 hrs CoT: after 24 hr infusion DoT: up to 38 wks, unless labor occurs* Placebo suppository (identical in appearance to indomethacin suppository) Tx2 Ritodrine hyrdochloride, IV in 5% glucose, 200 µg/min CoT: after admission DoT: at least 1hr Ritodrine hyrdochloride, IV in 5% glucose, adjusted to according to the needs of individual patients CoT: after initial infusion DoT: at least 24 hrs Ritodrine intramuscularly or orally, 10 mg/4-6 hrs CoT: after 24 hr infusion DoT: up to 38 wks, unless labor occurs* Indomethacin suppository 50 mg/8 hrs CoT: dk DoT: for 2 wks unless labor occurs or rectal intolerance occurs *If patients under oral or intramuscular tx present w/ recurrent regular uterine contractions, IV infusion of ritodrine was repeated for at least 24 hrs. | | Bedrest | Inpatient | Country: dk Time period: dk | M=88% C=71%
  22 | 22
  24.8 | 22.05
  (1.18) | (1.04)

Evidence Table 6: Tocolytic first line: Nonsteroidal Anti-inflammatory agents - Study design

Author (year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion/Exclusion Characteristics | Sample Size Initial/End | | | Demographic Characteristics | | | Tocolytic Intervention | Uniform Adjunctive Drug Intervention | Uniform Non-Drug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Author (year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion/Exclusion Characteristics | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tocolytic Intervention | Uniform Adjunctive Drug Intervention | Uniform Non-Drug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Morales WJ, Smith SG, Angel JL, et al. ^123^ (1989) | To compare the relative efficacy and maternal/neonatal effects of indomethacin and ritodrine hydrochloride | RCT; Masking: Subject, physician, other care givers: no pharmacist: dk | PTL: Contractions: 4 in 20 minand(Dilation or Effacement) Successful tocolysis: not defined | EGA: 32 wks or less Intact membranes Also no: abnormal fetus, chorioamnionitis, dilation >4 cm, evidence of intra-amniotic infection, pyelonephritis, complications contraindicating tocolysis | 106/106 | | | Mean Age (SD) Black | | | Tx1 Indomethacin rectal suppository 100 mg CoT: initial DoT: once or twice Indomethacin oral 25 mg/4 hrs CoT: after initial DoT: 48 hrs Magnesium sulfate IV 5g CoT: if serious side effects from indomethacin DoT: one dose Magnesium sulfate IV 2-4g /hr CoT: after initial dose of mag sulfate DoT: dk Terbutaline CoT: after first-line tx completed DoT: dk, prophylaxis Tx2 Ritodrine IV 50 µg/min, increasing by 50 µg/min every 20 min CoT: initial DoT: until contraction cease or max dose of 350 µg/min Terbutaline CoT: after first-line tx completed DoT: dk , prophylaxis | | | Inpatient | Country: United States Time Period: 1987-1988 | M=60% C=32%
  52 | 54
  21.8 | 20.9
  (3.9) | (4.1)
  39% | 56%

Evidence Table 6: Tocolytic first line: Nonsteroidal Anti-inflammatory agents - Study design

Author (year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion/Exclusion Characteristics | Sample Size Initial/End | | | Demographic Characteristics | | | Tocolytic Intervention | Uniform Adjunctive Drug Intervention | Uniform Non-Drug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Author (year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion/Exclusion Characteristics | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tocolytic Intervention | Uniform Adjunctive Drug Intervention | Uniform Non-Drug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Kurki TK, Eronen M, Lumme R, et al. (1991) | To compare the tocolytic effects of indomethacin and nylidrin where the appearance of the treatment was identical to the subjects | RCT; Masking: Subject, physician: yes Pharm., other care providers: dk | PTL: Contractions: painful and >1 every 10 minand Dilation: 2-4 cmandBishop score: 1-9 Unsuccessful tocolysis: delivery during tocolysis or recurrence of contractions w/in 48 hrs after cessation of treatment | EGA: 25-34 wks Intact membranes Also no: abnormal amniotic fluid volume, abnormal fetus, chorioamnionitis, dilation >4 cm, fetal distress, multiple gestation, placenta previa, PROM, fetal growth retardation, previous tocolytics in current pregnancy, illness contraindicating tocolysis | 60/60 | | | Age (SD) | | | Tx1 Indomethacin rectal suppository 100 mg CoT: initial DoT: single dose Indomethacin oral 50 mg CoT: 8 hrs after initial dose DoT: every 8 hrs for up to 1 day (2 doses) or until contractions cease Indomethacin oral 50 mg CoT: after day 1 DoT: every 8 hours for up to 2 days or until contractions cease Tx2 Nylidrin IV 50 µg /min CoT: initial DoT: 30 min Nylidrin IV 100-150 µg/min CoT: within 30 min of initial dose DoT: 3 days or until contrac- tions cease | Tx1 Saline IV Tx2 Placebo rectal suppository & oral capsules | IV Fluids, Routine Observation, Uterine Monitoring, Cervical exam 24 hrs after initiation of tx | Inpatient | Country: Finland Time period: 1987-1990 | M=79% C=52%
  30 | 30
  29.0 | 29.1
  (1.0) | (1.1)

Evidence Table 6: Tocolytic first line: Nonsteroidal Anti-inflammatory agents - Study design

Author (year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion/Exclusion Characteristics | Sample Size Initial/End | | | Demographic Characteristics | | | Tocolytic Intervention | Uniform Adjunctive Drug Intervention | Uniform Non-Drug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Author (year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion/Exclusion Characteristics | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tocolytic Intervention | Uniform Adjunctive Drug Intervention | Uniform Non-Drug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Morales WJ, Madhav H ^167^ | To compare the efficacy of indomethacin and magnesium sulfate in pregnancies <32 wks gestation. | RCT; Masking: Subject, physician, other direct care givers: no | Contractions: 4 in 20 minand Dilation (>2 cm) or Effacement Successful tocolysis: not defined | EGA:<32 wks Intact membranes Also no: Abnormal fetus, dilation >4 cm, congenital anomalies, growth retardation | 114/101 | | | Mean Age (SD) | | | Tx1 Indomethacin rectal suppository 100 mg CoT: initial DoT: one dose Indomethacin oral 25 mg/4 hr CoT: after initial DoT: 48 hrs Tx2 Magnesium Sulfate IV 6g CoT: initial CoT: 30 min Magnesium Sulfate IV 2g/hr increasing by 1g/h CoT: after initial DoT: Max of 5g/hr | | Routine Observation | | Country: United States Time Period: 1988-1989 | M=83% C=36%
  49 | 52
  24.6 | 22.9
  (4.3) | (4.1)

Evidence Table 6: Tocolytic first line: Nonsteroidal Anti-inflammatory agents - Study design

Author (year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion/Exclusion Characteristics | Sample Size Initial/End | | | Demographic Characteristics | | | Tocolytic Intervention | Uniform Adjunctive Drug Intervention | Uniform Non-Drug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Author (year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion/Exclusion Characteristics | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tocolytic Intervention | Uniform Adjunctive Drug Intervention | Uniform Non-Drug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Eronen M, Pesonen E, Kurki TM, et al. (1994) | To assess the effect on neonatal outcomes of either an inhibitor of prostoglandin synthesis or a β-adrenergic agonist to treat PTL. | RCT; Masking: Subject, physician, pharm., other care providers: none | PTL: Contractions: 1 in 10 min or lessand Cervical change (dilation 2-4 cm, softening) Successful Tocolysis: not defined | EGA: 24-34 wks Intact Membranes Also no: abnormal fetus, suspected chorioamnionitis, fetal distress, vaginal bleeding, pregnancy-induced hypertension, sensitivity to salicylates, history of peptic ulcer. | 80/80 | | | Mean Age (SD) | | | Tx1 Placebo IV Indoethacin suppository 100 mg CoT: initial DoT: single dose Indoethacin oral 50 mg every 8 hrs CoT: after initial dose DoT: until contractions cease or max of 3 days Nylidrin IV dose:dk CoT: if labor reoccurs within 72 hrs of initial cessation and if before 35 wks DoT: dk Tx2 Nylidrin IV 50 µg/min CoT: initial DoT: <30 min Nylidrin IV 100-150 µg/min CoT: after initial dose DoT: until contractions cease or maximum of 8 days Placebo suppository Nylidrin IV dose:dk CoT: if labor reoccurs within 72 hrs of initial cessation and if before 35 wks DoT: dk | | Bedrest, Routine observation | Inpatient | Country: Finland Time period: 1988-1992 | M=76% C=66%
  40 | 40
  28.2 | | 29.7
  (5.7) | | (5.0)

Evidence Table 6: Tocolytic first line: Nonsteroidal Anti-inflammatory agents - Study design

Author (year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion/Exclusion Characteristics | Sample Size Initial/End | | | Demographic Characteristics | | | Tocolytic Intervention | Uniform Adjunctive Drug Intervention | Uniform Non-Drug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Author (year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion/Exclusion Characteristics | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tocolytic Intervention | Uniform Adjunctive Drug Intervention | Uniform Non-Drug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Spearing G ^146^ | To compare various approaches to arresting PTL | Non-randomized control trial; Masking: dk | PTL: Contractions, >1 per 10 min, regular and painful Successful Tocolysis: 48 hrs free of uterine activity | EGA: 26-35 wks Also no: inadvisable to arrest labor, antepartum hemorrhage, known fetal abnormality, gross hydramnios | 66/62 | | | | | | Tx1 Alcohol IV 10% solution of 5% dextrose, 15 ml/kg CoT: dk DoT: 2 hrs Alcohol IV 1.5 ml/kg of body weight CoT: after loading dose DoT: dk Tx2 Alcohol (same as Tx1, dose 1) Alcohol (same as Tx1, dose 2) Indomethacin rectal suppository 100 mg/12 hrs CoT: dk DoT: 2 doses Indomethacin oral 25 mg/6 hr CoT: after 2 rectal doses DoT: 48 hrs after cessation of contractions Tx3 Salbutamol IV (5 ml of salbutamol to 500 ml of 5% dextrose, a concentration of 10 µg/min) infusion rate of 20 drops/min, increased by increments of 10 drop/min every 10 min (max rate 80 drops/min) CoT: dk DoT: until contractions ceased, maternal pulse rate >140 beats/min, or maternal distress due to palpitations or hypertension Salbutamol IV effective dose CoT: after initial dose DoT: 6 hrs Salbutamol oral 4 mg q.d.s. CoT: after IV doses DoT:>48 hrs after contractions ceased | | Fetal monitoring, Maternal heart rate and blood pressure, Uterine monitoring | Inpatient | Country: dk Time period: dk | M=34% C=34%
  22 | 20 | 20
  Tx1: alcohol Tx2: alcohol and indomethacin Tx3: salbutamol

Evidence Table 6: Tocolytic first line: Nonsteroidal Anti-inflammatory agents - Study design

Author (year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion/Exclusion Characteristics | Sample Size Initial/End | | | Demographic Characteristics | | | Tocolytic Intervention | Uniform Adjunctive Drug Intervention | Uniform Non-Drug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Author (year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion/Exclusion Characteristics | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tocolytic Intervention | Uniform Adjunctive Drug Intervention | Uniform Non-Drug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Lewis DF, Grimshaw A, Brooks G, et al. ^165^ | To compare the combination of magnesium sulfate and indomethacin with magnesium sulfate alone inpatients with cervical dilation of at least 3 cm and to assess the safety and efficacy of this combination | Retrospective cohort study; Masking: none | PTL: (Dilation or Effacement)andregular contractions Successful tocolysis is delay of delivery >48 hrs | EGA: 24-34 wks Dilation>3 cm Also no: chorioamnionitis, current bleeding /hemorrhage, dilation >6 cm, fetal distress, fetal or maternal indications for delivery | 82/44 | | | Mean Age (SD) Race White Race Black | | | Tx1 Magnesium sulfate IV 6 g/ 30 min CoT: dk DoT: 30 min Magnesium sulfate intravenous 2.0-3.5 g/hr CoT: after first 30 min DoT: until contractions stopped or side effects representing toxicity occurred Indomethacin rectal 50 g CoT: dk DoT: one loading dose Indomethacin oral 25 mg CoT: after loading dose DoT: every 6 hrs until <72 hrs of continuous treatment or 72 hrs with EGA <32 wks Terbutaline oral dose: dk CoT: when patient stabilized & primary tocolytic stopped DoT: dk Tx2 Magnesium sulfate IV 6 g/ 30 min CoT: dk DoT: 30 min Magnesium sulfate IV 2.0-3.5 g/hr CoT: after first 30 min DoT: until contractions stopped or side effects representing toxicity occurred Terbutaline oral dose: dk CoT: when patient stabilized & primary tocolytic stopped DoT: dk | Ampicillin AoT: group B streptococci prophylaxis Antibiotic AoT: if group B streptococci culture positive | bedrest, routine monitoring | Inpatient | Country: United States Time period: 1990-1992 | C=56% M=33%
  21 | 23
  22.2 | 21.4
  (5.5) | (4.6)
  5 | 3
  16 | 20

Evidence Table 6: Tocolytic first line: Nonsteroidal Anti-inflammatory agents - Study design

Author (year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion/Exclusion Characteristics | Sample Size Initial/End | | | Demographic Characteristics | | | Tocolytic Intervention | Uniform Adjunctive Drug Intervention | Uniform Non-Drug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Author (year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion/Exclusion Characteristics | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tocolytic Intervention | Uniform Adjunctive Drug Intervention | Uniform Non-Drug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Zuckerman H, Reiss U, Rubinstein I ^168^ | To study the inhibitory effect of indomethacin on PTL | Case Series; Masking: dk | PTL: Contractions, regular, frequent, mild to strong and continuous over a 30 min period Successful Tocolysis: Premature contractions arrested completely for >1 wk and the fetus reached maturity. (Prematurity defined as <2500 g.) Partial success: uterine activity ceased 48 hrs - 7 days. | EGA: 25-36 wks Maternal age: 17-42 yrs Also no: dilation >5 cm | 50/50 | | | Mean age (Range) | | | Tx1 Indomethacin rectal suppository 100 mg CoT: after registration of the base uterine activity DoT: one dose* Indomethacin oral 25 mg every 6 hrs CoT: after rectal treatment concluded DoT: until contractions were inhibited for 24 hrs * If contractions reactivated, the tx was reinstituted | | Fetal monitoring, Maternal heart rate and blood pressure | Inpatient | Country: Israel Time period: 1973 | M=18% C=25%
  50
  Intact membranes: N=37 PROM: N=13
  26 (17-42)

Evidence Table 6: Tocolytic first line: Nonsteroidal Anti-inflammatory agents - Study design

Author (year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion/Exclusion Characteristics | Sample Size Initial/End | | | Demographic Characteristics | | | Tocolytic Intervention | Uniform Adjunctive Drug Intervention | Uniform Non-Drug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Author (year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion/Exclusion Characteristics | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tocolytic Intervention | Uniform Adjunctive Drug Intervention | Uniform Non-Drug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Zuckerman H, Shalev E, Gilad G, et al. ^169^ | To test the efficacy and safety of indomethacin in suppressing PTL | Case Series; Masking: dk | PTL: Contractions, >2 per 10 min, regular and painful Successful Tocolysis: Premature contractions arrested completely for >1 wk. Partial success: uterine activity ceased 48 hrs - 7 days. | EGA: 24-34 wks Maternal age: 16-44 yrs Also no: intra-uterine growth retardation, toxemia, uterine malformation, fever, vaginal bleeding, oligohydramnios and polyhydramnios. | 297/297 | | | | | | Tx1 Indomethacin rectal suppository 100 mg CoT: initial DoT: one dose Indomethacin rectal suppository 100 mg CoT: if uterine contractions do not cease 1 hr after first treatment DoT: one dose Indomethacin oral 25 mg every 6 hrs CoT: after rectal treatment concluded DoT: until contractions were inhibited for 24 hrs | | Fetal monitoring, Maternal heart rate and blood pressure, Routine observation | Inpatient | Country: Israel Time period: dk | M=34% C=24%
  297 Intact membranes: N=252 PROM: N=45

Evidence Table 6: Tocolytic first line: Nonsteroidal Anti-inflammatory agents - Outcomes

Author (year) | Delivery | | | | | | | | | Maternal | | | | | | Infant | | | | | | | | | | | | Other Analyses | Conclusions
Author (year) | Estimated Gestational Age | | | Prolongation of Pregnancy Days | | | Gestational Weeks | | | Length of Hospital Stay | | | Maternal Morbidity | | | Birth Weight (g) | | | APGAR Score | | | Length of Hospital Stay | | | Other Infant Outcomes | | | Other Analyses | Conclusions
Author (year) | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Other Analyses | Conclusions
Gamissans O, Cañas E, Cararach J, et al. ^118^ | Mean (SEM) | | | Mean Prolongation Days Median Prolongation Days Gain in Days < 10 days 11-30 days 31-60 days >60 days p<0.05* *Difference is between all gain in days categories | | | Delivered <37 wks p<0.05 | | | | | | | | | Mean p<0.05 Median | | | APGAR <7 at 1 min p<0.02 APGAR <7 at 5 min p=NS | | | | | | Fetal and postnatal mortality p=NS Respiratory distress syndrome | | | Details presented of the cases with fetal or neonatal mortality. | Ritodrine & indomethacin showed efficacy over ritodrine & placebo: -delivery <37 wks - -APGAR <7 at 1 min
  30.54 | 30.63
  (1.04) | (0.96)
  25.93 | 41.34
  20.5 | 33.0
  10 | 2
  4 | 7
  5 | 8
  3 | 5
  14 | 7
  2367 | 2798
  2700 | 3010
  9 | 3
  4 | 2
  4 | 2
  1 | 1

Evidence Table 6: Tocolytic first line: Nonsteroidal Anti-inflammatory agents - Outcomes

Author (year) | Delivery | | | | | | | | | Maternal | | | | | | Infant | | | | | | | | | | | | Other Analyses | Conclusions
Author (year) | Estimated Gestational Age | | | Prolongation of Pregnancy Days | | | Gestational Weeks | | | Length of Hospital Stay | | | Maternal Morbidity | | | Birth Weight (g) | | | APGAR Score | | | Length of Hospital Stay | | | Other Infant Outcomes | | | Other Analyses | Conclusions
Author (year) | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Other Analyses | Conclusions
Morales WJ, Smith SG, Angel JL, et al. ^123^ | | | | Mean days p=NS >2 days p=NS >7 days p=NS | | | | | | | | | | | | Mean p=NS | | | 1 min p=NS | | | | | | Neonatal deaths p=NS | | | | Indomethacin & ritodrine did not show differences in efficacy.
  30.6 | 24.6
  94% | 83%
  75% | 70%
  2001 | 2178
  6.9 | 7.3
  3 | 3

Evidence Table 6: Tocolytic first line: Nonsteroidal Anti-inflammatory agents - Outcomes

Author (year) | Delivery | | | | | | | | | Maternal | | | | | | Infant | | | | | | | | | | | | Other Analyses | Conclusions
Author (year) | Estimated Gestational Age | | | Prolongation of Pregnancy Days | | | Gestational Weeks | | | Length of Hospital Stay | | | Maternal Morbidity | | | Birth Weight (g) | | | APGAR Score | | | Length of Hospital Stay | | | Other Infant Outcomes | | | Other Analyses | Conclusions
Author (year) | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Other Analyses | Conclusions
Kurki T, Eronen M, Lumme R, et al. (1991) | Mean (SD) p=NS | | | Mean (SD) p=NS Labor Delayed <24 hrs p=NS Labor Delayed 24-48 hrs p<.05 Labor Delayed 48-72 hrs p=NS | | | Delivery at >37 wks p<.05 | | | | | | Reported Side Effects p<.001 | | | Mean (SD) p=NS | | | <6 at 1 min p=NS <6 at 5 min p=NS | | | | | | Neonatal Deaths p=NS NRDS p=NS Intraventricular Hemorrhage p=NS Neonatal Sepsis p=NS Necrotizing Enterocolitis p=NS Respirator Treatment p=NS Symptomatic Ductal Patency p=NS | | | Gestational outcomes by tocolytic & baby born <30 wks v. >30 wks. Neonatal outcomes by tocolytic & baby born during tocolysis v. born after tocolysis. | Indomethacin showed efficacy over nylidrine: -labor delayed 24-48 hrs -delivery >37 wks -fewer maternal side effects
  36.7 | 35.2
  (0.8) | (0.8)
  65.0 | 55.9
  (4.7) | (4.1)
  100% | 100%
  96% | 76%
  90% | 73%
  70% | 43%
  20% | 83%
  2892.0 | 2558.3
  (173.9) | (152.3)
  4 | 4
  1 | 0
  1 | 0
  3 | 2
  2 | 0
  1 | 1
  1 | 0
  6 | 4
  2 | 2

Evidence Table 6: Tocolytic first line: Nonsteroidal Anti-inflammatory agents - Outcomes

Author (year) | Delivery | | | | | | | | | Maternal | | | | | | Infant | | | | | | | | | | | | Other Analyses | Conclusions
Author (year) | Estimated Gestational Age | | | Prolongation of Pregnancy Days | | | Gestational Weeks | | | Length of Hospital Stay | | | Maternal Morbidity | | | Birth Weight (g) | | | APGAR Score | | | Length of Hospital Stay | | | Other Infant Outcomes | | | Other Analyses | Conclusions
Author (year) | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Other Analyses | Conclusions
Morales WJ, Madhav H ^167^ | Mean (SD) p=NS | | | Mean (SD) p=NS | | | | | | | | | | | | Mean (SD) p=NS | | | | | | | | | | | | | No significant difference between tx w/ indomethacin & tx w/magnesium sulfate
  28.0 | 29.1
  (2.7) | (2.5)
  22.9 | 22.7
  (11.5) | (13.4)
  1808 | 2030
  (390) | (627)

Evidence Table 6: Tocolytic first line: Nonsteroidal Anti-inflammatory agents - Outcomes

Author (year) | Delivery | | | | | | | | | Maternal | | | | | | Infant | | | | | | | | | | | | Other Analyses | Conclusions
Author (year) | Estimated Gestational Age | | | Prolongation of Pregnancy Days | | | Gestational Weeks | | | Length of Hospital Stay | | | Maternal Morbidity | | | Birth Weight (g) | | | APGAR Score | | | Length of Hospital Stay | | | Other Infant Outcomes | | | Other Analyses | Conclusions
Author (year) | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Other Analyses | Conclusions
Eronen M, Pesonen E, Kurki TM et al. (1994) ^376^ | Mean (SD) p=0.049 | | | Mean (SD) p=0.4 | | | | | | | | | | | | Mean (SD) p=0.2 | | | APGAR <7 at 1 min p=0.9 APGAR <7 at 5 min p=0.5 | | | Median Days (SD) p=0.56 | | | Neonatal Deaths p=0.5 Respiratory distress syndrome p=0.2 Bronchio-pulmonary Dysplasia p=0.02 Survival with serious morbidity p=0.1 | | | | Indomethacin showed efficacy over nylidrin: - greater EGA at birth - lower rate of bronchio-pulmonary dysplasia - infant survival w/serious morbidity
  35.6 | 34.1
  (5.4) | (4.3)
  6.6 | 4.5
  2570 | | 2289
  (1191) | | (847)
  15 | 15
  9 | 6
  13.7 | 12.4
  1 | 1
  26% | 13%
  24% | 5%
  11 | 2

Evidence Table 6: Tocolytic first line: Nonsteroidal Anti-inflammatory agents - Outcomes

Author (year) | Delivery | | | | | | | | | Maternal | | | | | | Infant | | | | | | | | | | | | Other Analyses | Conclusions
Author (year) | Estimated Gestational Age | | | Prolongation of Pregnancy Days | | | Gestational Weeks | | | Length of Hospital Stay | | | Maternal Morbidity | | | Birth Weight (g) | | | APGAR Score | | | Length of Hospital Stay | | | Other Infant Outcomes | | | Other Analyses | Conclusions
Author (year) | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Other Analyses | Conclusions
Spearing G ^146^ | | | | Delivery delayed < 48 hrs p=NS Delivery delayed 48 hrs - 14 days p=NS Delivery delayed >14 days p=NS | | | | | | | | | Failed to inhibit contractions Relapse <48 hrs Relapse >48 hrs No relapse (p<0.05 for Tx1 vs. Tx2) (p=NS for Tx1 vs. Tx3) | | | Mean : <1500 g 1500-2000 g 2001-2500 g 2501-3000 g >3000 g | | | | | | Mean stay (days) | | | Mean neonatal deaths | | | Table 5 shows distribution of ruptured membranes. | Unresolved due to discontinuation to study. Insufficient statistical analysis to compare study ars. | Trial was discontinued due to the small sample and statistical analysis of doubtful value.
  10 | 4 | 5
  4 | 6 | 3
  8 | 10 | 12
  11 | 5 | 5
  4 | 1 | 3
  3 | 7 | 4
  4 | 7 | 8
  5 | 3 | 3
  4 | 3 | 4
  4 | 4 | 3
  3 | 4 | 5
  7 | 6 | 10
  5 | 2 | 1
  0 | 3 | 1

Evidence Table 6: Tocolytic first line: Nonsteroidal Anti-inflammatory agents - Outcomes

Author (year) | Delivery | | | | | | | | | Maternal | | | | | | Infant | | | | | | | | | | | | Other Analyses | Conclusions
Author (year) | Estimated Gestational Age | | | Prolongation of Pregnancy Days | | | Gestational Weeks | | | Length of Hospital Stay | | | Maternal Morbidity | | | Birth Weight (g) | | | APGAR Score | | | Length of Hospital Stay | | | Other Infant Outcomes | | | Other Analyses | Conclusions
Author (year) | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Other Analyses | Conclusions
Lewis DF, Grimshaw A, Brooks G, et al. ^165^ | | | | Mean Days p<.001 Delayed >48 hrs p<.09 | | | | | | | | | Maternal Complications | | | | | | APGAR <7 at 5 min | | | | | | | | | | Tocolysis w/magnesium sulfate, indomethacin showed relative effectiveness over magnesium sulfate: -prolongation of pregnancy days
  15.4 | 2.9
  17 | 12
  0 | 0
  3 | 3

Evidence Table 6: Tocolytic first line: Nonsteroidal Anti-inflammatory agents - Outcomes

Author (year) | Delivery | | | | | | | | | Maternal | | | | | | Infant | | | | | | | | | | | | Other Analyses | Conclusions
Author (year) | Estimated Gestational Age | | | Prolongation of Pregnancy Days | | | Gestational Weeks | | | Length of Hospital Stay | | | Maternal Morbidity | | | Birth Weight (g) | | | APGAR Score | | | Length of Hospital Stay | | | Other Infant Outcomes | | | Other Analyses | Conclusions
Author (year) | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Other Analyses | Conclusions
Zuckerman H, Reiss U, Rubinstein I ^168^ | | | | Mean prolongation (weeks) Tocolysis successful (%) Intact membranes: PROM: | | | | | | | | | Adverse drug reactions | | | <2500 g | | | | | | | | | Fetal mortality Neonatal deaths | | | Identifies success versus failure by: maternal age, parity, gestational age on admission, cervical dilation, membranes. Also shows number of patients and delay in delivery in days (<2-84). | No statistical analysis provided since only one study group.
  7
  29
  (78)
  11
  (85)
  4
  12
  1
  4

Evidence Table 6: Tocolytic first line: Nonsteroidal Anti-inflammatory agents - Outcomes

Author (year) | Delivery | | | | | | | | | Maternal | | | | | | Infant | | | | | | | | | | | | Other Analyses | Conclusions
Author (year) | Estimated Gestational Age | | | Prolongation of Pregnancy Days | | | Gestational Weeks | | | Length of Hospital Stay | | | Maternal Morbidity | | | Birth Weight (g) | | | APGAR Score | | | Length of Hospital Stay | | | Other Infant Outcomes | | | Other Analyses | Conclusions
Author (year) | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Other Analyses | Conclusions
Zuckerman H, Shalev E, Gilad G, et al. ^169^ | | | | Delivery <48 hrs Intact membranes: PROM: Delivery 48 hrs - 7 days Intact membranes: PROM: Delivery > 7 days Intact membranes: PROM: | | | <37 wks | | | | | | Adverse drug reactions | | | | | | | | | | | | Mean neonatal deaths (from NRDS) | | | | No statistical analysis provided since only one study arm.
  5
  (2%)
  16
  (36%)
  25
  (10%)
  5
  (11%)
  222
  (88%)
  24
  (53%)
  51
  8
  15

Evidence Table 7: Tocolytic first line: Other - Study design

Author (year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion/Exclusion Characteristics | Sample Size Initial/End | | | Demographic Characteristics | | | Tocolytic Intervention | Uniform Adjunctive Drug Intervention | Uniform Non-Drug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Author (year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion/Exclusion Characteristics | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tocolytic Intervention | Uniform Adjunctive Drug Intervention | Uniform Non-Drug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Castrén O, Gummerus M, Saarikoski ^144^ | To compare and adequate series of patients and the drugs most generally used in imminent premature labor | RCT; Masking: Subject, physician: none Pharm., other care providers: dk | PTL: Contractions: "active" contractions verified by tocography Successful Tocolysis: premature contractions arrested and the pregnancy prolonged such that was >2500 or (PTL postponed for >7 days and pregnancy continued until >37^th^ week) | EGA: 24-36 wks Intact membranes | 194/194 | | | | | | Tx1 Nylidrin IV 50 mg in 500 ml of 5% glucose, at a rate of 0.2 mg/min CoT: on admission DoT: 1 hr Nylidrin IV 0.1 mg/min CoT: after initial infusion DoT: 5 hrs Nylidrin intramuscularly 5 mg CoT: immediately following last dose DoT: once Nylidrin intramuscularly 5 mg/3 hrs CoT: immediately following last dose DoT: 3 times Nylidrin intramuscularly 5 mg/5 hrs CoT: immediately following last dose DoT: 48 hrs Nylidrin intramuscularly 6 mg/5 hrs CoT: immediately following last dose DoT: dk Tx2 Isoxuprine IV 100 mg in 500 ml of 5% glucose, rate of 0.4 mg/min CoT: on admission DoT: 1 hr Isoxuprine IV 25 mg CoT: after initial dose DoT: once Isoxuprine intramuscularly 10 mg/3 hrs CoT: following last dose DoT: 4 doses Isoxuprine intramuscularly 10 mg/4 hrs CoT: following last dose DoT: 48 hrs Isoxuprine intramuscularly 10 mg/4 hrs CoT: following last dose DoT: continued at home, duration: dk Tx3 Ethanol solution IV 96 ml of 96% ethanol in 1000 ml of 5% glucose, at rate of 0.8 ml/min CoT: on admission DoT: 2 hrs Ethanol solution IV 0.13 ml/min CoT: following last dose DoT: 4 hrs Cognac oral 40 ml/6 hrs CoT: dk DoT: dk Cx Placebo given according to same schedule as Tx1 | | Fetal monitoring, routine observation | Inpatient | Country: Finland Time period: dk | M=50% C=58%
  Tx1(n=43) Tx2 (n=60) Tx3 (n=50) Cx (n=41)

Evidence Table 7: Tocolytic first line: Other - Study design

Author (year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion/Exclusion Characteristics | Sample Size Initial/End | | | Demographic Characteristics | | | Tocolytic Intervention | Uniform Adjunctive Drug Intervention | Uniform Non-Drug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Author (year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion/Exclusion Characteristics | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tocolytic Intervention | Uniform Adjunctive Drug Intervention | Uniform Non-Drug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Lauersen NH, Merkatz IR, Tejani N, et al. ^117^ | To compare the effectiveness and acceptability of ethanol versus ritodrine in a randomized controlled multicenter study. | RCT; Masking: none | Contractions: 1/10 min, lasting 30-60 sec each and Cervical effacement and Dilation< 4 cm Successful Tocolysis: Delivery postponed for more than 72 hrs | EGA: 20-36 wks Estimated Fetal Weight <2500g Intact Membranes Uterine fundus above the umbilicus Also no: bulging membranes, premature separation of the placenta, preeclampsia, chronic renal disease, chronic hypertension, cardiac disease, diabetes mellitus, other severe maternal diseases, dead or malformed fetus, placenta previa (if bleeding is severe enough to require intervention), maternal or fetal complications which require immediate delivery | 150/135 | | | Mean Age (SD) Race, White Race, Non-white | | | Tx1 Ethanol IV 7.5 ml/kg/hr (10% in 5% dextrose in water) CoT: after diagnosis and 30 min of observation DoT: 2 hrs Ethanol IV 1.5 ml/kg/hr CoT: after initial dose DoT: 10 hrs or more Ethanol IV dose: variable, up to 2 add. courses of tx CoT: upon reoccurrence of labor DoT: same as above Tx2 Ritodrine IV 50 µg/min, increasing by 50 µg every 10 min, maximum 350 µg, until uterine relaxation (or decreased if disturbing palpitations or maternal heart rate over 120 beats/min observed) CoT: after diagnosis and 30 min of observation DoT: 12 hrs Ritodrine oral 10 µg every 2 hrs CoT: 30 min before end of IV infusion DoT: 24 hrs Ritodrine oral 20-60 µg daily CoT: after discharge DoT: 4 wks or until 38 wks gestation Ritodrine IV, up to 2 repeat courses CoT: upon reoccurrence of labor while on oral ritodrine DoT: same as above | | Bedrest, Uterine monitoring, Fetal monitoring | Weekly clinic or physician visits | Country: United States Time period: dk | M=75% C=71%
  67 | 68
  23.6 | 23.9
  (5.8) | (5.2)
  25 | 22
  42 | 46

Evidence Table 7: Tocolytic first line: Other - Study design

Author (year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion/Exclusion Characteristics | Sample Size Initial/End | | | Demographic Characteristics | | | Tocolytic Intervention | Uniform Adjunctive Drug Intervention | Uniform Non-Drug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Author (year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion/Exclusion Characteristics | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tocolytic Intervention | Uniform Adjunctive Drug Intervention | Uniform Non-Drug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Sims CD, Chamberlain GVP, Boyd IE, et al. ^145^ | To compare IV salbutanol & ethanol as treatments for PTL. | RCT; Masking: Subject, none Physician, pharm., other care providers: dk | PTL: Contractions: history of >6/hr Successful Tocolysis: stopping contractions | EGA: 27-35 wks Maternal age: >15 yrs Also no: abruptio placentae, fulminating pre-eclampsia, intrauterine growth retardation, dilation > 4 cm, multiple gestation, placenta previa | 100/88 | | | | | | Tx1 Salbutamol IV 4mg in 500 ml of 5% dextrose in water, administered at 5 µg/min and increased by 5 µg/10 min CoT: initial tx DoT: until contractions abolished or max of 50 µg/min reached or unacceptable side effects occurred Salbutamol IV, lowest dose from above to stop contractions CoT: after initial treatment DoT: 12 hrs (or 24 for those with PROM, if the cervix showed progressive dilation, or contractions were not abolished) (If contractions reappeared, the treatment was repeated) Tx2 Ethanol IV 10% ethanol in 5% dextrose in water rate of 15 ml/kg of body weight CoT: initial tx DoT: 2 hrs Ethanol IV 1.5 ml.kg body weight/hr CoT: after initial 2 hrs DoT: 10 hrs (If contractions reappeared, the treatment was repeated) | Betamethasone AoT: patients randomized and either received betamethasone or placebo intramuscularly to determine whether it had any influence on the development of respiratory distress syndrome in preterm infants | | | Country: England Time period: dk | M=32% C=44%
  42 | 46

Evidence Table 7: Tocolytic first line: Other - Study design

Author (year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion/Exclusion Characteristics | Sample Size Initial/End | | | Demographic Characteristics | | | Tocolytic Intervention | Uniform Adjunctive Drug Intervention | Uniform Non-Drug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Author (year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion/Exclusion Characteristics | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tocolytic Intervention | Uniform Adjunctive Drug Intervention | Uniform Non-Drug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Caritis SN, Carson D, Greenbon D, et al. ^148^ | To compare terbutaline and ethanol to determine the relative efficacy and safety of these agents in women with PTL | RCT; Masking: Subject, physician: none Pharm., other care providers: dk | Contractions:>1 every 5-7 min as documented by a tocodynamometer, each contraction lasting >30 sec for at least 1 hr Successful Tocolysis: If intact membrane: "Complete success": pregnancy >36 wks, "Partial success": mature lecithin/sphingomyelin (L/S) ratio obtained or a full course of betamethasone is given. If PROM: delayed delivery for 36 hrs to administer betamethasone. | EGA: 20-36 wks or 24-34 wks for PROM; Also no: obstetrical or medical contraindications to the inhibition of labor (including maternal hypertension, diabetes mellitus, heart disease, hyperthyroidism), preeclampsia or eclampsia, abruptio placentae, chorioamnionitis, abnormal or dead fetus, cervical dilation >5 cm, other tocolytic use in this pregnancy | 92/85 Intact Membrane PROM | | | | | | Tx1 Terbutaline IV 5 µg/min, increased by 5 µg/min every 20 min to max dose 30 µg/min CoT: dk DoT: 1 hr after contractions stop or if side effects Terbutaline IV 5-10 µg/min CoT: after loading dose, for those without side effects DoT: 8 hrs Terbutaline oral 5 µg/min (intact membranes only) CoT: for those whose labor was successfully inhibited, received drug 30 min before end of IV maintenance infusion DoT: 4 times daily for 5 days Tx2 Ethanol IV 7.5 ml/kg/hr of 10% ethanol in 5% dextrose CoT: dk DoT: 2 hrs Ethanol IV 1.5 ml/kg.hr CoT: after loading dose DoT: 10 hrs Ethanol IV Reloading dose reduced by 10% for each hr less than 10 elapsing from the end of the previous maintenance infusion CoT: after maintenance infusion if labor reoccurs DoT: dk Magnesium Sulfate if ethanol intolerance led to discontinuation of treatment & patient continues to experience labor or if patient refuses to be treated with the assigned drug for a recurrent episode of PTL. | Betamethasone AoT: to enhance fetal lung maturation | | Inpatient | Country: United States Time period: 1979-1980 | M=60% C=71%
  28 | 28
  17 | 12

Evidence Table 7: Tocolytic first line: Other - Study design

Author (year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion/Exclusion Characteristics | Sample Size Initial/End | | | Demographic Characteristics | | | Tocolytic Intervention | Uniform Adjunctive Drug Intervention | Uniform Non-Drug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Author (year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion/Exclusion Characteristics | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tocolytic Intervention | Uniform Adjunctive Drug Intervention | Uniform Non-Drug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Schröck A, Fidi C, Löw M, et al. ^170^ | To test the efficacy of low doses of ethanol infused alone or in combination with beta-mimetics to arrest preterm labor and prevent pretrem labor. Successful tocolysis: uterine contractions stopped or reduced to 2. | Prospective cohort; Masking: none | Contractions: >3/10 min and Dilation:<3 cm and Other:Bishop score >4 | EGA: 20-36 wks Intact membranes | 54/54 | | | | | | Tx1 Ethanol intravenous 10% solution in 5% dextrose 60 ml/hr (increased to 90 ml/hr or 120 ml/hr if needed) CoT: dk DoT: 12 hrs then decrease by 30 ml/hr every 12 hrs until 36 wks or side effects Tx2 Ritodrine intravenous 0.2 mg/min CoT: dk DoT: until labor stopped, 0.5-199 hrs Ethanol intravenous 10% solution in 5% dextrose 60 ml/hr (increased to 90 ml/hr or 120 ml/hr if needed) CoT: dk DoT: 12 hrs then decrease by 30 ml/hr every 12 hrs until 36 wks or side effects | | Fetal monitoring, uterine monitoring | | Country: dk Time period: dk | M=30% C=27%
  14 | 40

Evidence Table 7: Tocolytic first line: Other - Study design

Author (year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion/Exclusion Characteristics | Sample Size Initial/End | | | Demographic Characteristics | | | Tocolytic Intervention | Uniform Adjunctive Drug Intervention | Uniform Non-Drug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Author (year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion/Exclusion Characteristics | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tocolytic Intervention | Uniform Adjunctive Drug Intervention | Uniform Non-Drug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Goodwin TM, Valenzuela G, Silver H, et al. (1996) | Multisite study to describe the course of PTL in patients receiving a standard infusion of atosiban (300 µg/min) & to describe any adverse side effects. | Prospective Cohort Study; Masking: none | PTL: Contractions:>6 per hr and Cervical change:>1 cm change in dilation or length (3 sites), "some" change in dilation or effacement (1 site) Successful tocolysis: the absence of 1) unplanned delivery w/in 48 hrs of starting atosiban and 2) the need for an alternative tocolytic | EGA: 20-36 wks Intact membranes Also no: current bleeding, dilation >3 cm, fetal distress, PROM, fetal demise, systemic or uterine infection, major medical disorders, prior tocolytic therapy, contractions < 6/hr, no cervical change | 62/61 | | | Age (SD) Race White: 19.4% Black: 14.5% Hispanic: 61.3% Other: 4.8% | | | Tx1 Atosiban IV 300 µg/min CoT: dk DoT: until no contractions for 6 hrs or up to 12 hrs of tx Alternative tocolytic Dose not stated CoT: if atosiban inadequate DoT: not stated | | | | Country: United States Time period: dk | M=58% C=35%
  61
  23.5
  (5.7)

Evidence Table 7: Tocolytic first line: Other - Outcomes

Author (year) | Delivery | | | | | | | | | Maternal | | | | | | Infant | | | | | | | | | | | | Other Analyses | Conclusions
Author (year) | Estimated Gestational Age | | | Prolongation of Pregnancy Days | | | Gestational Weeks | | | Length of Hospital Stay | | | Maternal Morbidity | | | Birth Weight (g) | | | APGAR Score | | | Length of Hospital Stay | | | Other Infant Outcomes | | | Other Analyses | Conclusions
Author (year) | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Tx3 | Tx1 | Tx2 | Tx3 | Tx1 | Tx2 | Tx3 | Tx1 | Tx2 | Tx3 | Other Analyses | Conclusions
Castrén O, Gummerus M, Saarikoski ^144^ | | | | Postponed >7 days and attained at least 37 wks | | | | | | | | | | | | Birth weight >2500 g | | | | | | | | | Neonatal deaths | | | Summarizes success of treatment by week of gestation at onset of tx, showing that results are better the further the gestation had progressed at the time of treatment. | No statistical analysis provided comparing study arms.
  Tx1 | Tx2 | Tx3 | Cx
  33 | 37 | 28 | 30
  (77%) | (62%) | (56%) | (73%)
  Tx1 | Tx2 | Cx | Tx3
  37 | 45 | 29 | 35
  (86%) | (75%) | (71%) | (70%)
  Tx1 | Tx2 | Tx3 | Cx
  5 | 5 | 5 | 3

Evidence Table 7: Tocolytic first line: Other - Outcomes

Author (year) | Delivery | | | | | | | | | Maternal | | | | | | Infant | | | | | | | | | | | | Other Analyses | Conclusions
Author (year) | Estimated Gestational Age | | | Prolongation of Pregnancy Days | | | Gestational Weeks | | | Length of Hospital Stay | | | Maternal Morbidity | | | Birth Weight (g) | | | APGAR Score | | | Length of Hospital Stay | | | Other Infant Outcomes | | | Other Analyses | Conclusions
Author (year) | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Tx3 | Tx1 | Tx2 | Tx3 | Tx1 | Tx2 | Tx3 | Tx1 | Tx2 | Tx3 | Other Analyses | Conclusions
Lauersen NH, Merkatz IR, Tejani N, et al. ^117^ | | | | Mean Prolongation Days (SD) Singleton births Multiple births Prolonged > 3 days Singleton births: p<0.05 Multiple births: p>0.05 | | | Delivered <29 wks Singleton births: Multiple births: Delivered 30-33 wks Singleton births: Multiple births: Delivered 34-37 wks Singleton births: Multiple births: Delivered >37 wks Singleton births: Multiple births: | | | | | | | | | Birth weight: <1500 g Singleton births: Multiple births: 1500-2500 g Singleton births: Multiple births: >2500 g Singleton births: p<0.01 Multiple births: | | | | | | | | | Fetal Mortality NRDS | | | Some results are given by center site. | Insufficient statistical analysis provided to compare relative efficacy of treatments.
  26.6 | 46.2
  (3.4) | (4.1)
  30.7 | 22.0
  (9.2) | (6.0)
  41 | 8
  56 | 5
  6 | 3
  0 | 0
  11 | 6
  2 | 1
  20 | 20
  2 | 3
  21 | 33
  5 | 2
  8 | 3
  3 | 2
  24 | 13
  9 | 9
  26 | 44
  6 | 1
  7 | 3
  15 | 6

Evidence Table 7: Tocolytic first line: Other - Outcomes

Author (year) | Delivery | | | | | | | | | Maternal | | | | | | Infant | | | | | | | | | | | | Other Analyses | Conclusions
Author (year) | Estimated Gestational Age | | | Prolongation of Pregnancy Days | | | Gestational Weeks | | | Length of Hospital Stay | | | Maternal Morbidity | | | Birth Weight (g) | | | APGAR Score | | | Length of Hospital Stay | | | Other Infant Outcomes | | | Other Analyses | Conclusions
Author (year) | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Tx3 | Tx1 | Tx2 | Tx3 | Tx1 | Tx2 | Tx3 | Tx1 | Tx2 | Tx3 | Other Analyses | Conclusions
Sims CD, Chamberlain GVP, Boyd IE, et al. ^145^ | | | | Mean Prolongation Days (SD) Prolongation of Delivery: <24 hrs >48 hrs Prolongation Index * *# of days delivery delayed as a % of EGA at onset of tx | | | >37 wks | | | | | | | | | | | | | | | | | | Neonatal deaths | | | Analysis of hours, days, and weeks prolonged by salbutamol and ethanol, with and without the use of steroids; delivery delay of women w/intact membranes and dilatation <2 cm. | No statistical analysis provided comparing study arms.
  239 | 244
  (25) | (25)
  15.0 | 20.4
  (24.5) | (24.0)
  35 | 34
  20 | 26
  6.9 | 9.4
  (11.5) | (11.3)
  10 | 14
  4 | 10

Evidence Table 7: Tocolytic first line: Other - Outcomes

Author (year) | Delivery | | | | | | | | | Maternal | | | | | | Infant | | | | | | | | | | | | Other Analyses | Conclusions
Author (year) | Estimated Gestational Age | | | Prolongation of Pregnancy Days | | | Gestational Weeks | | | Length of Hospital Stay | | | Maternal Morbidity | | | Birth Weight (g) | | | APGAR Score | | | Length of Hospital Stay | | | Other Infant Outcomes | | | Other Analyses | Conclusions
Author (year) | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Tx3 | Tx1 | Tx2 | Tx3 | Tx1 | Tx2 | Tx3 | Tx1 | Tx2 | Tx3 | Other Analyses | Conclusions
Caritis SN, Carson D, Greenbon D, et al. ^148^ | Mean (SD) Intact Membranes PROM | | | Mean Prolongation Days (SD) Intact Membranes (P<0.05) | | | Delivery at >36 wks Intact Membranes Delivery as "partial success" Intact Membranes (P<0.025) Delivery as "failure" Intact Membranes (P<0.025) Delivery as "success" PROM | | | | | | | | | Mean (SD) PROM EGA <28 wks at entry Intact Membranes EGA >28<32 wks at entry Intact Membranes EGA >32 wks at entry Intact Membranes | | | <7 at 1 min PROM <7 at 5 min | | | | | | # of Neonatal Deaths Intact Membranes PROM # of Fetal Deaths Intact Membranes PROM Hyaline Membrane Disease Intact membranes PROM | | | Separate analysis for PROM | Terbutaline showed efficacy over ethanol: -mean prolongation days (intact membranes) -delivery as "partial success" (intact membranes) (see def. of successful tocolysis)
  30 | 31
  (3) | (3)
  31 | 31
  (2) | (2)
  15 | 10
  (3.7) | (3.2)
  5 | 5
  18 | 8
  5 | 15
  12 | 7
  (71%) | (58%)
  1,565 | 1,531
  (436) | (487)
  921 | 1,137
  (269) | (602)
  2032 | 1,907
  (612) | (713)
  2,367 | 2,402
  (237) | (766)
  7 | 6
  1 | 3
  6 | 2
  3 | 4
  2 | 1
  0 | 0
  9 | 9
  7 | 7

Evidence Table 7: Tocolytic first line: Other - Outcomes

Author (year) | Delivery | | | | | | | | | Maternal | | | | | | Infant | | | | | | | | | | | | Other Analyses | Conclusions
Author (year) | Estimated Gestational Age | | | Prolongation of Pregnancy Days | | | Gestational Weeks | | | Length of Hospital Stay | | | Maternal Morbidity | | | Birth Weight (g) | | | APGAR Score | | | Length of Hospital Stay | | | Other Infant Outcomes | | | Other Analyses | Conclusions
Author (year) | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Tx3 | Tx1 | Tx2 | Tx3 | Tx1 | Tx2 | Tx3 | Tx1 | Tx2 | Tx3 | Other Analyses | Conclusions
Schröck A, Fidi C, Löw M, et al. ^170^ | | | | | | | | | | | | | Successful tocolysis | | | | | | | | | | | | | | | By successful tocolysis | No statistical analysis provided comparing study arms.
  11 | 32

Evidence Table 7: Tocolytic first line: Other - Outcomes

Author (year) | Delivery | | | | | | | | | Maternal | | | | | | Infant | | | | | | | | | | | | Other Analyses | Conclusions
Author (year) | Estimated Gestational Age | | | Prolongation of Pregnancy Days | | | Gestational Weeks | | | Length of Hospital Stay | | | Maternal Morbidity | | | Birth Weight (g) | | | APGAR Score | | | Length of Hospital Stay | | | Other Infant Outcomes | | | Other Analyses | Conclusions
Author (year) | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Tx3 | Tx1 | Tx2 | Tx3 | Tx1 | Tx2 | Tx3 | Tx1 | Tx2 | Tx3 | Other Analyses | Conclusions
Goodwin TM, Valenzuela G, Silver H, et al. (1996) | see other analyses | | | see other analyses | | | <37 wks | | | | | | Adverse Drug Reactions Contractions stopped Contractions decreased 50% Successful tocolysis | | | Mean (SD) | | | | | | | | | Respiratory Distress Grade II Intraventricular Hemorrhage Neonatal Sepsis Pneumonia Hyper-bilirubinemia PDA Facial petechiae Apnes bradycardia Poor feeder SGA Any complications | | | 1) Successful tocolysis by EGA at entry: % of group w/successful tocolysis declined as EGA increased. 2) Successful tocolysis by dilation at entry: % of group w/successful tocolysis declined w/increasing dilation. 3) Mean EGA at delivery & Mean interval to delivery by EGA at treatment: a) 20 - <28 wks, b) 28- <32 wks, c) 32-36 wks Mean EGA at delivery: a) 37.8 (4.7) b) 36.8 (3.5) c) 37.4 (2.3) Mean interval to delivery: a) 11.8 (5.0) b) 6.4 (4.0) c) 3.4 (2.7) | No statistical analysis provided since one study arm.
  36.2%
  6.5%
  62.3%
  82%
  70.5%
  2827
  (744)
  10%
  1.7%
  1.7%
  3.3%
  15%
  3.3%
  1.7%
  5.0%
  1.7%
  3.3%
  25%

Evidence Table 8: Tocolytic maintenance: Beta-mimetics - Study design

Author (year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion/Exclusion Characteristics | Sample Size Initial/End | | | Demographic Characteristics | | | Tocolytic Intervention | Uniform Adjunctive Drug Intervention | Uniform Non-Drug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Author (year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion/Exclusion Characteristics | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tocolytic Intervention | Uniform Adjunctive Drug Intervention | Uniform Non-Drug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Creasy RK, Golbus MS, Laros RK, et al. ^40^ | To determine the efficacy of oral ritodrine in the prevention of recurrent PTL once the initial episode has been controlled by intramuscular ritodrine treatment | RCT; Masking: Subject, physician: yes Pharm., other care providers: dk | PTL: Contractions: 3-4/20 min and Dilation: change from baseline Successful tocolysis is not defined | EGA: 20-36 wks Intact Membranes live fetus w/estimated weight <2500g Also no: dilation >3-4 cm, maternal fever, erythro-blastosis fetalis, cardiovascular/hypertensive disorders, active thyroid disease, diabetes mellitus, known drug addiction, abnormal vaginal bleeding | 59/55 | | | Mean Age (n=70) (SD) | | | Tx1 & Cx Ritodrine intramuscularly 5-10 mg every 2-4 hrs CoT: initial DoT: 24 hrs or beyond Tx1 Ritodrine oral 10-20 mg CoT: 2 hrs after last ritodrine injection DoT: until 37-38 wks Cx Placebo oral identical tablets | | Bedrest, fetal monitoring, routine observation, uterine monitoring | | Country: United States Time period: dk | C=74% M=73%
  27 | | 28
  25.4 | | 26.0
  (0.8) | | (0.9)

Evidence Table 8: Tocolytic maintenance: Beta-mimetics - Study design

Author (year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion/Exclusion Characteristics | Sample Size Initial/End | | | Demographic Characteristics | | | Tocolytic Intervention | Uniform Adjunctive Drug Intervention | Uniform Non-Drug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Author (year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion/Exclusion Characteristics | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tocolytic Intervention | Uniform Adjunctive Drug Intervention | Uniform Non-Drug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Brown SM and Tejani NA ^172^ | To determine if recurrences of PTL may be prevented or postponed by prolonged oral use of a beta-mimetic agent, terbutaline sulfate, after initial therapy with ethanol | RCT; Masking: Subject, physician: yes Pharm., other care provider: dk | PTL: Contractions: Painful uterine contractions at intervals of <5 minutes Successful tocolysis is not defined. | EGA: 24 to 36 wks, Intact Membranes Also no: dilation >4 cm, placenta previa, abnormal fetal heart rate patterns, abruptio placentae, fetal complications requiring immediate delivery, IUGR | 51/46 | | | Mean Age Race, White Race, Black Race, Hispanic | | | Tx1 & Cx Ethanol IV 15 ml/kg body weight for 2 hrs CoT: loading dose EthanolIV 1.5 ml/kg/hr CoT: after loading dose DoT: 10 hrs Tx1 Terbutaline oral 5 mg CoT: 2 hrs before maintenance ethanol ended DoT: every 6 hrs until 38^th^ wk of gestation or unrelenting labor Cx Placebo oral Tx1 & Cx Cycle repeated if PTL recurred & no contraindication | Compazine intramuscularly 10 mg AoT: dk | Bedrest, fetal monitoring, routine observation, uterine monitoring | | Country: dk Time period: dk | M=71% C=72%
  23 | | 23
  23.5 | | 29.5
  7 | | 11
  15 | | 12
  1 | | 0

Evidence Table 8: Tocolytic maintenance: Beta-mimetics - Study design

Author (year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion/Exclusion Characteristics | Sample Size Initial/End | | | Demographic Characteristics | | | Tocolytic Intervention | Uniform Adjunctive Drug Intervention | Uniform Non-Drug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Author (year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion/Exclusion Characteristics | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tocolytic Intervention | Uniform Adjunctive Drug Intervention | Uniform Non-Drug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Kopelman JN, Duff P, Read JA ^173^ | To evaluate the long-term use of oral ritodrine & terbutaline for the prevention of recurrent preterm labor | RCT; Masking: subject, physician, other care givers: dk | PTL: (Contractions: irregular and Dilation & Effacement)or Contractions: >8/hr for 1 hr For either def., contractions must continue for 8-12 hrs following 1 .25mg of terbutaline Successful tocolysis: not defined | EGA: 20-35 wks Also no: chorioamnionitis, dilation >5 cm, complete effacement, lethal fetal anomolies | 102/91 | | | Mean age (SD) White | | | Tx1 & Tx2 Ritodrine IV 50 µg/min increased by 50 µg every 10 min CoT: after initial terbutaline tx DoT: until cessation of contractions or intolerable side effects Magnesium sulfate IV 4g/20 min followed by 2-4g/h CoT: if ritodrine discontinued DoT: until cessation of contractions for 12 hrs Tx1 Ritodrine oral 10 mg/2hr CoT: 30 min before discontinuing initial tx DoT: 24 hrs Ritodrine oral 20 mg/4hr CoT: after 24 hr ritodrine tx DoT: until 36 wks gestation Tx2 Terbutaline oral 2.5 mg/2h CoT: 30 min before discontinuing initial tx DoT: 24 hr Terbutaline oral 5.0 mg/4h CoT: after 24 hr terbutaline tx DoT: until 36 wks gestation | Betamethasone: fetal lung development | Bedrest, fetal monitoring, routine observation, uterine monitoring, amniocentesis | | Country: United States Time Period: 1984-1986 | M=64% C=38%
  42 | 49
  22.6 | 24.3
  (3.9) | (4.7)
  55% | 67%

Evidence Table 8: Tocolytic maintenance: Beta-mimetics - Study design

Author (year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion/Exclusion Characteristics | Sample Size Initial/End | | | Demographic Characteristics | | | Tocolytic Intervention | Uniform Adjunctive Drug Intervention | Uniform Non-Drug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Author (year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion/Exclusion Characteristics | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tocolytic Intervention | Uniform Adjunctive Drug Intervention | Uniform Non-Drug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Ridgway LE, Muise K, Wright JW, et al. ^174^ | To compare oral magnesium oxide with oral terbutaline sulfate in the maintenance of tocolysis | RCT; Masking: dk | PTL: Contractions: >3 in 20 min. that persisted despite IV hydration (500 ml saline) and prolonged sedation (8-20 mg morphine sulfate) and Cervical change Successful Tocolysis: not defined | EGA: 25-35 wks | 60/50 | | | Mean Age (SD) p=NS Median Education Level, Years p=NS | | | Tx1 & Tx2 Tocolytic IV (Choice of drug at physician discretion) CoT: initial DoT: uterine quiescence for 12-24 hrs Tx1 Terbutaline sulfate oral 2.5-5 mg every 3-4 hrs CoT: 12-24 hrs after successful tocolysis DoT: 36 wks gestation Tx2 Magnesium oxide oral 200 mg every 3-4 hrs CoT: 12-24 hrs after successful tocolysis DoT: 36 wks gestation Tx1 & Tx2 Those with recurrent preterm labor received parenteral therapy, if successful randomized back into their initial drug. | Morphine sulfate AoT: sedation | First 24 hrs strict bedrest, light ambulation on 2^nd^ day, IV fluids | Inpatient, Outpatient: weekly visits or if missed, phone call | Country: United States Time period: dk. | M=60% C=60%
  27 | 23
  22.9 | 24.1
  (5.8) | (7.1)
  12 | 11

Evidence Table 8: Tocolytic maintenance: Beta-mimetics - Study design

Author (year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion/Exclusion Characteristics | Sample Size Initial/End | | | Demographic Characteristics | | | Tocolytic Intervention | Uniform Adjunctive Drug Intervention | Uniform Non-Drug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Author (year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion/Exclusion Characteristics | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tocolytic Intervention | Uniform Adjunctive Drug Intervention | Uniform Non-Drug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
van Assche A, Thoumsin H, HendrickxB ^182^ | To demonstrate that oral sustained-release ritodrine administered after an intravenous perfusion results in a prolongation of the gestation; to assess the side effects; and to evaluate patient compliance | Prospective cohort; Masking: none | PTL: Baumgarten tocolytic index >3 Successful tocolysis: not defined | EGA: 20-35 wks Also no:abnormal fetus, chorioamnionitis, current bleeding/hemorrhage, hypertensive disorders, cardiac disease, intra-uterine infection, fetal death, condition contraindicating prolongation of pregnancy, receiving concurrent therapy with other β-sympathicomimetic drugs, βblockers, progestatives or prostaglanding inhibitors | 45/41 | | | Age (SD) | | | Tx1 Ritodrine intravenous 100 µg/hr (increased to 200 µg/hr if needed) CoT: dk DoT: 24 hrs after tocolysis or if dose exceeded 100 µg/hr, stepwise reduced by 50 µg/ 24 hrs until 100 µg/hr Ritodrine oral 40 mg every 8 hr CoT: one hr before stopping ritodrine transfusion DoT: 36 wks gestation | | | | Country: dk Time period: dk | M=32% C=27%
  41
  26.7
  (4.56)

Evidence Table 8: Tocolytic maintenance: Beta-mimetics - Study design

Author (year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion/Exclusion Characteristics | Sample Size Initial/End | | | Demographic Characteristics | | | Tocolytic Intervention | Uniform Adjunctive Drug Intervention | Uniform Non-Drug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Author (year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion/Exclusion Characteristics | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tocolytic Intervention | Uniform Adjunctive Drug Intervention | Uniform Non-Drug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Bivins HA, Newman RB, Fyfe DA, et al. ^181^ | To determine the efficacy and safety of long-term oral tocolysis with indomethacin or terbutaline | RCT; Masking: none | PTL: (Contractions:>4/20 min and Cervical change) or Dilation:>2 cmor Effacement:> 80% Successful tocolysis: not defined | EGA: 26-32 wks Singleton Intact membrane Also: cervix <4 cm dilated, no: abnormal fetus, allergy to protocol drug, chorioamnionitis, multiple gestation, placenta previa, rupture of membranes, abruptio placentae, oligohydranios (amniotic fluid index <7cm), insulin-dependent diabetes, allergy to aspirin | 71/63 | | | Mean Age (SD) Race, White (%) Race, Black (%) | | | Tx1 & Tx2 MgSO_4_ IV dose: dk CoT: initially & if recurrent PTL DoT: 12 hrs initially & 24 hrs recurrent Tx1 Indomethacin oral 25 mg CoT: after MgSO_4_ DoT: every 6 hrs until 34 wks gestation Terbutaline sulfate oral 5mg CoT: if evidence of fetal ductal constriction, oligohydramniosis, or achieved 34 wks gestation DoT: 37 wks gestation Tx2 Terbutaline sulfate oral 5mg CoT: after MgSO_4_ DoT: every 4 hrs, 37 wks gestation Indomethacin oral 25 mg CoT: if intolerable β-mimetic adverse affects on terbutaline DoT: every 6 hrs until 34 wks gestation | | Routine observation | | Country: United States Time period: dk | M=75% C=74%
  33 | 32
  22.3 | 21.6
  (5.1) | (4.6)
  6 | 9
  (18.2) | (28.1)
  27 | 23
  (81.8) | (71.9)

Evidence Table 8: Tocolytic maintenance: Beta-mimetics - Study design

Author (year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion/Exclusion Characteristics | Sample Size Initial/End | | | Demographic Characteristics | | | Tocolytic Intervention | Uniform Adjunctive Drug Intervention | Uniform Non-Drug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Author (year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion/Exclusion Characteristics | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tocolytic Intervention | Uniform Adjunctive Drug Intervention | Uniform Non-Drug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Parilla BV, Dooley SL, Minogue JP et al. ^175^ | To determine the efficacy of oral tocolytic therapy after successful intravenous tocolysis in reducing the rate of preterm birth. | RCT; Masking: dk | PTL: Contractions: Regular for at least 1 hrand Dilation:> 1 cm decrease in length (or to complete effacement) or > 1 cm increase at the internal os or > 2 cm decrease w/out dilation or > 2 cm increase at the internal os w/out effacement Successful tocolysis: not defined | EGA: 28-35 wks Intact membranes Also no: Abnormal fetus, chorioamnionitis, current bleeding, dilation >4 cm, severe intrauterine growth retardation, nonreassuring fetal heart rate pattern | 55/55 | | | Mean Age (SD) White Black Other | | | Tx1 & Cx Magnesium Sulfate IV 8g for 1^st^ hr, 4g for 2^nd^ hr CoT: initial DoT: 2 hrs Magnesium Sulfate IV 2.5g/hr, increased by .5g/hr every hr until 3.5g/hr reached CoT: after initial DoT: 12 hrs after cessation of contractions Tx1 Terbutaline oral dose adjusted to achieve a maternal pulse >100 beats/min CoT: 30 min before discontinuation of mag sulfate DoT: 36 wks gestation Cx No treatment | | Bedrest, routine observation | | Country: United States Time Period: 1991-1992 | M=62% C=68%
  28 | | 27
  22.1 | | 23.6
  (4.5) | | (5.5)
  4 | | 3
  16 | | 17
  8 | | 7

Evidence Table 8: Tocolytic maintenance: Beta-mimetics - Study design

Author (year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion/Exclusion Characteristics | Sample Size Initial/End | | | Demographic Characteristics | | | Tocolytic Intervention | Uniform Adjunctive Drug Intervention | Uniform Non-Drug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Author (year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion/Exclusion Characteristics | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tocolytic Intervention | Uniform Adjunctive Drug Intervention | Uniform Non-Drug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
How HY, Hughes SA, Vogel RL et al. ^176^ | To test the hypothesis that once PTL is controlled w/ IV tocolysis, oral terbutaline, as a maintenance drug, does not prolong pregnancy. Tx1: Bishop score > 5 w/ oral terbutaline Tx2: Bishop score <5 w/ oral terbutaline Cx1: Bishop score > 5 w/ no oral terbutaline Cx2: Bishop score <5 w/ no oral terbutaline | RCT; Masking: Subject, physician: no | PTL: Contractions:> 6/hr, unresponsive to hydration or Dilation &/or Effacement: progressive or Dilation:> 2 cm & 50% Effacement &Contractions Successful tocolysis: not defined | EGA: 24-35 wks Intact membranes Also no: placenta previa, premature termination for obstetric indications, inability to reliably assess cervical change | 212/184 Cx1=53 Cx2=40 | | | Mean Age (SD) Nonwhite | | | Tx1, Tx2, Cx1, Cx2 Magnesium Sulfate IV 6g CoT: initial DoT: loading dose Magnesium Sulfate IV 2-5g/hr CoT: after loading dose DoT: uterine quiescence for 12-24 hrs Terbutaline oral CoT: after mag tx DoT: 12-24 hrs Tx1 & Tx2 Terbutaline oral 5-10 mg every 4-6 hr CoT: after initial terbutaline tx DoT: until 37 wks gestation | Betamethasone AoT: fetal lung development Ampicillin or clindamycin AoT: group b strep | Bedrest, Routine observation | | Country: United States Time Period: 1989-1993 | M=82% C=60%
  50 | 41
  22 | 23.7
  (4.7) | (4.7)
  Cx1 | Cx2
  21.4 | 22.3
  (5.1) | (5.4)
  Tx1 | Tx2
  62% | 73%
  Cx1 | Cx2
  64% | 73%

Evidence Table 8: Tocolytic maintenance: Beta-mimetics - Study design

Author (year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion/Exclusion Characteristics | Sample Size Initial/End | | | Demographic Characteristics | | | Tocolytic Intervention | Uniform Adjunctive Drug Intervention | Uniform Non-Drug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Author (year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion/Exclusion Characteristics | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tocolytic Intervention | Uniform Adjunctive Drug Intervention | Uniform Non-Drug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Lewis R, Mercer BM, Salama M, et al. ^177^ | To determine whether maintenance oral terbutaline therapy is more effective than placebo in prolonging gestation in women deemed to require maintenance therapy after successful tocolysis. | RCT; Masking: subject, physician, other direct care givers: yes | PTL: Contractions:> 3/30 min despite conservative therapy and Dilation:> 4 cm & Effacement: >25% Successful tocolysis: not defined | EGA: 24-34 wks Intact membranes Also no: chorioamnionitis, vaginal bleeding consistent w/abruptio placentae, contraindication for use of study medication, maternal/fetal indication for delivery | 203/200 | | | Median Age p=NS Black P=NS | | | Tx1 Terbutaline Sulfate oral 5 mg/5 hrs CoT: 1/2 hr before cessation of tocolytic tx DoT: 36 wks gestation Cx Placebo oral every 5 hrs CoT: 1/2 hr before cessation of tocolytic tx DoT: 36 wks gestation | | Fetal & uterine monitoring, routine observation | Questioned 1-2 times/wk, pill counts | Country: United States Time Period: 1990-1995 | M=N/A C=74%
  100 | 100
  21.0 | 20.0
  82.2% | 80.4%

Evidence Table 8: Tocolytic maintenance: Beta-mimetics - Study design

Author (year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion/Exclusion Characteristics | Sample Size Initial/End | | | Demographic Characteristics | | | Tocolytic Intervention | Uniform Adjunctive Drug Intervention | Uniform Non-Drug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Author (year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion/Exclusion Characteristics | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tocolytic Intervention | Uniform Adjunctive Drug Intervention | Uniform Non-Drug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Guinn DA, Goepfert AR, Owen J, et al. ^179^ | To determine whether maintenance therapy w/terbutaline administered by pump prolongs gestation in women with preterm labor after tx w/ IV magnesium sulfate | RCT; Masking: subject, physician, other care givers: yes | PTL: Contractions: >4/hr & 1 or more of the following: Dilation:> 1 cm, Effacement: 80%, Cervical change Successful tocolysis: not defined | EGA: 22-336/7 wks Intact membranes Also no: multiple gestations, chorioamnionitis, contraindication to tocolysis, persistent maternal tachycardia, history of cardiac arrhythmia, history of pulmonary edema, uncontrolled diabetes | 52/52 | | | Mean Age (SD) White Black | | | Tx1 Terbutaline continuous infusion using a pump .05 mL/h CoT: 30 min before discontinuation of parenteral mag sulfate DoT: until 36 wks gestation Terbutaline bolus injection .25 mL 5 times/day CoT: concurrent w/ pump therapy DoT: until 36 wks gestation Cx Placebo: administered similarly to tx | | Intensive education program | Follow-up visits | Country: United States Time Period: dk | M=86% C=68%
  24 | | 28
  21.2 | | 22.0
  (6.6) | | (4.9)
  42% | | 50%
  58% | | 50%

Evidence Table 8: Tocolytic maintenance: Beta-mimetics - Study design

Author (year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion/Exclusion Characteristics | Sample Size Initial/End | | | Demographic Characteristics | | | Tocolytic Intervention | Uniform Adjunctive Drug Intervention | Uniform Non-Drug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Author (year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion/Exclusion Characteristics | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tocolytic Intervention | Uniform Adjunctive Drug Intervention | Uniform Non-Drug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Rust OA, Bofill JA, Arrriola RM, et al. ^178^ | To determine whether maintenance oral tocolysis decreases uterine activity, prevents recurrent labor, and subsequent preterm birth or improves neonatal outcome | RCT; Masking: yes | PTL: Contractions: >4/hr and Dilation: change from baseline and Other: absence of any medical or obstetric condition requiring delivery Successful tocolysis is not defined | EGA: 24-34 wks, Intact Membranes Also: informed consent, arrest of PTL with parenteral tocolysis, uterine quiescence documented by tocodynamometry, absence of further cervical change | 248/205 | | | | | | Tx1 Magnesium chloride oral 128 mg CoT: dk DoT: every 4 hrs until readmission for parenteral tocolysis, diagnosis of active labor, EGA of 37 wks, or voluntary withdrawal Tx2 Terbutaline sulfate oral 5 mg Cot: dk DoT: every 4 hrs until readmission for parenteral tocolysis, diagnosis of active labor, EGA of 37 wks, or voluntary withdrawal Cx Placebo | Betamethasone AoT: dk Antibiotics AoT: treatment of urinary tract infection, gonorrhea, and group B streptococci Tocolysis AoT: if readmission for PTL | Home uterine monitoring, PTL education,Pwkly clinic visit | pill count | Country: United States Time period: 1995 | C=84% M=76%
  65 | 72 | 68

Evidence Table 8: Tocolytic maintenance: Beta-mimetics - Study design

Author (year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion/Exclusion Characteristics | Sample Size Initial/End | | | Demographic Characteristics | | | Tocolytic Intervention | Uniform Adjunctive Drug Intervention | Uniform Non-Drug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Author (year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion/Exclusion Characteristics | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tocolytic Intervention | Uniform Adjunctive Drug Intervention | Uniform Non-Drug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Wenstrom KD, Weiner CP, Merrill D, et al. ^179^ | To determine the efficacy of terbutaline pump therapy in preventing preterm delivery. | RCT; Masking: Subject, physician: yes Pharm.: no Other care providers: yes | Contractions: regular, consistent, and Cervical change Successful Tocolysis: not defined | EGA: 20 to >35 wks Also not: no contraindications to β-mimetic therapy: heart disease, insulin-dependent diabetes mellitus, intolerance of terbutaline; any contraindications to terbutaline in general, cervical dilation >4 cm. | 42/42 | | | Mean age (SD) p=0.008 | | | Tx1 Terbutaline oral 5-10 mg/ 2-6 hrs CoT: dk DoT: dk Tx2 Terbutaline infusion with portable pump, 1 mg terbutaline per ml of saline, rate of 0.05ml/hr CoT: dk DoT: dk Terbutaline oral 0.25 ml/ 6 hrs CoT: taken at same time as the infusion therapy DoT: dk Cx Saline infusion, 0.05 ml/hr CoT: dk DoT: dk Saline oral 0.25 ml/ 6 hrs CoT: taken at same time as the infusion therapy DoT: dk | Magnesium sulfate AoT: to reduce contractions to fewer than 4/hr and to halt cervical dilation and/or effacement Indomethacin AoT: if the magnesium sulfate was not successful, patients were switched to this therapy Betamethasone AoT: dk | Bedrest, Routine observation | Inpatient, Outpatient | Country: United States Time period: 1990-1994 | M=72% C=92%
  15 | 15 | 12
  23.7 | 25.5 | 30.2
  (6.2) | (4.8) | (4.5)

Evidence Table 8: Tocolytic maintenance: Beta-mimetics - Study design

Author (year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion/Exclusion Characteristics | Sample Size Initial/End | | | Demographic Characteristics | | | Tocolytic Intervention | Uniform Adjunctive Drug Intervention | Uniform Non-Drug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Author (year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion/Exclusion Characteristics | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tocolytic Intervention | Uniform Adjunctive Drug Intervention | Uniform Non-Drug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Brown HL, Hiett AK, Britton KA et al. (1997) | To determine the efficacy of intravenous tocolysis, followed by oral maintenance therapy, in delaying birth for women with preterm contractions versus actual preterm labor Tx1: contractions w/ no cervical change, closed cervix Tx2: contractions & presented w/ or developed cervical changes | Prospective Cohort; Masking: Subject, physician: none Pharm., other care providers: dk | PTL: Contractions:>6 per hour and (Dilation:>1 cmor Dilation: 1 cm change from baseline) Successful Tocolysis not defined | EGA: 20-35 wks Intact membranes Also no: chorioamnionitis, dilation >5 cm, hypertensive disorders, nonreassuring fetal testing | 375/375 | | | Mean Age (SD) Percent White Percent Black | | | Tx1 & Tx2 Magnesium Sulfate 6 g IV CoT: after hydration DoT: one dose 2-3 g IV CoT: after initial dose DoT: every hr until 24 hrs after termination of contractions Subgroups of Tx1 (n=91) & Tx2 (n=115) Terbutaline Sulfate 2.5-5 mg oral CoT: after IV Magnesium Sulfate DoT: every 4 hrs until 37 wks | | Bedrest, Rehydration | Inpatient, Outpatient: wkly follow-up | Country: United States Time period: 1990-1993 | M=56% C=48%
  200 | 175
  21.4 | 21.3
  (4.4) | (4.6)
  43.0% | 36.4%
  57.0% | 64.6%

Evidence Table 8: Tocolytic maintenance: Beta-mimetic-Outcomes

Author (year) | Delivery | | | | | | | | | Maternal | | | | | | Infant | | | | | | | | | | | | Other Analyses | Conclusions
Author (year) | Estimated Gestational Age | | | Prolongation of Pregnancy Days | | | Gestational Weeks | | | Length of Hospital Stay | | | Maternal Morbidity | | | Birth Weight (g) | | | APGAR Score | | | Length of Hospital Stay | | | Other Infant Outcomes | | | Other Analyses | Conclusions
Author (year) | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Tx3 | Tx1 | Tx2 | Tx3 | Tx1 | Tx2 | Tx3 | Tx1 | Tx2 | Tx3 | Other Analyses | Conclusions
Creasy RK, Golbus MS, Laros RK, et al. ^40^ | Mean (SD) p=NS | | | Prolongation <24 hrs Prolongation 1-7 days Prolongation 8-14 days Prolongation > 14 days Prolongation Days (SD) p=NS | | | Delivery at > 36 wks p=NS | | | | | | Palpitations/flushing | | | Mean (SD) | | | Mean at 1 min (SD) Mean at 5 min (SD) | | | | | | Fetal mortality NRDS or HMD | | | Comparison of number of relapses w/oral ritodrine and placebo; patients w/ a priori cerclage or prior tx with IV ethanol. | No significant difference shown between oral ritodrine & placebo.
  36 | | 36
  (.7) | | (.8)
  6 | | 4
  6 | | 6
  1 | | 5
  4 | | 2
  34.1 | | 34.6
  (5) | | (5)
  18 | | 17
  50% | | 33%
  2501 | | 2527
  (137) | | (145)
  6.1 | | 6.9
  (0.5) | | (0.4)
  7.5 | | 8.2
  (0.4) | | (0.3)
  3 | | 2
  6 | | 6

Evidence Table 8: Tocolytic maintenance: Beta-mimetic-Outcomes

Author (year) | Delivery | | | | | | | | | Maternal | | | | | | Infant | | | | | | | | | | | | Other Analyses | Conclusions
Author (year) | Estimated Gestational Age | | | Prolongation of Pregnancy Days | | | Gestational Weeks | | | Length of Hospital Stay | | | Maternal Morbidity | | | Birth Weight (g) | | | APGAR Score | | | Length of Hospital Stay | | | Other Infant Outcomes | | | Other Analyses | Conclusions
Author (year) | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Tx3 | Tx1 | Tx2 | Tx3 | Tx1 | Tx2 | Tx3 | Tx1 | Tx2 | Tx3 | Other Analyses | Conclusions
Brown SM, Tejani NA ^172^ | | | | Mean days (SD) p=<0.05 | | | | | | | | | | | | Mean (SD) p<.01 | | | | | | | | | Fetal mortality NRDS, HMD p<.05 | | | | Terbutaline showed efficacy over placebo: - greater prolongation of pregnancy days - greater - lower rate of NRDS, HMD
  42.5 | | 29.4
  (22.6) | | (22.2)
  2757 | | 2386
  (182.3) | | (263.1)
  0 | | 0
  1 | | 6

Evidence Table 8: Tocolytic maintenance: Beta-mimetic-Outcomes

Author (year) | Delivery | | | | | | | | | Maternal | | | | | | Infant | | | | | | | | | | | | Other Analyses | Conclusions
Author (year) | Estimated Gestational Age | | | Prolongation of Pregnancy Days | | | Gestational Weeks | | | Length of Hospital Stay | | | Maternal Morbidity | | | Birth Weight (g) | | | APGAR Score | | | Length of Hospital Stay | | | Other Infant Outcomes | | | Other Analyses | Conclusions
Author (year) | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Tx3 | Tx1 | Tx2 | Tx3 | Tx1 | Tx2 | Tx3 | Tx1 | Tx2 | Tx3 | Other Analyses | Conclusions
Kopelman JN, Duff P, Read JA ^173^ | Mean (SD) p=NS | | | Mean (SD) p=NS | | | | | | | | | | | | Mean (SD) p=NS | | | <8 at 5 min p=NS | | | | | | Neonatal deaths p=NS | | | Outcomes for 4 non-compliant patients | Ritodrine & terbutaline showed no differences in efficacy.
  266.2 | 265.4
  (16.6) | (12.8)
  38.3 | 37.1
  (18.2) | (19.2)
  3104 | 3142.3
  (642.6) | (557.5)
  1 | 1
  1 | 0

Evidence Table 8: Tocolytic maintenance: Beta-mimetic-Outcomes

Author (year) | Delivery | | | | | | | | | Maternal | | | | | | Infant | | | | | | | | | | | | Other Analyses | Conclusions
Author (year) | Estimated Gestational Age | | | Prolongation of Pregnancy Days | | | Gestational Weeks | | | Length of Hospital Stay | | | Maternal Morbidity | | | Birth Weight (g) | | | APGAR Score | | | Length of Hospital Stay | | | Other Infant Outcomes | | | Other Analyses | Conclusions
Author (year) | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Tx3 | Tx1 | Tx2 | Tx3 | Tx1 | Tx2 | Tx3 | Tx1 | Tx2 | Tx3 | Other Analyses | Conclusions
Ridgway LE, Muise K, Wright JW, et al. ^174^ | Mean (SD) p=NS | | | | | | | | | | | | Adverse Drug Reactions p<0.01 | | | Mean (SD) p=NS | | | | | | | | | | | | Cost per day | Magnesium oxide showed efficacy over terbutaline sulfate: - maternal adverse drug reactions
  37.9 | 38.3
  (2.4) | (2.3)
  81.5% | 47.8%
  3028 | 2954
  (438) | (513)

Evidence Table 8: Tocolytic maintenance: Beta-mimetic-Outcomes

Author (year) | Delivery | | | | | | | | | Maternal | | | | | | Infant | | | | | | | | | | | | Other Analyses | Conclusions
Author (year) | Estimated Gestational Age | | | Prolongation of Pregnancy Days | | | Gestational Weeks | | | Length of Hospital Stay | | | Maternal Morbidity | | | Birth Weight (g) | | | APGAR Score | | | Length of Hospital Stay | | | Other Infant Outcomes | | | Other Analyses | Conclusions
Author (year) | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Tx3 | Tx1 | Tx2 | Tx3 | Tx1 | Tx2 | Tx3 | Tx1 | Tx2 | Tx3 | Other Analyses | Conclusions
van Assche A, Thoumsin H, Hendrickx B ^182^ | Mean (SD) | | | Mean Prolongation (SD) | | | | | | | | | | | | Mean (SD) <2500 g <2000 g | | | Mean at 1 min (SD) Mean at 5 min (SD) | | | | | | Fetal Mortality Hyperbilirubinemia Meningitis Hypothermia | | | Gestational age and days gained reported for four risk groups: high risk (n=8) were 30.5 wks at entry, APGAR 9.28 at 1 and 5 min. | No statistical analysis provided since no comparison group.
  37.76
  (2.11)
  44.61
  (20.85)
  3006.1
  (537.72)
  8
  1
  8.33
  (1.08)
  9.38
  (0.99)
  0
  4
  1
  1

Evidence Table 8: Tocolytic maintenance: Beta-mimetic-Outcomes

Author (year) | Delivery | | | | | | | | | Maternal | | | | | | Infant | | | | | | | | | | | | Other Analyses | Conclusions
Author (year) | Estimated Gestational Age | | | Prolongation of Pregnancy Days | | | Gestational Weeks | | | Length of Hospital Stay | | | Maternal Morbidity | | | Birth Weight (g) | | | APGAR Score | | | Length of Hospital Stay | | | Other Infant Outcomes | | | Other Analyses | Conclusions
Author (year) | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Tx3 | Tx1 | Tx2 | Tx3 | Tx1 | Tx2 | Tx3 | Tx1 | Tx2 | Tx3 | Other Analyses | Conclusions
Bivins HA, Newman RB, Fyfe DA, et al. ^181^ | Mean (SD) p=.501 | | | Prolongation > 48 hrs (%) Prolongation >7 days (%) p=.355 | | | Attained 34^th^ wk p=.577 | | | | | | | | | Mean (SD) p=.691 | | | Mean 5 min APGAR (SD) p=.521 | | | Mean NICU days (SD) p=.202 | | | Neonatal Deaths Intraventricular Hemorrhage Necrotizing Enterocolitis Ventilation required Primary pulmonary hypertension Patent ductus arteriosus | | | | No significant differences shown between oral indomethacin & oral terbutaline.
  36.1 | 36.5
  (2.86) | (2.18)
  33 | 32
  (100) | (100)
  29 | 31
  (87.9) | (96.9)
  75.8% | 84.4%
  2581 | 2633
  (570) | (474)
  7.6 | 7.8
  (1.8) | (1.4)
  1.51 | 0.34
  (4.89) | (1.60)
  0 | 0
  0 | 0
  0 | 0
  1 | 0
  0 | 0
  0 | 0

Evidence Table 8: Tocolytic maintenance: Beta-mimetic-Outcomes

Author (year) | Delivery | | | | | | | | | Maternal | | | | | | Infant | | | | | | | | | | | | Other Analyses | Conclusions
Author (year) | Estimated Gestational Age | | | Prolongation of Pregnancy Days | | | Gestational Weeks | | | Length of Hospital Stay | | | Maternal Morbidity | | | Birth Weight (g) | | | APGAR Score | | | Length of Hospital Stay | | | Other Infant Outcomes | | | Other Analyses | Conclusions
Author (year) | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Tx3 | Tx1 | Tx2 | Tx3 | Tx1 | Tx2 | Tx3 | Tx1 | Tx2 | Tx3 | Other Analyses | Conclusions
Parilla BV, Dooley SL, Minogue JP, et al. ^175^ | Mean (SD) p=.562 | | | Mean (SD) p=.412 | | | Delivered at >37 wks p=.291 | | | | | | | | | Mean (SD) p=.785 | | | | | | | | | | | | | No significant differences were found between oral terbutaline and no treatment.
  35.6 | | 36.1
  (2.7) | | 2.4
  4.0 | | 4.6
  (2.7) | | (3.1)
  9 | | 13
  2616 | | 2645
  (633) | | (599)

Evidence Table 8: Tocolytic maintenance: Beta-mimetic-Outcomes

Author (year) | Delivery | | | | | | | | | Maternal | | | | | | Infant | | | | | | | | | | | | Other Analyses | Conclusions
Author (year) | Estimated Gestational Age | | | Prolongation of Pregnancy Days | | | Gestational Weeks | | | Length of Hospital Stay | | | Maternal Morbidity | | | Birth Weight (g) | | | APGAR Score | | | Length of Hospital Stay | | | Other Infant Outcomes | | | Other Analyses | Conclusions
Author (year) | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Tx3 | Tx1 | Tx2 | Tx3 | Tx1 | Tx2 | Tx3 | Tx1 | Tx2 | Tx3 | Other Analyses | Conclusions
How HY, Hughes SA, Vogel RL, et al. ^176^ | Median (Interquartile Range) p<.05 (Tx1 v. Tx2 v. Cx1) p<.05 (Tx2 v. Cx2) p=NS | | | Median wks (Interquartile Range) p<.05 (Tx1 v. Cx1) p<.05 (Tx2 v. Cx2) p=NS | | | Delivered >37 wks p<.05 (Tx1 v. Cx1) p<.05 (Tx2 v. Cx2) | | | | | | | | | Mean (SD) p<.05 (Tx1 v. Tx2 v. Cx1) p<.05 (Tx2 v. Cx1 v. Cx2) p=NS | | | | | | | | | | | | | No significant difference between maintenance tx w/ oral terbutaline and no tx.
  36.1 | 37.6
  (3.6) | (2.6)
  Cx1 | Cx2
  35.8 | 38.4
  (2.4) | (2.8)
  Tx1 & Tx2 | Cx1 & Cx2
  36.4 | 36.8
  (3.8) | (4.0)
  3.5 | 6.4
  (2.9) | (3.8)
  Cx1 | Cx2
  3.9 | 7.0
  (3.7) | (5.2)
  Tx1 & Tx2 | Cx1 & Cx2
  5.0 | 5.0
  (3.8) | (4.2)
  32% | 61%
  Cx1 | Cx2
  28% | 75%
  2558 | 2759
  (584) | (692)
  Cx1 | Cx2
  2793 | 2865
  (544) | (675)
  Tx1 & Tx2 | Cx1 & Cx2
  2648 | 2651
  (640) | (628)

Evidence Table 8: Tocolytic maintenance: Beta-mimetic-Outcomes

Author (year) | Delivery | | | | | | | | | Maternal | | | | | | Infant | | | | | | | | | | | | Other Analyses | Conclusions
Author (year) | Estimated Gestational Age | | | Prolongation of Pregnancy Days | | | Gestational Weeks | | | Length of Hospital Stay | | | Maternal Morbidity | | | Birth Weight (g) | | | APGAR Score | | | Length of Hospital Stay | | | Other Infant Outcomes | | | Other Analyses | Conclusions
Author (year) | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Tx3 | Tx1 | Tx2 | Tx3 | Tx1 | Tx2 | Tx3 | Tx1 | Tx2 | Tx3 | Other Analyses | Conclusions
Lewis R, Mercer BM, Salama M, et al. ^177^ | Mean p=NS | | | Delayed <7 days p=NS | | | Delivery at term p=NS | | | | | | | | | Mean (SD) p=NS | | | | | | Mean Days p=NS | | | Fetal Mortality p=NS NRDS p=NS | | | Survival analysis: no difference 1wk after randomization Sig difference in prolongation found for women <32 wks & <30 wks at randomization | No significance difference found between maintenance therapy w/ oral terbutaline & placebo.
  35.6 | | 36.2
  18 | | 24
  37% | | 37%
  2532 | | 2420
  (649) | | (664)
  33 | | 30.1
  6% | | 2%
  9.7% | | 5.8%

Evidence Table 8: Tocolytic maintenance: Beta-mimetic-Outcomes

Author (year) | Delivery | | | | | | | | | Maternal | | | | | | Infant | | | | | | | | | | | | Other Analyses | Conclusions
Author (year) | Estimated Gestational Age | | | Prolongation of Pregnancy Days | | | Gestational Weeks | | | Length of Hospital Stay | | | Maternal Morbidity | | | Birth Weight (g) | | | APGAR Score | | | Length of Hospital Stay | | | Other Infant Outcomes | | | Other Analyses | Conclusions
Author (year) | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Tx3 | Tx1 | Tx2 | Tx3 | Tx1 | Tx2 | Tx3 | Tx1 | Tx2 | Tx3 | Other Analyses | Conclusions
Guinn DA, Goepfert AR, Owen J, et al. ^179^ | Mean (SD) p=.56 | | | Mean (SD) p=.78 | | | Delivery at <34 wks P=.93p Delivery at <37 wks p=.44 | | | | | | | | | Mean (SD) p=.95 | | | | | | NICU >24 hrs p=.28 | | | NRDS p=.51 | | | Outcomes comparing: those who continued tx relative to those who discontinued tx and those who continued terbutaline relative to those who continued placebo | No significant difference between terbutaline pump maintenance therapy and placebo.
  34.4 | | 34.9
  (3.4) | | (4.1)
  28.8 | | 27.9
  (22.0) | | (22.9)
  42% | | 43%
  71% | | 61%
  2349 | | 2324
  (770) | | (768)
  10/23 | | 13/28
  2 | | 4

Evidence Table 8: Tocolytic maintenance: Beta-mimetic-Outcomes

Author (year) | Delivery | | | | | | | | | Maternal | | | | | | Infant | | | | | | | | | | | | Other Analyses | Conclusions
Author (year) | Estimated Gestational Age | | | Prolongation of Pregnancy Days | | | Gestational Weeks | | | Length of Hospital Stay | | | Maternal Morbidity | | | Birth Weight (g) | | | APGAR Score | | | Length of Hospital Stay | | | Other Infant Outcomes | | | Other Analyses | Conclusions
Author (year) | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Tx3 | Tx1 | Tx2 | Tx3 | Tx1 | Tx2 | Tx3 | Tx1 | Tx2 | Tx3 | Other Analyses | Conclusions
Rust OA, Bofill JA, Arriola RM, et al. ^178^ | Mean (SD) p=NS | | | Mean (SD) p=NS | | | | | | | | | >1 Side Effect p<.02 | | | Mean (SD) p=NS | | | | | | Mean (SD) p<.005 | | | NICU Admission (%) p=NS | | | Bonferroni correction, two-way anova controlling for twins. | Both magnesium chloride & terbutaline sulfate showed poorer outcomes compared to placebo: - number of maternal side effects - Infant length of hospital stay There were no significant differences in other outcome measures.
  36.0 | 35.2 | 36.4
  (2.7) | (3.2) | (2.5)
  34.2 | 34.4 | 36.5
  (20.6) | (22.7) | (19.4)
  41.5% | 48.6% | 22.1%
  2653 | 2382 | 2871
  (605) | (751) | (714)
  5.2 | 9.6 | 3.5
  (7.7) | (16.7) | (3.2)
  22.4 | 23.7 | 14.1
  (25.8) | (21.0) | (16.1)

Evidence Table 8: Tocolytic maintenance: Beta-mimetic-Outcomes

Author (year) | Delivery | | | | | | | | | Maternal | | | | | | Infant | | | | | | | | | | | | Other Analyses | Conclusions
Author (year) | Estimated Gestational Age | | | Prolongation of Pregnancy Days | | | Gestational Weeks | | | Length of Hospital Stay | | | Maternal Morbidity | | | Birth Weight (g) | | | APGAR Score | | | Length of Hospital Stay | | | Other Infant Outcomes | | | Other Analyses | Conclusions
Author (year) | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Tx3 | Tx1 | Tx2 | Tx3 | Tx1 | Tx2 | Tx3 | Tx1 | Tx2 | Tx3 | Other Analyses | Conclusions
Wenstrom KD, Weiner CP, Merrill D, et al. ^179^ | Mean EGA at delivery (SD) p=0.4 | | | Mean Prolongation of Delivery (weeks) p=0.79 | | | | | | | | | | | | Mean birth weight (SD) p=0.19 | | | Median APGAR score at 1 min p=0.39 at 5 min p=0.32 | | | Mean neonatal hospital days (SD) p=0.79 | | | mean neonatal deaths Neonatal complications* | | | Analyses of crossovers and unblinded patients. | Terbutaline pump, saline by pump, and oral terbutaline appear equivalent for the prevention of PTL. | Small study sample for a 4.5 yr study, Recruited only low-risk PTL patients, Discusses 8 sets of twins in Table 1 yet neonatal outcomes are reported on number of mothers.
  34.3 | 35.7 | 35.4
  (4) | (3) | (3)
  4.2 | 5.0 | 5.0
  (3.9) | (4.1) | (2.5)
  2204 | 2688 | 2457
  (808) | (599) | (727)
  6.5 | 7.5 | 7.7
  8.1 | 8.4 | 8.4
  15.4 | 10.9 | 15.0
  (17.0) | (19.4) | (18.8)
  0 | 0 | 0
  5 | 3 | 5
  (Complications included for Tx1: RDS, hyperbilirubine-mia, pulmonary stenosis (1); RDS & sepsis (1); amnionitis (1); hyper-bilirubinemia (2). Tx2: apnea (1); RDS (1); RDS, hyperbilirubine-mia, retinopathy of prematurity (1). Cx: apnea & bradycardia (1); placental clot & neonatal polycythemia (1); tachycardia (1); RDS (1); hypoglycemia & jaundice (1).

Evidence Table 8: Tocolytic maintenance: Beta-mimetic-Outcomes

Author (year) | Delivery | | | | | | | | | Maternal | | | | | | Infant | | | | | | | | | | | | Other Analyses | Conclusions
Author (year) | Estimated Gestational Age | | | Prolongation of Pregnancy Days | | | Gestational Weeks | | | Length of Hospital Stay | | | Maternal Morbidity | | | Birth Weight (g) | | | APGAR Score | | | Length of Hospital Stay | | | Other Infant Outcomes | | | Other Analyses | Conclusions
Author (year) | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Tx3 | Tx1 | Tx2 | Tx3 | Tx1 | Tx2 | Tx3 | Tx1 | Tx2 | Tx3 | Other Analyses | Conclusions
Brown HL, Hiett AK, Britton KA, et al. (1997) | Mean (SD) p=NS | | | | | | Delivery at <37 wks p<.05 Delivery at <35 wks p<.05 | | | | | | | | | Mean (SD) p<.05 | | | | | | | | | | | | Comparison of those w/ & those w/out oral tocolytic treatment. No sig differences in Tx1 groups. Sig difference in Tx2 groups: having received oral higher readmit rate after >24 hrs & more likely to be treated with IV tocolytics when readmitted. | No sig difference in days gained by using oral maintenance tocolytics following IV tocolytics for subjects in Tx1 (no cervical change) or Tx2 (cervical change).
  37.7 | 36.2
  (2.8) | (3.2)
  22.0% | 45.1%
  9.5% | 22.8%
  3026.3 | 2816
  (616.1) | (686.3)

Evidence Table 9: Tocolytic maintenance: Calcium channel blockers - Study design

Author (year) | Research Objective | Study design & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion/Exclusion Characteristics | Sample SizeInitial/End | | | Demographic Characteristics | | | Tocolytic Intervention | Uniform Adjunctive Drug Intervention | Uniform Non-Drug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Author (year) | Research Objective | Study design & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion/Exclusion Characteristics | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tocolytic Intervention | Uniform Adjunctive Drug Intervention | Uniform Non-Drug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
El-Sayed YY, Holbrook RH Jr., Gibson R, et al. ^183^ | To compare the safety and efficacy of maintenance tocolysis with oral diltiazem to oral nifedipine in achieving 37 wks gestation | RCT; Masking: Subject, physician: dk Pharm: yes Other care providers: dk | PTL: Contractions and Cervical change Successful Tocolysis: achieving 37 wks gestation | EGA: <35 wks Intact membranes Also successfully treated with IV magnesium sulfate. no: cerclage, dilation >4 cm, placental abruption, placenta previa, hypertension, fetal anomaly, maternal or fetal contraindications to tocolysis, maternal or fetal indications for delivery. | 69/69 | | | | | | Tx1 & Tx2 Magnesium sulfate IV dose: dk CoT: prior to randomization DoT: until uterine quiescence (<4 contractions/hr and no further cervical change) for 12-24 hrs, then weaned off by 1 g/hr maintaining the <4 contractions/hr Tx1 Nifedipine oral 20 mg/4-6 hrs (max 120 mg/day) CoT: after successful magnesium sulfate tx DoT: until 37 wks Tx2 Diltiazem oral 30-60 mg/4-6 hrs (max 360 mg/day) CoT: after successful magnesium sulfate tx DoT: until 37 wks Tx1 & Tx2 Magnesium sulfate IV dose: dk CoT: persistent contractions despite max. dose oral tocolysis DoT: completion of course of tx-placed back on oral tx | | Fetal monitoring, Uterine monitoring | Inpatient, Outpatient: dk | Country: United States Time period: 1992-1996 | M=76% C=72%
  36 | 33

Evidence Table 9: Tocolytic maintenance: Calcium channel blockers - Outcomes

Author (year) | Delivery | | | | | | | | | Maternal | | | | | | Infant | | | | | | | | | | | | Other Analyses | Conclusions
Author (year) | Estimated Gestational Age | | | Prolongation of Pregnancy Days | | | Gestational Weeks | | | Length of Hospital Stay | | | Maternal Morbidity | | | Birth Weight (g) | | | APGAR Score | | | Length of Hospital Stay | | | Other Infant Outcomes | | | Other Analyses | Conclusions
Author (year) | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Tx3 | Tx1 | Tx2 | Tx3 | Tx1 | Tx2 | Tx3 | Tx1 | Tx2 | Tx3 | Other Analyses | Conclusions
El-Sayed YY, Holbrook RH Jr, Gibson R, et al. ^183^ | Mean (SD) p=0.022 | | | Mean prolongation days (SD) p=0.086 | | | Delivered >37 wks p=0.019 | | | | | | | | | Mean (SD) p=NS | | | APGAR <7 at 5 min p=NS | | | NICU admissions in days (SD) p=NS | | | NRDS p=NS Intraventricular hemorrhage p=NS | | | | Nifedipine showed efficacy over diltiazem: - delivery at >37 wks
  35.5 | 33.4
  (3.5) | (3.9)
  31.2 | 22.4
  (24.4) | (16.3)
  15 | 5
  (41.7%) | (15.1%)
  2337.5 | 2159.9
  (819) | (808)
  0 | 3
  9.3 | 17.0
  (15.9) | (29.9)
  4 | 4
  (12.5%) | (13.0%)
  0 | 1
  (--) | (3.2%)

Evidence Table 10: Tocolytic maintenance: Magnesium sulfate - Study design

Author (year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion/Exclusion Characteristics | Sample SizeInitial/End | | | Demographic Characteristics | | | Tocolytic Intervention | Uniform Adjunctive Drug Intervention | Uniform Non-Drug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Author (year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion/Exclusion Characteristics | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tocolytic Intervention | Uniform Adjunctive Drug Intervention | Uniform Non-Drug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Ridgway LE, Muise K, Wright JW, et al. ^174^ | To compare oral magnesium oxide with oral terbutaline sulfate in the maintenance of tocolysis | RCT; Masking: dk | PTL: Contractions:>3 in 20 min. that persisted despite IV hydration (500 ml saline) and prolonged sedation (8-20 mg morphine sulfate)and Cervical change Successful Tocolysis: not defined | EGA: 25-35 wks | 60/50 | | | Mean Age (SD) p=NS Median Education Level, Years p=NS | | | Tx1 & Tx2 Tocolytic IV (Choice of drug at physician discretion) CoT: initial DoT: uterine quiescence for 12-24 hrs Tx1 Terbutaline sulfate oral 2.5-5 mg every 3-4 hrs CoT: 12-24 hrs after successful tocolysis DoT: 36 wks gestation Tx2 Magnesium oxide oral 200 mg every 3-4 hrs CoT: 12-24 hrs after successful tocolysis DoT: 36 wks gestation Tx1 & Tx2 Those with recurrent preterm labor received parenteral therapy, if successful randomized back into their initial drug. | Morphine sulfate AoT: sedation | First 24 hrs strict bedrest, light ambulation on 2^nd^ day, IV fluids | Inpatient, Outpatient: weekly visits or if missed, phone call | Country: United States Time period: dk. | M=60% C=60%
  27 | 23
  22.9 | 24.1
  (5.8) | (7.1)
  12 | 11

Evidence Table 10: Tocolytic maintenance: Magnesium sulfate - Study design

Author (year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion/Exclusion Characteristics | Sample SizeInitial/End | | | Demographic Characteristics | | | Tocolytic Intervention | Uniform Adjunctive Drug Intervention | Uniform Non-Drug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Author (year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion/Exclusion Characteristics | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tocolytic Intervention | Uniform Adjunctive Drug Intervention | Uniform Non-Drug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Ricci JM, Hariharan S, Helfgott A, et al. ^180^ | To observe whether orally administered enteric-coated magenesium chloride (SLOW MAG) in patients with arrested preterm labor would prolong gestation and prevent recurrent preterm labor. | RCT; Masking: none | PTL: (Contractions: at least 2/10 min, of 30 sec in duration and Dilation >2 cm) or (Contractions: at least 2/10 min, of 30 sec in duration and Dilation change from baseline) Successful Tocolysis: not defined | EGA: 24-34 wks Intact membranes Also no: multiple gestation, obstetric hemorrhage ,dilation >4cm, previous PTL, chorioamnionitis, preeclampsia, eclampsia, fetal death, lethal congenital anomaly | 75/75 | | | Mean Age (SD) p=NS Race White American p=NS Race Black American p=NS Race White Latin p=NS Race Haitian p=NS | | | Tx1, Tx2 & Cx Magnesium sulfate IV 4 gm CoT: initial DoT: 20 min Magnesium sulfate IV 2g/hr CoT: after initial dose DoT: until 12 hrs after contractions cease Tx1 Ritodrine oral 10 mg CoT: 30 min before discontinuation of IV Magnesium sulfate DoT: every 2 hrs for 24 hrs Ritodrine oral 20 mg CoT: after first 24 hrs DoT: every 4 hrs until delivery or 36 wks Tx2 Magnesium Chloride (SLOW MAG) oral 535 mg CoT: 30 min before of discontinuation of IV Magnesium sulfate DoT: every 4 hrs until delivery or 36 wks Cx Observation only following IV tx Tx1, Tx2, Cx If recurrent PTL, IV tocolysis. Oral tocolysis at physician discretion. | | Routine observation, Uterine monitoring | Inpatient, Outpatient: weekly follow-up | Country: United States Time period: 1988-1989 | M=84% C=80%
  25 | 25 | 25
  22.28 | 21.36 | 25.00
  (5.02) | (5.79) | (5.99)
  4 | 3 | 1
  14 | 12 | 11
  5 | 7 | 11
  2 | 3 | 2

Evidence Table 10: Tocolytic maintenance: Magnesium sulfate - Study design

Author (year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion/Exclusion Characteristics | Sample SizeInitial/End | | | Demographic Characteristics | | | Tocolytic Intervention | Uniform Adjunctive Drug Intervention | Uniform Non-Drug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Author (year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion/Exclusion Characteristics | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tocolytic Intervention | Uniform Adjunctive Drug Intervention | Uniform Non-Drug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Rust OA, Bofill JA, Arrriola RM, et al. ^178^ | To determine whether maintenance oral tocolysis decreases uterine activity, prevents recurrent labor, and subsequent preterm birth or improves neonatal outcome | RCT; Masking: yes | PTL: Contractions: >4/hr and Dilation: change from baseline and Other: absence of any medical or obstetric condition requiring delivery Successful tocolysis is not defined | EGA: 24-34 wks, Intact Membranes Also: informed consent, arrest of PTL with parenteral tocolysis, uterine quiescence documented by tocodynamometry, absence of further cervical change | 248/205 | | | | | | Tx1 Magnesium chloride oral 128 mg CoT: dk DoT: every 4 hrs until readmission for parenteral tocolysis, diagnosis of active labor, EGA of 37 wks, or voluntary withdrawal Tx2 Terbutaline sulfate oral 5 mg Cot: dk DoT: every 4 hrs until readmission for parenteral tocolysis, diagnosis of active labor, EGA of 37 wks, or voluntary withdrawal Cx Placebo | Betamethasone AoT: dk Antibiotics AoT: treatment of urinary tract infection, gonorrhea, and group B streptococci Tocolysis AoT: if readmission for PTL | Home uterine monitoring, PTL education, wkly clinic visit | pill count | Country: United States Time period: 1995 | C=84% M=76%
  65 | 72 | 68

Evidence Table 10: Tocolytic maintenance: Magnesium sulfate - Outcomes

Author (year) | Delivery | | | | | | | | | Maternal | | | | | | Infant | | | | | | | | | | | | Other Analyses | Conclusions
Author (year) | Estimated Gestational Age | | | Prolongation of Pregnancy Days | | | Gestational Weeks | | | Length of Hospital Stay | | | Maternal Morbidity | | | Birth Weight (g) | | | APGAR Score | | | Length of Hospital Stay | | | Other Infant Outcomes | | | Other Analyses | Conclusions
Author (year) | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Other Analyses | Conclusions
Ridgway LE, Muise K, Wright JW, et al. ^174^ | Mean (SD) p=NS | | | | | | | | | | | | Adverse Drug Reactions p<0.01 | | | Mean (SD) p=NS | | | | | | | | | | | | Cost per day | Magnesium oxide showed efficacy over terbutaline sulfate: -maternal adverse drug reactions
  37.9 | 38.3
  (2.4) | (2.3)
  81.5% | 47.8%
  3028 | 2954
  (438) | (513)

Evidence Table 10: Tocolytic maintenance: Magnesium sulfate - Outcomes

Author (year) | Delivery | | | | | | | | | Maternal | | | | | | Infant | | | | | | | | | | | | Other Analyses | Conclusions
Author (year) | Estimated Gestational Age | | | Prolongation of Pregnancy Days | | | Gestational Weeks | | | Length of Hospital Stay | | | Maternal Morbidity | | | Birth Weight (g) | | | APGAR Score | | | Length of Hospital Stay | | | Other Infant Outcomes | | | Other Analyses | Conclusions
Author (year) | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Other Analyses | Conclusions
Ricci JM, Hariharan S, Helfgott A, et al. ^180^ | Mean (SD) p=NS | | | Mean Prolongation Days (SD) IV & oral tx days p=NS oral tx days only p=NS | | | Delivery at >36 wks p=NS | | | | | | PROM p=NS | | | Mean (SD) p=NS | | | APGAR at 5 min (SD) p=NS | | | Mean Days (SD) p=NS | | | Neonatal Mortality p=NS NRDS p=NS Intraventricular hemorrhage p=NS Necrotizing enterocolitis p=NS Jaundice p=NS Infection p=NS Hypermagnesemia p=NS | | | Examined relationship between dilation at onset of therapy & days gained. Regression analysis revealed a neg assoc between time gained & cervical dilation at onset in the control group (r= -.51, p=.01), but not in SLOW MAG (r=-.42 p=.05), or ritodrine (r= -.32, p=.12). | No significant difference shown between oral ritodrine & magnesium chloride (SLOW MAG).
  34.86 | 34.82 | 36.0
  (3.72) | (3.61) | (3.03)
  25.16 | 30.23 | 37.64
  (19.24) | (21.89) | (28.42)
  24.16 | 29.28 | 31.56
  (19.31) | (22.03) | (24.39)
  56% | 56% | 48%
  2 | 4 | 0
  2528 | 2610 | 2766
  (612) | (759) | (681)
  8.52 | 8.60 | 8.56
  (1.3) | (0.7) | (0.7)
  7.29 | 6.50
  6.32
  (9.1) | (4.9) | (4.9)
  0 | 2 | 0
  2 | 1 | 0
  1 | 1 | 0
  1 | 2 | 0
  | 10 | 11 | 6
  0 | 0 | 0
  0 | 0 | 0

Evidence Table 10: Tocolytic maintenance: Magnesium sulfate - Outcomes

Author (year) | Delivery | | | | | | | | | Maternal | | | | | | Infant | | | | | | | | | | | | Other Analyses | Conclusions
Author (year) | Estimated Gestational Age | | | Prolongation of Pregnancy Days | | | Gestational Weeks | | | Length of Hospital Stay | | | Maternal Morbidity | | | Birth Weight (g) | | | APGAR Score | | | Length of Hospital Stay | | | Other Infant Outcomes | | | Other Analyses | Conclusions
Author (year) | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Other Analyses | Conclusions
Rust OA, Bofill JA, Arriola RM, et al. ^178^ | Mean (SD) p=ns | | | Mean (SD) p=ns | | | | | | | | | >1 Side Effect p<.02 | | | Mean (SD) p=NS | | | | | | Mean (SD) p<.005 | | | NICU Admission (%) p=NS | | | Bonferroni correction, two-way ANOVA controlling for twins. | Both magnesium chloride & terbutaline sulfate showed poorer Outcomes compared to placebo: -number of maternal side effects -Infant length of hospital stay There were no significant differences in other outcome measures.
  36.0 | 35.2 | 36.4
  (2.7) | (3.2) | (2.5)
  34.2 | 34.4 | 36.5
  (20.6) | (22.7) | (19.4)
  41.5% | 48.6% | 22.1%
  2653 | 2382 | 2871
  (605) | (751) | (714)
  5.2 | 9.6 | 3.5
  (7.7) | (16.7) | (3.2)
  22.4 | 23.7 | 14.1
  (25.8) | (21.0) | (16.1)

Evidence Table 11: Tocolytic maintenance: Nonsteroidal anti-inflammatory agents - Study design

Author (year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion/Exclusion Characteristics | Sample Size Initial/End | | | Demographic Characteristics | | | Tocolytic Intervention | Uniform Adjunctive Drug Intervention | Uniform Non-Drug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Author (year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor & Successful Tocolysis | Patient Inclusion/Exclusion Characteristics | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tocolytic Intervention | Uniform Adjunctive Drug Intervention | Uniform Non-Drug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Bivins HA, Newman RB, Fyfe DA, et al. ^181^ | To determine the efficacy and safety of long-term oral tocolysis with indomethacin or terbutaline | RCT; Masking: none | PTL: (Contractions: >4/20 min and Cervical change) or Dilation:>2 cm or Effacement:>80% Successful tocolysis: not defined | EGA: 26-32 wks Singleton Intact membrane Also: cervix <4 cm dilated, no: abnormal fetus, allergy to protocol drug, chorioamnionitis, multiple gestation, placenta previa, rupture of membranes, abruptio placentae, oligohydranios (amniotic fluid index <7cm), insulin-dependent diabetes, allergy to aspirin | 71/63 | | | Mean Age (SD) Race, White (%) Race, Black (%) | | | Tx1 & Tx2 MgSO _ 4 _ IV dose: dk CoT: initially & if recurrent PTL DoT: 12 hrs initially & 24 hrs recurrent Tx1 Indomethacin oral 25 mg CoT: after MgSO_4_ DoT: every 6 hrs until 34 wks gestation Terbutaline sulfate oral 5mg CoT: if evidence of fetal ductal constriction, oligohydramniosis, or achieved 34 wks gestation DoT: 37 wks gestation Tx2 Terbutaline sulfate oral 5mg CoT: after MgSO_4_ DoT: every 4 hrs, 37 wks gestation Indomethacin oral 25 mg CoT: if intolerable β-mimetic adverse affects on terbutaline DoT: every 6 hrs until 34 wks gestation | | Routine observation | | Country: United States Time period: dk | M=75% C=74%
  33 | 32
  22.3 | 21.6
  (5.1) | (4.6)
  6 | 9
  (18.2) | (28.1)
  27 | 23
  (81.8) | (71.9)

Evidence Table 11: Tocolytic maintenance: Nonsteroidal anti-inflammatory agents - Outcomes

Author (year) | Delivery | | | | | | | | | Maternal | | | | | | Infant | | | | | | | | | | | | Other Analyses | Conclusions
Author (year) | Estimated Gestational Age | | | Prolongation of Pregnancy Days | | | Gestational Weeks | | | Length of Hospital Stay | | | Maternal Morbidity | | | Birth Weight (g) | | | APGAR Score | | | Length of Hospital Stay | | | Other Infant Outcomes | | | Other Analyses | Conclusions
Author (year) | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Other Analyses | Conclusions
Bivins HA, Newman RB, Fyfe DA, et al. ^181^ | Mean (SD) p=.501 | | | Prolongation > 48 hrs (%) Prolongation >7 days (%) p=.355 | | | Attained 34^th^ wk p=.577 | | | | | | | | | Mean (SD) p=.691 | | | Mean 5 min APGAR (SD) p=.521 | | | Mean NICU days (SD) p=.202 | | | Neonatal Deaths Intraventricular Hemorrhage Necrotizing Entercolitis Ventilation required Primary pulmonary hypertension Patent ductus arteriosus | | | | No significant differences shown between oral indomethacin & oral terbutaline.
  36.1 | 36.5
  (2.86) | (2.18)
  33 | 32
  (100) | (100)
  29 | 31
  (87.9) | (96.9)
  75.8% | 84.4%
  2581 | 2633
  (570) | (474)
  7.6 | 7.8
  (1.8) | (1.4)
  1.51 | 0.34
  (4.89) | (1.60)
  0 | 0
  0 | 0
  0 | 0
  1 | 0
  0 | 0
  0 | 0

Evidence Table 12: Antibiotics - Study design

Author (year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor | Patient Inclusion/Exclusion Characteristics | Sample Size Initial/End | | | Demographic Characteristics | | | Antibiotics Intervention | Uniform Adjunctive Drug Intervention | Uniform Non-Drug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Author (year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor | Patient Inclusion/Exclusion Characteristics | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Antibiotics Intervention | Uniform Adjunctive Drug Intervention | Uniform Non-Drug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Morales WJ, Angel JL, O'Brien WF, et al. ^198^ | To determine whether antibiotic treatment enhances the effectiveness of established methods of tocolysis | RCT; Masking: Subject: dk Physician: none Pharm.: dk Other care providers: | Contractions: "regular"and Dilation: >1 cm <5 and regular, progressive change from baseline, and Contractions unresolved w/: hydration & sedation | EGA: 21-34 wks Intact membranes Also no: abnormal fetus, multiple gestation, uterine anomaly, abruptio placenta, urinary tract infection, or recent cocaine use | 205/150 | | | Mean Age (SD) p=NS Race, Black (%) p=NS | | | Tx1 Ampicillin 500 mg oral CoT: dk DoT: every 6 hrs for 10 days Tx2 Erythromycin 500 mg oral CoT: dk DoT: every 6 hrs for 10 days | Magnesium Sulfate AoT: tocolysis Ritodrine AoT: tocolysis Indomethacin AoT: tocolysis Terbutaline AoT: tocolysis | Bedrest, Routine observation, Cervical exam, Amniocente-sis | Inpatient | Country: USA Time period: 1986-1987 | M=66% C=46%
  53 | 50 | 47
  21.1 | 22.1 | 22.8
  (4.7) | (5.3) | (5.6)
  22 | 18 | 23
  (42) | (36) | (49)

Evidence Table 12: Antibiotics - Study design

Author (year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor | Patient Inclusion/Exclusion Characteristics | Sample Size Initial/End | | | Demographic Characteristics | | | Antibiotics Intervention | Uniform Adjunctive Drug Intervention | Uniform Non-Drug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Author (year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor | Patient Inclusion/Exclusion Characteristics | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Antibiotics Intervention | Uniform Adjunctive Drug Intervention | Uniform Non-Drug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Winkler M, Baumann L, Ruckhäberle KE, et al. ^202^ | To examine the possible effect of erythromycin in prolongation of pregnancy in cases to threatened preterm delivery | RCT; Masking: dk | | Other: singleton gestation, informed consent, premature rupture of membranes and/or PTL | 43/43 | | | | | | Tx1 Erythromycin oral 1.2 g/day CoT: dk DoT: 7 days | Fenoterol AoT: tocolysis | | | Country: dk Time period: dk | C=36% M=21%
  20 | 23

Evidence Table 12: Antibiotics - Study design

Author (year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor | Patient Inclusion/Exclusion Characteristics | Sample Size Initial/End | | | Demographic Characteristics | | | Antibiotics Intervention | Uniform Adjunctive Drug Intervention | Uniform Non-Drug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Author (year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor | Patient Inclusion/Exclusion Characteristics | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Antibiotics Intervention | Uniform Adjunctive Drug Intervention | Uniform Non-Drug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Newton ER, Dinsmoor MJ, Gibbs RS ^195^ | To examine the benefit of adjunctive antibiotic therapy in idiopathic PTL in patients w/cervical dilation >1 cm | RCT; Masking: Subject, physician: yes Pharm.: none Other care providers: dk | Contractions: 3/20 minand Dilation: >1 cmand Contractions unresolved w/: hydration & sedationand Other: need for parenteral tocolysis | EGA: 24-34 wks Fetal weight est: 750-2500 g Also: no: premature rupture of membranes, multiple gestation, hypertension, known uterine abnormalities, abnormal fetus, allergy to protocol drug, 3^rd^ trimester bleeding, clinical evidence of maternal infection, suspected growth retardation, incompetent cervix, oligohydramnies, abnormal fetal testing | 103/95 | | | Age <19 years p=NS Non-Hispanic p=NS | | | Tx1 Ampicillin 2 gm IV CoT: dk DoT: every 6 hours for 12 doses Erythromycin 333 gm oral CoT: w/ampicillin treatment DoT: every 8 hrs for 7 days | Terbutaline or Ritodrine or Magnesium AoT: stop contractions Terbutaline or Ritodrine AoT: stop contractions | Hydration, Sedation | Inpatient | Country: United States Time period: 1987-1988 | M=84% C=88%
  48 | | 47
  41% | | 59%
  51% | | 49%

Evidence Table 12: Antibiotics - Study design

Author (year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor | Patient Inclusion/Exclusion Characteristics | Sample Size Initial/End | | | Demographic Characteristics | | | Antibiotics Intervention | Uniform Adjunctive Drug Intervention | Uniform Non-Drug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Author (year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor | Patient Inclusion/Exclusion Characteristics | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Antibiotics Intervention | Uniform Adjunctive Drug Intervention | Uniform Non-Drug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
McGregor JA, French JI, Seo K ^199^ | To evaluate clindamycin to determine the pathogenic roles for reproductive tract infection in preterm birth and to identify women most likely to benefit from such a antimicrobial treatment | RCT; Masking: Subject, physician: yes Pharm: no Others: dk | Contractions: >2/20 min, unresolved with bedrest and IV hydrationand Required tocolysis because of change in Dilation or Effacement | EGA:<34 wks Informed consent Also no: presence of recognized cause of PTL such as placenta previa, multiple gestation, abrupto placentae, cervical cerclage, known uterine or fetal anomaly, hypertension, PROM; known or suspected infection necessitating treatment such as chorioamnionitis, urinary tract infection, or pneumonia; fetal indication for delivery; significant maternal cardiac, respiratory, liver, renal or immunologic disease; use of antibiotics w/in 2 wks before start of study; history of diarrhea or colitis; sensitivity or intolerance to clindamycin. | 117/103 | | | Age (SD) p=NS Race, White (%) p=NS Race, Black (%) p=NS Race, Hispanic (%) p=NS Race, Asian (%) p=NS | | | Tx1 Clindamycin IV 900 mg/ 8 hrs CoT: after lab specimens obtained DoT: 9 doses Clindamycin oral 300 mg/ 6 hrs CoT: after IV treatment DoT: 4 days Cx Saline solution IV 900 mg/ 8 hrs CoT: after lab specimens obtained DoT: 9 doses Lactose solution oral 300 mg/ 6 hrs CoT: after IV treatment DoT: 4 days | Terbutaline AOT: tocolysisor Magnesium sulfate AOT: tocolysisor Ritodrine AOT: tocolysisor Nifedipine AOT: tocolysis | | Inpatient, Outpatient | Country: USA Time period: 1986-1989 | M=81% C=96%
  53 | | 50
  22.2 | | 21.5
  (4.2) | | (4.6)
  34 | | 35
  (64) | | (70)
  9 | | 6
  (17) | | (12)
  10 | | 8
  (19) | | (16)
  0 | | 1
  (0) | | (2)

Evidence Table 12: Antibiotics - Study design

Author (year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor | Patient Inclusion/Exclusion Characteristics | Sample Size Initial/End | | | Demographic Characteristics | | | Antibiotics Intervention | Uniform Adjunctive Drug Intervention | Uniform Non-Drug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Author (year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor | Patient Inclusion/Exclusion Characteristics | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Antibiotics Intervention | Uniform Adjunctive Drug Intervention | Uniform Non-Drug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Newton ER, Sheilds L, Ridgway LE ^196^ | To determine if a combination of antibiotics and a prostaglandin inhibitor will reduce tocolytic failure | RCT; Masking: Subject, physician: yes Pharm.: none Other care providers: dk | Contractions: 3/20 minand Dilation:>2 cm and Effacement:>50% or Contractions: 3/20 minand Change in dilation from baseline and Other: observed effacement | EGA: 24-33 6/7 wks Fetal weight: 750-2200 g Also: no: allergy to protocol drug, 3^rd^ trimester bleeding, hypertension, rupture of membranes, uterine anomaly, incompetent cervix, oligohydramnies, liver disease, asthma, clinical evidence of maternal infection, growth retardation, abnormal fetal testing | 91/86 | | | Mean Age (SD) p=NS | | | Tx1 Ampicillin-salbactam 2 gm ampicillin IV; 1gm salbactam IV CoT: after commencement of tocolytic therapy DoT: every 6 hrs for 12 doses Indomethacin 50 mg oral CoT: after commencement of tocolytic therapy DoT: one load dose Indomethacin 25 mg oral CoT: after load dose DoT: every 6 hrs for 7 doses | Magnesium sulfate AoT: tocolysisand Magnesium oxide AoT: tocolysisor Terbutaline sulfate AoT: tocolysis | Hydration, Sedation, Fetal echocardiography | 3-4 days hospitalization | Country: United States Time period: 1989-1991 | M=92% C=88%
  43 | | 43
  23.8 | | 23.8
  (5.5) | | (5.0)

Evidence Table 12: Antibiotics - Study design

Author (year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor | Patient Inclusion/Exclusion Characteristics | Sample Size Initial/End | | | Demographic Characteristics | | | Antibiotics Intervention | Uniform Adjunctive Drug Intervention | Uniform Non-Drug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Author (year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor | Patient Inclusion/Exclusion Characteristics | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Antibiotics Intervention | Uniform Adjunctive Drug Intervention | Uniform Non-Drug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
McCaul JF, Perry KG Jr., Moore JL Jr., et al. ^203^ | To assess the ability of a broad spectrum of antibiotic to prolong pregnancy and/or reduce the incidence of clinical infection in patients with PTL, PROM but not in labor, or in those with idiopathic PTL with intact membranes | RCT; Masking: Subject, physician: yes Pharm.: dk Other care providers: dk | Contractions: for >12 hrsand Change in dilation from baseline or Contractions >12 hrsand Cervical dilation >1 cm <4 cm | EGA: >18 to <33 wks Maternal age: 14-45 yrs Intact membranes Also no: known reasons for early labor such as multiple gestation, urinary tract infection, nonvertex presentation, uterine anomalies, positive group B streptococcus cultures, fetal distress, abrupto placentae, cord prolapse, and history of penicillin allergy. | PTL 75/40 | | | PTL Mean Age (SD) p=NS PTL Race, White p=NS PTL Race, Black p=NS | | | Tx1 Ampicillan IV 2 g CoT: dk DoT: 4 hrs, for one dose Ampicillan oral 500 mg CoT: after infusion DoT: every 6 hrs for 7 days | Magnesium sulfate AoT: tocolysis for uterine quiescence | Bedrest, uterine monitoring limited activity for 3-7 days | Pill count | Country: United States Time period: dk | C=56% M=65%
  21 | | 19
  23.0 | | 21.9
  (5.5) | | (5.1)
  6 | | 3
  15 | | 16

Evidence Table 12: Antibiotics - Study design

Author (year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor | Patient Inclusion/Exclusion Characteristics | Sample Size Initial/End | | | Demographic Characteristics | | | Antibiotics Intervention | Uniform Adjunctive Drug Intervention | Uniform Non-Drug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Author (year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor | Patient Inclusion/Exclusion Characteristics | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Antibiotics Intervention | Uniform Adjunctive Drug Intervention | Uniform Non-Drug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Romero R, Sibai B, Caritis S, et al. ^194^ | To determine the effect of ampicillin- amoxicillin and erythromycin treatment on prolongation of pregnancy, the rate of preterm birth, and neonatal morbidity in patients w/PTL and intact membranes | RCT; Masking Subject, physician: yes Pharm., other care providers, path.: dk | Contractions: history of and Dilation: >2 cm and Effacement:>80% and Nulliparous or Contractions: history of and Dilation: >3 cm and Effacement:>80% and Mulitparous or Contractions: 4/20 min for 1 hr | EGA: 24-36 wks Intact Membranes Singleton Also: no: abnormal fetus, allergy to protocol drug, current bleeding/hemorrhage, dilation>5 cm, fetal distress, hypertensive disorders, maternal fever/pyrexia, placenta previa, positive urine culture, fetal death, abruptio placentae, renal disease leading to dialysis, maternal and medical complications (cardiac disease II-IV, adrenal disease requiring meds, sickle cell, AIDS, FSI <0.7, prior noncesarean uterine surgery, use of antibiotics w/in 5 days of screening | 277/dk | | | Mean Age (SD) p=NS Race, White (%) p=NS Race, Black (%) p<0.05 Race, Hispanic (%) p=NS Race, Other (%) p=NS | | | Tx1 Ampicillin 1 gm IV CoT: dk DoT: every 4 hrs for 48 hrs Erythromycin 250 mg IV CoT: w/ ampicillin DoT: every 6 hrs for 48 hrs Amoxicillin 250 mg oral CoT: after ampicillin/erythromycin DoT: every 8 hrs for 5 days Erythromycin 333 mg oral CoT: w/ amoxicillin DoT: every 8 hrs for 5 days | Terbutaline, Ritodrine, or Magnesium Sulfate AoT: tocolysis Betamethasone AoT: dk | | | Country: United States Time period: 1989-1991 | M=84% C=92%
  133 | | 144
  23.3 | | 23.7
  (5.45) | | (5.96)
  25 | | 41
  (18.8) | | (28.5)
  92 | | 80
  (69.2) | | (55.6)
  13 | | 23
  (9.8) | | (16)
  3 | | 0
  (2.3) | | (0)

Evidence Table 12: Antibiotics - Study design

Author (year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor | Patient Inclusion/Exclusion Characteristics | Sample Size Initial/End | | | Demographic Characteristics | | | Antibiotics Intervention | Uniform Adjunctive Drug Intervention | Uniform Non-Drug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Author (year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor | Patient Inclusion/Exclusion Characteristics | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Antibiotics Intervention | Uniform Adjunctive Drug Intervention | Uniform Non-Drug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Norman K, Pattinson RC, de Souza J, et al. ^200^ | To ascertain whether ampicillin & metronidazole given to women in PTL w/intact membranes would prolong pregnancy & decrease perinatal mortality & morbidity | RCT; Masking: dk | Contractions: >3/20 min and Dilation: 1-5 cm and Contractions unresolved w/: rehydration and & sedation w/in 1 hr | EGA: 26-34 wks Fetal wgt: 800-1500 g if uncertain EGA Intact membrane Also no: abnormal fetus, allergy to protocol drug, current or recent antibiotic treatment, chorioamnionitis, antepartum hemorrhage, fetal distress, hypertensive disorders, maternal fever, placenta previa, pyelouephritis, multiple pregnancies, pyrexia of unknown origin, or intrauterine death | 82/80 | | | Mean Age (SD) | | | Tx1 Ampicillin 1 g IV CoT: first 24 hrs DoT: every 6 hrs for 24 hrs Amoxicillin 500 mg oral CoT: after ampicillin DoT: every 8 hrs for 5 days Metronidazole 1 g suppository CoT: concurrent w/ Ampicillin DoT: 1 dose Metronidazole 400 mg oral CoT: after metronidazole suppository DoT: every 8 hrs for 5 days | Hexoprenaline AoT: to suppress contractions Indomethacin AoT: dk Betamethasone AoT: increase fetal lung maturity | Bedrest, Rehydration, Sedation, Routine observation | Inpatient | Country: South Africa Time period: 1990-1991 | M=75% C=79%
  42 | | 38
  23.7 | | 25.1
  (5) | | (5.2)

Evidence Table 12: Antibiotics - Study design

Author (year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor | Patient Inclusion/Exclusion Characteristics | Sample Size Initial/End | | | Demographic Characteristics | | | Antibiotics Intervention | Uniform Adjunctive Drug Intervention | Uniform Non-Drug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Author (year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor | Patient Inclusion/Exclusion Characteristics | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Antibiotics Intervention | Uniform Adjunctive Drug Intervention | Uniform Non-Drug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Gordon M, Samuels P, Shubert P et al. ^193^ | To determine the effect of ceftizoxime in the prolongation of pregnancies receiving tocolysis for PTL | RCT; Masking: Subject, physician: yes Pharm., other care providers, path.: dk | Contractions: > 6/hr and Dilation: 2-5 cm or Effacement: >50% and Contractions unresolved w/: bedrest or IV fluids or Contractions and Cervical change | EGA: 24-35 wks Also: intact membranes, met standard criteria for tocolytic treatment, no: allergy to protocol drug, current/recent antibiotic therapy, cerclage, chorioamnionitis, maternal age <18, maternal fever >100°F, maternal WBC >15,000/mm^3^, placenta previa, uterine anomaly, other indication for delivery, >2 fetuses, fetal heart rate >180 bpm, lethal congenital fetal anomaly, fetal distress, maternal illness indicating delivery, significant hemorrhage, recent positive vaginal culture for group B strep. | 117/117 | | | Mean Age (SD) (5.5) p=0.65 Race, White | | | Tx1 Ceftizoxime IV 2g CoT: dk DoT: every 8 hrs for 3-5 days | Magnesium Sulfate AoT: tocolysis Beta-symathomimetics AoT: dk | | | Country: United States Time period: 1990-1994 | M=92% C=92%
  58 | | 59
  24.5 | | 23.3
  (5.6)
  74% | | 72%

Evidence Table 12: Antibiotics - Study design

Author (year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor | Patient Inclusion/Exclusion Characteristics | Sample Size Initial/End | | | Demographic Characteristics | | | Antibiotics Intervention | Uniform Adjunctive Drug Intervention | Uniform Non-Drug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Author (year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor | Patient Inclusion/Exclusion Characteristics | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Antibiotics Intervention | Uniform Adjunctive Drug Intervention | Uniform Non-Drug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Nadisauskiene R, Bergström S, Kilda A ^191^ | To assess whether the use of oral ampicillin vs. placebo therapy in women w/latent-phase PTL delays delivery and improves pregnancy outcome | RCT, Masking: MD: yes patient:yes pharm: dk other prov: dk path: dk | Contractions: "painful"and Dilation: <3 cm | EGA:<34 wks Also: live fetus, informed consent, no: allergy to protocol drug, current/recent antibiotic therapy, maternal fever >37.5 °C, placenta previa, membrane rupture >72 hours, maternal/fetal indication for delivery, history of vaginal bleeding, active infection requiring therapy, multiple gestation, medical condition necessitating delivery. | 166/110 | | | Mean Age (SD) p=NS Married p=NS More than secondary school education (%) p=NS | | | Tx1 Ampicillin: 1 g oral COT: dk DoT: every 8 hrs for 7 days | Magnesium Sulfate AoT: tocolysis Fenoterol hydrobromid AoT: tocolysis | | Inpatient for 7 days | Country: Lithuania Time period: dk | M=69% C=75%
  59 | | 51
  24.5 | | 26.5
  (4.9) | | (6.6)
  57 | | 47
  (96.6%) | | (92.2%)
  19 | | 11
  (32.2) | | (21.6)

Evidence Table 12: Antibiotics - Study design

Author (year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor | Patient Inclusion/Exclusion Characteristics | Sample Size Initial/End | | | Demographic Characteristics | | | Antibiotics Intervention | Uniform Adjunctive Drug Intervention | Uniform Non-Drug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Author (year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor | Patient Inclusion/Exclusion Characteristics | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Antibiotics Intervention | Uniform Adjunctive Drug Intervention | Uniform Non-Drug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Nadisauskiene R, Bergstrom S ^201^ | To determine whether the use of IV ampicillin (vs. placebo) in women in early active-phase PTL reduces infectious complications postpartum in mothers and their newborns. | RCT; Masking: Path: yes All others: dk | Dilation:>4 cm | EGA: < 37 wks, Other: fetus alive, no: allergy to protocol drug, current or recent antibiotic therapy, failure to give informed consent, multiple gestation, placenta previa, rupture of membranes >72 hrs, other maternal/fetal indication for delivery, history of vaginal bleeding during pregnancy, temperature >37.5 C, medical infections requiring antibiotics. | dk/102 | | | Age (SD) p=NS High School Grads (%) p=NS Married (%) p<0.05 | | | Tx1 Ampicillin IV 5 g/4 hrs CoT: dk DoT: for 2 doses | Magnesium sulfate AoT: tocolysis Phenoterolhydrobromide AoT: tocolysis | | | Country: Lithuania Time period: dk | C=42% M=46%
  44 | | 58
  26 | | 25
  (6) | | (5)
  26 | | 20
  (36.4) | | (34.5)
  44 | | 52
  (100) | | (89.7)

Evidence Table 12: Antibiotics - Study design

Author (year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor | Patient Inclusion/Exclusion Characteristics | Sample Size Initial/End | | | Demographic Characteristics | | | Antibiotics Intervention | Uniform Adjunctive Drug Intervention | Uniform Non-Drug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Author (year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor | Patient Inclusion/Exclusion Characteristics | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Antibiotics Intervention | Uniform Adjunctive Drug Intervention | Uniform Non-Drug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
CoxBeta SM, Bohman VR, Sherman ML, et al. ^197^ | To determine whether antimicrobial therapy given to women in PTL is effective in preventing preterm delivery. | RCT; Masking: Subject: yes All others: dk | Contractions: regular and Dilation: 1-5 cm or Change in dilation from baseline | EGA: 24 to 34 wks Intact membranes Other: no allergy to protocol drug, dilation > 5cm, rupture of membranes, other maternal/fetal indication for delivery | 86/78 | | | Mean Age (SEM) p=NS Race, White (%) p=NS Race, Black (%) p=NS Race, Hispanic (%) p=NS | | | Tx1 Ampicillan sodium IV 2 gm every 6 hrs CoT: dk DoT: 8 doses Sulbactam sodium IV 1 gm every 6 hrs CoT: dk DoT: 8 doses Ampicillin-clavulanate oral 250 mg CoT: after iv DoT: 5 days | | Fetal monitoring, routine observation | Inpatient until 34 wks gestation | Country: United States Time period: 1989-1992 | M=83% C=80%
  39 | | 39
  19.8 | | 20.5
  (0.6) | | (0.5)
  7 | | 9
  (18) | | (23)
  21 | | 17
  (54) | | (44)
  11 | | 13
  (28) | | (33)

Evidence Table 12: Antibiotics - Study design

Author (year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor | Patient Inclusion/Exclusion Characteristics | Sample Size Initial/End | | | Demographic Characteristics | | | Antibiotics Intervention | Uniform Adjunctive Drug Intervention | Uniform Non-Drug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Author (year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor | Patient Inclusion/Exclusion Characteristics | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Antibiotics Intervention | Uniform Adjunctive Drug Intervention | Uniform Non-Drug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Svare J, Langhoff-Roos J, Andersen LF, et al. ^192^ | To determine whether tx with ampicillin and metronidazole in women with threatened idiopathic PTL will prolong the gestation | RCT; Masking: Subject, physician, other care providers: dk Pharm.: yes | Contractions: <10 min apart for >60 min | EGA: 26-34 wks, Intact Membranes Other: threatened idiopathic PTL, no: allergy to protocol drug, chorioamnionitis, dilation >4 cm, maternal age < 18 yrs, multiple gestation, placenta previa, uterine anomaly, placental abruption, infections requiring antibiotic therapy, severe preeclampsia, antibiotic therapy at admission. | 112/110 | | | Age (SD) p=NS | | | Tx1 Ampicillin IV 2 g / 6 hrs CoT: study entry DoT: 24 hrs Pivampicillinoral 500 mg CoT: after iv DoT: every 8 hrs for 7 days Metronidazole intravenous 500 mg/8 hrs CoT: with in ampicillin DoT: 24 hrs Metronidazole oral 400 mg CoT: with pivampicillin DoT: every 8 hrs for 7 days | Ritodrine AoT: tocolysis Dexamethasone AoT: fetal lung maturity Betamethasone AoT: fetal lung maturation | | | Country: Denmark Time periuod: 1989-1994 | C=84% M=64%
  59 | | 51
  28.4 | | 27.7
  (4.5) | | (5.3)

Evidence Table 12: Antibiotics - Study design

Author (year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor | Patient Inclusion/Exclusion Characteristics | Sample Size Initial/End | | | Demographic Characteristics | | | Antibiotics Intervention | Uniform Adjunctive Drug Intervention | Uniform Non-Drug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Author (year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor | Patient Inclusion/Exclusion Characteristics | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Antibiotics Intervention | Uniform Adjunctive Drug Intervention | Uniform Non-Drug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Oyarzún E,Gómez R, Rioseco A, et al. ^211^ | To assess the efficacy of antibiotic admin on pregnancy outcome in women w/PTL and intact membranes receiving adjunctive parenteral tocolysis | RCT; Masking: Subject, physician: yes Pharm., other care providers: dk | Contractions: 4/20 min for 1 hr or History of contractions and Dilation>1 cm and Effacement:>80% | EGA: 22-36 wks Other: no: abnormal fetus, allergy to protocol drug, current or recent antibiotic therapy, current bleeding/hemorrhage, dilation >5 cm, fetal distress, hypertensive disorders, maternal fever, multiple gestation, placenta previa, rupture of membranes, fetal death, abruption, renal disease, cardiac disease, urinary tract infection, use of antibiotics w/in 5 days of entering study | 196/173 | | | Mean Age (Range) p=NS *statistics based on N=80 vs. the total sample of the antibiotic group N=83 | | | Tx1 Amoxicillin 250 mg oral CoT: dk DoT: every 8 hrs for 7 days Erythromycin 500 mg oral CoT: dk DoT: every 6 hrs for 7 days | Ritodrine AoT: tocolysis or Fenoterol AoT: tocolysis and Betamethasone AoT: fetal lung maturity | Amnio-centesis | | Country: Chile Time period: 1991-1994 | M=96% C=68%
  83 | | 90
  28.7* | | 27.3
  (18-41) | | (18-41)

Evidence Table 12: Antibiotics - Study design

Author (year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor | Patient Inclusion/Exclusion Characteristics | Sample Size Initial/End | | | Demographic Characteristics | | | Antibiotics Intervention | Uniform Adjunctive Drug Intervention | Uniform Non-Drug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Author (year) | Research Objective | Study design (continued) & Masking | Definition of Preterm Labor | Patient Inclusion/Exclusion Characteristics | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Antibiotics Intervention | Uniform Adjunctive Drug Intervention | Uniform Non-Drug Intervention | Compliance Assessment | Country & Time Period | Quality Scores
Winkler M, Gelings R, Putz I, et al. (1997) | To examine if pre-partum adjuvant antibiotic treatment could reduce the rate of inflammatory lesions in patients with PTL | Prospective cohort study; Masking: none | Contractions: 3/30 minand Dilation:<3 cm | EGA: 18 to 35 wks Intact membranes Other no: multiple gestation, uterine anomaly, polyhydramnion, diabetes mellitus, amniotic infectious syndrome, dilation >3 cm, hypertension. | 140/140 | | | Age (Range) p=NS | | | Tx1 Polyvidon-iodine suppository 1 time/day CoT: dk DoT: 7 days Tx2 Ceftizoxaim IV 2 g/ 2 times per day CoT: dk DoT: dk or Ampicillan IV 2 g/ 3 times per day CoT: dk DoT: dk or Erythromycin IV 500 mg/ 3 times per day CoT: dk DoT: dk | Fenoterol AoT: tocolysis Magnesium AoT: tocolysis | | Inpatient | Country: Germany Time period: dk | M=56% C=35%
  74 | 66
  28.5 | 29.0
  (19-41) | (20-42)

Evidence Table 12: Antibiotics - Outcomes

Author (year) | Delivery | | | | | | | | | Maternal | | | | | | Infant | | | | | | | | | | | | Other Analyses | Conclusions
Author (year) | Estimated Gestational Age | | | Prolongation of Pregnancy Days | | | Gestational Weeks | | | Length of Hospital Stay | | | Maternal Morbidity | | | Birth Weight (g) | | | APGAR Score | | | Length of Hospital Stay | | | Other Infant Outcomes | | | Other Analyses | Conclusions
Author (year) | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Other Analyses | Conclusions
Morales WJ, Angel JL, O'Brien WF, et al. ^198^ | Mean (SD) p=NS | | | Mean (SD) Tx1 vs Cx: p<0.01 Tx2 vs Cx: p<0.05 | | | Delivery at Term: 37 wks Tx1 vs Cx: p<.01 Tx2 vs Cx: p=NS | | | | | | | | | Mean (SD) p=NS | | | | | | | | | | | | Patients w/neg amniotic fluid cultures: prolongation of pregnancy days In women with vaginal specimens consistent with: G. Vaginalis Ampicillin p<.05 Erthromycin p=NS Group B Strep Ampicillin p<.05 Erthromycin p<.05 G. Vaginalis & Group B Strep Ampicillin p<.05 Erthromycin p<.05 | Antibiotic therapy sig improves prolongation days, Erthromycin sig improves delivery at term
  30.9 | 30.8 | 31.8
  (2.9) | (2.5) | (2.1)
  31.7 | 28.5 | 16.6
  (23.2) | (19.0) | (17.7)
  45% | 30% | 15%
  2437 | 2409 | 2135
  (767) | (807) | (675)

Evidence Table 12: Antibiotics - Outcomes

Author (year) | Delivery | | | | | | | | | Maternal | | | | | | Infant | | | | | | | | | | | | Other Analyses | Conclusions
Author (year) | Estimated Gestational Age | | | Prolongation of Pregnancy Days | | | Gestational Weeks | | | Length of Hospital Stay | | | Maternal Morbidity | | | Birth Weight (g) | | | APGAR Score | | | Length of Hospital Stay | | | Other Infant Outcomes | | | Other Analyses | Conclusions
Author (year) | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Other Analyses | Conclusions
Winkler M, Baumann L, Ruckhäberle, KE, et al. ^202^ | | | | Mean (SD) p=NS | | | | | | | | | | | | Mean (SD) p=dk | | | | | | | | | | | | Analyses by intact membranes, u urealyticum-positive, u urealyticum-negative | Intervention effectively alters cervical effacement, intact membranes, vaginal ueraplasmal colonization and possibly elevated C-reactive protein values
  34 | | 25
  (26) | | (23)
  2545 | | 2270
  (660) | | (760)

Evidence Table 12: Antibiotics - Outcomes

Author (year) | Delivery | | | | | | | | | Maternal | | | | | | Infant | | | | | | | | | | | | Other Analyses | Conclusions
Author (year) | Estimated Gestational Age | | | Prolongation of Pregnancy Days | | | Gestational Weeks | | | Length of Hospital Stay | | | Maternal Morbidity | | | Birth Weight (g) | | | APGAR Score | | | Length of Hospital Stay | | | Other Infant Outcomes | | | Other Analyses | Conclusions
Author (year) | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Other Analyses | Conclusions
Newton ER, Dinsmoor MJ, Gibbs RS ^195^ | Mean (SD) p=ns | | | Mean (SD) p=ns Time gained <14 days p=NS | | | Delivery at >37 wks p=ns | | | | | | Maternal Infection p=ns Mean episodes recurrent PTL (SD) p=ns | | | Mean (SD) p=NS | | | | | | | | | Neonatal Sepsis p=ns Pneumonia p=ns Meningitis p=NS | | | Findings for groups by <32 wks, fetal weight <2000 gms, initial cervical dilation >2cm, elevated c-reactive protein levels, elevated erythrocyte sedimentation rate (>32), bacterial vaginosis all non-sig | Adjunctive antibiotic treatment in idiopathic PTL in patients w/cervical dilation >1 cm is ineffective in altering measured outcomes
  36.8 | | 36.8
  (2.9) | | (2.8)
  34.2 | | 34.1
  (21) | | (24)
  20% | | 24%
  62% | | 56%
  0.49 | | 0.43
  (0.9) | | (0.8)
  2855 | | 2847
  (667) | | (607)
  0 | | 0

Evidence Table 12: Antibiotics - Outcomes

Author (year) | Delivery | | | | | | | | | Maternal | | | | | | Infant | | | | | | | | | | | | Other Analyses | Conclusions
Author (year) | Estimated Gestational Age | | | Prolongation of Pregnancy Days | | | Gestational Weeks | | | Length of Hospital Stay | | | Maternal Morbidity | | | Birth Weight (g) | | | APGAR Score | | | Length of Hospital Stay | | | Other Infant Outcomes | | | Other Analyses | Conclusions
Author (year) | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Other Analyses | Conclusions
McGregor JA, French JI, Seo K ^199^ | Mean (SD) p=NS | | | Mean Days (SD) p=0.02 | | | Delivered at <37 wks (%) p=NS Delivered at <32 wks (%) p=NS PROM (%) p=NS | | | | | | Chorioamnionitis (%) p=NS Postpartum endometritis (%) p=NS | | | Mean (SD) (643.0) (694.2 ) p=NS Birth weight <2500 g (%) p=NS | | | | | | Days in level 2 or 3 nursery (SD) p=0.02 | | | Neonatal deaths (%) p=NS SIDS (%) p=NS Neonatal sepsis (%) p=NS Pneumonia (%) p=NS | | | | Clindamycin therapy effectively reduced incidence of PROM, and increased interval to delivery if enrolled before 33 wks.
  35.4 | | 34.9
  (3.3) | | (3.3)
  35.3 | | 25.4
  (24.1) | | (20.0)
  33 | | 31
  (62.3) | | (62.0)
  8 | | 7
  (20.5) | | (21.9)
  5 | | 7
  (9.4) | | (21.9)
  1 | | 3
  (1.9) | | (6.0)
  4 | | 4
  (11.1) | | (11.4)
  2586.2 | | 2441.0
  21 | | 26
  (39.6) | | (52.0)
  7.1 | | 16.8
  (11.6) | | (51.0)
  2 | | 0
  (3.8) | | (0)
  1 | | 1
  (1.9) | | (2.0)
  16 | | 14
  (30.2) | | (28.0)
  1 | | 3
  (1.9) | | (6.0)

Evidence Table 12: Antibiotics - Outcomes

Author (year) | Delivery | | | | | | | | | Maternal | | | | | | Infant | | | | | | | | | | | | Other Analyses | Conclusions
Author (year) | Estimated Gestational Age | | | Prolongation of Pregnancy Days | | | Gestational Weeks | | | Length of Hospital Stay | | | Maternal Morbidity | | | Birth Weight (g) | | | APGAR Score | | | Length of Hospital Stay | | | Other Infant Outcomes | | | Other Analyses | Conclusions
Author (year) | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Other Analyses | Conclusions
Newton ER, Shields L, Ridgway LE, et al. ^196^ | Mean (SD) p=ns | | | Median (Range) p=ns | | | Delivery at >36 wks p=ns | | | | | | Maternal infection p=ns Recurrent PTL p=ns | | | Mean (SD) p=ns Birth weight <2500 g p=ns Net gain in fetal weight (SD) p=ns | | | <7 at 5 min p=ns | | | | | | Fetal Mortality p=ns HMD p=ns Intraventricular Hemorrhage p=ns Neonatal Sepsis p=ns NEC p=ns Mechanical ventilation p=ns Congenital abnormality p=ns No perinatal morbidity p=ns | | | Findings for groups by singleton gestation, gestation <31 wks, elevated c-reactive protein levels, white blood cell count >13,000 cells/mm^3^, abnormal vaginal flora, presence of U. urealyticam | A combination of antibiotics and a prostaglandin inhibitor is ineffective in altering the measured outcomes
  34.5 | | 33.5
  (4.1) | | (4.0)
  26 | | 26
  (1-79) | | (1-71)
  46% | | 37%
  1 | | 6
  8 | | 8
  2430 | | 2295
  (899) | | (795)
  55% | | 69%
  789 | | 645
  (674) | | (649)
  4 | | 5
  2 | | 0
  12 | | 13
  2 | | 2
  1 | | 1
  1 | | 1
  12 | | 11
  2 | | 0
  62% | | 58%

Evidence Table 12: Antibiotics - Outcomes

Author (year) | Delivery | | | | | | | | | Maternal | | | | | | Infant | | | | | | | | | | | | Other Analyses | Conclusions
Author (year) | Estimated Gestational Age | | | Prolongation of Pregnancy Days | | | Gestational Weeks | | | Length of Hospital Stay | | | Maternal Morbidity | | | Birth Weight (g) | | | APGAR Score | | | Length of Hospital Stay | | | Other Infant Outcomes | | | Other Analyses | Conclusions
Author (year) | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Other Analyses | Conclusions
McCaul JF, Perry KG Jr., Moore JL Jr., et al. ^203^ | Mean for PTL (SD) p=dk | | | Mean for PTL (SD) p=dk | | | | | | | | | Chorioamnionitis for PTL | | | Mean for PTL (SD) p=NS | | | | | | Mean for PTL (SD) p=NS | | | NRDS/HMD for PTL p=NS Neonatal Sepsis for PTL p=NS | | | | Intervention ineffective in altering studied outcomes
  30.1 | | 31.2
  (3.5) | | (2.5)
  35.2 | | 34.7
  (29.6) | | (21.1)
  0 | | 1
  2403.3 | | 2462.6
  (850.3) | | (617.5)
  27.7 | | 24.4
  (161.3) | | (52.6)
  0 | | 1
  1 | | 1

Evidence Table 12: Antibiotics - Outcomes

Author (year) | Delivery | | | | | | | | | Maternal | | | | | | Infant | | | | | | | | | | | | Other Analyses | Conclusions
Author (year) | Estimated Gestational Age | | | Prolongation of Pregnancy Days | | | Gestational Weeks | | | Length of Hospital Stay | | | Maternal Morbidity | | | Birth Weight (g) | | | APGAR Score | | | Length of Hospital Stay | | | Other Infant Outcomes | | | Other Analyses | Conclusions
Author (year) | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Other Analyses | Conclusions
Romero R, Sibai B, Caritis S, et al. ^194^ | | | | Median (Range) p=ns Randomization to delivery interval (%) <24 hrs <48 hrs <7days p=NS | | | Delivery <37 wks (%) p=ns Delivery <32 wks (%) p=ns | | | Readmission for PTL requiring tocolysis (%) p=ns | | | Chorioamniotitis (%) p=ns Endometritis (%) p=ns | | | Mean (SEM) p=ns | | | | | | Median NICU stay in days (Range) p=ns Admission to NICU (%) p=NS | | | NRDS or HMD (%) p=NS Grade 3 Intraventricular Hemorrhage (%) p=NS Neonatal sepsis (%) p=NS NEC (%) p=NS Neonatal death (%) p=NS <Stage III retinopathy (%) p=NS | | | Patients w/microbial invasion of amniotic cavity: 10/115 on antibiotics, 4/124 on placebo, difference not sig. Patients w/positive vaginal cultures 21 (46%) on antibiotics, 36 (45%) on placebo p=0.20 | Intervention ineffective in altering outcomes
  35 | | 32
  (0-112) | | (1-101)
  3 | | 4
  (2.3) | | (2.8)
  11 | | 6
  (8.4) | | (4.2)
  29 | | 24
  (22.1) | | (16.7)
  69 | | 74
  (52.7) | | (51.4)
  22 | | 15
  (16.8) | | (10.4)
  19 | | 20
  (14.3) | | (13.9)
  3 | | 7
  (2.3) | | (4.9)
  4 | | 7
  (3.1) | | (4.9)
  2535 | | 2683
  (69) | | (60)
  13 | | 11
  (<1-136) | | (<1-172)
  44 | | 46
  (34) | | (32)
  14 | | 11
  (11) | | (8)
  1 | | 1
  (1) | | (1)
  14 | | 15
  (11) | | (11)
  3 | | 5
  (2) | | (4)
  2 | | 0
  (2) | | (0)
  2 | | 0
  (2) | | (0)

Evidence Table 12: Antibiotics - Outcomes

Author (year) | Delivery | | | | | | | | | Maternal | | | | | | Infant | | | | | | | | | | | | Other Analyses | Conclusions
Author (year) | Estimated Gestational Age | | | Prolongation of Pregnancy Days | | | Gestational Weeks | | | Length of Hospital Stay | | | Maternal Morbidity | | | Birth Weight (g) | | | APGAR Score | | | Length of Hospital Stay | | | Other Infant Outcomes | | | Other Analyses | Conclusions
Author (year) | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Other Analyses | Conclusions
Norman K, Pattison RC, de Souza J, et al. ^200^ | Mean (SD) p=NS | | | Median (25Q-75Q) p=.04 | | | | | | | | | Endometritis p=NS | | | Mean (SD) p=NS | | | | | | Median (25Q-75Q) p=NS | | | HMD p=NS Neonatal Sepsis p=NS NEC p=.02 Pneumonia p=NS PDA p=NS Neonatal Mortality p=NS | | | 26-30 wks gestation: > prolongation days than full group. p=NS >30 wks gestation: prolongation days same as full study | Ampicillin & Metronidazole: add gestational days, sig. difference in NEC
  34.4 | | 33.1
  (3.3) | | (3.8)
  15 | | 2.5
  (2-35) | | (1-29.5)
  1 | | 3
  2318 | | 2093
  (609) | | (653)
  6 | | 6
  (1-37) | | (1-50)
  3 | | 6
  2 | | 1
  0 | | 5
  2 | | 3
  3 | | 0
  2 | | 2

Evidence Table 12: Antibiotics - Outcomes

Author (year) | Delivery | | | | | | | | | Maternal | | | | | | Infant | | | | | | | | | | | | Other Analyses | Conclusions
Author (year) | Estimated Gestational Age | | | Prolongation of Pregnancy Days | | | Gestational Weeks | | | Length of Hospital Stay | | | Maternal Morbidity | | | Birth Weight (g) | | | APGAR Score | | | Length of Hospital Stay | | | Other Infant Outcomes | | | Other Analyses | Conclusions
Author (year) | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Other Analyses | Conclusions
Gordon M, Samuels P, Shubert P, et al. ^193^ | Mean (SD) p=0.86 | | | Mean (SD) p=0.99 Prolongation >7 days p=0.71 Prolongation >14 days p=0.91 | | | Delivery <37 wks p=0.91 Delivery <36 wks p=1.00 Delivery <35 wks p=0.50 Delivery <34 wks p=0.98 | | | | | | Maternal Infection p=ns Need for re-tocolysis p=1.00 | | | Mean (SD) p=0.85 | | | | | | | | | Neonatal Sepsis p=ns Pneumonia p=ns Neonatal Infection p=ns | | | Linear regression to compare gestational age at enrollment to preterm delivery at 34, 35, 36, 37wks p=ns Outcomes for subgroups of 9 doses, neg for GBS, twins, singletons, or <36 wk same as full study | Ceftizoxime does not change outcomes for pregnancies receiving tocolysis for PTL
  36.0 | | 35.9
  (2.9) | | (2.9)
  34.5 | | 34.6
  (21) | | (24.5)
  90% | | 85%
  81% | | 81%
  60% | | 58%
  34% | | 34%
  33% | | 29%
  21% | | 20%
  3.5% | | 5.1%
  15% | | 15%
  2660 | | 2634
  (750) | | (691)
  n=0 | | n=0
  n=0 | | n=0
  3.5% | | 5.1%

Evidence Table 12: Antibiotics - Outcomes

Author (year) | Delivery | | | | | | | | | Maternal | | | | | | Infant | | | | | | | | | | | | Other Analyses | Conclusions
Author (year) | Estimated Gestational Age | | | Prolongation of Pregnancy Days | | | Gestational Weeks | | | Length of Hospital Stay | | | Maternal Morbidity | | | Birth Weight (g) | | | APGAR Score | | | Length of Hospital Stay | | | Other Infant Outcomes | | | Other Analyses | Conclusions
Author (year) | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Other Analyses | Conclusions
Nadisauskiene R, Bergström S, Kilda A. ^191^ | Mean (SD) p<.05 | | | Mean Weeks (SD) P<.05 | | | Delivery >35 wks (%) OR=3.9 95% CI (1.6-9.4) | | | | | | Absence of Puerperal Infection (%) OR=65.3 95% CI (9.3-2,715.7) Absence of histological chorioamnionitis (%) OR=13.0 95% CI (3.4-72.2) | | | >2500 gms (%) OR=3.9 95% CI (1.6-9.4) >10^th^ percentile for gestational age (%) OR=9.6 95% CI (2.8-41.3) | | | >7 at 1 min (%) OR=2.0 95% CI (0.4-13.7) | | | | | | Absence of Neonatal Infection (%) OR=15.5 95% CI (4.6-65.7) Live birth (%) OR=dk 95% CI (undefined) 1 wk Neonatal Survival (%) OR=2.0 95% CI (0.5-8.3) | | | | Oral ampicillin delayed delivery; reduced maternal and neonatal morbidity; reduced placental infection and postpartum fever
  36.6 | | 33.8
  (4.5) | | (5.8)
  7.3 | | 5.8
  (4.9) | | (5.2)
  35 | | 14
  (59) | | (27)
  58 | | 24
  (98) | | (47)
  56 | | 30
  (95) | | (59)
  35 | | 14
  (59) | | (27)
  55 | | 29
  (93) | | (57)
  56 | | 46
  (95) | | (90)
  55 | | 24
  (93) | | (47)
  59 | | 49
  (100) | | (96)
  54 | | 43
  (92) | | (84)

Evidence Table 12: Antibiotics - Outcomes

Author (year) | Delivery | | | | | | | | | Maternal | | | | | | Infant | | | | | | | | | | | | Other Analyses | Conclusions
Author (year) | Estimated Gestational Age | | | Prolongation of Pregnancy Days | | | Gestational Weeks | | | Length of Hospital Stay | | | Maternal Morbidity | | | Birth Weight (g) | | | APGAR Score | | | Length of Hospital Stay | | | Other Infant Outcomes | | | Other Analyses | Conclusions
Author (year) | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Other Analyses | Conclusions
Nadisauskiene R, Bergstrom S ^201^ | | | | | | | Delivered > 32 wks OR=1.6 95% CI (0.7-3.9) | | | | | | Absence of peuperal uterine infection OR=3.7 95% CI (1.3-10.3) Absence of histological chorioamnionitis OR=5.9 95% CI (2.0-19.4) | | | Mean (SD) >2000 g OR=1.3 95% CI (0.5-3.2) P=NS > 10^th^ percentile for gestational age OR=0.6 95% CI (0.2-1.6) p=NS | | | APGAR >7 at 1 min OR=1.5 95% CI (0.6-3.8) p=NS | | | | | | Fetal Mortality p=NS Absence of Neonatal Infection OR=19.0 95% CI (5.5-80.8) Perinatal Mortality p=NS Neonatal Survival 1^st^ wk OR=1.2 95% CI (0.4-3.6) p=NS Live Birth (%) p=NS | | | | Intervention effectively alters absence of neonatal infection, absence of histological chorioamnionitis, absence of puerperal uterine infections
  28 | | 30
  36 | | 32
  38 | | 30
  1743 | | 1687
  (490) | | (530)
  18 | | 20
  12 | | 22
  18 | | 18
  0 | | 0
  40 | | 20
  182/ 1000 | | 207/ 1000
  36 | | 46
  44 | | 58
  (100) | | (100)

Evidence Table 12: Antibiotics - Outcomes

Author (year) | Delivery | | | | | | | | | Maternal | | | | | | Infant | | | | | | | | | | | | Other Analyses | Conclusions
Author (year) | Estimated Gestational Age | | | Prolongation of Pregnancy Days | | | Gestational Weeks | | | Length of Hospital Stay | | | Maternal Morbidity | | | Birth Weight (g) | | | APGAR Score | | | Length of Hospital Stay | | | Other Infant Outcomes | | | Other Analyses | Conclusions
Author (year) | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Other Analyses | Conclusions
Cox SM, Bohman VR, Sherman ML, et al. ^197^ | Mean (SD) p=NS | | | Time gained in utero <1 day (%) p=NS 2-4days (%) p=NS 5-7 days (%) p=NS 8-28 days (%) p=NS >28 days (%) p=NS | | | 24-26 wks (%) p=NS 27-29 wks (%) p=NS 30-32 wks (%) p=.04 33-35 wks (%) p=.05 >36 wks (%) p=NS | | | | | | | | | Mean (SEM) p=NS <1000 gms (%) p=NS 1001-1500 gms (%) p=NS 1501-2000 gms (%) p=NS 2001-2500 gms (%) p=NS >2501 gms (%) p=NS | | | >7 at 5 min (%) p=NS | | | Mean NICU Days (SEM) p=NS | | | Neonatal Deaths (%) p=NS Stillbirth p=NS No respiratory distress (%) p=NS Respiratory distress, ventilator (%) p=NS | | | | Intervention ineffective in altering the studied outcomes.
  34.2 | | 34.1
  (0.7) | | (0.6)
  12 | | 11
  (31) | | (28)
  0 | | 3
  (--) | | (8)
  1 | | 0
  (3) | | (--)
  8 | | 9
  (21) | | (23)
  18 | | 16
  (46) | | (41)
  2 | | 0
  (5) | | (0)
  3 | | 3
  (8) | | (8)
  9 | | 13
  (23) | | (33)
  9 | | 6
  (23) | | (15)
  16 | | 17
  (41) | | (44)
  2394 | | 2225
  (125) | | (117)
  2 | | 0
  (5) | | (-)
  4 | | 7
  (10) | | (17)
  9 | | 14
  (23) | | (33)
  6 | | 5
  (15) | | (12)
  19 | | 16
  (48) | | (38)
  39 | | 41
  (98) | | (98)
  19 | | 22
  (0.2) | | (0.2)
  1 | | 0
  (3) | | (0)
  0 | | 0
  28 | | 27
  (70) | | (64)
  8 | | 8
  (20) | | (19)

Evidence Table 12: Antibiotics - Outcomes

Author (year) | Delivery | | | | | | | | | Maternal | | | | | | Infant | | | | | | | | | | | | Other Analyses | Conclusions
Author (year) | Estimated Gestational Age | | | Prolongation of Pregnancy Days | | | Gestational Weeks | | | Length of Hospital Stay | | | Maternal Morbidity | | | Birth Weight (g) | | | APGAR Score | | | Length of Hospital Stay | | | Other Infant Outcomes | | | Other Analyses | Conclusions
Author (year) | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Other Analyses | Conclusions
Svare J, Langhoff-Roos J, Andersen LF, et al. ^192^ | Median (range) p<0.05 | | | Median (range) p<0.05 | | | Delivery at < 37 wks (%) p=0.03 | | | | | | Chorioamnionitis (%) p=0.04 | | | Mean (SD) p=0.08 Birth weight <2500g (%) p=dk | | | APGAR < 7 at 5 min (%) p=0.28 | | | Days (range) p=0.03 | | | Admission to NICU (%) p=0.03 Mean Ventilation Days (SD) p=0.78 Days of neonatal antibiotics (SD) p=0.35 Umbilical arterial pH<7.17 (%) p=0.82 Septicemia/pneumonia/meningitis (%) p=0.18 | | | Comparison of background characteristics and outcomes of study participants and eligible women who were not included in the study. | Intervention effectively alters gestational age at birth.
  37 | | 34
  (26-43) | | (26-41)
  47.5 | | 27
  (0-97) | | (0-88)
  25 | | 33
  (42) | | (65)
  3 | | 0
  (5) | | (0)
  2662 | | 2370
  (842) | | (900)
  23 | | 27
  (59) | | (53)
  5 | | 1
  (9) | | (2)
  15.5 | | 27.0
  (1-60) | | (2-121)
  23 | | 32
  (40) | | (63)
  9.7 | | 10.8
  (15.7) | | (17.2)
  5.9 | | 6.6
  (2.8) | | (4.2)
  4 | | 2
  (7) | | (4)
  6 | | 11
  (10) | | (22)

Evidence Table 12: Antibiotics - Outcomes

Author (year) | Delivery | | | | | | | | | Maternal | | | | | | Infant | | | | | | | | | | | | Other Analyses | Conclusions
Author (year) | Estimated Gestational Age | | | Prolongation of Pregnancy Days | | | Gestational Weeks | | | Length of Hospital Stay | | | Maternal Morbidity | | | Birth Weight (g) | | | APGAR Score | | | Length of Hospital Stay | | | Other Infant Outcomes | | | Other Analyses | Conclusions
Author (year) | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Other Analyses | Conclusions
Oyarzún E, Gómez R, Rioseco A, et al. ^211^ | | | | Median Hours (range) p=ns Prolongation <48 hrs p=ns | | | Delivery at <37 wks p=ns Delivery at <34 wks p=ns | | | | | | Chorioamnionitis p=ns Endometritis p=ns Cesarean Section p<0.05 | | | Mean (SD) p=ns | | | | | | | | | Neonatal Deaths p=ns NRDS or HMD p=ns Neonatal Sepsis p=ns Pneumonia p=ns Suspected Sepsis p=0.03 Admit to NICU p=ns | | | Outcomes by positive vs. neg microbial invasion of amniotic cavity found differences for preterm delivery <34 wks, chorioamnionitis, and endometritis | Although results show that amoxicillin and erythromycin do not prolong pregnancy in patients with PTL and intact membranes, intervention effectively alters the outcome of suspected sepsis in neonates and approaches significance for bronchial pneumonia
  576 | | 648
  (1-2952) | | (1-2520)
  14% | | 16%
  46% | | 50%
  18% | | 12%
  3.6% | | 3.3%
  2.4% | | 5.6%
  12% | | 28%
  2879 | | 2942
  (723) | | (676)
  3% | | 1%
  11% | | 7%
  1% | | 2.2%
  0 | | 4%
  0 | | 6.7%
  6.4% | | 11%

Evidence Table 12: Antibiotics - Outcomes

Author (year) | Delivery | | | | | | | | | Maternal | | | | | | Infant | | | | | | | | | | | | Other Analyses | Conclusions
Author (year) | Estimated Gestational Age | | | Prolongation of Pregnancy Days | | | Gestational Weeks | | | Length of Hospital Stay | | | Maternal Morbidity | | | Birth Weight (g) | | | APGAR Score | | | Length of Hospital Stay | | | Other Infant Outcomes | | | Other Analyses | Conclusions
Author (year) | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Tx1 | Tx2 | Cx | Other Analyses | Conclusions
Winkler M, Gelings R, Putz I, et al. (1997) | Median (Range) p<0.01 | | | Median Days (Range) p<0.05 | | | | | | | | | | | | Median (Range) p=NS | | | | | | | | | | | | | Intervention ineffective in altering studied outcomes.
  35 | | 33
  (23-41) | | (23-41)
  22 | | 7
  (1-138) | | (1-92)
  2400 | | 1965
  (470-4610) | | (450-3680)

Evidence Table 13: Home Uterine Activity Monitoring-Study design

Author (year) | Research Objective& Definition of Preterm Labor | Study design (continued) & Masking | Experimental Intervention | Comparison Intervention (s) | Patient Inclusion/Exclusion Characteristics | Demographic Characteristics | Sample SizeInitial/End | Co-Interventions by Group | Compliance Assessment | Country & Time Period | Outcome Measures | Quality Scores
Iams et al. (1990) | To compare ambulatory tocodynamometry with self-palpation of uterine activity in a population of women treated for preterm labor. Definition of PTL was unclear, but all patients had been treated with tocolytics. | RCT; Masking: none | Education plus monitor (EM) | Education plus self-palpation (EP) | Inclusion: Treated for PTL, singleton gestation and informed consent | None provided. | | Experimental Group 1: Daily contact by center staff to report symptoms and transmit data Comparison Group 2: Daily nursing contact to report symptoms Oral tocolysis was administered in both groups, but discontinued in 2/46 EM patients and 2/EP patients. Note that in both groups physicians were free to modify therapy and activity levels, including adjusting oral tocolytic dosage to maintain contraction frequency of less than 4 per hour. | Nursing staff assessed compliance of both patients and physicians to study protocol through frequent contact | Country: United States Time period: dk | Mean gestational age Delivery @<36 weeks Delivery @<36 weeks with recurrent PTL Delivery @term PROM Infant | M=36% C=27%
  49/46 | | 27/21

Evidence Table 13: Home Uterine Activity Monitoring-Study design

Author (year) | Research Objective& Definition of Preterm Labor | Study design (continued) & Masking | Experimental Intervention | Comparison Intervention (s) | Patient Inclusion/Exclusion Characteristics | Demographic Characteristics | Sample SizeInitial/End | Co-Interventions by Group | Compliance Assessment | Country & Time Period | Outcome Measures | Quality Scores
Watson DL, Welch RA, Mariona FG, et al. ^206^ | To compare daily home uterine monitoring and perinatal nursing support with standard care in managing patients with recurrent preterm labor during the current pregnancy in an effort to reduce preterm birth. Definition of PTL: contractions for a period of one hour that were unresponsive to bed rest and hydration, accompanied by cervical change in a pregnancy of 20-37 gestational age with a viable fetus. | RCT; Masking: none | Daily uterine activity monitoring plus nursing support | Standard of care (Included instructions to contact physician if patient became aware of any symptoms of PTL and/or 4 or more palpated uterine contractions per hour that did not respond to hydration and 1hour bedrest) | Inclusion: Gestational ages of 20-37 weeks. All patients had been treated successfully for PTL and stabilized. | Exp Group: n=33 Age: 24.2±1.3 White: 7 Black: 25 Other: 1 Previous PTL: 10 Previous PTD: 12 Parity: 1.4±0.3 Comp Grp: n=34 Age: 22.6±1.09 White: 8 Black: 24 Other: 2 Previous PTL: 8 Previous PTD: 9 Parity: 1.6±0.3 | 86/67 | Both groups received education on self-palpation for contractions and signs and symptoms of PTL. Those patients diagnosed with recurrent PTL received unspecified tocolysis. Patients were managed according to protocols at each participating institution. | Not reported. | Country: United States Time period: dk | Mean gestational age Deliveries at <37 weeks Recurrent PTL Failed tocolysis at first recurrence of PTL | M=55% C=41%

Evidence Table 13: Home Uterine Activity Monitoring-Study design

Author (year) | Research Objective& Definition of Preterm Labor | Study design (continued) & Masking | Experimental Intervention | Comparison Intervention (s) | Patient Inclusion/Exclusion Characteristics | Demographic Characteristics | Sample SizeInitial/End | Co-Interventions by Group | Compliance Assessment | Country & Time Period | Outcome Measures | Quality Scores
Nagey et al. ^207^ | To determine whether HUAM reduces the likelihood of preterm birth in women successfully treated for PTL in their current pregnancies. PTL defined as contractions with cervical change. | RCT; Masking: none | HUAM | Routine subsequent care | Gestational ages of 20 to 34 weeks. All patients had been treated successfully for PTL were being considered for discharge, and who were in the University of Maryland medical system. PTL documented by cervical change in response to uterine contractions. | Exp Group: n=28 Black: 20 Previous PTD: 7 Married: 9 Living children: 13 Prior Abortions: 12 Comp Grp: n=28 Black: 21 Previous PTD: 8 Married: 7 Living children: 17 Prior abortions: 9 | | Both groups received a weekly cervical exam and continued tocolysis with terbutaline at whatever dosage achieved successful tocolysis during initial treatment for PTL. | HUAM group: Pill count and performance of scheduled monitoring. Standard care group: Pill count and return for visits as scheduled. | Country: United States Time period: dk | Delivery > 37 weeks Delivery > 34 weeks Delivery > 32 weeks Maternal characteristics on admission resulting in PTD: dilation <2cm effacement <50% station >3 Non-delivery admissions | M=64% C=59%
  28/28 | | 28/29

Evidence Table 13: Home Uterine Activity Monitoring-Study design

Author (year) | Research Objective& Definition of Preterm Labor | Study design (continued) & Masking | Experimental Intervention | Comparison Intervention (s) | Patient Inclusion/Exclusion Characteristics | Demographic Characteristics | Sample SizeInitial/End | Co-Interventions by Group | Compliance Assessment | Country & Time Period | Outcome Measures | Quality Scores
Brown et al. ^208^ | To evaluate HUAM as an intervention in reducing the rate of preterm birth among women treated for preterm labor | RCT; Masking: none | HUAM Both groups received daily perinatal telephone contact and oral terbutaline. | No monitoring | Gestational ages 24 to 34 weeks, singleton gestation, Medicaid coverage and functioning telephone service. Excluded patients with ruptured membranes or maternal/fetal indications for delivery | Exp Grp: n= 82 Age: 20.7 ± 4.4 Black: 48 (58.5%) Primigravid: 22 (26.8%) Previous PTD: 13 (15.8%) Dilation >2cm: 40 (48.5%) Comp Grp: n=80 Age: 20.5 ± 3.8 Black: 48 (60%) Primigravid: 17 (21.2%) Previous PTD: 22 (27.5%) Dilation >2cm: 31 (38.7%) | 186/162 | Both groups received daily phone follow-up and oral terbutilane.All women had been treated with magnesium sulfate in the hospital. | Compliance assessed via daily telephone contact and transmission of uterine activity via telephone daily. | Country: United States Time period: 7/91-1/96 | Mean gestational age Delivery at <35 weeks, 35-37 weeks and >37 weeks Mean Mean neonatal hospital days NICU admissions | M=77% C=82%

Evidence Table 13: Home Uterine Activity Monitoring-Outcomes

Author (year) | Delivery | | | | Maternal | | | | Infant | | | Other Analyses | Conclusions | Comments and Limitations
Author (year) | Estimated Gestational Age | | Delivery at Specific Gestational Weeks | | Recurrent PTL | | Other maternal outcomes | | Birth Weight (g) | | Other Infant Outcomes | Other Analyses | Conclusions | Comments and Limitations
Author (year) | Tx1 | Tx2 | Tx1 | Tx2 | Tx1 | Tx2 | Tx1 | Tx2 | Tx1 | Tx2 | Other Infant Outcomes | Other Analyses | Conclusions | Comments and Limitations
Iams et al. (1990) | | | < 36 weeks: < 36 weeks w/recurrent labor term (36 weeks) | | | | | | | | | | Uterine monitoring by machine did not improve outcomes compared to self-palpation (with both groups receiving nursing support, education and symptom identification services). | Study did not reach desired sample size, and did not compare HUAM to standard care. Information was lacking on definition of PTL for inclusion and demographic characteristics of subjects. Specific reasons for stopping tocolysis in some women were not provided. There were significantly more dropouts in the EP group (22% vs. 6%). Only birth weight was measured as a neonatal outcome.
  36.9±2.8 | | 36.9±1.8
  9/46 (19.6%) | | 3/21 (14.3%)
  6/17 (35.3%) | | 2/7 (28.6%)
  37 (80%) | | 18 (86%)
  2845±630 | | 2963±418

Evidence Table 13: Home Uterine Activity Monitoring-Outcomes

Author (year) | Delivery | | | | Maternal | | | | Infant | | | Other Analyses | Conclusions | Comments and Limitations
Author (year) | Estimated Gestational Age | | Delivery at Specific Gestational Weeks | | Recurrent PTL | | Other maternal outcomes | | Birth Weight (g) | | Other Infant Outcomes | Other Analyses | Conclusions | Comments and Limitations
Author (year) | Tx1 | Tx2 | Tx1 | Tx2 | Tx1 | Tx2 | Tx1 | Tx2 | Tx1 | Tx2 | Other Infant Outcomes | Other Analyses | Conclusions | Comments and Limitations
Watson et al. ^206^ | among pts with recurrent PTL: | | among pts with recurrent PTL: <37 wks: p=.025 | | | | Failed tocolysis at 1^st^ readmission: p=.02 | | | | | | The use of daily uterine activity monitoring and nursing contact resulted in a significant reduction in preterm birth compared with the standard-care group. | Study did not provide data on any neonatal outcomes, and addressed few maternal outcomes. Study does not address the affect of nursing contact separate from uterine activity monitoring.
  36.1±(0.9) | | 33.9±1.0
  7/15 (47%) | | 16/19 (84%)
  15 (45%) | | 19 (56%)
  0 | | 6 (32%)

Evidence Table 13: Home Uterine Activity Monitoring-Outcomes

Author (year) | Delivery | | | | Maternal | | | | Infant | | | Other Analyses | Conclusions | Comments and Limitations
Author (year) | Estimated Gestational Age | | Delivery at Specific Gestational Weeks | | Recurrent PTL | | Other maternal outcomes | | Birth Weight (g) | | Other Infant Outcomes | Other Analyses | Conclusions | Comments and Limitations
Author (year) | Tx1 | Tx2 | Tx1 | Tx2 | Tx1 | Tx2 | Tx1 | Tx2 | Tx1 | Tx2 | Other Infant Outcomes | Other Analyses | Conclusions | Comments and Limitations
Nagey et al. ^207^ | | | >37 weeks: >34 weeks: 2 >32 weeks: | | Non-delivery admissions: | | On admission resulting in PTD: dilation <2cm effacement <50% station 3 | | | | | | HUAM is not effective in reducing the likelihood of preterm delivery in patients successfully treated for preterm labor in their current pregnancies. | Small sample size. 4 patients assigned to HUAM group were not dismissed from the hospital and never received the intervention.
  12/28 | | 13/28
  1/28 | | 22/28
  23/28 | | 25/28
  11/28 | | 5/28
  10/16 | | 5/15
  8/16 | | 6/15
  11/16 | | 9/15

Evidence Table 13: Home Uterine Activity Monitoring-Outcomes

Author (year) | Delivery | | | | Maternal | | | | Infant | | | Other Analyses | Conclusions | Comments and Limitations
Author (year) | Estimated Gestational Age | | Delivery at Specific Gestational Weeks | | Recurrent PTL | | Other maternal outcomes | | Birth Weight (g) | | Other Infant Outcomes | Other Analyses | Conclusions | Comments and Limitations
Author (year) | Tx1 | Tx2 | Tx1 | Tx2 | Tx1 | Tx2 | Tx1 | Tx2 | Tx1 | Tx2 | Other Infant Outcomes | Other Analyses | Conclusions | Comments and Limitations
Brown et al. ^208^ | | | <35 weeks: 35-37 weeks: >37 weeks: | | | | | | | | Exp Grp: NICU admissions: 20 NICU Days: 3.3±11.4 Mechanical Ventilation: 2 (2.4%) Comp Grp: NICU Admissions: 22 NICU days: 2.2±6.5 Mechanical Ventilation: 3 (3.8%) | Multivariate logistic regression for predicting delivery at <35 weeks' gestation found only cervical dilation at enrollment predicted delivery (OR 4.35). Among women with cervical dilation 2cm at enrollment, effect of monitoring vs. not monitoring yielded OR of 2.01 (95% CI 0.47-9.2). Analysis showed no effect of cervical dilatation or enrollment on compliance. Levels of compliance also did not have an impact on rate of delivery <35 weeks gestation. | HUAM is not effective in reducing the likelihood of preterm delivery in patients successfully treated for preterm labor in their current pregnancies. | Compliance was lower than expected.
  37.0±2.5 | | 36.6±2.1
  9 (10.9%) | | 12 (15.0%)
  31 (37.8%) | | 36 (45.0%)
  42 (51.1%) | | 32 (40.0%)
  2933.0±639.9 | 2943.5±547.0