# Bibliography

Ablin RJ. Developing biotechnological and pharmacotherapeutic advances in early pregnancy. Early Pregnancy. 1996;2(2):133-5. [pmid: 9363211].
ACOG Committee Opinion: Committee on Obstretics: Maternal and Fetal Medicine. Home uterine activity monitoring. Int J Gynecol Obstet. 1993;41:203-6.
ACOG Committee Opinion: Committee on Obstretics Practice. Home uterine activity monitoring. Int J Gynecol Obstet. 1996;54:71-7.
ACOG technical bulletin. Preterm labor. Int J Gynecol Obstet. 1995;50:303-13.
Adams WG, Kinney JS, Schuchat A, et al. Outbreak of early onset Group B streptococcal sepsis. Pediatr Infect Dis J. 1993;12:565-70. [pmid: 8345997].
Akerlund M, Melin P, Maggi M. Potential use of oxytocin and vasopressin V1a antagonists in the treatment of preterm labour and primary dysmenorrhoea. Adv Exp Med Biol. 1995;395:595-600. [pmid: 8714023].
Akinbiyi AA. Unexplained elevated maternal serum alpha-fetoprotein in singleton pregnancies as a predictor of fetal risk. Int J Gynecol Obstet. 1996;53:17-21.
al-Najashi SS, al-Mulhim AA. Prolongation of pregnancy in multiple pregnancy. Int J Gynecol Obstet. 1996;54:131-5.
Alexander GR. Preterm birth: Etiology, mechanisms, and prevention. Prenat Neonat Med. 1998;3:3-9.
Allbert JR, Johnson C, Roberts WE, et al. Tocolysis for recurrent preterm labor using a continuous subcutaneous infusion pump. J Reprod Med. 1994;39:614-8. [pmid: 7996525].
Ally K, Nicolas A, Thoumsin H, et al. Apport du gluconate de magnesium dans la tocolyse parenterale par la ritodrine. J Gynecol Obstet Biol Reprod (Paris). 1992;21:370-4. [pmid: 1624721].
Almeida L, Schmauch A, Bergstrom S. A randomised study on the impact of peroral amoxicillin in women with prelabour rupture of membranes preterm. Gynecol Obstet Invest. 1996;41:82-4. [pmid: 8838964].
Alper M, Cohen WR. Pulmonary edema associated with ritodrine and dexamethasone treatment of threatened premature labor. A case report. J Reprod Med. 1983;28:349-52. [pmid: 6152991].
Amy JJ, Van Liedekerke D. Suppression of preterm labor: Means and policy [Dut]. Tijdschrift Voor Geneeskunde. 1996;52:591-8.
Ananth CV, Guise J-M, Thorp JM Jr. Utility of antibiotic therapy in preterm premature rupture of membranes: A meta-analysis. Obstet Gynecol Surv. 1996;51:324-8. [pmid: 8744417].
Andersen LF, Lyndrup J, Akerlund M, et al. Oxytocin receptor blockade: A new principle in the treatment of preterm labor?. Am J Perinatol. 1989;6:196-9. [pmid: 2540760].
Andersson KE, Forman A, Ulmsten U. Pharmacology of labor. Clin Obstet Gynecol. 1983;26:56-77. [pmid: 6132694].
Andreassi S, Teso A. Magnesium oxide and tocolysis. Eur Rev Med Pharmacol Sci. 1992;14:309-12.
Andrews WW, Goldenberg RL, Hauth JC. Preterm labor: Emerging role of genital tract infections. Infect Agents Dis. 1995;4:196-211. [pmid: 8665085].
Antsaklis A, Daskalakis G, Michalas S, Aravantinos D. Erythromycin treatment for subclinical Ureaplasma urealyticum infection in preterm labor. Fetal Diagn Ther. 1997;12:89-92. [pmid: 9218948].
Armer TL, Duff P. Intraamniotic infection in patients with intact membranes and preterm labour. Obstet Gynecol Surv. 1991;46:589-93. [pmid: 1745471].
Armson BA, Samuels P, Miller F, et al. Evaluation of maternal fluid dynamics during tocolytic therapy with ritodrine hydrochloride and magnesium sulfate. Am J Obstet Gynecol. 1992;167:758-65. [pmid: 1530035].
Arresting premature labour: Orciprenaline and other drugs. Drug Ther Bull. 1973;11:25-7. [pmid: 4580877].
Ascarelli MH, Morrison JC. Use of fetal fibronectin in clinical practice. Obstet Gynecol Surv. 1997;52(4 Suppl):S1-S12. [pmid: 9095493].
Ashworth MF, Spooner SF, Verkuyl DA, et al. Failure to prevent preterm labour and delivery in twin pregnancy using prophylactic oral salbutamol. Br J Obstet Gynecol. 1990;97:878-82.
Asrat T, Garite TJ. Management of preterm premature rupture of membranes. Clin Obstet Gynecol. 1991;34:730-41. [pmid: 1778015].
Atkinson MW, Goldenberg RL, Gaudier FL, et al. Maternal corticosteroid and tocolytic treatment and morbidity and mortality in very low birth weight infants. Am J Obstet Gynecol. 1995;173:299-305. [pmid: 7631708].
Ayhan A, Yarali H, Diker I, et al. Digoxin-like immunoreactive substance and preterm labor. Gynecol Obstet Invest. 1990;30:75-7. [pmid: 2245952].
Bakketeig LS, Hoffman HJ, Harley EE. The tendency to repeat gestational age and birth weight in successive births. Am J Obstet Gynecol. 1979;135:1086-103. [pmid: 517593].
Ballare M, Campanini M, Airoldi G, et al. Hepatotoxicity of hydroxy-methyl-glutaryl-coenzyme A reductase inhibitors. Minerva Gastroenterol Dietol. 1992;38:41-4. [pmid: 1520752].
Barden TP, Peter JB, Merkatz IR. Ritodrine hydrochloride: A betamimetic agent for use in preterm labor. I. pharmacology, clinical history, administration, side effects, and safety. Obstet Gynecol. 1980;56:1-6. [pmid: 6104316].
Barron Vallejo J, Kably Ambe A, Limon Luque L, et al. [New perspectives for an old problem: premature labor]. Nuevas perspectivas para un problema antiguo: El trabajo de parto pretermino. Ginecol Obstet Mex. 1997;65:326-31. [pmid: 9324468].
Beall MH, Platt LD. A prospective trial of the femur length to abdominal circumference ratio to predict the outcome of preterm labor. Am J Perinatol. 1989;6:284-6. [pmid: 2730731].
Beckmann CA, Beckmann CR, Stanziano GJ, et al. Perinatal and health care management consequences of twice-a-day versus once-a-day evaluation of home uterine activity monitoring data. J Health Care Finance. 1996;22:15-21.
Bedin M, Fournier T, Tanguy G, et al. In vivo and in vitro study of the mechanism of action of a synthetic progestin in lowering unconjugated estradiol and total estriol in plasma during normal human pregnancy. Am J Obstet Gynecol. 1983;145:373-5. [pmid: 6186145].
Behrman SJ. On reducing prematurity: The hospital's role. Hosp Pract (Hosp Ed). 1982;17:15-6. [pmid: 6125465].
Bell R. The prediction of preterm labour by recording spontaneous antenatal uterine activity. Br J Obstet Gynecol. 1983;90:884-7.
Benattar C, Taieb J, Fernandez H, et al. Rapid fetal fibronectin swab-test in preterm labor patients treated by betamimetics. Eur J Obstet Gynecol Reprod Biol. 1997;72:131-5. [pmid: 9134390].
Benedetti TJ. Treatment of preterm labor with the beta-adrenergic agonist ritodrine. N Engl J Med. 1992;327.
Benedetti TJ, Gonik B, Hayashi RH, et al. A multicenter evaluation of intramuscular ritodrine hydrochloride as initial parenteral therapy for preterm labor management. J Perinatol. 1994;14:403-7. [pmid: 7830157].
Bentley DL, Bentley JL, Watson DL, et al. Relationship of uterine contractility to preterm labor. Obstet Gynecol. 1990;76(1 Suppl):36S-38S. [pmid: 2193276].
Bergman B, Hedner T. Antepartum administration of terbutaline and the incidence of hyaline membrane disease in preterm infants. Acta Obstet Gynecol Scand. 1978;57:217-21. [pmid: 665163].
Berkowitz GS, Blackmore-Prince C, Lapinski RH, et al. Risk factors for preterm birth subtypes. Epidemiology. 1998;9:279-85. [pmid: 9583419].
Berkowitz GS, Papiernik E. Epidemiology of preterm birth. Epidemiol Rev. 1993;15:414-43. [pmid: 8174665].
Besinger RE. Preterm labor, premature rupture of membranes, and cervical incompetence. Cur Opinion Obstet Gynecol. 1993;5:33-9.
Besinger RE, Moniak CW, Paskiewicz LS, et al. The effect of tocolytic use in the management of symptomatic placenta previa. Am J Obstet Gynecol. 1995;172:1770-5. [pmid: 7778631].
Besinger RE, Niebyl JR. The safety and efficacy of tocolytic agents for the treatment of preterm labor. Obstet Gynecol Surv. 1990;45:415-40. [pmid: 2195409].
Besinger RE, Niebyl JR, Keyes WG, et al. Randomized comparative trial of indomethacin and ritodrine for the long-term treatment of preterm labor. Am J Obstet Gynecol. 1991;164:981-8. [pmid: 2014850].
Beta-adrenergic agonists and pulmonary edema in preterm labor. Br Med J. 1994;308:260-2. [pmid: 8111264].
Binienda Z, Massmann A, Mitchell MD, et al. Effect of food withdrawal on arterial blood glucose and plasma 13, 14-dihydro-15-keto-prostaglandin F2 alpha concentrations and nocturnal myometrial electromyographic activity in the pregnant rhesus monkey in the last third of gestation: A model for preterm labor?. Am J Obstet Gynecol. 1989 Mar;160(3):746-50.
Birnie E, Monincx WM, Zondervan HA, et al. Cost-minimization analysis of domiciliary antenatal fetal monitoring in high-risk pregnancies. Obstet Gynecol. 1997;89:925-9. [pmid: 9170466].
Bisits A, Madsen G, McLean M, et al. Corticotropin-releasing hormone: A biochemical predictor of preterm delivery in a pilot randomized trial of the treatment of preterm labor. Am J Obstet Gynecol. 1998;178:862-6. [pmid: 9579457].
Bittar RE, Yamasaki AA, Sasaki S, et al. Cervical fetal fibronectin in patients at increased risk for preterm delivery. Am J Obstet Gynecol. 1996;175:178-81. [pmid: 8694047].
Bivins HJ, Newman RB, Fyfe DA, et al. Randomized trial of oral indomethacin and terbutaline sulfate for the long-term suppression of preterm labor. Am J Obstet Gynecol. 1993;169:1065-70. [pmid: 8238121].
Black RS, Flint S, Lees C, et al. Preterm labour and delivery. Eur J Pediatr. 1996;15S(Suppl):S2-7.
Blackmore CA, Savitz DA, Edwards LJ, et al. Racial differences in the patterns of preterm delivery in central North Carolina, USA. Paediatr Perinat Epidemiol. 1995;9:281-95. [pmid: 7479277].
Blake DA, Niebyl JR, White RD, et al. Treatment of premature labor with indomethacin. Adv Prostaglandin Thromboxane Res. 1980;8:1465-7. [pmid: 6990720].
Blane GF. Comparative toxicity and safety profile of fenofibrate and other fibric acid derivatives. Am J Med. 1987;83:26-36. [pmid: 3318450].
Blondel B, Breart G, Berthoux Y, et al. Home uterine activity monitoring in France: A randomized, controlled trial. Am J Obstet Gynecol. 1992;167:424-9. [pmid: 1497046].
Boccuzzi SJ, Bocanegra TS, Walker JF, et al. Long-term safety and efficacy profile of simvastatin. Am J Cardiol. 1991;68:1127-31. [pmid: 1951069].
Bocking AD. Preterm labour: Recent advances in understanding of pathophysiology, diagnosis and management. Curr Opinion Obstet Gynecol. 1998;10:151-6.
Bootstaylor BS, Roman C, Parer JT, et al. Fetal and maternal hemodynamic and metabolic effects of maternal nitroglycerin infusions in sheep. Am J Obstet Gynecol. 1997;176:644-50. [pmid: 9077622].
Bossmar T, Akerlund M, Fantoni G, et al. Receptors for and myometrial responses to oxytocin and vasopressin in preterm and term human pregnancy: Effects of the oxytocin antagonist atosiban. Am J Obstet Gynecol. 1994;171:1634-42. [pmid: 7802081].
Boumendil E, Tubert-Bitter P. Depression-induced absenteeism in relation to antihyperlipidemic treatment: A study using GAZEL cohort data. Epidemiology. 1995;6:322-5. [pmid: 7619944].
Bowes WJ. Delivery of the very low birth weight infant. Clin Perinatol. 1980;8:183-95. [pmid: 6113072].
Boyle JG. Beta-adrenergic agonists. Clin Obstet Gynecol. 1995;38:688-96. [pmid: 8616966].
Bracero LA, Leikin E, Kirshenbaum N, et al. Comparison of nifedipine and ritodrine for the treatment of preterm labor. Am J Perinatol. 1991;8:365-9. [pmid: 1814297].
Braden GL, Von Oeyen PT, Germain MJ, et al. Ritodrine- and terbutaline-induced hypokalemia in preterm labor: mechanisms and consequences. Kidney Int. 1997;51:1867-75. [pmid: 9186877].
Bradford RH, Shear CL, Chremos AN, et al. Expanded clinical evaluation of lovastatin (EXCEL) study: Design and patient characteristics of a double-blind, placebo-controlled study in patients with moderate hypercholesterolemia. Am J Cardiol. 1990;66:44B-55B.
Brazy JE, Eckerman CO, Gross SJ. Follow-up of infants of less than 1500 gm birth weight with antenatal isoxsuprine exposure. J Pediatr. 1983;102:611-3. [pmid: 6834200].
Brelje MC, Kaltreider DF. The use of vaginal antibiotics in premature rupture of the membranes. Am J Obstet Gynecol. 1966;94:889-97. [pmid: 5325805].
Brinsmead M. Fetal and neonatal effects of drugs administered in labor. Med J Aust. 1987;146:481-6. [pmid: 2886897].
Brock DJ, Barron L, Jelen P, et al. Maternal serum-alpha-fetoprotein measurements as an early indicator of low birth-weight. Lancet. 1977;2(8032):267-8. [pmid: 69878].
Brocks V, Philipsen T, Secher NJ. A randomized trial of external cephalic version with tocolysis in late pregnancy. Br J Obstet Gynecol. 1984;91:653-6.
Brown C. At the bedside: Childbirth education tutoring for high-risk hospitalized antenatal women. Int Childbirth Educ. 1997;12:20-1.
Brown HL, Britton KA, Brizendine EJ, et al. A randomized comparison of home uterine activity monitoring in the outpatient management of women treated for preterm labor. Am J Obstet Gynecol. 1999;180:798-805. [pmid: 10203647].
Brown HL, Hiett AK, Britton KA, et al. Golichowski AM. Tocolytic treatment for preterm contractions with and without cervical changes. Am J Perinatol. 1997;14:405-9. [pmid: 9263560].
Brown SM, Tejani NA. Terbutaline sulfate in the prevention of recurrence of premature labor. Obstet Gynecol. 1981;57:22-5. [pmid: 7005777].
Brumfield CG, Cloud GA, Finley SC, et al. Amniotic fluid alpha-fetoprotein levels and pregnancy outcome. Am J Obstet Gynecol. 1987;157(4 Pt 1):822-5. [pmid: 2445206].
Bruner JP, Bruner TA, Sarno AP. Long-term intravenous tocolytic therapy. Mil Med. 1997;162:555-9. [pmid: 9271909].
Burrus DR, Ernest JM, Veille J-C. Fetal fibronectin, interleukin-6, and C-reactive protein are useful in establishing prognostic subcategories of idiopathic preterm labor. Am J Obstet Gynecol. 1995;173:1258-62. [pmid: 7485333].
Buyru F, Aydinhan E, Ermis H, et al. Tt tokolitik ilaclarin yan etkileri. Istanbul Tip Fakultesi Mecmuasi. 1995;58:43-8.
Buyru F, Aydinhan E, Yildirim A, et al. Comparison of magnesium and ritodrine therapies in preterm labor [Tur]. Jinekoloji Ve Obstetrik Dergisi. 1995;9:228-33.
Calvin C, Loutzenhizer R, Van Breeman C. Mechanisms of calcium antagonist-induced vasodilation. Ann Rev Pharmacol Toxicol. 1983;23:373-96. [pmid: 6307126].
Canadian Preterm Labor Investigators Group. Treatment of preterm labor with the beta-adrenergic agonist ritodrine. N Engl J Med. 1992;327:308-12. [pmid: 1620169].
Cano A, Tovar I, Parrilla JJ, et al. Metabolic disturbances during intravenous use of ritodrine: Increased insulin levels and hypokalemia. Obstet Gynecol. 1985;65:356-60. [pmid: 3883263].
Caritis SN. Treatment of preterm labour. A review of the therapeutic options. Drugs. 1983;26:243-61.
Caritis SN, Carson D, Greebon D, et al. A comparison of terbutaline and ethanol in the treatment of preterm labor. Am J Obstet Gynecol. 1982;142:183-90. [pmid: 7055183].
Caritis SN, Darby MJ, Chan L. Pharmacologic treatment of preterm labor. Clin Obstet Gynecol. 1988;31:635-51. [pmid: 3066546].
Caritis SN, Edelstone DI, Mueller-Heubach E. Pharmacologic inhibition of preterm labor. Am J Obstet Gynecol. 1979;133:557-78. [pmid: 35978].
Caritis SN, Toig G, Heddinger LA, et al. A double-blind study comparing ritodrine and terbutaline in the treatment of preterm labor. Am J Obstet Gynecol. 1984;150:7-14. [pmid: 6383045].
Carlan SJ, O'Brien WF, O'Leary TD, et al. Randomized comparative trial of indomethacin and sulindac for the treatment of refractory preterm labor. Obstet Gynecol. 1992;79:223-8. [pmid: 1731289].
Carroll S, Sebire N, Nicolaides K. Pre-term pre-labour amniorrhexis. Cur Opinion Obstet Gynecol. 1996;8:441-8.
Carstensen MH, Bahnsen J, Sterzing E. [Tocolysis with beta sympathomimetics alone or combined with the calcium antagonist verapamil? Influence of verapamil on the fetus]. Tokolyse mit beta-Sympathikomimetika allein oder in Kombination mit dem Kalzium-antagonisten Verapamil? 2. Einfluss des Verapamil auf den Feten. [Ger]. Geburtsh Frauenheilk. 1983;43:481-5. [pmid: 6555114].
Castren O, Gummerus M, Saarikoski S. Treatment of imminent premature labour. Acta Obstet Gynecol Scand. 1975;54:95-100. [pmid: 1094787].
Ceriani R, Borroni G, Bissoli F. Ritodrine-related liver injury. Case reports and review of the literature. Ital J Gastroenterol Hepatol. 1998;30:315-7. [pmid: 9759604].
Cetrulo CL, Freeman RK. Ritodrine HCL for the prevention of premature labor in twin pregnancies [Ita]. Acta Genet Med Gemellol (Roma). 1976;25:321-4. [pmid: 801412].
Chaim W, Maymon E, Mazor M. A review of the role of trials of the use of antibiotics in women with preterm labor and intact membranes. Arch Gynecol Obstet. 1998;261:167-72. [pmid: 9789646].
Chamberlain G. ABC of antenatal care. Preterm labour. BMJ. 1991;303(6793):44-8. [pmcid: 37315]. [pmid: 1859959].
Chang TC, Chew TS, Pang M, et al. Cervicovaginal foetal fibronectin in the prediction of preterm labour in a low-risk population. Ann Acad Med Singapore. 1997;26:776-80. [pmid: 9522979].
Chau AC, Gabert HA, Miller Jr JM. A prospective comparison of terbutaline and magnesium for tocolysis. Obstet Gynecol. 1992;80:847-51. [pmid: 1407926].
Cherouny PH, Pankuch GA, Botti JJ, et al. The presence of amniotic fluid leukoattractants accurately identifies histologic chorioamnionitis and predicts tocolytic efficacy in patients with idiopathic preterm labor. Am J Obstet Gynecol. 1992;167:683-8. [pmid: 1530023].
Chien PF, Khan KS, Ogston S, et al. The diagnostic accuracy of cervico-vaginal fetal fibronectin in predicting preterm delivery: An overview. Br J Obstet Gynecol. 1997;104:436-44.
Chimura T, Hirayama T, Oda T, et al. Clinical evaluation of flomoxef in the treatment of chorioamnionitis and changes in the fetal fibronectin level in vaginal secretion [Jap]. Jpn J Antibiot. 1993;46:164-70. [pmid: 8331777].
Chin BM, Lamont RF. The microbiology of preterm labor and delivery. Contemp Rev Obstet Gynecol. 1997;9:285-96.
Cho S, Durfee KK, Keel BA, et al. Perinatal outcomes in a prospective matched pair study of pregnancy and unexplained elevated or low AFP screening. J Perinat Med. 1997;25:476-83. [pmid: 9494919].
Chuileannain, FN, Bell, R, Brennecke, S. Cervicovaginal fetal fibronectin testing in threatened preterm labour-translating research findings into clinical practice. Aust NZ J Obstet Gynecol. 1998;38:399-402.
Cini MF. Overview of preterm labor and its consequences. ASHP Midyear Clinical Meeting. 1995;30:1-84.
Clayton J, Senior J, Marshall K. Drugs for preterm labour. Practitioner. 1993;237:582-4. [pmid: 8415391].
Cole RM, Lamont RF. Current perspectives on drug treatment for preterm labour. J Obstet Gynecol. 1998;18(4):309-14. [pmid: 15512097].
Coleman FH. Safety and efficacy of combined ritodrine and magnesium sulfate for preterm labor: a method for reduction of complications. Am J Perinatol. 1990;7:366-9. [pmid: 2222631].
Collaborative Group on Preterm Birth Prevention. Multicenter randomized, controlled trial of a preterm birth prevention program. Am J Obstet Gynecol. 1993;169:352-66. [pmid: 8362947].
Collaborative Home Uterine Monitoring Study (CHUMS) Group. A multicenter randomized controlled trial of home uterine monitoring: Active versus sham device. Am J Obstet Gynecol. 1995;173:1120-7. [pmid: 7485304].
Collins T, Bancroft K, Manyonda I. Ampicillin and metronidazole treatment in preterm labour: A multicentre, randomised trial [letter; comment]. Br J Obstet Gynecol. 1995;102:267-8.
Colton T, Kayne HL, Zhang Y, et al. A metaanalysis of home uterine activity monitoring. Am J Obstet Gynecol. 1995;173:1499-505. [pmid: 7503191].
Copper RL, Goldenberg RL, Creasy RK, et al. A multicenter study of preterm birth weight and gestational age-specific neonatal mortality. Am J Obstet Gynecol. 1993;168:78-84. [pmid: 8420354].
Copper RL, Goldenberg RL, Davis RO, et al. Warning symptoms, uterine contractions, and cervical examination findings in women at risk of preterm delivery. Am J Obstet Gynecol. 1990;162:748-54. [pmid: 2316582].
Corwin MJ, Mou SM, Sunderji SG, et al. Multicenter randomized clinical trial of home uterine activity monitoring: pregnancy outcomes for all women randomized. Am J Obstet Gynecol. 1996;175:1281-5. [pmid: 8942501].
Cotton DB, Strassner HT, Hill LM, et al. Comparison of magnesium sulfate, terbutaline and a placebo for inhibition of preterm labor. A randomized study. J Reprod Med. 1984;29:92-7. [pmid: 6708033].
Cowan M. Home care of the pregnant woman using terbutaline. MCN Am J Matern Child Nurs. 1993;18:99-105. [pmid: 8492654].
Cox SM, Bohman VR, Sherman ML, et al. Randomized investigation of antimicrobials for the prevention of preterm birth. Am J Obstet Gynecol. 1996;174:206-10. [pmid: 8572007].
Cox SM, Sherman ML, Leveno KJ. Randomized investigation of magnesium sulfate for prevention of preterm birth. Am J Obstet Gynecol. 1990;163:767-72. [pmid: 2206069].
Crane JM, Van den Hof M, Armson BA, et al. Transvaginal ultrasound in the prediction of preterm delivery: Singleton and twin gestations. Obstet Gynecol. 1997;90:357-63. [pmid: 9277644].
Creasy RK. Preterm birth prevention: Where are we?. Am J Obstet Gynecol. 1993;168:1223-30. [pmid: 8475969].
Creasy RK, Merkatz IR. Prevention of preterm birth: clinical opinion. Obstet Gynecol. 1990;76(1 Suppl):2S-4S. [pmid: 2193274].
Creasy RK, Resnik R. Maternal Fetal Medicine: Principles and Practice. 2nd ed. Philadelphia: W.B. Saunders; 1994.
Creasy RK, Golbus MS, Laros RKJ, et al. Oral ritodrine maintenance in the treatment of preterm labor. Am J Obstet Gynecol. 1980;137:212-9. [pmid: 6990761].
Crowther CA. Prevention of preterm birth in multiple pregnancy. Baillieres Clin Obstet Gynecol. 1998;12:67-75.
Dabbs AD, Kraemer KL, Hoops S. Pulmonary edema associated with the treatment of preterm labor: What critical care nurses need to know. Crit Care Nurse. 1996;16:44-51.
Daikoku NH, Burnhill MS. Diagnosis of prematurity and premature labor. Clin Obstet Gynecol. 1980;23:75-91. [pmid: 6988133].
Damare SM, Wells S, Offenbacher S. Eicosanoids in periodontal diseases: Potential for systemic involvement. Adv Exp Med Biol. 1997;433:23-35. [pmid: 9561098].
Danielian PJ. CA 125 and preterm prelabour rupture of the membranes. Br J Obstet Gynecol. 1991;98:835-6.
David M, Gungor L, Lichtenegger W. [Tocolysis with a nitroglycerin patch]. Tokolyse mit einem Nitroglycerinpflaster. [Ger]. Zentralbl Gynakol. 1998;120:126-8. [pmid: 9556903].
Dawson AJ, Middlemiss C, Coles EC, et al. A randomized study of a domiciliary antenatal care scheme: The effect on hospital admissions. Br J Obstet Gynecol. 1989;96:1319-22.
De Arcos F, Gratacos E, Palacio M, et al. Toxic hepatitis: A rare complication associated with the use of. Acta Obstet Gynecol Scand. 1996;75:340-2. [pmid: 8638452].
de Jong MW, Pinas IM, van Eijck J. Delayed interval delivery after intrauterine infection and immature birth of twin 1-a case report and literature review. Eur J Obstet Gynecol Reprod Biol. 1995;63:91-4. [pmid: 8674573].
de Jong M, van Lingen R, Wildschut J, et al. Delayed interval delivery of two remaining fetuses in quintuplet pregnancy after embryo reduction: Report and review of the literature. Acta Genet Med Gemellol (Roma). 1992;41:49-52. [pmid: 1488856].
de Veciana M, Porto M, Major CA, et al. Tocolysis in advanced preterm labor: Impact on neonatal outcome. Am J Perinatol. 1995;12:294-8. [pmid: 7575840].
DeGroot H. High-risk pregnancy: An educational experience for the educator. Int J Childbirth Educ. 1997;12:10-2.
Delaying premature labour [editorial]. Lancet. 1974;2(7885):875-6. [pmid: 4137621].
Desgranges MF, Moutquin JM, Peloquin A. Effects of maternal oral salbutamol therapy on neonatal endocrine status at birth. Obstet Gynecol. 1987;69:582-4. [pmid: 3547214].
Dewan DM. Anesthesia for preterm delivery, breech presentation, and multiple gestation. Clin Obstet Gynecol. 1987;30:566-78. [pmid: 2888558].
Ditzian-Kadanoff R, Reinhard JD, Thomas C, et al. Polymyositis with myoglobinuria in pregnancy: A report and review of the literature. J Rheumatol. 1988;15:513-4. [pmid: 3288755].
Dowd J, Permezel M. Pregnancy outcome following preterm premature rupture of the membranes at less than 26 weeks' gestation. Aust N Z J Obstet Gynecol. 1992;32:120-4.
Dudenhausen JW, Buscher U. Zuverlassigkeit der abschatzung des fruhgeburtsrisikos. Gynakologe. 1996;29:585-9.
Dudenhausen JW, Korebrits C. [Critical evaluation of markers for premature labor. Vaginal pH value, vaginal bacteriology, fibronectin, C-reactive protein]. Kritische wertung der fruhgeburtsmarker: Vaginaler ph-wert, vaginal-bakteriologie, fibronektin, crp. Gynakologe. 1995;28:168-74. [pmid: 7657177].
Dudley D, Gagnon D, Varner M. Long-term tocolysis with intravenous magnesium sulfate. Obstet Gynecol. 1989;73:373-8. [pmid: 2915861].
Dunphy PM. The Pregnancy Wellness Center: An extension of prenatal care for the 90s. J Perinat Educ. 1994;3:23-7.
Dyson DC, Crites YM, Ray DA, et al. Prevention of preterm birth in high-risk patients: the role of education and provider contact versus home uterine monitoring. Am J Obstet Gynecol. 1991;164:756-62. [pmid: 2003537].
Dyson DC, Danbe KH, Bamber JA, et al. Monitoring women at risk for preterm labor. N Engl J Med. 1998;338:15-9. [pmid: 9414326].
Eden RD, Sokol RJ. Predicting prematurity: the mammary stimulation test. Clin Perinatol. 1992;19:291-303. [pmid: 1617876].
Egarter C, Leitich H, Husslein P, et al. Adjunctive antibiotic treatment in preterm labor and neonatal morbidity: A meta-analysis. Obstet Gynecol. 1996;88:303-9. [pmid: 8692521].
Egarter C, Leitich H, Karas H, et al. Antibiotic treatment in preterm premature rupture of membranes and neonatal morbidity: A metaanalysis. Am J Obstet Gynecol. 1996;174(2):589-97. [pmid: 8623790].
El-Sayed YY, Holbrook RH Jr, Gibson R, et al. Diltiazem for maintenance tocolysis of preterm labor: comparison to nifedipine in a randomized trial. J Matern Fetal Med. 1998;7:217-21. [pmid: 9775988].
El-Sayed YY, Riley ET, Holbrook RH Jr, et al. Randomized comparison of intravenous nitroglycerin and magnesium sulfate for treatment of preterm labor. Obstet Gynecol. 1999;93:79-83. [pmid: 9916961].
Elder HA, Santamarina BA, Smith SA, et al. Excess prematurity in tetracycline-treated bacteriuric patients whose infection persisted or returned. Antimicrob Agents Chemother. 1967;7:101-9. [pmid: 4876085].
Elliott JP. Magnesium sulfate as a tocolytic agent. Am J Obstet Gynecol. 1983;147:277-84. [pmid: 6624792].
Elliott JP. Home uterine activity monitoring trial fatally flawed. Am J Obstet Gynecol. 1994;171:279-80. [pmid: 8030721].
Elliott JP, Radin TG. Serum magnesium levels during magnesium sulfate tocolysis in. J Reprod Med. 1995;40:450-2. [pmid: 7650659].
Elliott JP, Flynn MJ, Kaemmerer EL, et al. Terbutaline pump tocolysis in high-order multiple gestation. J Reprod Med. 1997;42:687-94. [pmid: 9408866].
Endl J, Baumgarten K. [Results of prophylactic oral long term tocolysis and cerclage for the prolongation of twin pregnancy (a multi-center study)]. Uber die Ergebnisse der prophylaktischen oralen Langzeittokolyse und Cerclage zur Verlangerung der Zwillingsschwangerschaften (Eine Multicenterstudie). [Ger]. Z Geburtsh Perinatol. 1982;186:319-25.
Engelhardt S, Zieger W, Kassubek J, et al. Tocolytic therapy with fenoterol induces selective down-regulation of beta-adrenergic receptors in human myometrium. J Clin Endocrinol Metabol. 1997;82:1235-42.
Ernest JM, Givner LB. A prospective, randomized, placebo-controlled trial of penicillin in preterm premature rupture of membranes. Am J Obstet Gynecol. 1994;170:516-21. [pmid: 8116706].
Eronen M, Pesonen E, Kurki T, et al. The effects of indomethacin and a beta-sympathomimetic agent on the fetal ductus arteriosus during treatment of premature labor: A randomized double-blind study. Am J Obstet Gynecol. 1991;164(1 Pt 1):141-6. [pmid: 1986601].
Eronen M, Pesonen E, Kurki T, et al. Increased incidence of bronchopulmonary dysplasia after antenatal administration of indomethacin to prevent preterm labor. J Pediatr. 1994;124:782-78. [pmid: 8176569].
Eschenbach DA, Nugent RP, Rao AV, et al. A randomized placebo-controlled trial of erythromycin for the treatment of Ureaplasma urealyticum to prevent premature delivery. Am J Obstet Gynecol. 1991;164:734-42. [pmid: 2003533].
Essed GGM, Struyker Boudier HAJ, Van Zijl JAWM. Biopharmaceutical aspects of ritodrine retard in pregnant women. Arch Int Pharmacodyn Ther. 1988;293:295-300. [pmid: 3421783].
Faber R, Robel R, Viehweg B. Pradiktive wertigkeit dopplersonographisch gemessener utero-plazento-fetaler perfusion bei drohender fruhgeburt. [Ger]. Geburtsh Frauenheilk. 1996;56:660-4.
Facchinetti F, Neri I, Genazzani AR. L-arginine infusion reduces preterm uterine contractions. J Perinat Med. 1996;24:283-5. [pmid: 8827578].
Fall O, Nilsson BA. External cephalic version in breech presentation under tocolysis. Obstet Gynecol. 1979;53:712-5. [pmid: 450339].
Fanaroff AA, Merkatz IR. Modern obstetrical management of the low birth weight infant. Clin Perinatol. 1977;4:215-37. [pmid: 332428].
Faron G, Boulvain M, Irion O, et al. Prediction of preterm delivery by fetal fibronectin: A meta-analysis. Obstet Gynecol. 1998;92:153-8. [pmid: 9649113].
Faron G, Boulvain M, Lescrainier JP, et al. A single cervical fetal fibronectin screening test in a population at low risk for preterm delivery: An improvement on clinical indicators?. Br J Obstet Gynecol. 1997;104:697-701.
Feinberg RF, Kliman HJ, Sadovsky Y, et al. Fetal fibronectin and preterm labor [2]. N Engl J Med. 1992;326:708-9. [pmid: 1736115].
Ferguson JE Jr, Dyson DC, Holbrook RHJ, et al. Cardiovascular and metabolic effects associated with nifedipine and ritodrine tocolysis. Am J Obstet Gynecol. 1989;161:788-95. [pmid: 2782362].
Ferguson JE Jr, Dyson DC, Schutz T, et al. A comparison of tocolysis with nifedipine or ritodrine: Analysis of efficacy and maternal, fetal, and neonatal outcome. Am J Obstet Gynecol. 1990;163:105-11. [pmid: 2197860].
Ferguson JE Jr, Hensleigh PA, Kredenster D. Adjunctive use of magnesium sulfate with ritodrine for preterm labor tocolysis. Am J Obstet Gynecol. 1984;148:166-71. [pmid: 6362416].
Ferguson JE Jr, Holbrook RHJ, Stevenson DK, et al. Adjunctive magnesium sulfate infusion does not alter metabolic changes associated with ritodrine tocolysis. Am J Obstet Gynecol. 1987;156:103-7. [pmid: 3541613].
Fernandez H, Ville Y, Bourget P. Antibioprophylaxie en obstetrique. Med Mal Infect 24:1123-36.
Fetal fibronectin measurement to predict preterm delivery. Am Fam Physician. 1992;45.
Fetal fibronectin preterm labor risk test. Int J Gynecol Obstet. 1997;59.
Fisher JE, Smith RS, Lagrandeur R, et al. Gestational diabetes mellitus in women receiving beta-adrenergics. Obstet Gynecol. 1997;90:880-83. [pmid: 9397094].
Fliegner JR, Gronow M. Treatment of pre-term cervical dilatation with glyceryl trinitrate, a nitric oxide donor [letter]. Aust N Z J Obstet Gynecol. 1997;37.
Floyd RC, McLauglin BN, Perry KG Jr, et al. Magnesium sulfate or nifedipine hydrochloride for acute tocolysis of preterm labor: Efficacy and side effects. J Matern Fetal Invest. 1995;5:25-9.
Floyd RL, Rimer BK, Giovino, GA, et al. A review of smoking in pregnancy: Effects on pregnancy outcomes and cessation efforts. Ann Rev Public Health. 1993;14:379-411. [pmid: 8323595].
Forman A, Andersson KE, Ulmsten U. Inhibition of myometrial activity by calcium antagonists. Semin Perinatol. 1981;5:288-94. [pmid: 7025218].
Forster F, During R. [Comparison of the effectiveness of Partusisten and ethanol tocolysis. II. Short-term tocolysis with Partusisten or ethanol]. Vergleich der Effektivitat von Partusisten-und Ethanoltokolyse. Teil Jr: Kurzzeittokolyse mit Partusisten oder Ethanol. [Ger]. Zentralbl Gynakol. 1987;109):843-9. [pmid: 3307228].
Fortunato SJ, Welt SI, Eggleston MK Jr, et al. Active expectant management in very early gestations complicated by premature rupture of the fetal membranes. J Reprod Med. 1994;39:13-6. [pmid: 8169909].
Foulon W, Van Liedekerke D, Demanet C, et al. Markers of infection and their relationship to preterm delivery. Am J Perinatol. 1995;12:208-11. [pmid: 7612097].
Fox MD, Allbert JR, McCaul JF, et al. Neonatal morbidity between 34 and 37 weeks' gestation. J Perinatol. 1993;13:349-53. [pmid: 8263618].
Friese K. Medicinal therapy of impending abortion and premature labor [Ger]. Deutsche Apotheker Zeitung. 1990;130:393-6.
Fuchs AR, Fuchs F. Ethanol for prevention of preterm birth. Semin Perinatal. 1981;5:236-51.
Fuchs F. Prevention of premature birth. Clin Perinatol. 1980;7:3-15. [pmid: 6105033].
Fuchs F, Fuchs AR, Poblete VF, et al. Effect of alcohol on threatened premature labor. Am J Obstet Gynecol. 1967;99:627-37. [pmid: 6051158].
[No authors listed]. Gallbladder disease as a side effect of drugs influencing lipid metabolism: Experience in the coronary drug project. N Engl J Med. 1977;296:1185-90. [pmid: 323705].
Gamissans O, Canas E, Cararach V, et al. A study of indomethacin combined with ritodrine in threatened preterm labor. Eur J Obstet Gynecol Reprod Biol. 1978;8:123-8. [pmid: 400862].
Garcia-Velasco JA, Gonzalez GA. A prospective, randomized trial of nifedipine vs. ritodrine in threatened preterm labor. Int J Gynecol Obstet. 1998;61:239-44.
Gardner MO, Owen J, Skelly S, et al. Preterm delivery after indomethacin. A risk factor for neonatal complications?. J Reprod Med. 1996;41:903-6. [pmid: 8979204].
Garite TJ, Keegan KA, Freeman RK, et al. A randomized trial of ritodrine tocolysis versus expectant management in patients with premature rupture of membranes at 25 to 30 weeks of gestation. Am J Obstet Gynecol. 1987;157:388-93. [pmid: 3303937].
Garite TJ, Rumney PJ, Briggs GG, et al. A randomized, placebo-controlled trial of betamethasone for the prevention of respiratory distress syndrome at 24 to 28 weeks' gestation. Am J Obstet Gynecol. 1992;166:646-51. [pmid: 1536246].
Gaucherand P, Guibaud S, Awada A, et al. Comparative study of three amniotic fluid markers in premature rupture of membranes: Fetal fibronectin, alpha-fetoprotein, diamino-oxydase. Acta Obstet Gynecol Scand. 1995;74:118-21. [pmid: 7534966].
Gibbens GLD, Chard T. Observations on maternal oxytocin release during human labor and the effect of intravenous alcohol administration. Am J Obstet Gynecol. 1976;126.
Gibbs RS, Eschenbach DA. Use of antibiotics to prevent preterm birth. Am J Obstet Gynecol. 1997;177:375-80. [pmid: 9290454].
Gilbert WM. Maternal, fetal, and neonatal physiology in pregnancy. Curr Opinion Obstet Gynecol. 1990;2:4-7.
Gill P, Smith M, McGregor C. Terbutaline by pump to prevent recurrent preterm labor. MCN Am J Matern Child Nurs. 1989;14:163-7. [pmid: 2498593].
Gjerdingen DK. Premature labor, Part I: Risk assessment, etiologic factors, and diagnosis. J Am Board Fam Pract. 1992;5:495-509. [pmid: 1414451].
Gjerdingen DK. Premature labor, Part II: Management. J Am Board Fam Pract. 1992;5:601-15. [pmid: 1462794].
Gleiter CH, Schreeb KH, Goldbach S, et al. Fenoterol increases erythropoietin concentrations during tocolysis. Br J Clin Pharmacol. 1998;45:157-9. [pmid: 9491829].
Glock JL, Morales WJ. Efficacy and safety of nifedipine versus magnesium sulfate in the management of preterm labor: A randomized study. Am J Obstet Gynecol. 1993;169:960-4. [pmid: 8238157].
Goepfert AR, Goldenberg RL. Prediction of prematurity. Curr Opinion Obstet Gynecol. 1996;8:417-27.
Goland RS, Wardlaw SL, Blum M, et al. Biologically active corticotropin-releasing hormone in maternal and fetal plasma during pregnancy. Am J Obstet Gynecol. 1988;159:884-90. [pmid: 2845784].
Goldenberg RL, Iams JD, Miodovnik M, et al. The preterm prediction study: Risk factors in twin gestations. Am J Obstet Gynecol. 1996;175:1046-53.
Goldenberg RL, Klebanoff MA, Nugent R, et al. Bacterial colonization of the vagina during pregnancy in four ethnic groups. Am J Obstet Gynecol. 1996;174:1618-21. [pmid: 9065140].
Goldenberg RL, Mercer BM, Meis PJ, et al. The preterm prediction study: Fetal fibronectin testing and spontaneous preterm birth. Obstet Gynecol. 1996;87:643-8. [pmid: 8677060].
Goldenberg RL, Rouse DJ. Prevention of premature birth. N Engl J Med. 1998;339:313-20. [pmid: 9682045].
Goldenberg RL, Thom E, Moawad AH, et al. The preterm prediction study: fetal fibronectin, bacterial vaginosis, and peripartum infection. NICHD Maternal Fetal medicine Units Network. Obstet Gynecol. 1996 May;87(5 Pt J):656-60.
Gomez R, Ghezzi F, Romero R, et al. Premature labor and intra-amniotic infection. Clinical aspects and role of the cytokines in diagnosis and pathophysiology. Clin Perinatol. 1995;22:281-342. [pmid: 7671540].
Gonik B, Benedetti T, Creasy RK, et al. Intramuscular versus intravenous ritodrine hydrochloride for preterm labor management. Am J Obstet Gynecol. 1988;159:323-8. [pmid: 3044111].
Goodwin TM, Millar L, North L, et al. The pharmacokinetics of the oxytocin antagonist atosiban in pregnant women with preterm uterine contractions. Am J Obstet Gynecol. 1995;173(3 Pt 1):913-7. [pmid: 7573268].
Goodwin TM, Paul R, Silver H, et al. The effect of the oxytocin antagonist atosiban on preterm uterine activity in the human. Am J Obstet Gynecol. 1994;170:474-8. [pmid: 8116700].
Goodwin TM, Valenzuela GJ, Silver H, et al. Dose ranging study of the oxytocin antagonist atosiban in the treatment of preterm labor. Atosiban Study Group. Obstet Gynecol. 1996;88:331-6. [pmid: 8752234].
Goodwin TM, Valenzuela G, Silver H, et al. Treatment of preterm labor with the oxytocin antagonist atosiban. Am J Perinatol. 1996;13:143-6. [pmid: 8688103].
Gookin KS. Randomized comparison of home uterine activity monitoring and routine care in patients discharged after treatment for preterm labor. Obstet Gynecol. 1994;83:159-60. [pmid: 8272300].
Gordon MC, Iams JD. Magnesium sulfate. Clin Obstet Gynecol. 1995;38:706-12. [pmid: 8616968].
Gordon MC, Samuels P. Indomethacin. Clin Obstet Gynecol. 1995;38:697-705. [pmid: 8616967].
Gordon M, Samuels P, Shubert P, et al. A randomized, prospective study of adjunctive ceftizoxime in preterm labor. Am J Obstet Gynecol. 1995;172:1546-52. [pmid: 7755069].
Gotoff SP, Boyer KM. Prevention of group B streptococcal early onset sepsis: 1989. Pediatr Infect Dis J. 1989;8:268-70. [pmid: 2657614].
Graber EA. Dilemmas in the pharmacological management of preterm labor. Obstet Gynecol Surv. 1989;44:512-7. [pmid: 2662077].
Grable IA, Garcia PM, Perry D, et al. Group B Streptococcus and preterm premature rupture of membranes: A randomized, double-blind clinical trial of antepartum ampicillin. Am J Obstet Gynecol. 1996;175:1036-42. [pmid: 8885772].
Graf RA, Perez-Woods R. Trends in preterm labor. J Perinatol. 1992;12:51-8. [pmid: 1560292].
Graham JM, Oshiro BT, Blanco JD, et al. Uterine contractions after antibiotic therapy for pyelonephritis in pregnancy. Am J Obstet Gynecol. 1993;168:577-80. [pmid: 8438931].
Gravett MG, Nelson HP, DeRouen T, et al. Independent associations of bacterial vaginosis and Chlamydia trachomatis infection with adverse pregnancy outcome. JAMA. 1986;256:1899-903. [pmid: 3761496].
Gray DR, Morgan T, Chretien SD, et al. Efficacy and safety of controlled-release niacin in dyslipoproteinemic veterans. Ann Intern Med. 1994;121:252-8. [pmid: 7741833].
Greenhagen JB, Van Wagoner J, Dudley D, et al. Value of fetal fibronectin as a predictor of preterm delivery for a low-risk population. Am J Obstet Gynecol. 1996;175(4 Pt 1):1054-6. [pmid: 8885775].
Greenhouse B, Hook R, Hehre F. Aspiration pneumonia following intravenous administration of alcohol during labor. JAMA. 1969;210:2393-5. [pmid: 4902527].
Grella P, Zanor P. Premature labor and indomethacin. Prostaglandins. 1978;16:1007-17. [pmid: 373019].
Grimes DA, Schulz KF. Randomized controlled trials of home uterine activity monitoring: A review and critique. Obstet Gynecol. 1992;79:137-42. [pmid: 1727572].
Grospietsch G. [Medical tocolysis in threatening premature labor: what is safe in therapy]? Medikamentose Tokolyse bei der drohenden Fruhgeburg: Was ist gesichert in der Therapie?. Gynakol. 1991;24:188-97.
Guilliams S, Held B. Contemporary management and conduct of preterm labor and delivery: A review. Obstet Gynecol Surv. 1979;34:248-55. [pmid: 372871].
Guinn DA, Goepfert AR, Owen J, et al. Management options in women with preterm uterine contractions: A randomized clinical trial. Am J Obstet Gynecol. 1997;177:814-8. [pmid: 9369825].
Guinn DA, Goepfert AR, Owen J, et al. Terbutaline pump maintenance therapy for prevention of preterm delivery: A double-blind trial. Am J Obstet Gynecol. 1998;179:874-8. [pmid: 9790362].
Guinn DA, Goldenberg RL, Hauth JC, et al. Risk factors for the development of preterm premature rupture of the membranes after arrest of preterm labor. Am J Obstet Gynecol. 1995;173:1310-5. [pmid: 7485344].
Giussani DA, Jenkins SL, Mecenas CA, et al. The oxytocin antagonist atosiban prevents androstenedione-induced myometrial contractions in the chronically instrumented, pregnant Rhesus monkey. Endocrinology. 1996;137:3302-7. [pmid: 8754755].
Gummerus M. The management of premature labor with salbutamol. Acta Obstet Gynecol Scand. 1981;60:375-7. [pmid: 7025554].
Gummerus M. [Tocolysis with hexoprenalin and salbutamol in a clinical comparison]. Tokolyse mit Hexoprenalin und Salbutamol im klinischen Vergleich. Geburtsh Frauenheilk. 1983;43:151-5. [pmid: 6552999].
Gummerus M, Halonen O. Prophylactic long-term oral tocolysis of multiple pregnancies. Br J Obstet Gynecol. 1987;94:249-51.
Gutsche BB, Samuels P. Anesthetic considerations in premature birth. Int Anesthesiol Clin. 1990;28:33-43. [pmid: 1967245].
Hagay ZJ, Epstein M, Goldchmit R, et al. A prospective randomized clinical trial comparing a new oral sustained-release ritodrine with conventional tablets. Eur J Obstet Gynecol Reprod Biol. 1994;56:83-7. [pmid: 7805972].
Hahn DW, Demarest KT, Ericson E, et al. Evaluation of 1-deamino-[D-Tyr(Oethyl)2, Thr4, Orn8] vasotocin, an oxytocin antagonist, in animal models of uterine contractility and preterm labor; a new tocolytic agent. Am J Obstet Gynecol. 1987;157:977-82. [pmid: 3674173].
Hales KA, Matthews JP, Rayburn WF, et al. Intravenous magnesium sulfate for premature labor: Comparison between twin and singleton gestations. Am J Perinatol. 1995;12:7-10. [pmid: 7710584].
Halle H, Bettin S, Schurenkamper P, et al. Bacterial colonization in threatening premature labor and cervix insufficiency. Arch Gynecol Obstet. 1993;254:1494-6.
Halle H, Hengst P. [Additional tocolysis via inhibition of prostaglandin synthetase with indometacin (author's transl)]. Zusatztokolyse durch Prostaglandinsythetasehemmung mit Indometacin. Z Geburtshilfe Perinatol. 1978;182:367-70. [pmid: 104461].
Hameed C, Tejani N, Verma UL, et al. Silent chorioamnionitis as a cause of preterm labor refractory to tocolytic therapy. Am J Obstet Gynecol. 1984;149:726-30. [pmid: 6465222].
Hampl M, Friese K, Hofmann I, et al. Quantitative determination of fetal fibronectin in the cervicovaginal smear: A new marker for assessing premature birth risk in case of premature labour. Geburtsh Frauenheilk. 1994;54:685-90. [pmid: 7851710].
Hampl M, Hofmann I, Gallati H, et al. Fetal fibronectin, tumor necrosis factor and interleukin 6: New diagnosis in premature labor and membrane rupture. Arch Gynecol Obstet. 1993;254:1470-2.
Haning RV Jr, Curet LB, Poole WK, et al. Effects of fetal sex and dexamethasone on preterm maternal serum concentrations of human chorionic gonadotropin, progesterone, estrone, estradiol, and estriol. Am J Obstet Gynecol. 1989;161(6 Pt 1):1549-53. [pmid: 2690631].
Harbert GM, Cornell GW, Thorton WN. Effect of toxemia therapy on uterine dynamics. Am J Obstet Gynecol. 1969;105.
Hardy CC, Lorigan P, Ratcliffe A, et al. Asthma in pregnancy complicated by iatrogenic pulmonary oedema. Postgrad Med J. 1989;65:407-9. [pmid: 2692013].
Harlass FE. The use of tocolytics in patients with preterm premature rupture of the membranes. Clin Obstet Gynecol. 1991;34:751-8. [pmid: 1778017].
Harmon P. The common continuum. Midwifery Today Childbirth Educ. 1990;15.
Hartmann K, Thorp JM, McDonald TL, et al. Cervical dimensions and risk of preterm birth: A prospective cohort study. Obstet Gynecol. 1999;93:504-9. [pmid: 10214823].
Hasenburg A. Vorzeitige wehentatickeit. Ursachen und therpiemoglichkeiten. Gynakol. 1996;9:640-4.
Hasselblad, V. Meta-analysis of multitreatment studies. Med Decis Making. 1998;18:37-43. [pmid: 9456207].
Hastwell G, Lambert BE. A comparison of salbutamol and ritodrine when used to inhibit premature labour complicated by ante-partum haemorrhage. Curr Med Res Opinion. 1979;5:785-9.
Hastwell GB, Halloway P, Taylo TL. Study of 208 patients in premature labour treated with orally administered salbutamol. Med J Aust. 1978;1:465-9. [pmid: 672733].
Hatjis CG, Swain M, Nelson LH, et al. Efficacy of combined administration of magnesium sulfate and ritodrine in the treatment of premature labor. Obstet Gynecol. 1987;69:317-22. [pmid: 3822278].
Hauth JC, Goldenberg RL, Andrews WW, et al. Reduced incidence of preterm delivery with metronidazole and erythromycin in women with bacterial vaginosis. N Engl J Med. 1995;333:1732-6. [pmid: 7491136].
Hawker F. Five cases of pulmonary oedema associated with beta 2-sympathomimetic treatment of premature labour. Anaesth Intensive Care. 1984;12:159-62. [pmid: 6476350].
Hawkins DF. Management of premature labour. J Obstet Gynecol. 1989;10(Supp l):S10-S12.
Hay PE, Lamont RF, Taylor-Robinson D, et al. Abnormal bacterial colonisation of the genital tract and subsequent preterm delivery and late miscarriage. BMJ. 1994;308(6924):295-8. [pmcid: 155691]. [pmid: 8124116].
Haznedaroglu S, Ozcan T, Malkoc S, et al. Hemostatic markers in preterm labor. Thromb Res. 1997;86:89-90. [pmid: 9172292].
Hedges LV, Olkin I. Statistical methods for meta-analysis. Orlando, Fla: Academic Press, 1985.
Hellemans P, Gerris J, Verdonk P. Fetal fibronectin detection for prediction of preterm birth in low risk women. Br J Obstet Gynecol. 1995;102:207-2.
Hellemans P, Verdonk P, Baekelandt M, et al. Preliminary results with the use of the ROM-check immunoassay in the early detection of rupture of the amniotic membranes. Eur J Obstet Gynecol Reprod Biol. 1992;43:173-9. [pmid: 1563568].
Henderson ED, Guentzel J, Kiser WR. Questionable research methods. Am J Obstet Gynecol. 1995;172(2 Pt 1):722-23. [pmid: 7856717].
Henderson JW The cost-effectiveness of prenatal care Health Care Financing Rev 1994 15 21 32View this and related citations using
Hendrickx B. Glyceryl trinitrate in management of preterm labour. Lancet. 1994;344(8921).
Hernandez-Martin C, Gomez-Garcia T, Espinosa Y, et al. Rotura preatura de mebranas en gestaciones pretermino. Analisis de factores maternos. Clin Invest Ginecol Obstet. 1996;23:3188-323.
Hesseldahl H. A Danish multicenter study on ritodrine in the treatment of pre-term labour. Dan Med Bull. 1979;26:116-8. [pmid: 446106].
Heymann MA. Arachidonic acid derivatives in the perinatal period. Adv Pediatr. 1989;36:151-75. [pmid: 2506749].
Heymann MA. Prostaglandins and leukotrienes in the perinatal period. Clin Perinatol. 1987;14:857-80. [pmid: 2827932].
Hickok DE, Hollenbach KA, Reilley SF, et al. The association between decreased amniotic fluid volume and treatment with nonsteroidal anti-inflammatory agents for preterm labor. Am J Obstet Gynecol. 1989;160:1525-31. [pmid: 2660576].
Higby K, Xenakis EM, Pauerstein CJ. Do tocolytic agents stop preterm labor? A critical and comprehensive review of efficacy and safety. Am J Obstet Gynecol. 1993;168:1247-56. [pmid: 8097367].
Hildebrandt R, Wagner B, Preiss-Nowzohour et al. Fenoterol metabolism in man: Sulphation versus glucuronidation. Xenobiotica. 1994;24:71-7. [pmid: 8165823].
Hill WC. Risks and complications of tocolysis. Clin Obstet Gynecol. 1995;38:725-45. [pmid: 8616971].
Hill WC, Fleming AD, Martin RW, et al. Home uterine activity monitoring is associated with a reduction in preterm birth [see comments]. Obstet Gynecol. 1990;76(Supp l):S13-S18.
Hill WC, Gookin KS. Home uterine activity monitoring. Clin Perinatol. 1992;19:333-43. [pmid: 1617879].
Hillier SL, Krohn MA, Cassen E, et al. The role of bacterial vaginosis and vaginal bacteria in amniotic fluid infection in women in preterm labor with intact fetal membranes. Clin Infect Dis. 1995;20(Suppl 2):S276-278. [pmid: 7548574].
Hollander DI, Nagey DA, Pupkin MJ. Magnesium sulfate and ritodrine hydrochloride: A randomized comparison. Am J Obstet Gynecol. 1987;156:631-7. [pmid: 3548382].
Holleboom CA, Merkus JM, van Elferen LW, et al. A loading model for ritodrine administration in preterm labour. Br J Obstet Gynecol. 1993;100:1107-10.
Holleboom CA, Merkus JM, van Elferen LW. A loading-dose infusion scheme for intravenous tocolysis with ritodrine: A pilot study. Eur J Obstet Gynecol Reprod Biol. 1987;26:119-26. [pmid: 3666270].
Holleboom CA, Merkus JM, van Elferen LW, et al. Double-blind evaluation of ritodrine sustained release for oral maintenance of tocolysis after active preterm labour. Br J Obstet Gynecol. 1996;103:702-5.
Holleboom CA, Merkus JM, van Elferen LW, et al. Randomised comparison between a loading and incremental dose model for ritodrine administration in preterm labour. Br J Obstet Gynecol. 1996;103:695-701.
Holohon TV, Green I. Home uterine activity monitoring. Health Technology Review No. 1. Rockville, MD: Agency for Health Care Policy and Research, Office of Health Technology; 1992. Publication No. 92-0064.
Holst E, Goffeng AR, Andersch B. Bacterial vaginosis and vaginal microorganisms in idiopathic premature labor and association with pregnancy outcome. J Clin Microbiol. 1994;32:176-86. [pmcid: 262991]. [pmid: 8126176].
Hong S, Berkowitz G, Wang W, et al. Unexplained elevated maternal serum alpha-fetoprotein levels and pregnancy outcome in twins. Obstet Gynecol. 1996;88:337-42. [pmid: 8752235].
Houlton MC, Marivate M, Philpott RH. Factors associated with preterm labour and changes in the cervix before labour in twin pregnancy. Br J Obstet Gynecol. 1982;89:190-4.
How HY, Hughes SA, Vogel RL, et al. Oral terbutaline in the outpatient management of preterm labor. Am J Obstet Gynecol. 1995;173:1518-22. [pmid: 7503194].
Howard TEJ, Killam AP, Penney LL, et al. A double blind randomized study of terbutaline in premature labor. Mil Med. 1982;147:305-7. [pmid: 6815559].
Huddleston JF. Preterm labor. Clin Obstet Gynecol. 1982;25:123-36. [pmid: 6121640].
Hueston WJ. Prevention and treatment of preterm labor. Am Fam Physician. 1989;40:139-46. [pmid: 2683688].
Hueston WJ. A critical assessment of preterm labor prevention strategies. J Fam Pract. 1992;35:81-9. [pmid: 1613478].
Hueston WJ. Variations between family physicians and obstetricians in the evaluation and treatment of preterm labor. J Fam Pract. 1997;45:336-40. [pmid: 9343055].
Hurst-Prager C. Therapeutic interventions in pregnancy. Int J Childbirth Educ. 1991;6:36-7.
Hux CH, Trolice MP, Kadar N. The value of a single fetal fibronectin assay as a screen for preterm labor and delivery. J Matern Fetal Med. 1995;4:100-4.
Iams JD. Randomized controlled trials of home uterine activity monitoring: A review and critique. Obstet Gynecol. 1992;79:1052-3. [pmid: 1579307].
Iams JD. Cervical ultrasonography. Ultrasound Obstet Gynecol. 1997;10:156-60. [pmid: 9339521].
Iams JD, Casal D, McGregor JA, et al. Fetal fibronectin improves the accuracy of diagnosis of preterm labor. Am J Obstet Gynecol. 1995;173:141-5. [pmid: 7631671].
Iams JD, Goldenberg RL, Meis PJ, et al. The length of the cervix and the risk of spontaneous premature delivery. N Engl J Med. 1996;334:567-72. [pmid: 8569824].
Iams JD, Goldenberg RL, Mercer BM, et al. The preterm prediction study: recurrence risk of spontaneous preterm birth. Am J Obstet Gynecol. 1998;178:1035-40. [pmid: 9609580].
Iams JD, Johnson FF, Creasy RK. Prevention of preterm birth. Clin Obstet Gynecol. 1988;31:599-615. [pmid: 3066545].
Iams JD, Johnson FF, O'Shaughnessy RW. A prospective random trial of home uterine activity monitoring in pregnancies at increased risk of preterm labor. Part II. Am J Obstet Gynecol. 1988;159:595-603. [pmid: 3421258].
Iams JD, Johnson FF, O'Shaughnessy RW. Ambulatory uterine activity monitoring in the post-hospital care of patients with preterm labor. Am J Perinatol. 1990;7:170-3. [pmid: 2331280].
Iams JD, Johnson FF, O'Shaughnessy RW, et al. A prospective random trial of home uterine activity monitoring in pregnancies at increased risk of preterm labor. Am J Obstet Gynecol. 1987;157:638-43. [pmid: 3307423].
Iams JD, Paraskos J, Landon MB, et al. Cervical sonography in preterm labor. Obstet Gynecol. 1994;84:40-6. [pmid: 8008320].
Ingemarsson I. Effect of terbutaline on premature labor. A double-blind placebo-controlled study. Am J Obstet Gynecol. 1976;125:520-4. [pmid: 790961].
Ingemarsson I. Pharmacology of tocolytic agents. Clinics Obstet Gynecol. 1984;11:337-51.
Ingemarsson I, Arulkumaran S, Kottegoda SR. Complications of beta-mimetic therapy in preterm labour. Aust N Z J Obstet Gynecol. 1985;25:182-9.
Inglis SR. Biochemical markers predictive of preterm delivery. Infect Dis Obstet Gynecol. 1997;5:158-64. [pmid: 18476169].
Inglis SR, Jeremias J, Kuno K, et al. Detection of tumor necrosis factor-alpha, interleukin-6, and fetal fibronectin in the lower genital tract during pregnancy: Relation to outcome. Am J Obstet Gynecol. 1994;171:5-10. [pmid: 8030732].
Irion O, Matute J, Bischof P. [Prediction of prematurity by oncofetal fibronectin. Prospective cohort study]. Prediction de la prematurite par la fibronectine oncofoetale. Etude de cohorte prospective. [Fre]. J Gynecol Obstet Biol Reprod (Paris). 1995;24:624-9. [pmid: 8830085].
Jannet D, Abankwa A, Guyard B, et al. Nicardipine versus salbutamol in the treatment of premature labor. A prospective randomized study. Eur J Obstet Gynecol Reprod Biol. 1997;73:11-6. [pmid: 9175683].
Joesoef MR, Hillier SL, Wiknjosastro G, et al. Intravaginal clindamycin treatment for bacterial vaginosis: Effects on preterm delivery and low birth weight. Am J Obstet Gynecol. 1995;173:1527-31. [pmid: 7503196].
Johnson P. Suppression of preterm labour: Current concepts. Drugs. 1993;45:684-92. [pmid: 7686464].
Johnson WC, Harbert GM, Martin CB. Pharmacologic control of uterine contractility. Am J Obstet Gynecol. 1975;123:364-75. [pmid: 241259].
Kanayama N, El Maradny E, Yamamoto N, et al. Urinary trypsin inhibitor: A new drug to treat preterm labor: A comparative study with ritodrine. Eur J Obstet Gynecol Reprod Biol. 1996;67:133-8. [pmid: 8841801].
Kardong-Edgren S. Full moon, barometric pressure, and human birth. J Perinat Educ. 1995;4:21-5.
Karim SM. Appearance of prostaglandin F2a in human blood during labor. Br Med J. 1968;4(631):618-21. [pmid: 5723366].
Karim SM. On the use of blockers of prostaglandin synthesis in the control of labor. Adv Prostaglandin Thromboxane Res. 1978;4:301-6. [pmid: 347913].
Karim SM, Devlin J. Prostaglandin content of amniotic fluid during pregnancy and labor. J Obstet Gynecol Br Commonw. 1967;74.
Katz M. Randomized controlled trials of home uterine activity monitoring: A review and critique. Obstet Gynecol. 1992;79:1051-2. [pmid: 1579306].
Katz M, Gill PJ. Initial evaluation of an ambulatory system for home monitoring and transmission of uterine activity data. Obstet Gynecol. 1985;66.
Katz M, Newman RB. Ritodrine in the treatment of preterm labor: Second Danish multicenter study. Obstet Gynecol. 1987;69:281-3. [pmid: 3543770].
Katz M, Gill PJ, Newman RB. Detection of preterm labor by ambulatory monitoring of uterine activity for the management of oral tocolysis. Am J Obstet Gynecol. 1986;154:1253-6. [pmid: 3717236].
Katz M, Newman RB, Gill PJ. Assessment of uterine activity in ambulatory patients at high risk of preterm labor and delivery. Am J Obstet Gynecol. 1986;154:44-7. [pmid: 3946503].
Keirse MJ. New perspectives for the effective treatment of preterm labor. Am J Obstet Gynecol. 1995;173:618-28. [pmid: 7645643].
Keirse MJ, Van Hoven M. Reanalysis of a multireported trial on home uterine activity monitoring. Birth. 1993;20:117-22. [pmid: 8240617].
Kerem E, Dollberg S, Paz I, et al. Prenatal ritodrine administration and the incidence of respiratory distress syndrome in premature infants. J Perinatol. 1997;17:101-6. [pmid: 9134506].
Khan Z. Active management of preterm labour and preterm prelabour rupture of membranes. JPMA J Pak Med Assoc. 1994;44:258-60. [pmid: 7830304].
Khandelwal M, Lynch L, Lockwood CJ, et al. Maternal serum levels of alpha-fetoprotein and fetal fibronectin as markers of labor in the third trimester. Am J Perinatol. 1995;12:161-63. [pmid: 7541997].
Khoo SK, Mackay EV. Effects of adrenocorticosteroid therapy on urinary oestriol excretion in pregnancy. Med J Aust. 1969;2:1296-1300. [pmid: 5379104].
King DE. Electronic fetal monitoring. Int J Childbirth Educ. 1997;12:28-9.
King JF, Grant A, Keirse MJNC, et al. Beta-mimetics in preterm labour: An overview of the randomized controlled trials. Br J Obstet Gynecol. 1988;95:211-22.
Kiningham RB. Asymptomatic bacteriuria in pregnancy. Am Fam Physician. 1993;47:1232-8. [pmid: 8465718].
Kirschbaum T. Antibiotics in the treatment of preterm labor. Am J Obstet Gynecol. 1993;168:1239-46. [pmid: 8475971].
Klaus P. Searching for underlying causes. Midwifery Today Childbirth Educ. 1995;35.
Klebanoff MA. Conceptualizing categories of preterm birth. Prenat Neonat Med. 1998;3:13-5.
Klebanoff MA, Regan JA, Rao AV, et al. Outcome of the Vaginal Infections and Prematurity Study: Results of a clinical trial of erythromycin among pregnant women colonized with group B streptococci. Am J Obstet Gynecol. 1995;172:1540-5. [pmid: 7755068].
Kleinman JC, Kessel SS. Racial differences in low birth weight: trends and risk factors. N Engl J Med. 1987;317:749-53. [pmid: 3627185].
Knuppel RA, Lake MF, Watson DL, et al. Preventing preterm birth in twin gestation: Home uterine activity monitoring and perinatal nursing support. Obstet Gynecol. 1990;76(1 Suppl):24S-27S. [pmid: 2359575].
Knuppel RA, Lake MF, Watson DL, et al. The contribution of symptomatology and/or uterine activity to the incidence of unscheduled visits. Obstet Gynecol. 1990;76(1 Suppl):28S-31S. [pmid: 2193275].
Ko-Kivok-Yun P, Elgahoui A, Martin F, et al. La menace d'accouchement premature. Rev Fr Gynecol Obstet. 1996;91:558-66.
Kogan MD, Alexander GR. Social and behavioral factors in preterm birth. Prenat Neonat Med. 1998;3:29-31.
Koh KS. Premature labour. Can Med Assoc J. 1976;114:700-4, 707. [pmid: 4217].
Koks CA, Brolmann HA, de Kleine MJK, et al. A randomized comparison of nifedipine and ritodrine for suppression of preterm labor. Eur J Obstet Gynecol Reprod Biol. 1998;77:171-6. [pmid: 9578274].
Konchak PS, Bernstein IM, Capeless EL. Uterine artery Doppler velocimetry in the detection of adverse obstetric outcomes in women with unexplained elevated maternal serum alpha-fetoprotein levels. Am J Obstet Gynecol. 1995;173:1115-9. [pmid: 7485303].
Kopelman JN, Duff P, Read JA. Randomized comparison of oral terbutaline and ritodrine for preventing recurrent preterm labor. J Reprod Med. 1989;34:225-30. [pmid: 2657045].
Kosasa TS, Busse R, Wahl N, et al. Long-term tocolysis with combined intravenous terbutaline and magnesium sulfate: A 10-year study of 1000 patients. Obstet Gynecol. 1994;84:369-73. [pmid: 8058233].
Kosasa TS, Nakayama RT, Hale RW, et al. Ritodrine and terbutaline compared for the treatment of preterm labor. Acta Obstet Gynecol Scand. 1985;64:421-26. [pmid: 3904315].
Kose D, Karaosmanoglu S, Yeniguc CT, et al. Erken Dogum eyleminde nifedipinin tokolitik etkinligi. Jinekoloji Ve Obstetrik Dergisi. 1995;9:165-70.
Kovacs L, Meszaros G, Pal A, Szasz K. [Tocolysis with clenbuterol tablets]. Tokolyse mit Clenbuterol-Tabletten [Ger]. Zentralbl Gynakol. 1987;109:1368-73. [pmid: 3324563].
Kovacs L, Zalanyi SJ, Szasz K, et al. [Use of terbutaline sulfate (Bricalyn Astra-Egyt) for betamimetic tocolysis]. Die Anwendung von Terbutalin-Sulfat (Bricanyl ASTRA-EGYT) zur betamimetischen Tokolyse [Ger]. Zentralbl Gynakol. 1982;104:1445-50. [pmid: 6891878].
Kramer MS. Preventing preterm birth: Are we making progress?. Prenat Neonat Med. 1998;3:10-2.
Kramer MS, Coates AL, Michoud MC, et al. Maternal anthropometry and idiopathic preterm labor. Obstet Gynecol. 1995;86:744-8. [pmid: 7566841].
Kristoffersen K, Hansen MK. The condition of the foetus and infant in cases treated with ritodrine [Dan]. Dan Med Bull. 1979;26:121-2. [pmid: 376230].
Kullander S, Svanberg L. On resorption and the effects of vaginally administered terbutaline in women with premature labor. Acta Obstet Gynecol Scand. 1985;64:613-6. [pmid: 3909732].
Kupferminc M, Lessing JB, Yaron Y, et al. Nifedipine versus ritodrine for suppression of preterm labour. Br J Obstet Gynecol. 1993;100:1090-4.
Kupferminc MJ, Peaceman AM, Wigton TR, et al. Fetal fibronectin levels are elevated in maternal plasma and amniotic fluid of patients with severe preeclampsia. Am J Obstet Gynecol. 1995;172:649-53. [pmid: 7856700].
Kurki T. A survey of etiological mechanisms and therapy of preterm labor. Acta Obstet Gynecol Scand. 1998;77:137-41. [pmid: 9512315].
Kurki T, Eronen M, Lumme R, et al. A randomized double-dummy comparison between indomethacin and nylidrin in threatened preterm labor. Obstet Gynecol. 1991;78:1093-7. [pmid: 1945214].
Kurki T, Schultz E, Linden IB, et al. Catechol-O-methyltransferase activity in red blood cells in threatened preterm labor; effect of indomethacin and nylidrin. Acta Obstet Gynecol Scand. 1991;70:187-91. [pmid: 1927294].
Lagace E. Oral terbutaline after parenteral tocolysis. J Fam Pract. 1997;44:131-2. [pmid: 9040511].
Lam F, Gill P, Smith M, et al. Use of the subcutaneous terbutaline pump for long-term tocolysis. Obstet Gynecol. 1988;72:810-3. [pmid: 3173932].
Lamont RF. The management of preterm labour. Clinics Obstet Gynecol. 1986;13:231-46.
Lamont RF. New approaches in the management of preterm labour of infective aetiology. Br J Obstet Gynecol. 1998;105:134-7.
Landesman R, Fuchs F. Control of uterine activity and prevention of premature birth. Basic Life Sci. 1974;4(Pt. B):219-41. [pmid: 4156643].
Lands AM, Arnold A, McAuliff JP, et al. Differentiation of receptor systems by sympathomimetic amines. Nature. 1967;214.
Langer B, Boudier E, Schlaeder G. Cervico-vaginal fetal fibronectin: Predictive value during false labor. Acta Obstet Gynecol Scand. 1997;76:218-21. [pmid: 9093134].
Larsen JF, Eldon K, Lange AP, et al. Ritodrine in the treatment of preterm labor: second Danish Multicenter Study. Obstet Gynecol. 1986;67:607-13. [pmid: 3515261].
Larsen JF, Hansen MK, Hesseldahl H, et al. Ritodrine in the treatment of preterm labour. A clinical trial to compare a standard treatment with three regimens involving the use of ritodrine. Br J Obstet Gynecol. 1980;87:949-57.
Lauersen NH. Treatment of preterm labor with the beta-adrenergic agonist ritodrine. N Engl J Med. 1992;327:1759-60. [pmid: 1435926].
Lauersen NH, Merkatz IR, Tejani N, et al. Inhibition of premature labor: a multicenter comparison of ritodrine and ethanol. Am J Obstet Gynecol. 1977;127:837-45. [pmid: 851140].
Leake RD, Hobel CJ, Okada DM, et al. Neonatal metabolic effects of oral ritodrine hydrochloride administration. Pediatr Pharmacol. 1983;3:101-6.
Ledger WJ. Identification of the high risk mother and fetus-does it work?. Clin Perinatol. 1980;7:125-34. [pmid: 6994984].
Ledger WJ. Treatment of preterm labor with the beta-adrenergic agonist ritodrine. N Engl J Med. 1992;327:1758-9. [pmid: 1435925].
Lees C, Campbell S, Jauniaux E, et al. Arrest of preterm labour and prolongation of gestation with glyceryl trinitrate, a nitric oxide donor. Lancet. 1994;343(8909):1325-6. [pmid: 7910325].
Leeson SC, Maresh MJ, Martindale EA, et al. Detection of fetal fibronectin as a predictor of preterm delivery in high risk asymptomatic pregnancies. Br J Obstet Gynecol. 1996;103:48-53.
Lefevre ML. Preventing the complications of preterm birth. Am Fam Physician. 1992;46:441-8. [pmid: 1636560].
LeFevre ML, Hueston WJ. Preterm birth. Prim Care. 1993;20:639-53. [pmid: 8378456].
Leonardi MR, Hankins GD. What's new in tocolytics. Clin Perinatol. 1992;19:367-84. [pmid: 1352193].
Leveno KJ, Cunningham FG. Beta-adrenergic agonists for preterm labor. N Engl J Med. 1992;327:349-51. [pmid: 1352375].
Leveno KJ, Klein VR, Guzick DS, et al. Single-centre randomised trial of ritodrine hydrochloride for preterm labour. Lancet. 1986;1(8493):1293-6. [pmid: 2872429].
Lewis DF, Bergstedt S, Edwards MS, et al. Successful magnesium sulfate tocolysis: is 'weaning' the drug necessary?. Am J Obstet Gynecol. 1997;177:742-5. [pmid: 9369812].
Lewis DF, Brody K, Edwards MS, et al. Preterm premature ruptured membranes: A randomized trial of steroids after treatment with antibiotics. Obstet Gynecol. 1996;88:801-5. [pmid: 8885917].
Lewis DF, Grimshaw A, Brooks G, et al. A comparison of magnesium sulfate and indomethacin to magnesium. South Med J. 1995;88:737-40. [pmid: 7597478].
Lewis R, Mercer BM. Adjunctive care of preterm labor-the use of antibiotics. Clin Obstet Gynecol. 1995;38:755-70. [pmid: 8616973].
Lewis R, Mercer BM, Salama M, et al. Oral terbutaline after parenteral tocolysis: A randomized, double-blind, placebo-controlled trial. Am J Obstet Gynecol. 1996;175(4 Pt 1):834-7. [pmid: 8885731].
Lewit E, Baker L, Corman H, et al. The direct cost of low birth weight. Future Child. 1995 Spring;5(1):35-56.
Leylek OA, Songur S, Erselcan T, et al. Cervicovaginal washing prolactin assay in prediction of preterm delivery. Int J Gynecol Obstet. 1997;59:7-12.
Lindenbaum C, Ludmir J, Teplick FB, et al. Maternal glucose intolerance and the subcutaneous terbutaline pump. Am J Obstet Gynecol. 1992;166:925-8. [pmid: 1550166].
Lipshitz J. Preterm parturition. Beta-adrenergic agonists. Semin Perinatol. 1981;5:252-65. [pmid: 6116282].
Ljungstrom B, Mamsen A, Secher NJ. Indications for tocolytic therapy: Incidence of true preterm labor with uterine contractions as the sole deciding factor. Am J Perinatol. 1989;6:218-21. [pmid: 2785389].
Lockwood CJ. Recent advances in elucidating the pathogenesis of preterm delivery, the detection of patients at risk, and preventative therapies. Curr Opinion Obstet Gynecol. 1994;6:7-18.
Lockwood CJ. The diagnosis of preterm labor and the prediction of preterm delivery. Clin Obstet Gynecol. 1995;38:675-87. [pmid: 8616965].
Lockwood CJ, Costigan K, Ghidini A, et al. Double-blind; placebo-controlled trial of piperacillin prophylaxis in preterm membrane rupture. Am J Obstet Gynecol. 1993;169:970-6. [pmid: 8238159].
Lockwood CJ, Dudenhausen JW. New approaches to the prediction of preterm delivery. J Perinat Med. 1993;21:441-52. [pmid: 8006770].
Lockwood CJ, Senyei AE, Dische MR, et al. Fetal fibronectin in cervical and vaginal secretions as a predictor of preterm delivery. N Engl J Med. 1991;325:669-74. [pmid: 1870640].
Lockwood CJ, Wein R, Lapinski R, et al. The presence of cervical and vaginal fetal fibronectin predicts preterm delivery in an inner-city obstetric population. Am J Obstet Gynecol. 1993;169:798-804. [pmid: 8238134].
Lohr KN, Carey TS. Assessing "best evidence": Issues in grading the quality of studies for systematic reviews. J Qual Improv. 1999;25:470-9.
Lorenz-Eberhardt G, Weiss PAM, Haas J, et al. [Premature labor and fetal fibronectin in cervical and vaginal secretions]. Fruhgeburt und fetales fibronectin im zervikal- und vaginalsekret. Geburtsh Frauenheilk. 1994;54:414-6. [pmid: 7926575].
Lorenz RP, Comstock CH, Bottoms SF, et al. Randomized prospective trial comparing ultrasonography and pelvic examination for preterm labor surveillance. Am J Obstet Gynecol. 1990;162:1603-10. [pmid: 2193518].
Lovastatin Study Groups. Lovastatin 5-year safety and efficacy study. Lovastatin Study Groups I through IV. Arch Intern Med. 1993;153:1079-87. [pmid: 8481075].
Luke B, Bigger HR, Leurgans S, et al. The cost of prematurity: A case-control study of twins vs. singletons. Am J Public Health. 1996;86:809-14. [pmid: 8659654]. [pmcid: 1380399].
Lukes AS, Thorp JMJr, Eueker B, et al. Predictors of positivity for fetal fibronectin in patients with symptoms of preterm labor. Am J Obstet Gynecol. 1997;176:639-41. [pmid: 9077620].
Lumley J. The epidemiology of preterm birth. Baillieres Clin Obstet Gynecol. 1993;7:477-98.
Mabie WC, Pernoll ML, Witty JB, et al. Pulmonary edema induced by betamimetic drugs. South Med J. 1983;76:1354-60. [pmid: 6635722].
Macones GA, Sehdev HM, Berlin M, et al. Evidence for magnesium sulfate as a tocolytic agent. Obstet Gynecol Surv. 1997;52:652-8. [pmid: 9326758].
Madden C, Owen J, Hauth JC. Magnesium tocolysis: Serum levels versus success. Am J Obstet Gynecol. 1990;162:1177-80. [pmid: 2339717].
Main DM, Gabbe SG, Richardson D, et al. Can preterm deliveries be prevented?. Am J Obstet Gynecol. 1985;151:892-8. [pmid: 3885736].
Major, CA, Lewis, DF, Harding, JA, et al. Tocolysis with indomethacin increases the incidence of necrotizing enterocolitis in the low-birth-weight neonate. Am J Obstet Gynecol. 1994;170:102-6. [pmid: 8296809].
Malak TM, Sizmur F, Bell SC, et al. Fetal fibronectin in cervicovaginal secretions as a predictor of preterm birth. Br J Obstet Gynecol. 1996;103:648-53.
Mansouri A, Tadjerouni A, El Rabiey G, et al. [Is fetal fibronectin a valid test predictive of premature labor]? La fibronectin foetale est-elle un bon test de prediction de l'accouchement premature?. Contracept Fertil Sex. 1997;25:380-4. [pmid: 9273109].
Marivate M, de Villiers KQ, Fairbrother P. Effect of prophylactic outpatient administration of fenoterol on the time of onset of spontaneous labor and fetal growth rate in twin pregnancy. Am J Obstet Gynecol. 1977;128:707-8. [pmid: 327814].
Martin AJ. Severe unwanted effects associated with betasympathomimetics when used in the treatment of premature labour: Causes, incidence and preventative measures. Br J Clin Pract. 1981;35:325-9. [pmid: 6120000].
Martin RW, Gookin KS, Hill WC, et al. Uterine activity compared with symptomatology in the detection of preterm labor. Obstet Gynecol. 1990;76(1 Suppl):19S-23S. [pmid: 2193273].
Martin RW, Perry KG Jr, Hess W, et al. Oral magnesium and the prevention of preterm labor in a high-risk group of patients. Am J Obstet Gynecol. 1992;166:144-7. [pmid: 1733187].
Martius J, Eschenbach DA. The role of bacterial vaginosis as a cause of amniotic fluid infection, chorioamnionitis and prematurity-a review. Arch Gynecol Obstet. 1990;247:1-13. [pmid: 2178562].
Martius J, Krohn MA, Hillier SL, et al. Relationships of vaginal lactobacillus species, cervical chlamydia trachomatis, and bacterial vaginosis to preterm birth. Obstet Gynecol. 1988;71:89-95. [pmid: 3336545].
Masse J, Forest JC, Moutquin JM. Microalbumin as a marker of premature delivery. Obstet Gynecol. 1996;87(5 Pt 1):661-3. [pmid: 8677063].
Matsuda Y, Ikenoue T, Hokanishi H. Premature rupture of the membranes-aggressive versus conservative approach: Effect of tocolytic and antibiotic therapy. Gynecol Obstet Invest. 1993;36:102-7. [pmid: 8225043].
Matsuda Y, Maeda Y, Ito M, et al. Effect of magnesium sulfate treatment on neonatal bone. Gynecol Obstet Invest. 1997;44:82-8. [pmid: 9286718].
Mazor M, Chaim W, Maymon E, et al. The role of antibiotic therapy in the prevention of prematurity. Clin Perinatol. 1998;25:659-85. [pmid: 9779340].
Mazor M, Hershkowitz R, Ghezzi F, et al. Maternal plasma and amniotic fluid 17 beta-estradiol, progesterone and cortisol concentrations in women with successfully and unsuccessfully treated preterm labor. Arch Gynecol Obstet. 1996;258:89-96. [pmid: 8779616].
McCaughan D. The long-term effects of probucol on serum lipid levels. Arch Intern Med. 1981;141:1428-32. [pmid: 7025778].
McCaul JF, Perry KG Jr, Moore JL Jr, et al. Adjunctive antibiotic treatment of women with preterm rupture of membranes of preterm labor. Int J Gynecol Obstet. 1992;38:19-24.
McCombs J. Update on tocolytic therapy. Ann Pharmacother. 1995;29:515-22. [pmid: 7655136].
McCormick MC. The contribution of low birth weight to infant mortality and childhood morbidity. N Engl J Med. 1985;312:82-9. [pmid: 3880598].
McDonald HM, O'Loughlin JA, Jolley P, et al. Prenatal microbiological risk factors associated with preterm birth. Br J Obstet Gynecol. 1992;99:190-6.
McGregor JA. Preterm birth, premature rupture of membranes, and cervical incompetence. Curr Opin Obstet Gynecol. 1992;4:37-42. [pmid: 1543827].
McGregor JA, French JI, Jones W, et al. Bacterial vaginosis is associated with prematurity and vaginal fluid mucinase and sialidase: Results of a controlled trial of topical clindamycin cream. Am J Obstet Gynecol. 1994;170:1048-59. [pmid: 8166188].
McGregor JA, French JI, Parker R, et al. Prevention of premature birth by screening and treatment for common genital tract infections: Results of a prospective controlled evaluation. Am J Obstet Gynecol. 1995;173:157-67. [pmid: 7631673].
McGregor JA, French JI, Reller LB, et al. Adjunctive erythromycin treatment for idiopathic preterm labor: Results of a randomized, double-blinded, placebo-controlled trial. Am J Obstet Gynecol. 1986;154:98-103. [pmid: 3511709].
McGregor JA, French JI, Seo K. Adjunctive clindamycin therapy for preterm labor: Results of a double-blind, placebo-controlled trial. Am J Obstet Gynecol. 1991;165:867-75. [pmid: 1951545].
McGregor JA, Jackson GM, Lachelin GC, et al. Salivary estriol as risk assessment for preterm labor: a prospective trial. Am J Obstet Gynecol. 1995;173:1337-42. [pmid: 7485350].
McIntosh MW. The population risk as an explanatory variable in research synthesis of clinical trials. Stat Med. 1996;15:1713-28. [pmid: 8870154].
McLean M, Walters WA, Smith R. Prediction and early diagnosis of preterm labor: A critical review. Obstet Gynecol Surv. 1993;48:209-25. [pmid: 8474759].
McQueen D, Neilson JP, Whittle MJ. Pre-labour rupture of membranes with an unripe cervix: a random trial of management. J Obstet Gynecol. 1990;10:495-8.
Meier U, Wolff F, Klingspohr HJ. [Effect of fenoterol (Partusisten) on the oxygen dissociation curve in pregnant women (author's transl)]. Der Einfluss von Fenoterol (Partusisten) auf die Sauerstoffbindungskurve bei schwangeren Frauen. Z Geburtshilfe Perinatol. 1978;182:288-93. [pmid: 360648].
Meinen K, Rahn M, Hermer M, et al. Oral tocolysis with clenbuterol-clinical facts [Ger]. Z Geburtsh Perinatol. 1988;192:163-8.
Meis PJ, Goldenberg RL, Mercer BM, et al. The preterm prediction study: Risk factors for indicated preterm births. Am J Obstet Gynecol. 1998;178:562-7. [pmid: 9539527].
Meis PJ, Goldenberg RL, Mercer B, et al. The preterm prediction study: Significance of vaginal infections. Am J Obstet Gynecol. 1995;173:1231-5. [pmid: 7485327].
Melin P. Oxytocin antagonists and their therapeutic use. Regul Pept. 1993;45:285-8. [pmid: 8390080].
Melin P. Oxytocin antagonists in preterm labour and delivery. Baillieres Clin Obstet Gynecol. 1993;7:577-600.
Mendonca D, Cavalcanti A, Mendonca F, et al. Complementary methods for treatment and diagnosis of premature rupture of the membranes in Lauro Wanderley Hospital [Por]. J Brasileiro Ginecol. 1994;104:281-5.
Mendoza N, Miranda JA, Miranda C, et al. Relationship between infection of the female genital tract and tocolytic response in preterm labor. J Matern Fetal Invest. 1997;7:21-4.
Menticoglou SM, Morrison I, Harman CR, et al. Maximum possible impact of tocolytics in preventing preterm birth: A retrospective assessment. Am J Perinatol. 1992;9:394-7. [pmid: 1418142].
Mercer BM, Lewis R. Preterm labor and preterm premature rupture of the membranes. Diagnosis and management. Infect Dis Clin North Am. 1997;11:177-201. [pmid: 9067791].
Merkatz IR, Peter JB, Barden TP. Ritodrine hydrochloride: A betamimetic agent for use in preterm labor. II. Evidence of efficacy. Obstet Gynecol. 1980;56:7-12. [pmid: 6992003].
Merkatz RB, Merkatz IR. The contributions of the nurse and the machine in home uterine activity monitoring systems. Am J Obstet Gynecol. 1991;164(5 Pt 1):1159-62. [pmid: 2035556].
Merkus JM, Roozen PH, Verhoeven AG, et al. Surfactant in the amniotic fluid and bromhexine metabolite VIII. Eur J Obstet Gynecol Reprod Biol. 1978;8:99-102. [pmid: 400861].
Merrill JD, Clyman RI, Norton ME. Indomethacin as a tocolytic agent: Controversy continues. J Pediatr. 1994;124:734-6. [pmid: 8176560].
Metzger BE, Ravnikar V, Vileisis RA et al. Accelerated starvation and the skipped breakfast in late normal pregnancy. Lancet. 1982 Mar 13;1(8272):588-92.
Meyer MB, Tonascia JA. Maternal smoking, pregnancy complications, and perinatal mortality. Am J Obstet Gynecol. 1977;128:494-502. [pmid: 560121].
Meyer WR, Randall HW, Graves WL. Nifedipine versus ritodrine for suppressing preterm labor. J Reprod Med. 1990;35:649-53. [pmid: 2359062].
Miller DD. Tocolytic therapy for the prevention of preterm labor. J Intravenous Nurs. 1995;18:233-8.
Minakami H, Takahashi T, Izumi A, et al. Enlargement of the salivary gland after ritodrine treatment in pregnant women. Br Med J. 1992;304.
Mittendorf R, Covert R, Boman J, et al. Is tocolytic magnesium sulphate associated with increased total paediatric mortality?. Lancet. 1997;350(9090):1517-8. [pmid: 9388401].
Mittendorf R, Pryde P, Khoshnood B, et al. If tocolytic magnesium sulfate is associated with excess total pediatric mortality, what is its impact?. Obstet Gynecol. 1998;92:308-11. [pmid: 9699773].
Moise KJ. Effect of advancing gestational age on the frequency of fetal ductal constriction in association with maternal indomethacin use. Am J Obstet Gynecol. 1993;168:1350-53. [pmid: 8498410].
Monga M, Creasy RK. Pharmacologic management of preterm labor. Semin Perinatol. 1995;19:84-96. [pmid: 7754414].
Morales WJ, Madhav H. Efficacy and safety of indomethacin compared with magnesium sulfate in the management of preterm labor: A randomized study. Am J Obstet Gynecol. 1993;169:97-102. [pmid: 8333483].
Morales WJ, Angel JL, O'Brien WF, et al. A randomized study of antibiotic therapy in idiopathic preterm labor. Obstet Gynecol. 1988;72:829-33. [pmid: 3186088].
Morales WJ, Schorr S, Albritton J. Effect of metronidazole in patients with preterm birth in preceding pregnancy and bacterial vaginosis: A placebo-controlled, double-blind study. Am J Obstet Gynecol. 1994;171:345-7. [pmid: 8059811].
Morales WJ, Smith SG, Angel JL, et al. Efficacy and safety of indomethacin versus ritodrine in the management of preterm labor: A randomized study. Obstet Gynecol. 1989;74:567-72. [pmid: 2677863].
Morrison JC, Allbert JR, Floyd RC, et al. Interval to delivery in high-risk patients: do tocolytic agents really work?. Int J Gynecol Obstet. 1992;38:189-93.
Morrison JC, Martin JN, Martin RW, et al. Prevention of preterm birth by ambulatory assessment of uterine activity: A randomized study. Am J Obstet Gynecol. 1987;156:536-43. [pmid: 3826196].
Morrison JC, Martin JN, Martin RW, et al. A program of uterine activity monitoring and its effect on neonatal morbidity. J Perinatol. 1988;8:228-31. [pmid: 3225664].
Morrison JC, Naef III, Botti JJ, et al. Prediction of spontaneous preterm birth by fetal fibronectin and uterine activity. Obstet Gynecol. 1996;87(5 Pt 1):649-55. [pmid: 8677061].
Morrison JC, Pittman KP, Martin RW, et al. Cost/health effectiveness of home uterine activity monitoring in a Medicaid population [published erratum appears in Obstet Gynecol 1990; 76: 307]. Obstet Gynecol. 1990;76(1 Suppl):76S-81S. [pmid: 2113663].
Morssink LP, Kornman LH, Hallahan TW, et al. Maternal serum levels of free beta-hCG and PAPP-A in the first trimester of pregnancy are not associated with subsequent fetal growth retardation or preterm delivery. Prenat Diagn. 1998;18:147-52. [pmid: 9516016].
Mosler KH. The dynamics of uterine muscle. Bibl Gynecol. 1968;48:1-82.
Mou SM, Sunderji SG, Gall S, et al. Multicenter randomized clinical trial of home uterine activity monitoring for detection of preterm labor. Am J Obstet Gynecol. 1991;165(4 Pt 1):858-66. [pmid: 1951544].
Muller-Holve W, Hermer M, Klock FK, et al. Fenoterol depot and fenoterol in premature uterine contractions-a multicentric double-blind comparative study. J Perinat Med. 1987;15:95-103. [pmid: 3295180].
Murakawa H, Utumi T, Hasegawa I, et al. Evaluation of threatened preterm delivery by transvaginal ultrasonographic measurement of cervical length. Obstet Gynecol. 1993;82:829-32. [pmid: 8414332].
Murphy PA. Preterm birth prevention programs. A critique of current literature. J Nurse Midwifery. 1993;38:324-35. [pmid: 8295015].
Murray C, Haverkamp AD, Orleans M, et al. Nifedipine for treatment of preterm labor: A historic prospective study. Am J Obstet Gynecol. 1992;167:52-6. [pmid: 1442954].
Nadisauskiene R, Bergstrom S. Impact of intrapartum intravenous ampicillin on pregnancy outcome in women with preterm labor: A randomised, placebo-controlled study. Gynecol Obstet Invest. 1996;41:85-8. [pmid: 8838965].
Nadisauskiene R, Bergstrom S, Kilda A. Ampicillin in the treatment of preterm labor: A randomised, placebo-controlled study. Gynecol Obstet Invest. 1996;41:89-92. [pmid: 8838966].
Nageotte MP, Casal D, Senyei AE. Fetal fibronectin in patients at increased risk for premature birth. Am J Obstet Gynecol. 1994;170(1 Pt 1):20-5. [pmid: 8296822].
Nagey DA, Bailey-Jones C, Herman AA. Randomized comparison of home uterine activity monitoring and routine care in patients discharged after treatment for preterm labor. Obstet Gynecol. 1993;82:319-23. [pmid: 8355927].
National Institutes of Child Health and Human Development. Report of the Consensus Development Conference on the Effect of Corticosteroids for Fetal Maturation on Perinatal Outcomes. Bethesda, MD: The Institute; 1994 Feb 28-Mar 2.
Neldam S, Osler M. Premature rupture of the membranes and ritodrine treatment. Acta Obstet Gynecol Scand. 1983;62:135-9. [pmid: 6346781].
Nelson LH, Meis PJ, Hatjis CG, et al. Premature rupture of membranes: A prospective, randomized evaluation of steroids, latent phase, and expectant management. Obstet Gynecol. 1985;66:55-8. [pmid: 4011071].
Newman RB, Gill PJ, Wittreich P, et al. Maternal perception of prelabor uterine activity. Obstet Gynecol. 1986;68:765-9. [pmid: 3785786].
Newton ER, Dinsmoor MJ, Gibbs RS. A randomized, blinded, placebo-controlled trial of antibiotics in idiopathic preterm labor. Obstet Gynecol. 1989;74:562-6. [pmid: 2677862].
Newton ER, Shields L, Ridgway III LE, et al. Combination antibiotics and indomethacin in idiopathic preterm labor: A randomized double-blind clinical trial. Am J Obstet Gynecol. 1991;165:1753-9. [pmid: 1750473].
Niebyl JR. Drugs for inhibition of premature labor. Clin Perinatol. 1979;6:53-63. [pmid: 38929].
Niebyl JR. Preterm parturition. Prostaglandin synthetase inhibitors. Semin Perinatol. 1981;5:274-87. [pmid: 6792710].
Niebyl JR, Blake DA, White RD, et al. The inhibition of premature labor with indomethacin. Am J Obstet Gynecol. 1980;136:1014-9. [pmid: 7369252].
Niebyl JR, Johnson JW. Inhibition of preterm labor. Clin Obstet Gynecol. 1980;23:115-26. [pmid: 6102498].
Noblot G, Audra P, Dargent D, et al. The use of micronized progesterone in the treatment of menace of preterm delivery. Eur J Obstet Gynecol Reprod Biol. 1991;40:203-9. [pmid: 1879595].
Norman K, Pattinson RC, de Souza J, et al. Ampicillin and metronidazole treatment in preterm labour: a multicentre, randomised controlled trial. Br J Obstetric Gynecol. 1994;101:404-8.
Norton, ME, Merrill, J, Cooper, BA, et al. Neonatal complications after the administration of indomethacin for preterm labor. N Engl J Med. 1993;329:1602-7. [pmid: 8232428].
Novy MJ, McGregor JA, Iams JD. New perspectives on the prevention of extreme prematurity. Clin Obstet Gynecol. 1995;38:790-808. [pmid: 8616976].
Nwosu UC, Thatcher SS. Premature rupture of membranes: A survey of the current clinical practices of the maternal-fetal medicine obstetricians in the United States. J Matern Fetal Invest. 1993;2:103-10.
O'Brien JM, Peeler GH, Pitts DW, et al. Cervicovaginal prolactin: A marker for spontaneous preterm delivery. Am J Obstet Gynecol. 1994;171:1107-11. [pmid: 7943080].
O'Connor MC, Murphy H, Dalrymple IJ. Double blind trial of ritodrine and placebo in twin pregnancy. Br J Obstet Gynecol. 1979;86:706-9.
Ogueh O, Khastgir G, Studd JW, et al. Antenatal corticosteroid therapy and risk of osteoporosis. Br J Obstet Gynecol. 1998;105:551-5.
Ohlsson A. Treatments of preterm premature rupture of the membranes: a meta-analysis. Am J Obstet Gynecol. 1989;160:890-906. [pmid: 2653041].
Ottman EH, Gall SA. Myocardial infarction in the third trimester of pregnancy secondary to an aortic valve thrombus. Obstet Gynecol. 1993;81(5 Pt 2):804-5. [pmid: 8469478].
Oyarzun E, Gomez R, Rioseco A, et al. Antibiotic treatment in preterm labor and intact membranes: A randomized, double-blinded, placebo-controlled trial. J Matern Fetal Med. 1998;7:105-10. [pmid: 9642605].
Oxorn H. Human labor and nirth. 5th ed. Norwalk, CT: Appleton Century Crofts; 1986. p. 113-51.
Ozcan T, Turan C, Ekici E, et al. Ritodrine tocolysis and neonatal intraventricular-periventricular hemorrhage. Gynecol Obstet Invest. 1995;39:60-2. [pmid: 7890256].
Palmieri JA, Hart LL. Use of nifedipine in inhibiting preterm labor. J Pharm Technol. 1989;5:243-5.
Palta M, Sadek M, Lim TS, et al. Association of tocolytic therapy with antenatal steroid administration and infant outcomes. Newborn Lung Project Am J Perinatol. 1998;15:87-92.
Paneth NS. The problem of low birth weight. Future Child. 1995;5:19-34. [pmid: 7633862].
Panter KS, Hannah ME, Amankwah KS, et al. The effect of idomethacin tocolysis in preterm labour on perinatal outcome: A randomised placebo-controlled trial. Br J Obstet Gynecol. 1999;106:467-73.
Papatsonis DN, Van Geijn HP, Ader HJ, et al. Nifedipine and ritodrine in the management of preterm labor: A randomized multicenter trial. Obstet Gynecol. 1997;90:230-4. [pmid: 9241299].
Papiernik E. Prediction of the preterm baby. Clin Obstet Gynecol. 1984;11:315-36.
Papiernik E. Preterm labor, preterm delivery, intrauterine infection, and preterm rupture of membranes. Curr Opinion Obstet Gynecol. 1990;2:8-12.
Papke KR. Management of preterm labor and prevention of premature delivery. Nurs Clin North Am. 1993;28:279-88. [pmid: 8516173].
Parilla BV, Dooley SL, Minogue JP, et al. The efficacy of oral terbutaline after intravenous tocolysis. Am J Obstet Gynecol. 1993;169:965-9. [pmid: 8238158].
Parker J, Bell R, Brennecke S. Fetal fibronectin in the cervicovaginal fluid of women with threatened preterm labour as a predictor of delivery before 34 weeks' gestation. Aust N Z J Obstet Gynecol. 1995;35:257-61.
Parsons MT, Owens CA, Spellacy WN. Thermic effects of tocolytic agents: Decreased temperature with magnesium sulfate. Obstet Gynecol. 1987;69:88-90. [pmid: 3796926].
Pattee CL, Penning DH. Obstetrical analgesia in a parturient with antithrombin III deficiency. Can J Anaesth. 1993;40:507-10. [pmid: 8403113].
Paul VK, Singh M, Buckshee K. Erythromycin treatment of pregnant women to reduce the incidence of low birth weight and preterm deliveries. Int J Gynecol Obstet. 1998;62:87-8.
Peaceman AM, Andrews WW, Thorp JM, et al. Fetal fibronectin as a predictor of preterm birth in patients with symptoms: A multicenter trial. Am J Obstet Gynecol. 1997;177:13-8. [pmid: 9240576].
Penney LL, Daniell WC. Estimation of success in treatment of premature labor: Applicability of prolongation index in a double-blind, controlled, randomized trial. Am J Obstet Gynecol. 1980;138:345-6. [pmid: 7416228].
Perlman JM. Antenatal glucocorticoid, magnesium exposure, and the prevention of brain injury of prematurity. Semin Pediatr Neurol. 1998;5:202-10. [pmid: 9777678].
Petersen LK, Skajaa K, Uldbjerg N. Serum relaxin as a potential marker for preterm labour. Br J Obstet Gynecol. 1992;99:292-5.
Petri M, Howard D, Repke J, et al. The Hopkins Lupus Pregnancy Center: 1987-1991 update. Am J Reprod Immunol. 1992;28:188-91. [pmid: 1283682].
Petrie RH. Preterm parturition. Tocolysis using magnesium sulfate. Semin Perinatol. 1981;5:266-73. [pmid: 7025217].
Pettibone DJ, Guidotti M, Harrell CM, et al. Progress in the development of oxytocin antagonists for use in preterm labor. Adv Exp Med Biol. 1995;395:601-12. [pmid: 8714024].
Phaneuf S, Asboth G, MacKenzie JZ, et al. Effect of oxytocin antagonists on the activation of human myometrium in vitro: Atosiban prevents oxytocin induced desensitization. Am J Obstet Gynecol. 1994;171:1627-34. [pmid: 7802080].
Philipsen T, Eriksen PS, Lynggard F. Pulmonary edema following ritodrine-saline infusion in premature labor. Obstet Gynecol. 1981;58:304-8. [pmid: 7266950].
Phuapradit W, Pongthai S, Chaturachinda K. Treatment of premature labour with terbutaline. J Med Assoc Thai. 1983;66:453-7. [pmid: 6685750].
Pincus R. Salbutamol infusion for premature labour-the Australian trials experience. Aust N Z J Obstet Gynecol. 1981;21:1-4.
Pircon RA, Strassner HT, Kirz DS, et al. Controlled trial of hydration and bed rest versus bed rest alone in the evaluation of preterm uterine contractions. Am J Obstet Gynecol. 1989;161:775-79. [pmid: 2782361].
Polomeno V. Brief historical overview of high-risk pregnancy. Int J Childbirth Educ. 1997;12:4-7.
Polomeno V. High-risk pregnancy: Teaching activities and strategies. Int J Childbirth Educ. 1997;12:14-7.
Powell D. The cornerstone of prevention. Midwifery Today Childbirth Educ. 1990;16.
Price AH, Clissold SP. Salbutamol in the 1980s. A reappraisal of its clinical efficacy. Drugs. 1989;38:77-122. [pmid: 2670512].
Quinn PG, Sherman BW, Tavill AS, et al. Terbutaline hepatitis in pregnancy: Report of two cases and literature review. Am J Gastroenterol. 1994;89:781-4. [pmid: 8172156].
Radetsky P. Stopping premature births before it's too late. Science. 1994;266(5190):1486-8. [pmid: 7985015].
Rasanen J, Jouppila P. Fetal cardiac function and ductus arteriosus during indomethacin and sulindac therapy for threatened preterm labor: A randomized study. Am J Obstet Gynecol. 1995;173:20-5. [pmid: 7631682].
Rausch K, Hermer M, Brehm H, et al. [A new long-acting Partusisten preparation for oral tocolysis--results of a multicenter study]. Ein neues, langwirkendes Partusisten-Praparat zur oralen Tokolyse-Ergebnisse einer multizentrischen Studie. [Ger]. Z Geburtsh Perinatol. 1984;188:185-90.
Ray D, Dyson D. Calcium channel blockers. Obstet Gynecol. 1995;38:7-721.
Read MD, Wellby DE. The use of a calcium antagonist (nifedipine) to suppress preterm labour. Br J Obstet Gynecol. 1986;93:93-937.
Rhoads GG, McNellis DC, Kessel SS. Home monitoring of uterine contractility: Summary of a workshop sponsored by the National Institute of Child Health and Human Development and the Bureau of Maternal and Child Health and Resources Development, Bethesda, MD; 1989 Mar 29-30. Am J Obstet Gynecol. 1991;165:2-6. [pmid: 1677235].
Ricci JM, Hariharan S, Helfgott A, et al. Oral tocolysis with magnesium chloride: A randomized controlled prospective clinical trial. Am J Obstet Gynecol. 1991;165:603-10. [pmid: 1892185].
Richter R, Hinselmann MJ. The treatment of threatened premature labor by betamimetic drugs: A comparison of fenoterol and ritodrine. Obstet Gynecol. 1979;53:81-7. [pmid: 32502].
Ridgway LE, Muise K, Wright JW, et al. A prospective randomized comparison of oral terbutaline and magnesium oxide for the maintenance of tocolysis. Am J Obstet Gynecol. 1990;163:879-82. [pmid: 2206076].
Riduan JM, Hillier SL, Utomo B, et al. Bacterial vaginosis and prematurity in Indonesia: Association in early and late pregnancy. Am J Obstet Gynecol. 1993;169:175-8. [pmid: 8333449].
Rizzo G, Capponi A, Arduini D, et al. The value of fetal fibronectin in cervical and vaginal secretions and of ultrasonographic examination of the uterine cervix in predicting premature delivery for patients with preterm labor and intact membranes. Am J Obstet Gynecol. 1996;175:1146-51. [pmid: 8942480].
Robel R, Stepan H, Viehweg B. [Clinical results of perfusion-oriented therapy of threatened premature labor]. Klinische Ergebnisse einer perfusionsorientierten Therapie der drohenden Fruhgeburt. Zentralbl Gynakol. 1994;116:531-6. [pmid: 7975965].
Roberts JM. Current understanding of pharmacologic mechanisms in the prevention of preterm birth. Clin Obstet Gynecol. 1984;27:592-605. [pmid: 6149027].
Roberts WE, Morrison JC. Has the use of home monitors, fetal fibronectin, and measurement of cervical length helped predict labor and/or prevent preterm delivery in twins?. Obstet Gynecol. 1998;41:94-102.
Robertson PA, Herron M, Katz M, et al. Maternal morbidity associated with isoxsuprine and terbutaline tocolysis. Eur J Obstet Gynecol Reprod Biol. 1981;11:371-8. [pmid: 7195835].
Robertson PA, Sniderman SH, Laros RK et al. Neonatal morbidity according to gestational age and birth weight from five tertiary care centers in the United States, 1983 through 1986. Am J Obstet Gynecol. 1992;166:1629-41. [pmid: 1615970].
Rodriguez MH. Polyhydramnios: Does reducing the amniotic fluid volume decrease the incidence of prematurity?. Clin Perinatol. 1992;19:359-66. [pmid: 1617881].
Rogowski JA. The economics of preterm delivery. Prenat Neonat Med. 1998;3:16-20.
Romero R, Avila C, Edwin SS, et al. Endothelin-1,2 levels are increased in the amniotic fluid of women with preterm labor and microbial invasion of the amniotic cavity. Am J Obstet Gynecol. 1992;166:95-9. [pmid: 1733226].
Romero R, Ceska M, Avila C, et al. Neutrophil attractant/activating peptide-1/interleukin-8 in term and preterm parturition. Am J Obstet Gynecol. 1991;165:813-20. [pmid: 1951537].
Romero R, Mazor M, Oyarzun E, et al. Is there an association between colonization with group B streptococcus and prematurity?. J Reprod Med. 1989;34:797-801. [pmid: 2677355].
Romero R, Quintero R, Nores J, et al. Amniotic fluid white blood cell count: A rapid and simple test to diagnose microbial invasion of the amniotic cavity and predict preterm delivery. Am J Obstet Gynecol. 1991;165:821-30. [pmid: 1951538].
Romero R, Sepulveda W, Mazor M, et al. The natural interleukin-1 receptor antagonist in term and preterm parturition. Am J Obstet Gynecol. 1992;167:863-72. [pmid: 1415417].
Romero R, Sibai B, Caritis S, et al. Antibiotic treatment of preterm labor with intact membranes: A multicenter, randomized, double-blinded, placebo-controlled trial. Am J Obstet Gynecol. 1993;169:764-74. [pmid: 8238130].
Romero R, Wu YK, Mazor M, et al. Amniotic fluid arachidonate lipoxygenase metabolites in preterm labor. Prostaglandins Leukotrienes Essential Fatty Acids. 1989;36:69-75.
Romero R, Wu YK, Sirtori M, et al. Amniotic fluid concentrations of prostaglandin F2a, 13, 14-dihydro-15-keto-prostaglandin F2a (PGFM) and 11-deoxy-13, 14-dihydro-15-keto-11, 16-cyclo-prostaglandin E2 (PGEM-LL) in preterm labor. Prostaglandins. 1989;37:149-61. [pmid: 2717777].
Romero R, Yoon BH, Mazor M, et al. The diagnostic and prognostic value of amniotic fluid white blood cell count, glucose, interleukin-6, and Gram stain in patients with preterm labor and intact membranes. Am J Obstet Gynecol. 1993;169:805-16. [pmid: 7694461].
Roopnarinesingh S, Manjoo R, Matadial L. Preterm labour. W Ind Med J. 1983;32:201-6.
Ross MG, Nicolls E, Stubblefield PG, et al. Intravenous terbutaline and simultaneous beta 1-blockade for advanced premature labor. Am J Obstet Gynecol. 1983;147:897-902. [pmid: 6359887].
Rothman, KJ, Greenland, S. Modern epidemiology. Philadelphia: Lippincott-Raven, 1998.
Rouse DJ, Hauth JC, Nelson KG, et al. The feasibility of a randomized clinical perinatal trial: maternal magnesium sulfate for the prevention of cerebral palsy. Am J Obstet Gynecol. 1996;175(3 Pt 1):701-5. [pmid: 8828437].
Rowlands S, Trudinger B, Visva-Lingam S. Treatment of preterm cervical dilatation with glyceryl trinitrate, a nitric oxide donor. Aust N Z J Obstet Gynecol. 1996;36:377-81.
Rozenberg P, Goffinet F, Malagrida L, et al. Evaluating the risk of preterm delivery: A comparison of fetal fibronectin and transvaginal ultrasonographic measurement of cervical length. Am J Obstet Gynecol. 1997;176:196-9. [pmid: 9024113].
Rozenberg P, Nisand I, Malagrida L, et al. [Rational use of fetal fibronectin in the evaluation of premature labor risk]. Utilisation rationnelle de la fibronectine foetale dans l'evaluation du risque d'accouchement premature. [Fre]. J Gynecol Obstet Biol Reprod (Paris). 1996;25:288-93. [pmid: 8767228].
Rubin PC, Butters L, Clark D, et al. Obstetric aspects of the use in pregnancy associated hypertension of the beta-adrenoceptor antagonist atenolol. Am J Obstet Gynecol. 1984;150:389-92. [pmid: 6385722].
Rush RW, Keirse MJ, Howat P, et al. Contribution of preterm delivery to perinatal mortality. Br Med J. 1976;2(6042):965-8. [pmid: 974709].
Rust OA, Bofill JA, Arriola RM, et al. The clinical efficacy of oral tocolytic therapy. Am J Obstet Gynecol. 1996;175:838-42. [pmid: 8885732].
Sachs BP, Ringer SA. Intrapartum and delivery room management of the very low birthweight infant. Clin Perinatol. 1989;16:809-23. [pmid: 2686888].
Sachs BP, Hellerstein MD, Freeman R, et al. Home monitoring of uterine activity. N Engl J Med. 1991;325:1374-7. [pmid: 1922241].
Sackett DL, Haynes RB, Guyatt GH, et al. Clinical Epidemiology: A basic science for clinical medicine. 2nd ed. Boston: Little, Brown, 1991.
Salafia CM, Vogel CA, Vintzileos AM, et al. Placental pathologic findings in preterm birth. Am J Obstet Gynecol. 1991;165:934-8. [pmid: 1951558].
Savitz DA, Blackmore CA, Thorp JM. Epidemiologic characteristics of preterm delivery: Etiologic heterogeneity. Am J Obstet Gynecol. 1991;164:467-71. [pmid: 1992685].
Savvidou M, Edwards G, Davies N. Use of steroids, tocolytics and antibiotics in the management of preterm labour in Wales. J Obstet Gynecol. 1998;18:315-7. [pmid: 15512098].
Scardo JA, Hogg BB, Newman RB. Favorable hemodynamic effects of magnesium sulfate in preeclampsia. Am J Obstet Gynecol. 1995;173:1249-53. [pmid: 7485331].
Scheid CR, Honeyman TW, Fay FS Mechanism of beta-adrenergic relaxation of smooth muscle Nature 1979 277 32 6View this and related citations using 233257
Scholl TO. High third-trimester ferritin concentration: Associations with very preterm delivery, infection, and maternal nutritional status. Obstet Gynecol. 1998;92:161-6. [pmid: 9699743].
Schorr SJ, Ascarelli MH, Rust OA, et al. A comparative study of ketorolac (Toradol) and magnesium sulfate for arrest of preterm labor. South Med J. 1998;91:1028-32. [pmid: 9824184].
Schrock A, Fidi C, Low M, et al. Low-dose ethanol for inhibition of preterm uterine activity. Am J Perinatol. 1989;6:191-5. [pmid: 2712916].
Schutte MF, Treffers PE, Koppe JG, et al. The influence of betamethasone and orciprenaline on the incidence of respiratory distress syndrome in the newborn after preterm labour. Br J Obstet Gynecol. 1980;87:127-31.
Sciscione AC, Stamilio DM, Manley JS, et al. Tocolysis of preterm contractions does not improve preterm. Am J Perinatol. 1998;15:177-81. [pmid: 9572373].
Seaward PGR, Hannah ME, Myhr TL, et al. International Multicenter Term PROM study: evaluation of predictors of neonatal infection in infants born to patients with premature rupture of membranes at term. Am J Obstet Gynecol. 1998;179:635-9. [pmid: 9757963].
Segarra A, Chacon P, Vilardell M, et al. Prospective case control study to determine the effect of lovastatin on serum testosterone and cortisol concentrations in hyperlipidemic nephrotic patients with chronic renal failure. Nephron. 1996;73:186-90. [pmid: 8773342].
Seidman DS, Laor A, Gale R, et al. Birth weight and intellectual performance in late adolescence. Obstet Gynecol. 1992;79:543-6. [pmid: 1553173].
Senden IPM, Owen P. Comparison of cervical assessment, fetal fibronectin and fetal breathing in the diagnosis of preterm labour. Clin Exp Obstet Gynecol. 1996;23:5-9. [pmid: 8653936].
Shah DM, Reed G. Parameters associated with adverse perinatal outcome in hypertensive pregnancies. J Hum Hypertens. 1996;10:511-5. [pmid: 8895034].
Sharts-Hopko NC. Ritodrine, reexamined. MCN Am J Matern Child Nurs. 1993;18.
Shubert PJ. Atosiban. Obstet Gynecol. 1995;38:722-4.
Siega-Riz AM, Adair LS, Hobel CJ. Maternal underweight status and inadequate rate of weight gain during the third trimester of pregnancy increases the risk of preterm delivery. J Nutr. 1996;126:146-53. [pmid: 8558295].
Sims CD, Chamberlain GV, Boyd IE, et al. A comparison of salbutamol and ethanol in the treatment of preterm labour. Br J Obstet Gynecol. 1978;85:761-6.
Singh VK, Sharma M, Rohatgi P. Effect of salbutamol on premature labour. J Indian Med Assoc. 1990;88:253-4. [pmid: 2286759].
Sciscione AC, Stamilio DM, Manley JS, et al. Tocolysis of preterm contractions does not improve preterm delivery rate or perinatal outcomes. Am J Perinatol. 1998;15:177-81. [pmid: 9572373].
Sisson MC. Preventing preterm labor: is terbutaline our best option?. AWHONN Lifelines. 1997;1:42-6. [pmid: 9208748].
Skjaerris J, Aberg A. Prevention of prematurity in twin pregnancy by orally administered terbutaline. Acta Obstet Gynecol Scand Suppl. 1982;108:39-40. [pmid: 6957127].
Smit DA, Essed GG, de Haan J. Predictive value of uterine contractility and the serum levels of progesterone and oestrogens with regard to preterm labour. Gynecol Obstet Invest. 1984;18:252-63. [pmid: 6526341].
Smith CS, Woodland MB. Clinical comparison of oral nifedipine and subcutaneous terbutaline for initial tocolysis. Am J Perinatol. 1993;10:280-4. [pmid: 8397562].
Smith CV. Antepartum fetal surveillance in the preterm fetus. Clin Perinatol. 1992;19:437-48. [pmid: 1617886].
Sorrel L. Don't rely on fetal monitors. Off Our Backs. 1990;20.
Souney PF, Kaul AF, Osathanondh R. Pharmacotherapy of preterm labor. Clin Pharm. 1983;2:29-44. [pmid: 6136361].
Spatling L, Fallenstein F, Schneider H, et al. Bolus tocolysis: treatment of preterm labor with pulsatile administration of a beta-adrenergic agonist. Am J Obstet Gynecol. 1989;160:713-7. [pmid: 2564741].
Spearing G. Alcohol, indomethacin, and salbutamol. Obstet Gynecol. 1979;53:171-4. [pmid: 418970].
Spellacy WN, Cruz AC, Birk SA, et al. Treatment of premature labor with ritodrine: A randomized controlled study. Obstet Gynecol. 1979;54:220-3. [pmid: 379722].
Spellacy WN, Cruz AC, Buhi WC, et al. The acute effects of ritodrine infusion on maternal metabolism: Measurements of levels of glucose, insulin, glucagon, triglycerides, cholesterol, placental lactogen and chorionic gonadotropin. Am J Obstet Gynecol. 1978;131:637-42. [pmid: 356601].
Spong CY, Ghidini A, Sherer DM, et al. Angiogenin: A marker for preterm delivery in midtrimester amniotic fluid. Am J Obstet Gynecol. 1997;176:415-8. [pmid: 9065191].
Stabile I, Grudzinskas JG, Chard T. Clinical applications of pregnancy protein estimations with particular reference to pregnancy-associated plasma protein A (PAPP-A). Obstet Gynecol Surv. 1988;43:73-82. [pmid: 2448714].
Statistics and Epidemiology Research Corporation. EGRET reference manual 1993. Revision 4. Seattle, WA: SERC; 1993.
Steer CM, Petrie RH. A comparison of magnesium sulfate and alcohol for the prevention of premature labor. Am J Obstet Gynecol. 1977;129:1-4. [pmid: 331952].
Stringer M, Cohen A. Fetal/maternal surveillance. J Perinat Educ. 1994;3:29-34.
Stubbs SM, Brudenell JM, Pyke DA, et al. Management of the pregnant diabetic: Home or hospital, with or without glucose meters?. Lancet. 1980;1(8178):1122-4. [pmid: 6103450].
Sullivan CA. Sonographic evaluation of the uterine cervix. Obstet Gynecol Clin North Am. 1998;25:623-37. [pmid: 9710915].
Surbek D, Bosiger H, Pavic N, et al. [Fetal fibronectin as a marker of prematurity in a high risk patient sample]. Fetales fibronectin als marker der fruhgeburtlichkeit im risikokollektiv. Z Geburtshilfe Perinatol. 1997;201:15-20.
Svare J, Langhoff-Roos J, Andersen LF, et al. Ampicillin-metronidazole treatment in idiopathic preterm labour: A randomised controlled multicentre trial. Br J Obstet Gynecol. 1997;104:892-7.
Svenningsen NW. Follow-up studies on preterm infants after maternal beta-receptor agonist treatment. Acta Obstet Gynecol Scand. 1982;108(Suppl):67-70.
Takahashi T, Minakami H, Tamada T, et al. Hyperamylasemia in response to ritodrine or ephedrine administered. J Am Coll Surg. 1997;184:31-6. [pmid: 8989297].
TambyRaja RL. Current concepts in the management of preterm labour. Singapore Med J. 1989;30:578-83. [pmid: 2699676].
TambyRaja RL, Ng SC, Ratnam SS. Fenoterol: An effective agent for the postponement of preterm birth. N Z Med J. 1981;93:218-20. [pmid: 7017512].
Tarnow-Mordi W, Phillips G, Taylor D, et al. Randomized controlled trials of antibiotics in preterm labor [1]. Am J Obstet Gynecol. 1994;171:865-6. [pmid: 8092243].
Tchilinguirian NG, Najem R, Sullivan GB, et al. The use of ritodrine and magnesium sulfate in the arrest of premature labor. Int J Gynecol Obstet. 1984;22:117-23.
Thomsen AC, Morup L, Hansen KB. Antibiotic elimination of group-B streptococci in urine in prevention of preterm labour. Lancet. 1987;1(8533):591-3. [pmid: 2881132].
Thoulon JM. [Stages of drug treatment in threatened premature labor]. Les etapes du traitement medical de la menace d'accouchement premature. [Fre]. Rev Fr Gynecol Obstet. 1992;87:379-80. [pmid: 1359624].
Timor-Tritsch IE, Boozarjomehri F, Masakowski Y, et al. Can a "snapshot" sagittal view of the cervix by transvaginal ultrasonography predict active preterm labor?. Am J Obstet Gynecol. 1996;174:990-5. [pmid: 8633681].
[No authors listed]. To be(ta) or not be(ta): a labouring question. Lancet. 1981;1(8232):1244-5.
Tolino A, Ronsini S, Zullo F, et al. Fetal fibronectin as a screening test for premature delivery in multiple pregnancies. Int J Gynecol Obstet. 1996;52:3-7.
Travis BE, McCullough JM. Pharmacotherapy of preterm labor. Pharmacother. 1993;13:28-36.
Tucker, JM, Goldenberg RL, Davis RO, et al. Etiologies of preterm birth in an indigent population: Is prevention a logical expectation. Obstet Gynecol. 1991;77:343-7. [pmid: 1992395].
Turnbull AC. The early diagnosis of impending premature labour. Eur J Obstet Gynecol Reprod Biol. 1989;33:11-24. [pmid: 2680674].
Tye KH, Desser KB, Benchimol A Angina pectoris associated with use of terbutaline for premature labor JAMA 1980;244(7):692-3View this and related citations using
Uldbjerg N, Ekman G, Malmstrom A, et al. Ripening of the human uterine cervix related to changes in collagen, glycosaminoglycans, and collagenolytic activity. Am J Obstet Gynecol. 1983;147:662-6. [pmid: 6638110].
US Preventive Services Task Force. Guide to Clinical preventive services. 2nd ed. Baltimore: Williams and Wilkins; 1996.
Van Assche A, Thoumsin H, Hendrickx B. Efficacy, safety and tolerance of oral sustained-release ritodrine given after intravenous administration in the treatment of premature labor. Eur J Obstet Gynecol Reprod Biol. 1990;34:229-34. [pmid: 2311810].
Van den Veyver IB, Moise KJJ. Prostaglandin synthetase inhibitors in pregnancy. Obstet Gynecol Surv. 1993;48:493-502. [pmid: 8355924].
Van den Veyver, IB, Moise, KJ Jr, Ou C, et al. The effect of gestational age and fetal indomethacin levels on the incidence of constriction of the fetal ductus arteriousus. Obstet Gynecol. 1993;82:500-3. [pmid: 8377971].
van Dijk K, Dekker GA, van Geijn H. Ritodrine and nifedipine as tocolytic agents: A preliminary comparison. J Perinat Med. 1995;23:409-15. [pmid: 8606348].
Ventura SJ, Martin JA, Curtin SC, et al. Final data for 1997. National Vital Statistics reports; Vol.47, No. 18. Hyattsville MD: National Center for Health Statistics, 1998.
Ventura SJ, Martin JA, Curtin SC, et al. Report of final natality statistics, 1996. Monthly Vital Statistics report; Vol. 46, No. 11, Supp. Hyattsville, MD: National Center for Health Statistics; 1998.
Vetr M, Kudela M, Prasilova J. Fetal fibronectin in patients at increased risk for premature birth [Cze]. Acta Univ Palacki Olomuc Fac Med. 1996;140:55-7. [pmid: 9431693].
Viamontes CM. Pharmacologic intervention in the management of preterm labor: An update. J Perinat Neonat Nurs. 1996;9:13-30.
Visintainer PF, Tejani N. Understanding and using confidence intervals in clinical research. J Matern Fetal Med. 1998;7:201-6. [pmid: 9730488].
Von Der Pool B. Preterm labor: diagnosis and treatment. Am Fam Physician. 1998;57:2457-64. [pmid: 9614414].
Von Mandach U, Boni R, Danko J, et al. Pharmacokinetics of fenoterol in pregnant women [Ger]. Arzeneimittel Forschung. 1995;45:186-9.
Wallace RL, Herrick CN. Pulmonary maturity studies in the evaluation of premature labor. Am J Obstet Gynecol. 1981;140:512-4. [pmid: 7246685].
Wallrich M, Bonneaux F, Delaporte MO, et al. Threatened premature labor and its treatment [Fre]. Lyon Pharmaceutique. 1996;47:338-43.
Walters BN, Lao T, Smith V, et al. Alpha-Fetoprotein elevation and proteinuric pre-eclampsia. Br J Obstet Gynecol. 1985;92:341-4.
Walters WA, Wood C. A trial of oral ritodrine for the prevention of premature labour. Br J Obstet Gynecol. 1977;84:26-30.
Wapner RJ, Cotton DB, Artal R, et al. A randomized multicenter trial assessing a home uterine activity monitoring device used in the absence of daily nursing contact. Am J Obstet Gynecol. 1995;172:1026-34. [pmid: 7892843].
Watson DL, Kim SJ, Humphrey MD. Study of cervicovaginal fetal fibronectin status to guide treatment of threatened preterm labour. Aust N Z J Obstet Gynecol. 1998;38:185-7.
Watson DL, Welch RA, Mariona FG, et al. Management of preterm labor patients at home: does daily uterine activity monitoring and nursing support make a difference?. Obstet Gynecol. 1990;76(1 Suppl):32S-35S. [pmid: 2359576].
Watson NA, Morgan B. Pulmonary oedema and salbutamol in preterm labour. Case report and literature review. Br J Obstet Gynecol. 1989;96:1445-8.
Weiner CP, Renk K, Klugman M. The therapeutic efficacy and cost-effectiveness of aggressive tocolysis for premature labor associated with premature rupture of the membranes [published erratum appears in Am J Obstet Gynecol 1991;165:785]. Am J Obstet Gynecol. 1988;159:216-22. [pmid: 3134815].
Weiss MA. Retrospective analysis of the effects of ritodrine and terbutaline in the management of preterm labor. Clin Pharm. 1982;1:453-6. [pmid: 7184677].
Wennerholm UB, Holm B, Mattsby-Baltzer I, et al. Fetal fibronectin, endotoxin, bacterial vaginosis and cervical length as predictors of preterm birth and neonatal morbidity in twin pregnancies. Br J Obstet Gynecol. 1997;104:1398-1404.
Wenstrom KD, Weiner CP, Merrill D, et al. A placebo-controlled randomized trial of the terbutaline pump for prevention of preterm delivery. Am J Perinatol. 1997;14:87-91. [pmid: 9259905].
Wessen A, Elowsson P, Axemo P, et al. The use of intravenous nitroglycerin for emergency cervico-uterine relaxation. Acta Anaesthesiol Scand. 1995;39:847-9. [pmid: 7484047].
West SL, Garbutt JC, Carey TS, et al. Evidence report on the pharmacotherapy for alcohol dependence. Rockville, MD: US Dept of Health and Human Services, Agency for Health Care Policy and Research; 1998. AHCPR Publication No. 99-E004.
West SL, Yawn BP, Thorp JM, et al. The preventability of preterm delivery after preterm labor: A population-based assessment. 14th International Conference on Pharmacoepidemiology, 1998 Aug 16; Berlin.
Wheeler DG. Preterm birth prevention. J Nurse Midwifery. 1994;39(2 Suppl):66S-80S. [pmid: 8035246].
Wilcox A, Skjaerven R, Buekens P, et al. Birth weight and perinatal mortality: A comparison of the United States and Norway. JAMA. 1995;273:709-11. [pmid: 7853628].
Wilcox LS, Kiely JL, Melvin CL, et al. Assisted reproductive technologies: Estimates of their contribution to multiple births and newborn hospital days in the United States. Fertil Steril. 1996;65(2):361-6. [pmid: 8566263].
Wilkins I, Creasy RK. Preterm labor. Obstet Gynecol. 1990;33:502-14.
Wilkins IA, Lynch L, Mehalek KE, et al. Efficacy and side effects of magnesium sulfate and ritodrine as tocolytic agents. Am J Obstet Gynecol. 1988;159:685-9. [pmid: 3048103].
Williams MA, Hickok DE, Zingheim RW, et al. Low birth weight and preterm delivery in relation to early-gestation vaginal bleeding and elevated maternal serum alpha-fetoprotein. Obstet Gynecol. 1992;80:745-9. [pmid: 1383900].
Winkler M, Baumann L, Ruckhaberle KE, et al. Erythromycin therapy for subclinical intrauterine infections in threatened preterm delivery-a preliminary report. J Perinat Med. 1988;16:253-6. [pmid: 3210111].
Winkler M, Biesterfeld S, Marquet KL, et al. [Incidence of inflammatory placental changes in threatened premature labor with and without additional antibiotic therapy]. Zur Haufigkeit entzundlicher Plazentaveranderungen bei drohender Fruhgeburt mit und ohne antibiotische Zusatztherapie. Zentralbl Gynakol. 1997;119:54-9.
Winkler M, Fendel H, Skopnik H, et al. [The value of adjuvant ampicillin therapy in idiopathic premature labor]. Zur Wertigkeit adjuvanter Ampicillin-Therapie bei idiopathischer vorzeitiger Wehentatigkeit. Z Geburtsh Perinatol. 1992;196:114-7.
Winkler M, Gellings R, Putz I, et al. [Puerperium after threatened premature labor--effects of infection screening in pregnancy]. Z Geburtsh Perinatol. 1994;198:72-6.
Wigvist N, Lundstrom V, Green K. Premature labor and indomethacin. Prostaglandins. 1975;10:515-26. [pmid: 1197785].
Wisborg K, Henriksen TB, Hedegaard M, et al. Smoking during pregnancy and preterm birth. Br J Obstet Gynecol. 1996;103:800-5.
Wischnik A, Hettenbach A, Schmidt R, et al. [The effect of magnesium sulfate on volume balance in tocolysis with the beta mimetic agent fenoterol]. Wochenbettverlauf nach drohender Fruhgeburt-Auswirkungen eines Infektions-Screenings in der Schwangerschaft. Gynakol Rundsch. 1989;29(Suppl 2):188-91.
Wischnik A, Zieger W. Tocolytic therapies in development for preterm labour. Expert Opin Invest Drugs. 1994;3:621-9.
Witter FR, Niebyl JR. Inhibition of arachidonic acid metabolism in the perinatal period: pharmacology, clinical application, and potential adverse effects. Semin Perinatol. 1986;10:316-33. [pmid: 3105069].
Wright JW, Patterson RM, Ridgway LE, et al. Effect of tocolytic agents on fetal umbilical velocimetry. Am J Obstet Gynecol. 1990;163:748-50. [pmid: 2206066].
Wright JW, Ridgway LE, Patterson RM. Adjusting the loading dose of magnesium sulfate for tocolysis. Am J Obstet Gynecol. 1990;163:889-92. [pmid: 1976297].
Wright JW, Ridgway LE, Wright BD, et al. Effect of MgSO4 on heart rate monitoring in the preterm fetus. J Reprod Med. 1996;41:605-8. [pmid: 8866390].
Wysowski DK, Gross TP. Deaths due to accidents and violence in two recent trials of cholesterol-lowering drugs. Arch Intern Med. 1990;150:2169-72. [pmid: 2222103].
Xenakis EM, Piper JM. Chemotherapeutic induction of labour: Rational approach. Drugs. 1997;54:61-8. [pmid: 9211080].
Zalar RJ. Transvaginal ultrasound and preterm prelabor: A nonrandomized intervention study. Obstet Gynecol. 1996;88:20-3. [pmid: 8684755].
Zingg H, Lefebvre D, Giaid A. Uterine oxytocin gene expression: A novel framework for oxytocin action. Reg Peptides. 1993;45:43-6.
Zuckerman H, Reiss U, Rubinstein I. Inhibition of human premature labor by indomethacin. J Obstet Gynecol. 1974;44:787-92.
Zuckerman H, Shalev E, Gilad G, et al. Further study of the inhibition of premature labor by indomethacin. Part I. J Perinat Med. 1984;12:19-23. [pmid: 6726590].
Zygmunt M, Lang U, Katz N, et al. Maternal plasma fibronectin: A predictor of preterm delivery. Eur J Obstet Gynecol Reprod Biol. 1997;72:121-6. [pmid: 9134388].