# References

1 Paneth NS. The problem of low birth weight. Future Child. 1995;5(1):19-34. [pmid: 7633862].
2 National Institute of Child Health and Human Development. Report of the Consensus Development Conference on the Effect of Corticosteroids for Fetal Maturation on Perinatal Outcomes. Bethesda, MD: The Institute; 1994 Feb 28-Mar 2.
3 Wilcox LS, Kiely JL, Melvin CL, et al. Assisted reproductive technologies: Estimates of their contribution to multiple births and newborn hospital days in the United States. Fertil Steril. 1996;65(2):361-6. [pmid: 8566263].
4 Ventura SJ, Martin JA, Curtin SC, et al. Report of final natality statistics, 1996. Monthly Vital Statistics Report, Vol. 46, No. 11, supp. Hyattsville, MD: National Center for Health Statistics; 1998.
5 Ventura SJ, Martin JA, Curtin SC, et al. Final data for 1997. National Vital Statistics reports, Vol. 47, No. 18. Hyattsville, MD: National Center for Health Statistics; 1998.
6 ACOG Technical Bulletin. Preterm labor. Int J Gynecol Obstet. 1995;50:303-13.
7 Copper RL, Goldenberg RL, Davis RO, et al. Warning symptoms, uterine contractions, and cervical examination findings in women at risk of preterm delivery. Am J Obstet Gynecol. 1990;162:748-54. [pmid: 2316582].
8 West SL, Yawn BP, Thorp JM, et al. The preventability of preterm delivery after preterm labor: A population-based assessment. 14th International Conference on Pharmacoepidemiology; 1998 Aug 16; Berlin.
9 Kramer MS. Preventing preterm birth: Are we making progress?. Prenat Neonat Med. 1998;3:10-2.
10 Rush RW, Keirse MJ, Howat P, et al. Contribution of preterm delivery to perinatal mortality. Br Med J. 1976;2(6042):965-8. [pmid: 974709].
11 McCormick MC. The contribution of low birth weight to infant mortality and childhood morbidity. N Engl J Med. 1985;312:82-9. [pmid: 3880598].
12 Robertson PA, Sniderman SH, Laros RK, et al. Neonatal morbidity according to gestational age and birth weight from five tertiary care centers in the United States, 1983 through 1986. Am J Obstet Gynecol. 1992;166:1629-41. [pmid: 1615970].
13 Creasy RK. Preterm birth prevention: Where are we?. Am J Obstet Gynecol. 1993;168:1223-30. [pmid: 8475969].
14 Copper RL, Goldenberg RL, Creasy RK, et al. A multicenter study of preterm birth weight and gestational age-specific neonatal mortality. Am J Obstet Gynecol. 1993;168:78-84. [pmid: 8420354].
15 Seidman DS, Laor A, Gale R, et al. Birth weight and intellectual performance in late adolescence. Obstet Gynecol. 1992;79:543-6. [pmid: 1553173].
16 Lewit E, Baker L, Corman H, et al. The direct cost of low birth weight. Future Child. 1995;5(1):35-56. [pmid: 7633866].
17 Savitz DA, Blackmore CA, Thorp JM. Epidemiologic characteristics of preterm delivery: Etiologic heterogeneity. Am J Obstet Gynecol. 1991;164:461-7.
18 Berkowitz GS, Blackmore-Prince C, Lapinski RH, et al. Risk factors for preterm birth subtypes. Epidemiology. 1998;9:279-85. [pmid: 9583419].
19 Meis PJ, Goldenberg RL, Mercer BM, et al. The preterm prediction study: Risk factors for indicated preterm births. Am J Obstet Gynecol. 1998;178:562-7. [pmid: 9539527].
20 Goldenberg RL, Rouse DJ. Prevention of premature birth. N Engl J Med. 1998;339:313-20. [pmid: 9682045].
21 Klebanoff MA, Regan JA, Rao AV, et al. Outcome of the vaginal Infections and Prematurity Study: Results of a clinical trial of erythromycin among pregnant women colonized with group B streptococci. Am J Obstet Gynecol. 1995;172:1540-5. [pmid: 7755068].
22 Guinn DA, Goldenberg RL, Hauth JC, et al. Risk factors for the development of preterm premature rupture of the membranes after arrest of preterm labor. Am J Obstet Gynecol. 1995;173:1310-5. [pmid: 7485344].
23 Berkowitz GS, Papiernik E. Epidemiology of preterm birth. Epidemiol Rev. 1993;15:414-43. [pmid: 8174665].
24 Bakketeig LS, Hoffman HJ, Harley EE. The tendency to repeat gestational age and birth weight in successive births. Am J Obstet Gynecol. 1979;135:1086-103. [pmid: 517593].
25 Kleinman JC, Kessel SS. Racial differences in low birth weight: Trends and risk factors. N Engl J Med. 1987;317:749-53. [pmid: 3627185].
26 Blackmore CA, Savitz DA, Edwards LJ, et al. Racial differences in the patterns of preterm delivery in central North Carolina, USA. Paediatr Perinat Epidemiol. 1995;9:281-95. [pmid: 7479277].
27 Kramer MS, Coates AL, Michoud MC, et al. Maternal anthropometry and idiopathic preterm labor. Obstet Gynecol. 1995;86:744-8. [pmid: 7566841].
28 Siega-Riz AM, Adair LS, Hobel CJ. Maternal underweight status and inadequate rate of weight gain during the third trimester of pregnancy increases the risk of preterm delivery. J Nutr. 1996;126:146-53. [pmid: 8558295].
29 Meyer MB, Tonascia JA. Maternal smoking, pregnancy complications, and perinatal mortality. Am J Obstet Gynecol. 1977;128:494-502. [pmid: 560121].
30 Floyd RL, Rimer BK, Giovino GA, et al. A review of smoking in pregnancy: Effects on pregnancy outcomes and cessation efforts. Ann Rev Public Health. 1993;14:379-411. [pmid: 8323595].
31 Wisborg K, Henriksen TB, Hedegaard M, et al. Smoking during pregnancy and preterm birth. Br J Obstet Gynaecol. 1996;103:800-5. [pmid: 8760711].
32 Metzger BE, Ravnikar V, Vileisis RA, et al. Accelerated starvation and the skipped breakfast in late normal pregnancy. Laucet. 1982 Mar 13;1(8272):588-92.
33 Binienda Z, Massmann A, Mitchell MD, et al. Effect of food withdrawal on arterial blood glucose and plasma 13, 14-dihydro-15-keto-prostaglandin F2 alpha concentrations and nocturnal myometrial electromyographic activity in the pregnant rhesus monkey in the last third of gestation: A model for preterm labor?. Am J Obstet Gynecol. 1989 Mar;160(3):746-50.
34 Martius J, Krohn MA, Hillier SL, et al. Relationships of vaginal lactobacillus species, cervical chlamydia trachomatis, and bacterial vaginosis to preterm birth. Obstet Gynecol. 1988;71:89-95. [pmid: 3336545].
35 Riduan JM, Hillier SL, Utomo B, et al. Bacterial vaginosis and prematurity in Indonesia: Association in early and late pregnancy. Am J Obstet Gynecol. 1993;169:175-8. [pmid: 8333449].
36 Hay PE, Lamont RF, Taylor-Robinson D, et al. Abnormal bacterial colonisation of the genital tract and subsequent preterm delivery and late miscarriage. BMJ. 1994;308(6924):295-8. [pmcid: 155691]. [pmid: 8124116].
37 McGregor JA, French JI, Jones W, et al. Bacterial vaginosis is associated with prematurity and vaginal fluid mucinase and sialidase: Results of a controlled trial of topical clindamycin cream. Am J Obstet Gynecol. 1994;170:1048-59. [pmid: 8166188].
38 Holst E, Goffeng AR, Andersch B. Bacterial vaginosis and vaginal microorganisms in idiopathic premature labor and association with pregnancy outcome. J Clin Microbiol. 1994;32:176-86. [pmcid: 262991]. [pmid: 8126176].
39 Meis PJ, Goldenberg RL, Mercer B, et al. The preterm prediction study: Significance of vaginal infections. Am J Obstet Gynecol. 1995;173:1231-5. [pmid: 7485327].
40 Gravett MG, Nelson HP, DeRouen T, et al. Independent associations of bacterial vaginosis and Chlamydia trachomatis infection with adverse pregnancy outcome. JAMA. 1986;256:1899-903. [pmid: 3761496].
41 McGregor JA, French JI, Parker R, et al. Prevention of premature birth by screening and treatment for common genital tract infections: Results of a prospective controlled evaluation. Am J Obstet Gynecol. 1995;173:157-67. [pmid: 7631673].
42 Hillier SL, Krohn MA, Cassen E, et al. The role of bacterial vaginosis and vaginal bacteria in amniotic fluid infection in women in preterm labor with intact fetal membranes. Clin Infect Dis. 1995;20(Suppl 2):S276-S278. [pmid: 7548574].
43 Goldenberg RL, Klebanoff MA, Nugent R, et al. Bacterial colonization of the vagina during pregnancy in four ethnic groups. Am J Obstet Gynecol. 1996;174:1618-21. [pmid: 9065140].
44 Creasy RK, Golbus MS, Laros RKJ, et al. Oral ritodrine maintenance in the treatment of preterm labor. Am J Obstet Gynecol. 1980;137:212-9. [pmid: 6990761].
45 Mercer BM, Lewis R. Preterm labor and preterm premature rupture of the membranes. Diagnosis and management. Infect Dis Clin North Am. 1997;11:177-201. [pmid: 9067791].
46 Peaceman AM, Andrews WW, Thorp JM, et al. Fetal fibronectin as a predictor of preterm birth in patients with symptoms: A multicenter trial. Am J Obstet Gynecol. 1997;177:13-8. [pmid: 9240576].
47 Main DM, Gabbe SG, Richardson D, et al. Can preterm deliveries be prevented?. Am J Obstet Gynecol. 1985;151:892-8. [pmid: 3885736].
48 Iams JD, Johnson FF, Creasy RK. Prevention of preterm birth. Clin Obstet Gynecol. 1988;31:599-615. [pmid: 3066545].
49 Dyson DC, Crites YM, Ray DA, et al. Prevention of preterm birth in high-risk patients: The role of education and provider contact versus home uterine monitoring. Am J Obstet Gynecol. 1991;164:756-62. [pmid: 2003537].
50 Collaborative Home Uterine Monitoring Study (CHUMS) Group. A multicenter randomized controlled trial of home uterine monitoring: Active versus sham device. Am J Obstet Gynecol. 1995;173:1120-7. [pmid: 7485304].
51 Dyson DC, Danbe KH, Bamber JA, et al. Monitoring women at risk for preterm labor. N Engl J Med. 1998;338:15-9. [pmid: 9414326].
52 Grimes DA, Schulz KF. Randomized controlled trials of home uterine activity monitoring: A review and critique. Obstet Gynecol. 1992;79:137-2. [pmid: 1727572].
53 Uldberg N, Ekman G, Malmstrom A, et al. Ripening of the human uterine cervix related to changes in collagen, glycosaminoglycans, and collagenolytic activity. Am J Obstet Gynecol. 1983;147:662-6. [pmid: 6638110].
54 Oxorn H. Human labor and birth. 5th ed. Norwalk, CT: Appleton Century Crofts; 1986. p. 113-51.
55 Iams JD, Paraskos J, Landon MB, et al. Cervical sonography in preterm labor. Obstet Gynecol. 1994;84:40-6. [pmid: 8008320].
56 Iams JD, Goldenberg RL, Mercer BM, et al. The preterm prediction study: Recurrence risk of spontaneous preterm birth. Am J Obstet Gynecol. 1998;178:1035-40. [pmid: 9609580].
57 Goldenberg RL, Mercer BM, Meis PJ, et al. The preterm prediction study: Fetal fibronectin testing and spontaneous preterm birth. Obstet Gynecol. 1996;87:643-8. [pmid: 8677060].
58 Hartmann K, Thorp JM, McDonald TL, et al. Cervical kimensions and risk of preterm birth: A prospective cohort study. Obstetrics and Gynecology. 1999;93:504-9. [pmid: 10214823].
59 Iams JD. Cervical ultrasonography. Ultrasound Obstet Gynecol. 1997;10:156-60. [pmid: 9339521].
60 Goland RS, Wardlaw SL, Blum M, et al. Biologically active corticotropin-releasing hormone in maternal and fetal plasma during pregnancy. Am J Obstet Gynecol. 1988;159:884-90. [pmid: 2845784].
61 McGregor JA, Jackson GM, Lachelin GC, et al. Salivary estriol as risk assessment for preterm labor: A prospective trial. Am J Obstet Gynecol. 1995;173:1337-42. [pmid: 7485350].
62 Lands AM, Arnold A, McAuliff JP, et al. Differentiation of receptor systems by sympathomimetic amines. Nature. 1967;214.
63 Scheid CR, Honeyman TW, Fay FS Mechanism of beta-adrenergic relaxation of smooth muscle Nature 1979 277 32 6View this and related citations using 233257
64 Roberts JM. Current understanding of pharmacologic mechanisms in the prevention of preterm birth. Clin Obstet Gynecol. 1984;27:592-605. [pmid: 6149027].
65 Besinger RE, Niebyl JR. The safety and efficacy of tocolytic agents for the treatment of preterm labor. Obstet Gynecol Surv. 1990;45:415-40. [pmid: 2195409].
66 Forman A, Andersson KE, Ulmsten U. Inhibition of myometrial activity by calcium antagonists. Semin Perinatol. 1981;5:288-94. [pmid: 7025218].
67 Calvin C, Loutzenhizer R, Van Breeman C. Mechanisms of calcium antagonist-induced vasodilation. Ann Rev Pharmacol Toxicol. 1983;23:373-96. [pmid: 6307126].
68 Petrie RH. Preterm parturition. Tocolysis using magnesium sulfate. Semin Perinatol. 1981;5:266-73.
69 Harbert GM, Cornell GW, Thorton WN. Effect of toxemia therapy on uterine dynamics. Am J Obstet Gynecol. 1969;105.
70 Karim SM. On the use of blockers of prostaglandin synthesis in the control of labor. Adv Prostaglandin Thromboxane Res. 1978;4:301-6. [pmid: 347913].
71 Johnson WC, Habert GM, Martin CB. Pharmacologic control of uterine contractility. Am J Obstet Gynecol. 1975;123:364-75. [pmid: 241259].
72 Wigvist N, Lundstrom V, Green K. Premature labor and indomethacin. Prostaglandins. 1975;10:515-26. [pmid: 1197785].
73 Niebyl JR, Blake DA, White RD, et al. The inhibition of premature labor with indomethacin. Am J Obstet Gynecol. 1980;136:1014-9. [pmid: 7369252].
74 Phaneuf S, Asboth G, MacKenzie JZ, et al. Effect of oxytocin antagonists on the activation of human myometrium in vitro: Atosiban prevents oxytocin induced desensitization. Am J Obstet Gynecol. 1994;171:1627-34. [pmid: 7802080].
75 Zingg H, Lefebvre D, Giaid A. Uterine oxytocin gene expression: A novel framework for oxytocin action. Reg Peptides. 1993;45:43-6.
76 Hahn DW, Demarest KT, Ericson E, et al. Evaluation of 1-deamino-[D-Tyr(Oethyl)2, Thr4, Orn8] vasotocin, an oxytocin antagonist, in animal models of uterine contractility and preterm labor; a new tocolytic agent. Am J Obstet Gynecol. 1987;157:977-82. [pmid: 3674173].
77 Bossmar T, Akerlund M, Fantoni G, et al. Receptors for and myometrial responses to oxytocin and vasopressin in preterm and term human pregnancy: Effects of the oxytocin antagonist atosiban. Am J Obstet Gynecol. 1994;171:1634-42. [pmid: 7802081].
78 Giussani DA, Jenkins SL, Mecenas CA, et al. The oxytocin antagonist atosiban prevents androstenedione-induced myometrial contractions in the chronically instrumented, pregnant Rhesus monkey. Endocrinology. 1996;137:3302-7. [pmid: 8754755].
79 Fuchs F, Fuchs AR, Poblete VF, et al. Effect of alcohol on threatened premature labor. Am J Obstet Gynecol. 1967;99:627-37. [pmid: 6051158].
80 Fuchs AR, Fuchs F. Ethanol for prevention of preterm birth. Semin Perinatal. 1981;5:236-51.
81 Gibbens GLD, Chard T. Observations on maternal oxytocin release during human labor and the effect of intravenous alcohol administration. Am J Obstet Gynecol. 1976;126.
82 Perlman JM. Antenatal glucocorticoid, magnesium exposure, and the prevention of brain injury of prematurity. Semin Pediatr Neurol. 1998;5:202-10. [pmid: 9777678].
83 Mittendorf R, Pryde P, Khoshnood B, et al. If tocolytic magnesium sulfate is associated with excess total pediatric mortality, what is its impact?. Obstet Gynecol. 1998;92:308-11. [pmid: 9699773].
84 Gibbs RS, Eschenbach DA. Use of antibiotics to prevent preterm birth. Am J Obstet Gynecol. 1997;177:375-80. [pmid: 9290454].
85 Andrews WW, Goldenberg RL, Hauth JC. Preterm labor: Emerging role of genital tract infections. Infect Agents Dis. 1995;4:196-211. [pmid: 8665085].
86 Sachs BP, Hellerstein MD, Freeman R, et al. Home monitoring of uterine activity. N Engl J Med. 1991;325:1374-7. [pmid: 1922241].
87 ACOG Committee Opinion: Committee on Obstretics Practice. Home uterine activity monitoring. Int J Gynecol Obstet. 1996;54:71-7.
88 Bell R. The prediction of preterm labour by recording spontaneous antenatal uterine activity. Br J Obstet Gynaecol. 1983;90:884-7. [pmid: 6626487].
89 Newman RB, Gill PJ, Wittreich P, et al. Maternal perception of prelabor uterine activity. Obstet Gynecol. 1986;68:765-9. [pmid: 3785786].
90 Morrison JC, Martin JN, Martin RW, et al. Prevention of preterm birth by ambulatory assessment of uterine activity: A randomized study. Am J Obstet Gynecol. 1987;156:536-43. [pmid: 3826196].
91 Holohon TV, Green I. Home uterine activity monitoring. Health Technology Review No. 1. Rockville, MD: Agency for Health Care Policy and Research, Office of Health Technology Assessment; 1992. Publication No. 92-0064.
92 Katz M, Gill PJ. Initial evaluation of an ambulatory system for home monitoring and transmission of uterine activity data. Obstet Gynecol. 1985;66.
93 Rogowski JA. The economics of preterm delivery. Prenat Neonat Med. 1998;3:16-20.
94 Creasy RK, Resnik R. Maternal fetal medicine: Principles and practice. 2nd ed. Philadelphia: W.B. Saunders; 1994.
95 Kogan MD, Alexander GR. Social and behavioral factors in preterm birth. Prenat Neonat Med. 1998;3:29-31.
96 Canadian Preterm Labor Investigators Group. Treatment of preterm labor with the beta-adrenergic agonist ritodrine. N Engl J Med. 1992;327:308-12. [pmid: 1620169].
97 Lohr KN, Carey TS. Assessing "best evidence": Issues in grading the quality of studies for systematic reviews. J Qual Improv. 1999;25:470-9.
98 West SL, Garbutt JC, Carey TS, et al. Evidence report on the pharmacotherapy for alcohol dependence. Rockville, MD: Agency for Health Care Policy and Research, US Dept of Health and Human Services; 1998. AHCPR Publication No. 99-E004.
99 US Preventive Services Task Force. Guide to clinical preventive services. 2nd ed. Baltimore: Williams and Wilkins; 1996.
100 Rothman, KJ, Greenland, S. Modern epidemiology. Philadelphia: Lippincott-Raven; 1998.
101 Lockwood CJ, Senyei AE, Dische MR, et al. Fetal fibronectin in cervical and vaginal secretions as a predictor of preterm delivery. N Engl J Med. 1991;325:669-74. [pmid: 1870640].
102 Inglis SR, Jeremias J, Kuno K, et al. Detection of tumor necrosis factor-alpha, interleukin-6, and fetal fibronectin in the lower genital tract during pregnancy: Relation to outcome. Am J Obstet Gynecol. 1994;171:5-10. [pmid: 8030732].
103 Iams JD, Casal D, McGregor JA, et al. Fetal fibronectin improves the accuracy of diagnosis of preterm labor. Am J Obstet Gynecol. 1995;173:141-5. [pmid: 7631671].
104 Irion O, Matute J, Bischof P. [Prediction of prematurity by oncofetal fibronectin. Prospective cohort study]. Prediction de la prematurite par la fibronectine oncofoetale. Etude de cohorte prospective. [Fre]. J Gynecol Obstet Biol Reprod (Paris). 1995;24:624-9. [pmid: 8830085].
105 Malak TM, Sizmur F, Bell SC, et al. Fetal fibronectin in cervicovaginal secretions as a predictor of preterm birth. Br J Obstet Gynaecol. 1996;103:648-53. [pmid: 8688390].
106 Rozenberg P, Nisand I, Malagrida L, et al. [Rational use of fetal fibronectin in the evaluation of premature labor risk]. Utilisation rationnelle de la fibronectine foetale dans l'evaluation du risque d'accouchement premature. [Fre]. J Gynecol Obstet Biol Reprod (Paris). 1996;25:288-93. [pmid: 8767228].
107 Vetr M, Kudela M, Prasilova J. Fetal fibronectin in patients at increased risk for premature birth [Cze]. Acta Univ Palacki Olomuc Fac Med. 1996;140:55-7. [pmid: 9431693].
108 Benattar C, Taieb J, Fernandez H, et al. Rapid fetal fibronectin swab-test in preterm labor patients treated by betamimetics. Eur J Obstet Gynecol Reprod Biol. 1997;72:131-5. [pmid: 9134390].
109 Langer B, Boudier E, Schlaeder G. Cervico-vaginal fetal fibronectin: Predictive value during false labor. Acta Obstet Gynecol Scand. 1997;76:218-21. [pmid: 9093134].
110 Watson DL, Kim SJ, Humphrey MD. Study of cervicovaginal fetal fibronectin status to guide treatment of threatened preterm labour. Aust N Z J Obstet Gynaecol. 1998;38:185-7. [pmid: 9653857].
111 Timor-Tritsch IE, Boozarjomehri F, Masakowski Y, et al. Can a "snapshot" sagittal view of the cervix by transvaginal ultrasonography predict active preterm labor?. Am J Obstet Gynecol. 1996;174:990-5. [pmid: 8633681].
112 Crane JM, Van den Hof M, Armson BA, et al. Transvaginal ultrasound in the prediction of preterm delivery: Singleton and twin gestations. Obstet Gynecol. 1997;90:357-63. [pmid: 9277644].
113 Rizzo G, Capponi A, Arduini D, et al. The value of fetal fibronectin in cervical and vaginal secretions and of ultrasonographic examination of the uterine cervix in predicting premature delivery for patients with preterm labor and intact membranes. Am J Obstet Gynecol. 1996;175:1146-51. [pmid: 8942480].
114 Rozenberg P, Goffinet F, Malagrida L, et al. Evaluating the risk of preterm delivery: A comparison of fetal fibronectin and transvaginal ultrasonographic measurement of cervical length. Am J Obstet Gynecol. 1997;176:196-9. [pmid: 9024113].
115 Chuileannain FN, Bell R, Brennecke S. Cervicovaginal fetal fibronectin testing in threatened preterm labour-translating research findings into clinical practice. Aust NZ J Obstet Gynaecol. 1998;38:399-402.
116 Sackett DL, Haynes RB, Guyatt GH, et al. Clinical epidemiology: A basic science for clinical medicine. 2nd ed. Boston: Little, Brown; 1991.
117 Lauersen NH, Merkatz IR, Tejani N, et al. Inhibition of premature labor: A multicenter comparison of ritodrine and ethanol. Am J Obstet Gynecol. 1977;127:837-45. [pmid: 851140].
118 Gamissans O, Canas E, Cararach V, et al. A study of indomethacin combined with ritodrine in threatened preterm labor. Eur J Obstet Gynecol Reprod Biol. 1978;8:123-8. [pmid: 400862].
119 Neldam S, Osler M. Premature rupture of the membranes and Ritodrine treatment. Acta Obstet Gynecol Scand. 1983;62:135-9. [pmid: 6346781].
120 Cotton DB, Strassner HT, Hill LM, et al. Comparison of magnesium sulfate, terbutaline and a placebo for inhibition of preterm labor. A randomized study. J Reprod Med. 1984;29:92-97. [pmid: 6708033].
121 Larsen JF, Eldon K, Lange AP, et al. Ritodrine in the treatment of preterm labor: Second Danish Multicenter Study. Obstet Gynecol. 1986;67:607-13. [pmid: 3515261].
122 Wilkins IA, Lynch L, Mehalek KE, et al. Efficacy and side effects of magnesium sulfate and ritodrine as tocolytic agents. Am J Obstet Gynecol. 1988;159:685-9. [pmid: 3048103].
123 Morales WJ, Smith SG, Angel JL, et al. Efficacy and safety of indomethacin versus ritodrine in the management of preterm labor: A randomized study. Obstet Gynecol. 1989;74:567-72. [pmid: 2677863].
124 Cox SM, Sherman ML, Leveno KJ. Randomized investigation of magnesium sulfate for prevention of preterm birth. Am J Obstet Gynecol. 1990;163:767-72. [pmid: 2206069].
125 Ferguson JE Jr, Dyson DC, Schutz T, et al. A comparison of tocolysis with nifedipine or ritodrine: Analysis of efficacy and maternal, fetal, and neonatal outcome. Am J Obstet Gynecol. 1990;163:105-11. [pmid: 2197860].
126 Meyer WR, Randall HW, Graves WL. Nifedipine versus ritodrine for suppressing preterm labor. J Reprod Med. 1990;35:649-53. [pmid: 2359062].
127 Bracero LA, Leikin E, Kirshenbaum N, et al. Comparison of nifedipine and ritodrine for the treatment of preterm labor. Am J Perinatol. 1991;8:365-9. [pmid: 1814297].
128 Chau AC, Gabert HA, Miller Jr JM. A prospective comparison of terbutaline and magnesium for tocolysis. Obstet Gynecol. 1992;80:847-51. [pmid: 1407926].
129 Kurki T, Eronen M, Lumme R, et al. A randomized double-dummy comparison between indomethacin and nylidrin in threatened preterm labor. Obstet Gynecol. 1991;78:1093-7. [pmid: 1945214].
130 Kupferminc M, Lessing JB, Yaron Y, et al. Nifedipine versus ritodrine for suppression of preterm labour. Br J Obstet Gynaecol. 1993;100:1090-4. [pmid: 8297841].
131 Holleboom CA, Merkus JM, van Elferen LW, et al. Double-blind evaluation of ritodrine sustained release for oral maintenance of tocolysis after active preterm labour. Br J Obstet Gynaecol. 1996;103:702-5. [pmid: 8688399].
132 Kanayama N, El Maradny E, Yamamoto N, et al. Urinary trypsin inhibitor: a new drug to treat preterm labor: A comparative study with ritodrine. Eur J Obstet Gynecol Reprod Biol. 1996;67:133-8. [pmid: 8841801].
133 Guinn DA, Goepfert AR, Owen J, et al. Management options in women with preterm uterine contractions: A randomized clinical trial. Am J Obstet Gynecol. 1997;177:814-8. [pmid: 9369825].
134 Jannet D, Abankwa A, Guyard B, et al. Nicardipine versus salbutamol in the treatment of premature labor. A prospective randomized study. Eur J Obstet Gynecol Reprod Biol. 1997;73:11-6. [pmid: 9175683].
135 Koks CA, Brolmann HA, de Kleine MJ, et al. A randomized comparison of nifedipine and ritodrine for suppression of preterm labor. Eur J Obstet Gynecol Reprod Biol. 1998;77:171-6. [pmid: 9578274].
136 Merkatz IR, Peter JB, Barden TP. Ritodrine hydrochloride: A betamimetic agent for use in preterm labor. II. Evidence of efficacy. Obstet Gynecol. 1980;56:7-12. [pmid: 6992003].
137 Caritis SN, Toig G, Heddinger LA, et al. A double-blind study comparing ritodrine and terbutaline in the treatment of preterm labor. Am J Obstet Gynecol. 1984;150:7-14. [pmid: 6383045].
138 Hatjis CG, Swain M, Nelson LH, et al. Efficacy of combined administration of magnesium sulfate and ritodrine in the treatment of premature labor. Obstet Gynecol. 1987;69:317-22. [pmid: 3822278].
139 Phuapradit W, Pongthai S, Chaturachinda K. Treatment of premature labour with terbutaline. J Med Assoc Thai. 1983;66:453-7. [pmid: 6685750].
140 Read MD, Wellby DE. The use of a calcium antagonist (nifedipine) to suppress preterm labour. Br J Obstet Gynaecol. 1986;93:933-7. [pmid: 3533134].
141 Kosasa TS, Busse R, Wahl N, et al. Long-term tocolysis with combined intravenous terbutaline and magnesium sulfate: A 10-year study of 1000 patients. Obstet Gynecol. 1994;84:369-73. [pmid: 8058233].
142 de Veciana M, Porto M, Major CA, et al. Tocolysis in advanced preterm labor: Impact on neonatal outcome. Am J Perinatol. 1995;12:294-8. [pmid: 7575840].
143 Sciscione AC, Stamilio DM, Manley JS, et al. Tocolysis of preterm contractions does not improve preterm. Am J Perinatol. 1998;15:177-81. [pmid: 9572373].
144 Castren O, Gummerus M, Saarikoski S. Treatment of imminent premature labour. Acta Obstet Gynecol Scand. 1975;54:95-100. [pmid: 1094787].
145 Sims CD, Chamberlain GV, Boyd IE, et al. A comparison of salbutamol and ethanol in the treatment of preterm labour. Br J Obstet Gynaecol. 1978;85:761-6. [pmid: 361067].
146 Spearing G. Alcohol, indomethacin, and salbutamol. Obstet Gynecol. 1979;53:171-4. [pmid: 418970].
147 TambyRaja RL. Current concepts in the management of preterm labour. Singapore Med J. 1989;30:578-83. [pmid: 2699676].
148 Caritis SN, Carson D, Greebon D, et al. A comparison of terbutaline and ethanol in the treatment of preterm labor. Am J Obstet Gynecol. 1982;142:183-90. [pmid: 7055183].
149 Gummerus M. [Tocolysis with hexoprenalin and salbutamol in a clinical comparison]. Tokolyse mit Hexoprenalin und Salbutamol im klinischen Vergleich. Geburtsh Frauenheilk. 1983;43:151-5. [pmid: 6552999].
150 Tchilinguirian NG, Najem R, Sullivan GB, et al. The use of ritodrine and magnesium sulfate in the arrest of premature labor. Int J Gynaecol Obstet. 1984;22:117-23. [pmid: 6145635].
151 Leveno KJ, Klein VR, Guzick DS, et al. Single-centre randomised trial of ritodrine hydrochloride for preterm labour. Lancet. 1986;1(8493):1293-6. [pmid: 2872429].
152 Coleman FH. Safety and efficacy of combined ritodrine and magnesium sulfate for preterm labor: A method for reduction of complications. Am J Perinatol. 1990;7:366-9. [pmid: 2222631].
153 Garcia-Velasco JA, Gonzalez GA. A prospective, randomized trial of nifedipine vs. ritodrine in threatened preterm labor. Int J Gynaecol Obstet. 1998;61:239-44. [pmid: 9688484].
154 Smith CS, Woodland MB. Clinical comparison of oral nifedipine and subcutaneous terbutaline for initial tocolysis. Am J Perinatol. 1993;10:280-4. [pmid: 8397562].
155 van Dijk K, Dekker GA, van Geijn H. Ritodrine and nifedipine as tocolytic agents: A preliminary comparison. J Perinat Med. 1995;23:409-15. [pmid: 8606348].
156 Hastwell GB, Halloway P, Taylo TL. Study of 208 patients in premature labour treated with orally administered salbutamol. Med J Aust. 1978;1:465-9. [pmid: 672733].
157 Hesseldahl H. A Danish multicenter study on ritodrine in the treatment of pre-term labour. Dan Med Bull. 1979;26:116-8. [pmid: 446106].
158 Gummerus M. The management of premature labor with salbutamol. Acta Obstet Gynecol Scand. 1981;60:375-7. [pmid: 7025554].
159 Papatsonis DN, Van Geijn HP, Ader HJ, et al. Nifedipine and ritodrine in the management of preterm labor: A randomized multicenter trial. Obstet Gynecol. 1997;90:230-34. [pmid: 9241299].
160 Noblot G, Audra P, Dargent D, et al. The use of micronized progesterone in the treatment of menace of preterm delivery. Eur J Obstet Gynecol Reprod Biol. 1991;40:203-9. [pmid: 1879595].
161 Eronen M, Pesonen E, Kurki T, et al. The effects of indomethacin and a beta-sympathomimetic agent on the fetal ductus arteriosus during treatment of premature labor: A randomized double-blind study. Am J Obstet Gynecol. 1991;164(1 Pt 1):141-6. [pmid: 1986601].
162 Glock JL, Morales WJ. Efficacy and safety of nifedipine versus magnesium sulfate in the management of preterm labor: A randomized study. Am J Obstet Gynecol. 1993;169:960-4. [pmid: 8238157].
163 Floyd RC, McLauglin BN, Perry KG Jr, et al. Magnesium sulfate or nifedipine hydrochloride for acute tocolysis of preterm labor: Efficacy and side effects. J Matern Fetal Invest. 1995;5:25-9.
164 Elliott JP. Magnesium sulfate as a tocolytic agent. Am J Obstet Gynecol. 1983;147:277-84. [pmid: 6624792].
165 Lewis DF, Grimshaw A, Brooks G, et al. A comparison of magnesium sulfate and indomethacin to magnesium. South Med J. 1995;88:737-40. [pmid: 7597478].
166 Fox MD, Allbert JR, McCaul JF, et al. Neonatal morbidity between 34 and 37 weeks' gestation. J Perinatol. 1993;13:349-53. [pmid: 8263618].
167 Morales WJ, Madhav H. Efficacy and safety of indomethacin compared with magnesium sulfate in the management of preterm labor: A randomized study. Am J Obstet Gynecol. 1993;169:97-102. [pmid: 8333483].
168 Zuckerman H, Reiss U, Rubinstein I. Inhibition of human premature labor by indomethacin. J Obstet Gynecol. 1974;44:787-92.
169 Zuckerman H, Shalev E, Gilad G, et al. Further study of the inhibition of premature labor by indomethacin. Part I. J Perinat Med. 1984;12:19-23. [pmid: 6726590].
170 Schrock A, Fidi C, Low M, et al. Low-dose ethanol for inhibition of preterm uterine activity. Am J Perinatol. 1989;6:191-5. [pmid: 2712916].
171 Goodwin TM, Paul R, Silver H, et al. The effect of the oxytocin antagonist atosiban on preterm uterine activity in the human. Am J Obstet Gynecol. 1994;170:474-8. [pmid: 8116700].
172 Brown SM, Tejani NA. Terbutaline sulfate in the prevention of recurrence of premature labor. Obstet Gynecol. 1981;57:22-5. [pmid: 7005777].
173 Kopelman JN, Duff P, Read JA. Randomized comparison of oral terbutaline and ritodrine for preventing recurrent preterm labor. J Reprod Med. 1989;34:225-30. [pmid: 2657045].
174 Ridgway LE, Muise K, Wright JW, et al. A prospective randomized comparison of oral terbutaline and magnesium oxide for the maintenance of tocolysis. Am J Obstet Gynecol. 1990;163:879-82. [pmid: 2206076].
175 Parilla BV, Dooley SL, Minogue JP, et al. The efficacy of oral terbutaline after intravenous tocolysis. Am J Obstet Gynecol. 1993;169:965-9. [pmid: 8238158].
176 How HY, Hughes SA, Vogel RL, et al. Oral terbutaline in the outpatient management of preterm labor. Am J Obstet Gynecol. 1995;173:1518-22. [pmid: 7503194].
177 Lewis R, Mercer BM, Salama M, et al. Oral terbutaline after parenteral tocolysis: A randomized, double-blind, placebo-controlled trial. Am J Obstet Gynecol. 1996;175(4 Pt 1):834-7. [pmid: 8885731].
178 Rust OA, Bofill JA, Arriola RM, et al. The clinical efficacy of oral tocolytic therapy. Am J Obstet Gynecol. 1996;175:838-42. [pmid: 8885732].
179 Guinn DA, Goepfert AR, Owen J, et al. Terbutaline pump maintenance therapy for prevention of preterm delivery: A double-blind trial. Am J Obstet Gynecol. 1998;179:874-8. [pmid: 9790362].
180 Ricci JM, Hariharan S, Helfgott A, et al. Oral tocolysis with magnesium chloride: A randomized controlled prospective clinical trial. Am J Obstet Gynecol. 1991;165:603-10. [pmid: 1892185].
181 Bivins HJ, Newman RB, Fyfe DA, et al. Randomized trial of oral indomethacin and terbutaline sulfate for the long-term suppression of preterm labor. Am J Obstet Gynecol. 1993;169:1065-70. [pmid: 8238121].
182 Van Assche A, Thoumsin H, Hendrickx B. Efficacy, safety and tolerance of oral sustained-release ritodrine given after intravenous administration in the treatment of premature labor. Eur J Obstet Gynecol Reprod Biol. 1990;34:229-34. [pmid: 2311810].
183 El-Sayed YY, Holbrook RH Jr, Gibson R, et al. Diltiazem for maintenance tocolysis of preterm labor: Comparison to nifedipine in a randomized trial. J Matern Fetal Med. 1998;7:217-21. [pmid: 9775988].
184 Norton ME, Merrill J, Cooper BA, et al. Neonatal complications after the administration of indomethacin for preterm labor. N Engl J Med. 1993;329:1602-7. [pmid: 8232428].
185 Major CA, Lewis DF, Harding JA, et al. Tocolysis with indomethacin increases the incidence of necrotizing enterocolitis in the low-birth-weight neonate. Am J Obstet Gynecol. 1994;170:102-6. [pmid: 8296809].
186 Moise KJ. Effect of advancing gestational age on the frequency of fetal ductal constriction in association with maternal indomethacin use. Am J Obstet Gynecol. 1993;168:1350-3. [pmid: 8498410].
187 Van den Veyver IB, Moise KJ Jr, Ou C, et al. The effect of gestational age and fetal indomethacin levels on the incidence of constriction of the fetal ductus arteriousus. Obstet Gynecol. 1993;82:500-3. [pmid: 8377971].
188 Romero R, Mazor M, Oyarzun E, et al. Is there an association between colonization with group B streptococcus and prematurity?. J Reprod Med. 1989;34:797-801. [pmid: 2677355].
189 Salafia CM, Vogel CA, Vintzileos AM, et al. Placental pathologic findings in preterm birth. Am J Obstet Gynecol. 1991;165:934-8. [pmid: 1951558].
190 Armer TL, Duff P. Intraamniotic infection in patients with intact membranes and preterm labour. Obstet Gynecol Surv. 1991;46:589-93. [pmid: 1745471].
191 Nadisauskiene R, Bergstrom S, Kilda A. Ampicillin in the treatment of preterm labor: A randomised, placebo-controlled study. Gynecol Obstet Invest. 1996;41:89-92. [pmid: 8838966].
192 Svare J, Langhoff-Roos J, Andersen LF, et al. Ampicillin-metronidazole treatment in idiopathic preterm labour: A randomised controlled multicentre trial. Br J Obstet Gynaecol. 1997;104:892-7. [pmid: 9255079].
193 Gordon M, Samuels P, Shubert P, et al. A randomized, prospective study of adjunctive ceftizoxime in preterm labor. Am J Obstet Gynecol. 1995;172:1546-52. [pmid: 7755069].
194 Romero R, Sibai B, Caritis S, et al. Antibiotic treatment of preterm labor with intact membranes: A multicenter, randomized, double-blinded, placebo-controlled trial. Am J Obstet Gynecol. 1993;169:764-74. [pmid: 8238130].
195 Newton ER, Dinsmoor MJ, Gibbs RS. A randomized, blinded, placebo-controlled trial of antibiotics in idiopathic preterm labor. Obstet Gynecol. 1989;74:562-6. [pmid: 2677862].
196 Newton ER, Shields L, Ridgway III LE, et al. Combination antibiotics and indomethacin in idiopathic preterm labor: A randomized double-blind clinical trial. Am J Obstet Gynecol. 1991;165:1753-9. [pmid: 1750473].
197 Cox SM, Bohman VR, Sherman ML, et al. Randomized investigation of antimicrobials for the prevention of preterm birth. Am J Obstet Gynecol. 1996;174:206-10. [pmid: 8572007].
198 Morales WJ, Angel JL, O'Brien WF, et al. A randomized study of antibiotic therapy in idiopathic preterm labor. Obstet Gynecol. 1988;72:829-33. [pmid: 3186088].
199 McGregor JA, French JI, Seo K. Adjunctive clindamycin therapy for preterm labor: Results of a double-blind, placebo-controlled trial. Am J Obstet Gynecol. 1991;165:867-75. [pmid: 1951545].
200 Norman K, Pattinson RC, de Souza J, et al. Ampicillin and metronidazole treatment in preterm labour: A multicentre, randomised controlled trial. Br J Obstetric Gynaecol. 1994;101:404-8.
201 Nadisauskiene R, Bergstrom S. Impact of intrapartum intravenous ampicillin on pregnancy outcome in women with preterm labor: A randomised, placebo-controlled study. Gynecol Obstet Invest. 1996;41:85-8. [pmid: 8838965].
202 Winkler M, Baumann L, Ruckhaberle KE, et al. Erythromycin therapy for subclinical intrauterine infections in threatened preterm delivery-a preliminary report. J Perinat Med. 1988;16:253-6. [pmid: 3210111].
203 McCaul JF, Perry KG Jr, Moore JL Jr, et al. Adjunctive antibiotic treatment of women with preterm rupture of membranes of preterm labor. Int J Gynecol Obstet. 1992;38:19-24.
204 Ernest JM, Givner LB. A prospective, randomized, placebo-controlled trial of penicillin in preterm premature rupture of membranes. Am J Obstet Gynecol. 1994;170:516-21. [pmid: 8116706].
205 Iams JD, Johnson FF, O'Shaughnessy RW. Ambulatory uterine activity monitoring in the post-hospital care of patients with preterm labor. Am J Perinatol. 1990;7:170-3. [pmid: 2331280].
206 Watson DL, Welch RA, Mariona FG, et al. Management of preterm labor patients at home: Does daily uterine activity monitoring and nursing support make a difference?. Obstet Gynecol. 1990;76(1 Suppl):32S-35S. [pmid: 2359576].
207 Nagey DA, Bailey-Jones C, Herman AA. Randomized comparison of home uterine activity monitoring and routine care in patients discharged after treatment for preterm labor. Obstet Gynecol. 1993;82:319-23. [pmid: 8355927].
208 Brown HL, Britton KA, Brizendine EJ, et al. A randomized comparison of home uterine activity monitoring in the outpatient management of women treated for preterm labor. Am J Obstet Gynecol. 1999;180:798-805. [pmid: 10203647].
209 Hasselblad, V. Meta-analysis of multitreatment studies. Med Decis Making. 1998;18:37-43. [pmid: 9456207].
210 Hedges LV, Olkin I. Statistical Methods for Meta-Analysis. Orlando, FL: Academic Press; 1985.
211 Oyarzun E, Gomez R, Rioseco A, et al. Antibiotic treatment in preterm labor and intact membranes: A randomized, double-blinded, placebo-controlled trial. J Matern Fetal Med. 1998;7:105-10. [pmid: 9642605].