# Recommendations for Future Research

Our evidence report has identified two domains that demand attention from future investigators and funding agencies. One domain involves numerous issues regarding definitions and methods that were discussed in the opening sections of Chapter 3 on results; the other domain concerns various substantive issues that warrant specific efficacy or effectiveness and health services research. The main portion of this chapter focuses on the second domain, but first we reiterate here the main problem with the current literature and the research on which it is based. We also note areas in which we believe that further research is not likely to be productive.

## Definitional and Methods Issues

### Definitional Issues

Depending on the topic and the release date of the pharmaceuticals, we reviewed a literature base that could date back more than three decades. In that time, the standards for research, including the conduct of RCTs as well as case control, longitudinal cohort, and similar effectiveness studies, have risen appreciably.

Nonetheless, in our view, a good deal of work needs to be done to shore up critical building blocks of research in this area. In particular, researchers need to attend to three issues:

1 Define preterm labor explicitly and carefully.
2 Be clear about which cointerventions were used and when were they administered during the study.
3 Separately analyze outcomes for those women with medically indicated preterm births and compare the results with those for the larger group of women with preterm labor.

### Outcome Measures

Perhaps the most important methodologic issue is that of measuring outcomes in trials or other studies of interventions for women in preterm labor. Our work has documented the extent to which researchers differ in their definitions of even standard outcomes. This matter is especially important if regulators (e.g., the FDA) or health plan administrators insist that an intervention must improve perinatal outcomes before it can be approved or adopted (as the FDA did with the oxytocin-agonist atosiban). However, any trial using perinatal endpoints would have to be quite large and expensive because progress in the care of tiny newborns has resulted in a relative rarity of poor perinatal outcomes; indeed, the numbers and expense of such trials are likely to be prohibitive.

Insistence on improvements in perinatal outcome is epidemiologically sound. Therefore, investigators and policymakers are likely to continue to rely on surrogates relating to delivery such as pregnancy prolongation or the number of preterm births before an arbitrary cutoff.

One way to address this problem is to improve the analysis of available data. As an answer to this problem, we have already noted the utility of survival analysis, which could provide continuous delivery outcomes stratified by gestational age at enrollment in the study. Such an approach is clinically and biologically relevant. It allows both clinicians and the public to decide whether an intervention's effects were relevant to an individual's particular situation, meaning that researchers can begin to clarify whether (and if so, to what extent) even a small delay in delivery at a particular gestational age has the potential to be significant.

Our recommendation, therefore, is that investigators, to the extent possible, supplement the use of categorical outcomes measures (e.g., preterm or term birth) and variables involving specific cutoff points for gestational age by including concepts such as the length of time a pregnancy was extended-prolongation-as a form of survival of the pregnancy. That is, we advocate for the assessment of the impact of an intervention on pregnancy prolongation through the use of survival analysis stratified by gestational age at the onset of preterm labor.

Implicit in this recommendation is an assumption that prolongation will improve perinatal outcome. This assumption has intuitive appeal given that the correlation between gestational age at birth and improved perinatal mortality and morbidity is strongly positive; however, no one knows the advantages or disadvantages of delaying delivery for an individual once preterm labor is established. Perhaps the in utero environment of the mother who is experiencing preterm labor is hostile and prolongation does more harm than good. Thus, the ultimate test for any therapeutic intervention will always be improvements in perinatal outcome.

Given the rarity of poor perinatal outcomes in an age of effective neonatal care, the need exists for composite perinatal outcomes that reflect the morbidity and mortality of premature birth. Potential measures that could be combined include perinatal death, neurologic deficit, and oxygen requirement at hospital discharge. Perinatologists could advance the field in important ways by constructing composite markers that accurately and consistently reflect the burden of being born before term. Such an approach has been useful in other fields such as cardiology. A valid composite measure could then become the outcome of choice in intervention trials.

Moreover, long-term followup of neonates is needed. Certain conditions that could be a direct harm from an intervention or a byproduct of pregnancy prolongation in a hostile environment may not become obvious until an infant matures. Followup of particular importance regarding developmental and neurologic outcomes as the fetal and neonatal brain has yet to complete development at the time of birth and hospital discharge.

## A Future Research Agenda

This report on the evidence concerning current care of the woman who presents with labor symptoms before term provides insights and directions to investigators in this field along several dimensions. These topics, covered in the remainder of this section, include basic epidemiology, use of biologic markers and better understanding of the test characteristics of the biologic markers most likely to be used in further efficacy or effectiveness studies, and use of pharmaceuticals (both tocolytics and antibiotics). We also comment here on questions for which we believe further research is not warranted.

### Epidemiology

First, the reader of this report will appreciate the need for basic and epidemiologic research in preterm labor. In our judgment, far more work needs to be done in this area just to lay a better framework for future intervention-specific efficacy and effectiveness research. Said another way: a field of knowledge so primitive that the patient's complaints (i.e., preterm labor symptoms) are used as the diagnostic criterion for the condition possessing the same name must invest in basic and epidemiologic research.

We lack basic knowledge regarding the biologic mechanisms resulting in birth before term. Moreover, there is a dearth of knowledge regarding the incidence and prevalence of preterm symptoms and modifiable risk factors for preterm birth. The issue of etiologic heterogeneity versus homogeneity for preterm birth is especially poorly understood.

We also draw attention to the need for better understanding of these basic facts in ethnic minorities, for at least two reasons. First, the demographics of this nation are changing rapidly, including among women of child-bearing ages. Second, clinicians should have better information at hand to address the needs of women who may have low English literacy skills, and who may thus be at a disadvantage in terms of communicating their symptoms or understanding the medical management regimens being recommended to them.

Finally, African American women and their offspring face profound disadvantages in terms of preterm birth. The discrepancy between perinatal outcomes in black and white women and the mechanisms contributing to such disparities must be investigated, so that clinicians and the public gain a better understanding of the epidemiologic, social, and other causal and contributing factors.

Also, the best type of clinician and optimal setting for care of the woman with preterm labor remains to be answered. Given the ubiquitous nature of these symptoms and our inability to assess risks, the minimum level of expertise and capacity needed to triage these patients effectively is not known.

Preterm labor with subsequent preterm birth has remained an enigma to clinicians and investigators. The condition has proven remarkably resistant to the inquiry of modern science. No satisfactory "meta-narrative" or paradigm has been constructed that reconciles all the observed phenomena. From the perspective of the authors of the evidence report, the failure to solve the muddled picture is because of faulty science and inadequate resources for investigation. By implication, better science and more resources to invest in efficacy and effectiveness studies will help to end the enigma.

Conversely, preterm labor and subsequent preterm birth may be the culmination of a complex, biopsychosocial process such as poverty or obesity. A narrow scientific focus on the clinical endpoint of preterm labor and relentless pursuit of a meta-narrative threaten to direct attention and resources from the changes needed in society that might ultimately result in substantial reductions in preterm birth rates.

### Risk Factors and Biologic Markers

Additional study regarding risk factors is important, and this issue bridges the epidemiologic and clinical realms of research. Clinicians and researchers need to be able to assess accurately the risk of preterm birth in women with symptoms of preterm labor and to exclude women at low risk of early birth from intervention trials. Failure to assess risk will not only dilute the effects of the intervention in question, but also expose numerous women who are at low risk to unnecessary and potentially harmful intervention. Some investigators have tried to assess risk by constructing strict definitions of preterm labor (e.g., by incorporating a measure of contraction frequency and duration with measures obtained from digital examination of the cervix).

Biologic markers may enhance this goal because they are objective and reproducible and are superior to purely clinical assessment or prognostication of preterm birth. At least two of the biologic markers we reviewed-fFN and EVUSD-can serve in this role. Thus, we recommend that investigators studying tocolytics and antibiotics (in their capacity as part of a medical regimen for women in or suspected of preterm labor) use biologic marker negativity as an exclusion criterion.

Moreover, we advise that further clinical trials be conducted to demonstrate whether the enhanced knowledge and precision provided by biologic markers with respect to preterm birth risk actually can improve perinatal outcomes. Trials should be conducted in which clinicians are provided with biologic marker information on a subset of participants and not on others, so as to clarify the level of efficacy and usefulness of this information in "ideal" settings. This step is fundamental before the use of biologic markers is incorporated into routine care in "average" settings, so as to avoid dilemmas in which better measurement precision does not improve outcomes (as has been seen with electronic fetal monitoring).

### Pharmaceutical Agents

Our meta-analytic results for the first-line tocolytics and for antibiotics (reported in Chapter 4) suggest that further trials of these modalities are needed. Use of antibiotics is almost universally recommended in women with preterm labor symptoms as a form of prophylaxis to prevent early-onset group B streptococcal sepsis. By contrast, the use of acute tocolysis has been disparaged by many. Well-designed trials of adequate size with appropriate outcome measures of acute tocolysis to prevent preterm birth in women with symptoms of preterm labor would be helpful and reasonable. We would call attention, in particular, to the likely benefits of a focus on beta-mimetics, calcium channel blockers, and magnesium sulfate.

Review of our evidence tables highlights not only the numerous agents used for tocolysis, but also the wide range of dosages prescribed. Clinicians and patients could potentially benefit from pharmacologic studies to assess optimal dosing and duration of therapy. Overdosing could lead to excessive harms from tocolysis, whereas underdosing could result in an inability to optimize outcomes. The same arguments and limitations apply to the duration of tocolytic dosing. Although we did not find evidence to support the use of so-called maintenance tocolysis once the acute preterm labor phase is over, the optimal duration for acute tocolysis is unknown.

Our report emphasizes the small, potential benefits of acute tocolysis-in terms of pregnancy prolongation-in the face of substantial potential maternal harms. This marginal benefits-to-risk ratio argues for continued development and testing of new tocolytic drugs. Clinicians and patients would benefit from agents that are selective for uterine smooth muscle quiescence. The oxytocin-agonist atosiban is an example of a novel tocolytic drug that met utero-selective criteria. Its failure to improve perinatal outcome kept the FDA from approving it as a tocolytic, but many authorities predict approval within the European community because of its ability to prolong pregnancy and lack of side effects. Should the European experience with atosiban be favorable, perhaps approval of this agent as a tocolytic should be reconsidered in the United States. Moreover, other oxytocin antagonists and novel classes of compounds with the ability to quiet the uterus should be studied and tested.

The studies we reviewed provided virtually no information on the quality of the mother's life while receiving treatment-other than in relation to physical harm. Data on lost wages or lost days of work would support cost-benefit analyses of treatment effectiveness. In addition, information on the psychological impacts of treatment and the treatment process could also provide valuable insights.

The best type of clinician and the optimal care setting of a woman with preterm labor remains to be answered. Given the ubiquitous nature of these symptoms and the inability to adequately assess risks, clinicians and institutions caring for these women need to be able to triage these patients. However, whether this needs to be at a tertiary perinatal center or a lower level of care is a topic for future study.

If the optimal class of drug, dose, and duration of tocolytic therapy is obfuscated, the evidence to guide clinicians' use of antibiotics is even more obscure. Given the array of microbicidal and static agents in the full evidence tables, we cannot delineate a rational approach to the selection and duration of such therapies. At present, it seems prudent in light of the marginal benefits of antibiotics to follow protocols for prophylaxis against early-onset Group B streptococcal sepsis with the expectation that such interventions will not only accomplish that goal, but also prolong pregnancy. Investigators should focus their research on determining the optimal agent, dose, duration, and possible combinations for antibiotics in women presenting with preterm labor.

### Areas Not Warranting Further Research

Our review casts doubts on the wisdom of future research in three areas. The first is maintenance tocolysis, where we saw from both the synthesis of the literature and the meta-analyses that tocolytics used in a maintenance modality (as contrasted with first-line interventions) offered no demonstrable benefit in preventing preterm birth. Second, it seems clear that no further work need ever be done on ethanol as either a first-line or maintenance tocolytic. The third area is home uterine activity monitoring, where we were unable to find even indirect evidence that using this device alone is useful in preventing preterm birth.