# Meta-Analyses Chapter 4 was developed by Norma Gavin, Ph.D., of Research Triangle Institute and Victor Hasselblad, Ph.D., Duke Clinical Research Institute, Durham, North Carolina.

## Introduction

Although a few trials of both first-line and maintenance tocolytic treatment for women in preterm labor had significant, positive effects, as discussed in Chapter 3 and presented in the evidence tables, most found the different tocolytics to be equally effective and to have little benefit, if any, over placebo or no tocolytic therapy. Similarly, a few trials of adjunctive antibiotic therapy also found significant effects of antibiotic treatment over placebo or no adjunctive antibiotic therapy, but again most of these trials found no statistically significant effects. Virtually no benefits were found in the trials of home uterine activity monitoring compared with trials involving no monitoring of women in preterm labor; however, many of the trials for these interventions had so few patients enrolled that only very large differences would have been statistically significant.

To determine whether the lack of significance in these various studies resulted from the small sample sizes or negligible impact of the interventions, we conducted a series of meta-analyses, statistically combining results from similar trials into summary measures. These meta- analyses were focused on the efficacy of the interventions for preterm labor as measured by one or more of the following outcomes: (1) prolongation of pregnancy, (2) estimated gestational age at delivery, and (3) birth weight. These outcomes were most frequently reported in the abstracted studies. In particular, for each group of interventions first-line tocolytics, maintenance tocolytics, adjunctive antibiotics, and home uterine activity monitoring we sought answers to the following questions:

- Does the intervention result in significantly prolonged pregnancies compared to placebo or no intervention for women in preterm labor? This outcome is measured in days of increased pregnancy.
- Does the intervention result in deliveries at significantly later gestational age compared with placebo or no intervention for women in preterm labor? This outcome is measured in weeks of gestation.
- Does the intervention result in higher birth weight babies compared with placebo or no intervention for women in preterm labor? This outcome is measured in grams or kilograms.

## Methods

### Selection Criteria for Inclusion of Studies

We first reviewed the completed evidence tables for the various interventions to identify studies for inclusion in the meta-analyses. We included only RCTs. Results from prospective cohort studies, case series, retrospective analyses, and other nonrandomized trials were excluded from the analyses. For inclusion in the meta-analyses, the trials also had either to be restricted to women with intact membranes or to have reported the outcomes separately for this subgroup.

Furthermore, only RCTs making comparisons of interest were considered for inclusion. For adjunctive antibiotic and home uterine activity monitoring trials, the comparison of interest was between standard treatment with the intervention and standard treatment with either placebo or no intervention. All antibiotic and home uterine activity monitoring RCTs had at least one intervention arm and one arm without the intervention and, therefore, were potential candidates for the meta-analyses.

By contrast, the tocolytic trials frequently compared one tocolytic agent with another; only a small number of trials included a placebo or an arm with no tocolytic treatment. Because the various tocolytics work through different mechanisms, we were interested in comparisons among different classes of tocolytics; therefore, tocolytic trials were considered for the meta-analyses if they compared one class of tocolytics with another and/or to placebo or no tocolytic treatment. The tocolytic classes included were beta-mimetics, calcium channel blockers, magnesium sulfate, NSAIDs, and ethanol. Because trials comparing one beta-mimetic with another one calcium channel blocker with another added no additional information for the comparisons of interest, they were excluded from the meta-analyses unless they also had an arm with another class of tocolytic or a placebo or no tocolytic arm.

Of all the trials considered for these analyses, 23 trials of first-line tocolytics, 10 trials of maintenance tocolytics, 13 trials of adjunctive antibiotic treatment, and 3 trials of home uterine activity monitoring met the inclusion criteria. We then extracted the information on the outcomes of interest for each trial.

Although the three outcomes of interest were the most frequently reported, they were by no means universally or uniformly reported. For prolongation of pregnancy, some trials reported the mean number of days that pregnancy was prolonged as well as either the standard deviation, the standard error, or both. Others reported only the means. Others reported the number or percentage of pregnancies prolonged for various durations (e.g., <2 days, >7 days, <14 days). Similarly, some trials reported mean gestational age at delivery with or without standard deviations or standard errors; others reported the number or percentage of deliveries at or beyond different gestational age cutoffs (e.g.,>32 weeks, >36 weeks, >37 weeks). Still others reported mean birth weight with or without standard deviations or standard errors and a few reported the percentage of births greater than or equal to 2500 g. Some trials neglected to report any data on one or more of these outcomes altogether. Thus, the actual number of trial results that could be combined for any particular analysis was smaller than the number of trials meeting the inclusion criteria.

### Methodology

Where possible, we used the continuous measures of the outcomes of interest and combined the mean differences, d, across studies: d = M_t_ - M_c_ where M _t_ and M _c_ are the sample means of the treated and control arms, respectively. Assuming a normal distribution for the individual observations with equal variances in each arm of the trial, the variance of the difference, S ^2^, is computed: [image] where SEM _t_ ^2^ is the standard error of the mean of the treated arm and SEM _c_ ^2^ is the standard error of the mean of the control arm. Thus, to use this measure, the sample size, means, and standard errors (or standard deviations) must be available from the reported information. For analyses in which too few studies reported means with standard deviations or standard errors, we computed the odds ratio, ω, for selected cutoff values of the outcome measures. We could then use this value as the effect measure for combining results across studies: w = P_t_(1 - P_c_)/P_c_(1 - P_t_) where p _t_ is the proportion of the treated group that successfully reached the cutoff value and p _c_ is the proportion of the control group that successfully reached the cutoff value.

To manage the multiple treatment problem of first-line tocolytic treatments in which we had five classes of tocolytics to compare with placebo/no tocolytics, we used the generalization of the two-arm methods developed by Hasselblad. ^209^ For all interventions and outcomes, we combined the results using a Bayes random effects model as described by Hedges and Olkin, ^210^ allowing the true treatment effect to vary across studies. For dichotomous outcomes, we estimated the model parameters with the EGRET software package; for continuous measures, we used a customized program developed by one of the authors, Victor Hasselblad, Ph.D.

In addition to the meta-analysis results on the three main questions noted earlier (e.g., estimates of prolongation of gestation), we report the results of tests of homogeneity for the four main sets of analyses (both types of tocolytics, antibiotics, and home uterine activity monitoring). These tests indicate the extent to which the trials are sufficiently alike to permit them to be combined with confidence, and the possibility that various unknown factors are present that have not been adequately controlled for.

## Results

### First-Line Tocolytics

The odds ratio of delivery "at term" was the only measure reported in an adequate number of first-line tocolytic trials to conduct a meta-analysis of all five classes of tocolytics against a placebo/no tocolytic arm. We included studies as defining birth at term if they reported the fraction of women giving birth at or beyond 36, 37, or 38 weeks. Preliminary analyses of the odds ratios from the trials using the different cutoffs were similar, suggesting that the use of the three cutoffs as equivalent would not unduly affect the results. Thus, we treated these cutoffs as equivalent for purposes of our analysis. The 17 studies and the treatment arms used in the meta- analysis are listed in Table 13 (ordered by beta-mimetics included or not).

Table 14. Effect of first-line tocolytics: Odds of delivery at term (at or beyond 36 to 38 weeks gestation)

Treatment | Estimated Odds Ratio | Standard Error of Log | 95% Confidence Interval
Beta-mimetics | 1.622 | 0.147 | 1.216, 2.164
Calcium channel blockers | 2.485 | 0.237 | 1.562, 3.954
Magnesium sulfate | 1.867 | 0.231 | 1.187, 2.936
NSAIDs | 4.948 | 0.562 | 1.645, 14.89
Ethanol | 0.949 | 0.263 | 0.567, 1.589

Table 13. Trial arms used in the meta-analysis of first-line tocolytics: Odds ratio for delivery at term (at or beyond 36 to 38 weeks gestation)

Study | Placebo | Beta- Mimetics | Calcium Channel Blockers | Magnesium Sulfate | NSAIDs | Ethanol
Merkatz, et al., ^136^ 1980 | Yes | Yes | No | No | No | No
Larsen, et al., ^121^ 1986 | Yes | Yes | No | No | No | No
Leveno, et al., ^151^ 1986 | Yes | Yes | No | No | No | No
Guinn, et al., ^133^ 1997 | Yes | Yes | No | No | No | No
Meyer, et al., ^126^ 1990 | No | Yes | Yes | No | No | No
Kupferminc, et al., ^130^ 1993 | No | Yes | Yes | No | No | No
Jannet, et al., ^134^ 1997 | No | Yes | Yes | No | No | No
Papatsonis, et al., ^159^ 1997 | No | Yes | Yes | No | No | No
Garcia-Velasco and Gonzalez, ^153^ 1998 | No | Yes | Yes | No | No | No
Wilkins, et al., ^122^ 1988 | No | Yes | No | Yes | No | No
Kurki, et al., ^129^ 1991 | No | Yes | No | No | Yes | No
Castren, et al., ^144^ 1975 | Yes | Yes | No | No | No | Yes
Lauersen, et al., ^117^ 1977 | No | Yes | No | No | No | Yes
Caritis, et al., ^148^ 1982 | No | Yes | No | No | No | Yes
Glock and Morales, ^162^ 1993 | No | No | Yes | Yes | No | No
Floyd, et al., ^163^ 1995 | No | No | Yes | Yes | No | No

The results of the meta-analysis are presented in Table 14 and are shown graphically in Figure 21. The data on estimated odds ratios suggest that all tocolytics, except ethanol, are effective in extending deliveries to term compared with placebo/no tocolytic treatment (odds ratios ranging from 1.622 [beta-mimetics] to 2.485 [calcium channel blockers]). The evidence for NSAIDs (an odds ratio approaching 5.0) is based on only one study and thus should be viewed with extreme caution.

Figure 21. Meta-analysis results: Effect of first-line tocolytics on the odds of delivery at term (at or beyond 36 to 38 weeks gestation), by tocolytic class

We conducted an overall test for goodness of fit, which gave a chi-square of 11.476 for 13 degrees of freedom, p=0.571. Thus, there was no evidence of lack of fit. We also conducted a test to see if beta-mimetics, calcium channel blockers, and magnesium sulfate had the same effects. This calculation gave an overall chi-square test of 8.762 for 2 degrees of freedom, p=0.0125. Thus, there is evidence that these three tocolytics may have a differential effect from each other relative to placebo in terms of increasing the number of births at or beyond 36 to 38 weeks gestation.

### Maintenance Tocolytics

We found fewer studies that investigated the efficacy of maintenance tocolytics. Most of these studies compared beta-mimetics and/or magnesium sulfate with placebo/no maintenance tocolytics. Therefore, we were unable to compare all classes of tocolytics in a single meta- analysis, as we had for first-line tocolytics. Instead, we conducted separate meta-analyses for beta-mimetics versus placebo/no maintenance tocolytics and magnesium sulfate versus placebo/no maintenance tocolytics. The eight studies, six with beta-mimetic arms and two with magnesium sulfate arms, in the analyses are listed in Table 15.

Table 15. Studies of the effects of tocolytics as maintenance therapies

Study | Placebo | Beta- Mimetics | Magnesium Sulfate
Creasy, et al., ^44^ 1980 | Yes | Yes | No
Brown and Tejani, ^172^ 1981 | Yes | Yes | No
Ricci, et al., ^180^ 1991 | Yes | Yes | Yes
Parilla, et al., ^175^ 1993 | Yes | Yes | No
How, et al., ^176^ 1994 | Yes | Yes | No
Lewis, et al., ^177^ 1996 | Yes | Yes | No
Rust, et al., ^178^ 1996 | Yes | Yes | Yes
Guinn, et al., ^179^ 1998 | Yes | Yes | No

The results of these meta-analyses are presented in Table 16; Figures 21 through 26 provide the plots for mean gestational age, prolongation of pregnancy, and birth weight, respectively, for beta-mimetics and magnesium sulfate. These analyses show that tocolytics are not effective when used as a maintenance therapy. No evidence of benefit was demonstrated for any of the outcomes investigated. Furthermore, all of the point estimates go in the direction of harm.

Table 16. Effect of maintenance tocolytics on pregnancy outcomes

Treatment | Endpoint (units) | Estimated Difference | 95% Confidence Interval
Beta-mimetics | Prolongation (days) Gestational age (weeks) Birth weight (grams) | -0.68 -0.46 -16.4 | -4.68, 3,33 -1.03, 0.11 -189.0, 155.3
Magnesium sulfate | Prolongation (days) Gestational age (weeks) Birth weight (grams) | -3.31 -0.55 -202.8 | -9.67, 3.06 -1.38, 0.28 -405.7, 0.1

Figure 22. Meta-analysis results: Effect of maintenance beta-mimetics on mean gestational age relative to placebo

Figure 23. Meta-analysis results: Effect of maintenance magnesium sulfate on mean gestational age relative to placebo

Figure 24. Meta-analysis: Effect of maintenance beta-mimetics on prolongation of pregnancy relative to placebo

Figure 25. Meta-analysis results: Effect of maintenance magnesium sulfate on prolongation of pregnancy relative to placebo

Figure 27. Meta-analysis results: Effect of maintenance magnesium sulfate on birth weight relative to placebo

Figure 26. Meta-analysis results: Effect of maintenance beta-mimetics on birth weight relative to placebo

Table 17 gives the results of tests for homogeneity for the above results. They show that the hypothesis that the studies are measuring the same effect can be rejected only for the birth weight outcome for beta-mimetics, thus providing support for the conclusion that the correct statistical methodology was used in the analysis.

Table 17. Homogeneity of effects of maintenance tocolytics on pregnancy outcomes

Treatment | Endpoint (Units) | Chi-square for Homogeneity | Degrees of Freedom | p-Value
Beta-mimetics | Prolongation (days) Gestational age (weeks) Birth weight (grams) | 7.57 0.67 46.27 | 6 5 7 | 0.272 0.985 <0.001
Magnesium sulfate | Prolongation (days) Gestational age (weeks) Birth weight (grams) | 0.43 0.58 0.07 | 1 1 1 | 0.512 0.445 0.790

### Adjunctive Antibiotics

For the 13 trials of adjunctive antibiotics in women with preterm labor and unknown infection, we were able to combine results on prolongation of pregnancy from 6 trials, gestational age at delivery from 9 trials, and birth weight from 12 trials. The individual and combined results for each outcome are shown in Tables 18 through 20 and Figures 28 through 30, respectively.

Table 18. Effect of antibiotics on prolongation of pregnancy (measured in days)

Study | Estimated Prolongation (Days) | Standard Error | 95% Confidence Interval
Morales, et al., ^198^ 1988 | 13.55 | 3.39 | 6.898, 20.20
Nadiasauskiene, et al., ^191^ 1996 | 10.50 | 6.91 | -3.067, 24.07
McGregor, et al., ^199^ 1991 | 9.90 | 4.44 | 1.174, 18.63
McCaul, et al., ^203^ 1992 | 0.50 | 8.53 | -16.34, 17.34
Newton, et al., ^195^ 1989 | 0.10 | 4.73 | -9.200, 9.400
Gordon, et al., ^193^ 1995 | -0.10 | 4.29 | -8.527, 8.327
COMBINED | 6.42 | 2.63 | 1.266, 11.56

Table 20. Effect of antibiotics on birth weight (measured in kilograms)

Study | Increase in Birth Weight (kg) | Standard Error | 95% Confidence Interval
Svare, et al., ^192^ 1997 | 0.292 | 0.170 | -0.04241, 0.6264
Morales, et al., ^198^ 1988 | 0.288 | 0.128 | 0.0375, 0.5385
Norman, et al., ^200^ 1994 | 0.225 | 0.145 | -0.060, 0.5104
Cox, et al., ^197^ 1996 | 0.169 | 0.176 | -0.1739, 0.5119
McGregor, et al., ^199^ 1991 | 0.145 | 0.135 | -0.1195, 0.4099
Newton, et al., ^196^ 1991 | 0.135 | 0.181 | -0.2174, 0.4874
Nadisauskiene and Bergstrom ^201^ 1996 | 0.056 | 0.104 | -0.1476, 0.2596
Gordon, et al., ^193^ 1995 | 0.026 | 0.124 | -0.2177, 0.2697
Newton, et al., ^195^ 1989 | 0.008 | 0.134 | -0.2547, 0.2707
McCaul, et al., ^203^ 1992 | -0.059 | 0.247 | -0.5481, 0.4295
Oyarzun, et al., ^211^ 1998 | -0.063 | 0.108 | -0.2748, 0.1488
Romero, et al., ^194^ 1993 | -0.148 | 0.092 | -0.3287, 0.0327
COMBINED | 0.068 | 0.045 | -0.01938, 0.1558

Figure 29. Meta-analysis results: Effect of adjunctive antibiotics on estimated gestation age at birth relative to no antibiotics

Figure 28. Meta-analysis: Effect of adjunctive antibiotics on prolongation of pregnancy relative to no antibiotics

Figure 30. Meta-analysis results: Effect of adjunctive antibiotics on birth weight relative to no antibiotics

Table 18 shows that adjunctive antibiotic treatment in women with preterm labor produces a marginally significant increase in length of pregnancy of about 6 days (see the last "combined" row); however, the individual studies are somewhat inconsistent. The estimated prolongation ranges from virtually no time ^195^ to nearly 14 days; ^198^ hence the final result should be viewed with caution. Also, the test for homogeneity gave a chi-square of 9.99 for 5 degrees of freedom, p=0.076, implying that the studies included in the analysis may not have come from the same underlying distribution.

We obtain a similar result using gestational age at birth (Table 19). The combined estimate of effect shows a marginally significant increase in gestational age of about 0.60 of a week from the use of adjunctive antibiotics (see the last, "combined" row, for which the 95 percent confidence interval includes 1.0). Although the individual studies do not reflect as much difference as for gestational prolongation (above), the effect is nonetheless relatively small and should be viewed with caution. The test for homogeneity gave a chi-square of 11.272 for 8 degrees of freedom, p=0.019.

Table 19. Effect of antibiotics on estimated gestational age at birth (measured in weeks)

Study | Increase in Gestation Age (Weeks) | Standard Error | 95% Confidence Interval
Nadiasaukiene, et al., ^191^ 1996 | 2.80 | 1.02 | 0.7942, 4.806
Norman, et al., ^200^ 1994 | 1.30 | 0.82 | -0.3110, 2.911
Newton, et al., ^196^ 1991 | 1.00 | 0.90 | -0.7581, 2.758
Morales, et al., ^198^ 1988 | 0.95 | 0.41 | 0.1380, 1.762
McGregor, et al., ^199^ 1991 | 0.50 | 0.66 | -0.8040, 1.804
Gordon, et al., ^193^ 1995 | 0.10 | 0.55 | -0.9718, 1.172
Cox, et al., ^197^ 1996 | 0.10 | 0.95 | -1.765, 1.965
Newton, et al., ^195^ 1989 | 0.00 | 0.60 | -1.174, 1.174
McCaul, et al., ^203^ 1992 | -1.10 | 1.01 | -3.093, 0.8931
COMBINED | 0.59 | 0.24 | 0.1198, 1.057

Finally, the meta-analysis of birth weight (Table 20) shows an increase in birth weight of about 0.07 kg (70 g) (see "combined" row); however, the effect is not only small but not quite statistically significant at the 0.05 level. The test for homogeneity gave a chi-square of 14.39 for 11 degrees of freedom, p=0.212.

### Home Uterine Activity Monitoring

Three studies meeting the selection criteria compared the effect of home uterine activity monitoring on gestational age, ^205^ ^207^ ^208^ and two compared the effect of home uterine activity monitoring on birth weight. ^205^ ^208^ For gestational age, we combined both the mean differences in gestational age and the odds of delivery at or beyond 37 weeks' gestation. For birth weight, we combined only the mean differences. The results of these meta-analyses are shown in Table 21 and Figures 31 through 33.

Table 21. Effect of home uterine activity monitoring on pregnancy outcomes

Endpoint (Units) | Estimated Difference (treated - control) | 95% Confidence Interval
Gestational age (weeks) | 0.19 | -0.37, 0.76
Survival to 37 weeks (odds ratio) | 1.22 | 0.73, 2.05
Birth weight (grams) | -47.0 | -201.1, 107.1

Figure 32. Meta-analysis results: Effect of home uterine activity monitoring on gestational age relative to no monitoring

Figure 31. Meta-analysis results: Effect of home uterine activity monitoring on the odds on the odds of delivery at 37 or more weeks gestation relative to no monitoring

Figure 33. Meta-analysis results: Effect of home uterine activity monitoring on birth weight relative to monitoring

The meta-analyses show that home uterine activity monitoring is not effective in increasing the gestational age or birth weight of infants born to women with suspected preterm labor and, at best, might prolong survival of the pregnancy to 37 weeks only very slightly; 95 percent confidence levels all include 1.0. Once again, the results should be viewed with caution because of the small number of studies and study subjects. Table 22 gives the tests for homogeneity for these analyses; none is significant.

Table 22. Homogeneity of effects of home uterine activity monitoring on pregnancy outcomes

Endpoint (units) | Chi-square for Homogeneity | Degrees of Freedom | p-Value
Gestational age (weeks) | 0.83 | 2 | 0.660
Survival to 37 weeks (odds ratio) | 0.44 | 1 | 0.508
Birth weight (grams) | 1.88 | 2 | 0.391

## Summary and Conclusions

We conducted a series of meta-analyses on the efficacy of various interventions for women with suspected preterm labor. These interventions included first-line tocolytics, maintenance tocolytics, adjunctive antibiotics for occult in utero, and home uterine activity monitoring. We restricted the analysis to evidence from RCTs for women with intact membranes and focused on three outcome measures: (1) prolongation of pregnancy in days, (2) gestational age at delivery, and (3) birth weight.

We found 23 first-line tocolytic studies, 10 maintenance tocolytic studies, 13 antibiotic studies, and 3 home uterine activity monitoring studies meeting our inclusion criteria. Because of the lack of complete and consistent reporting of outcomes, the meta-analyses for each intervention were conducted on fewer studies.

For first-line tocolytics, we first combined studies within tocolytic class and compared the results with placebo/no tocolytics. The only outcome measure with evidence from an adequate number of trials was the fraction of births occurring at term, defined as at or beyond 36 to 38 weeks' gestation. We found all tocolytic classes, except ethanol, were effective in increasing gestational age at birth. Beta-mimetics, calcium channel blockers, and magnesium sulfate nearly doubled the odds of birth at term, relative to control, with small but significant differences in effect size found between classes of drug.

We also found adjunctive antibiotic treatment to have small, beneficial effects for women in preterm labor with suspected occult in utero infection. We estimated increases of 6 days in the length of pregnancy, 0.6 of a week (i.e., slightly more than 4 days) in gestational age at delivery, and 70 g of weight at birth. The increase in birth weight was not found to be statistically significant.

Finally, we found no statistically significant effects from maintenance tocolytic treatment or of home uterine activity monitoring. For home uterine activity monitoring, however, no more than three trials were combined for estimates of these effects, and all trials entered few patients; therefore, the results should be interpreted with caution.