# Results

## Introduction

Based on the data presented in the evidence tables, this chapter presents the major findings from our review of the literature regarding the management of preterm labor. The chapter begins with a discussion of issues and limitations relevant to the collective body of literature. Subsequent sections focus on each assessment technique or therapy and provide a detailed discussion of efficacy and/or effectiveness results (benefits). We address, in turn, biologic markers (fFN and EVUSD), tocolytics (first-line and maintenance), antibiotics, and home uterine activity monitoring. Side effects (harms) data are presented only in relation to tocolytic treatment.

## Issues and Limitations in the Literature

Through our review, we found a number of issues affecting the quality of the studies reported in the literature that cut across categories of assessments and interventions in the management of preterm labor. Our ability to draw conclusions with confidence is diminished by the following five issues concerning research design and study execution: (1) the definition of preterm labor, (2) the size of the trials, (3) the confounding of results because of use of other interventions, (4) the sole reliance on bivariate analysis, and (5) the failure to analyze separately women with medically indicated preterm births and compare results with those of the larger group of women with preterm labor. We discuss other concerns specific to the literature about a particular assessment technique or therapy in the section of this chapter covering that specific topic.

Definitions used to delineate an episode of preterm labor vary widely across studies. Some investigators are quite precise, requiring a specified level of contraction duration, contraction frequency, and cervical change; however, within this group, the number or frequency of symptoms varies greatly. Other authors specify, as an entry criterion, a lack of response to nondrug interventions, such as bed rest and hydration. Still other authors do not define preterm labor or specify the symptoms used as an inclusion criteria for the study. Thus, the reviewer is presented with possible heterogeneity in study populations, a factor that limits the generalizability and aggregation of study results.

Because adverse perinatal outcomes (morbidity and mortality) are so rare, studies generally have inadequate numbers to provide the power to assess whether any observed differences were statistically significant. Hence, nonstatistically significant results may stem from a lack of power to detect positive outcomes rather than a true lack of benefit. Instead, investigators rely on surrogate outcomes such as pregnancy prolongation, mean gestational age at delivery, and rate of delivery before a specific cutoff point (most commonly 35 to 37 weeks). Reviewers are asked implicitly to make the assumption that improvements in these surrogate outcomes would translate into improvements in perinatal outcomes if applied to enough women with preterm labor symptoms.

Interpreting results is further complicated by the use of cointerventions. Most studies of one type of therapy allow the use of another type of intervention; for instance, antibiotic studies allow for tocolytic use and vice versa. Moreover, studies also allow for nondrug interventions, such as intravenous hydration and bed rest. To avoid confounding from cointerventions, analyses would need to impose study designs or include statistical techniques to control for use of the cointerventions. Very few of the studies reviewed for this evidence report include these controls.

Given the rarity of perinatal death and serious morbidity, assessing these outcomes would require enrolling thousands of women. As this is unlikely to be a practical solution, survival analysis is an analytic technique that can enhance outcome presentations by providing stratified analyses by gestational age at enrollment for the period from treatment to birth. (See Rothman and Greenland ^100^ for a general description of survival analysis.)

To date, however, studies typically rely on bivariate analyses of categorical and continuous outcomes. Although categorical measures can capture such outcomes as "preterm birth, yes or no," these results may not be clinically informative in and of themselves because women at a wide range of gestational ages may be included in the analysis. Comparisons of continuous outcomes, such as mean prolongation of pregnancy, may also be misleading. For example, a similar lengthening of gestation may be of greater value for a woman at 26 weeks' gestation relative to 34 weeks' gestation and, because a wide range of gestational ages are typically included in the studies, this distinction is not commonly available.

The etiologic pathways leading to preterm birth are uncertain. Given the lack of epidemiologic evidence, it remains unclear as to whether indicated preterm births are etiologically heterogeneous or homogeneous with spontaneous preterm births. The inclusion of dual analyses in the review of efficacy and effectiveness studies could provide useful insights into this controversy; results for women with indicated preterm births and those experiencing spontaneous preterm births could be analyzed separately and in combination. A body of literature of this kind could provide insights into this controversy and support conclusions concerning whether indicated preterm births should be included or excluded from the analyses of women with preterm labor.

## Biologic Markers

Chapter 1 discussed the clinician's limited ability to ascertain which symptomatic woman is at risk for imminent delivery and which is not. The inability to assign risk accurately, coupled with the ubiquity of preterm labor symptoms, exposes numerous women to unnecessary and potentially harmful treatment. Moreover, this phenomenon dilutes researchers' ability to detect a significant intervention effect in those with uterine activity that will result in cervical change and potential preterm birth. Thus, a rapid and reproducible biochemical or biophysical "diagnostic" test for women with preterm labor symptoms that could accurately assess the risk of preterm delivery would be of great value. In Chapter 1, we labeled such tests "biologic markers."

We proposed to study three biologic markers in this evidence report: fFN, EVUSD, and E3. Restricting our review to investigations that include women with symptoms of preterm labor, as we have done throughout this report, resulted in our finding no studies of E3 in symptomatic women. As a result, we cannot comment on estriol's efficacy to assess preterm delivery risk in women with preterm labor symptoms and will not address in this chapter this biologic marker. Also, the body of literature about the use of EVUSD as a screening tool is quite extensive; however, we have excluded screening studies in asymptomatic women, which substantially restricts the articles available for review in this evidence report.

Of the 17 reviewed studies about biologic markers, 12 examined fFN; ^46^ ^101^ ^102^ ^103^ ^104^ ^105^ ^106^ ^107^ ^108^ ^109^ ^110^ their findings can be found in Evidence Table 1. Three additional studies concern EVUSD alone; ^55^ ^111^ ^112^ the details can be found in Evidence Table 2. Finally, findings of two other studies that examined both fFN and EVUSD ^113^ ^114^ can be found in both Evidence Tables 1 and 2 for completeness.

### Description of the Biologic Marker Literature

#### General Limitations of this Literature

As discussed previously, all the literature relating to preterm labor has limitations including the definition of an episode of preterm labor, the trial size, the confounding of results because of the use of other interventions, the reporting of preterm birth outcomes in a categorical fashion, and the failure to analyze separately women experiencing medically indicated births.

With respect to biologic markers specifically, we note first that all biologic marker studies conducted to date have been observational. Although observational studies can give insights regarding the sensitivity and specificity of a biologic marker to predict preterm delivery within a certain period of time, they cannot assess whether clinicians and patients can use the additional information provided by biologic markers to improve perinatal outcomes. That hypotheses is best tested in an RCT in which clinicians are given biologic marker results for one set of patients and not for another. To our knowledge, no such study has been conducted. Moreover, masking and generalizability are further issues in the biologic marker research arena.

#### Study-Specific Characteristics of the Biologic Marker Literature

Overall, the study populations in these investigations were not large. Of the 12 fFN articles, 8 had fewer than 100 subjects relevant for our analysis. ^102^ ^104^ ^106^ ^107^ ^109^ ^110^ ^114^ ^115^ Of the two studies that combined fFN and EVUSD, one had a population of 108 ^113^ and the other 76. ^114^ Two studies on EVUSD alone enrolled fewer than 100 women, ^55^ ^111^ another had 162 participants. ^112^

Definitions of preterm labor symptoms were highly variable. If one deems an adequate definition of preterm labor symptoms to include uterine contraction frequency and duration along with cervical dilation status, then only six studies used definitions that can be labeled adequate. ^55^ ^108^ ^110^ ^111^ ^112^ ^113^ Five studies did not definite preterm labor symptoms. ^101^ ^102^ ^106^ ^107^ ^110^ In the largest study, a preterm labor symptom was defined as one that prompts an unscheduled visit to a clinician. ^46^

All but one report failed to control for confounding interventions that may have altered the likelihood of preterm birth in women with preterm labor symptoms. Peaceman, Andrews, Thorp, et al. ^46^ controlled for tocolytic use in two ways: (1) by calculating test performance characteristics in women who did and did not receive a tocolytic and (2) by including a study site that did not use tocolytics as a treatment to prevent preterm delivery.

Assessing the outcomes of interventions in women with preterm labor symptoms categorically (preterm birth: yes or no) as opposed to continuously (mean gestational age at delivery or mean prolongation of pregnancy in days) can make clinically important differences difficult to detect. This blurring phenomenon has been described in detail in other sections.

To avoid such problems, we have advocated survival analysis stratified by gestational age at enrollment as the ideal analytic technique. The largest fFN study, ^46^ a small French report on fFN, ^106^ and one of the combined reports ^113^ used this method of analysis. Three other fFN studies approximated survival analysis by using the categorical outcome of preterm delivery within 7, 14, and 21 days after sample collection, ^105^ ^108^ ^110^ and another evaluated 7- and 14-day intervals. ^46^

Preterm birth is thought by some to be etiologically heterogeneous; that is, medically indicated preterm births in nonlaboring women have different causal pathways than do births arising from preterm labor or premature rupture of membranes. If this concept of etiologic heterogeneity is accurate, then a corollary is that diagnostic tests designed to measure changes indicative of imminent preterm birth in women with preterm labor symptoms should have no predictive value for medically indicated preterm births. However, we do not know that this is true, since, to our knowledge, only Peaceman, Andrews, Thorp, et al. ^46^ have excluded medically indicated births before term.

In an observational study of a diagnostic test, an essential study design element is to mask clinicians (care providers, outcomes assessors) to the test result. Likewise, the ideal design is to ensure that the patients themselves are unaware of their fFN or ultrasound status. Failure to mask clinicians can alter clinician practices based on their biases and, thus, change test performance. We reviewed each study with respect to masking. If the articles states that clinicians caring for study subjects were unaware of the study results, we considered masking to be adequate; conversely, if the articles made no such statement, we judged masking to be inadequate. Three fFN studies, ^105^ ^107^ ^115^ one combined fFN-EVUSD study, ^114^ and one ultrasound study ^55^ had inadequate masking of clinicians.

Information about the number of patients eligible for the study who actually enrolled and completed the study is important because, in absence of such data, the assessment of the quality of the study and its generalizability to the universe of women with symptoms of preterm labor is difficult, if not impossible. Peaceman, Andrews, Thorp, et al. ^46^ and Iams, Casal, McGregor, et al. ^103^ were the only authors that provided information about the number of symptomatic women who were screened for study participation and the number ultimately enrolled. In these two studies, respectively, 52 percent and 46 percent of women screened for participation actually were enrolled and had fFN performed.

Each of the studies except that by Watson, Kim, and Humphrey ^110^ provided test characteristics such as sensitivity, specificity, and positive and negative predictive values of preterm delivery. Although influenced by the prevalence of preterm birth, predictive values, namely positive predictive value (PPV) and negative predictive value (NPV), are the most clinically relevant data. Predictive values answer the critical question: Given a positive or negative test result, what is the likelihood that a woman with symptoms of preterm labor will have a preterm delivery? All but two fFN studies ^102^ ^110^ provided the reader with PPV and NPV. Inglis, Jeremias, Kuno, et al. ^102^ provided sufficient detail to calculate predictive values.

### Results of the Biologic Marker Literature Review

In this section, we summarize test characteristics. Because these biologic markers appear to have clinical utility, at the end of this section we present aggregate information leading to a discussion of how biologic marker information can enhance clinical judgment and decisionmaking. We present graphs (Figures 9 and 10) that relate prior clinical assessment of the probability of preterm birth to probability estimates informed by biologic marker values.

Figure 9. Use of fFN to adjust clinical estimates of risk for preterm birth

Figure 10. Use of EVUSD to adjust clinical estimates of risk for preterm birth

#### fFN Studies

The predictive value of a positive fFN, that is, the proportion of women with a positive test who deliver before term, is moderate at best. (The cutoff point for fFN positivity was identical, i.e., 50 ng/ml in the fFN studies.) In the articles cited in Evidence Table 1, the PPV of predicting delivery within 7 days ranged from 13 percent to 44 percent ^46^ ^103^ ^104^ ^105^ ^108^ (singleton pregnancies only). When the outcome of interest was delivery at less than 37 weeks, the PPV ranged from 31 percent ^107^ to 83 percent. ^109^ In the largest fFN study, Peaceman, Andrews, Thorp, et al. ^46^ reported a PPV of 43 percent for delivery at less than 37 weeks.

In contrast to PPV, the NPV of fFN for identifying those at low risk of preterm birth is good, especially to assess risk of imminent delivery. The NPVs for birth before 37 weeks reported in these studies ranged between 69 and 92 percent ^102^ ^105^ and for birth within 7 days between 98 and 100 percent. ^104^ ^105^

Two studies of fFN ^46^ ^103^ compared the diagnostic accuracy of this biologic marker with that of traditional clinical risk assessment based on cervical dilation, contraction frequency, and vaginal bleeding. In both instances, fFN was superior to clinical assessment.

#### EVUSD Studies

We elected to aggregate the test performance data from EVUSD studies that evaluated comparable outcomes with composite estimates of sensitivity, specificity, PPV, NPV, and likelihood ratios. In the five EVUSD papers, we developed cutoff points for considering ultrasound findings abnormal (in other words, a positive test) from the study data. Timor-Trisch, Boozarjomehri, Masakowski, et al. ^111^ focused on dynamic cervical changes (e.g., wedging or funneling); the other studies relied on cervical length. Performance of sonography, evaluating cervical length using cutoff points of 2.6 and 3.0 cm, ^55^ ^112^ was similar to that of fFN: moderate PPVs of 50 to 55 percent and high NPVs of 76 to 100 percent. ^55^

#### fFN and EVUSD Studies

The two papers that compared fFN with EVUSD used cervical length as a criterion to assign risk. Rizzo, Capponi, Arduini, et al. ^113^ used 20 mm as a cutoff point; Rozenberg, Goffinet, Malagrida, et al. ^114^ used 26 mm. In one combined study, Rizzo, Capponi, Arduini, et al. ^113^ found that fFN testing was superior to sonography in terms of diagnostic performance; Rozenberg, Goffinet, Malagrida, et al. ^114^ found no difference between the two testing modalities. Both studies found that the combined use of fFN and EVUSD improved test performance and that each made independent contributions to the prediction of risk for preterm delivery.

#### Aggregate Performance of fFN and EVUSD

##### Overview

This section presents estimates of sensitivity, specificity, PPV, NPV, and likelihood ratios as a means of clarifying the potential value of these biologic markers in clinical practice. Of the 14 articles evaluating the use of fFN, 12 provided sufficient detail to construct contingency tables describing the relationship between test results and birth before 37 completed weeks' estimated gestational age (see Evidence Table 1). ^46^ ^101^ ^102^ ^103^ ^104^ ^105^ ^106^ ^107^ ^108^ ^109^ ^113^ ^114^ Each study used a cutoff point of greater than or equal to 50 ng/ml for a positive test.

Aggregating across these studies, 1,786 samples from women being evaluated or treated for preterm labor were available for this analysis. In this combined cohort, 488 preterm births occurred, for an overall prevalence of 27 percent. Of the 267 women who delivered before term, 267 had positive test results at their initial evaluation and 221 did not. Of those who delivered at term, 1,111 women had true-negative fFN results and 187 women had false-positive fFN values.

##### Results

Combined, the sensitivity of fFN (i.e., the ability to identify correctly those who delivered before 37 weeks) was 54.7 percent; specificity (i.e., the ability to identify those who delivered after 37 weeks) was 85.6 percent. The PPV (i.e., the probability that a woman with a positive test result would deliver before term) was 58.8 percent. The NPV (i.e., the probability that a woman with a negative test would deliver at term) was 83.4 percent. The likelihood ratio for a positive fFN is 3.8 (95 percent confidence interval [CI]: 3.3, 4.4) and 0.53 (95 percent CI: 0.48, 0.58) for a negative test result. The clinical application of likelihood ratios is reviewed briefly below.

The majority of these studies enrolled women in a 10-week range of gestational ages, meaning some subjects have longer time at risk for preterm birth than others, typically between 24 and 34 weeks. This factor has the effect of reducing sensitivity of testing at a single point in time for predicting birth before 37 weeks. Presumably, some women with an initial negative fFN test will subsequently develop positive tests. In a sense, these women actually do not reflect false-negative values on their initial test; rather, they reflect the time-dependent nature of using biologic markers and their relationship to outcomes.

Limiting the effect of weeks elapsing between fFN is informative about the utility of fFN as a reliable biologic marker. The five publications that examine the more immediate outcome of delivery within a week are instructive on this point. ^46^ ^103^ ^104^ ^105^ ^108^ The aggregate sensitivity of fFN (from these studies) to identify women who delivered in 7 days after testing was 89.4 percent; the specificity was 83.3 percent; the PPV was 22.9 percent; and the NPV was 99.3 percent. For the outcome of birth within 7 days, the likelihood ratio for a positive fFN is 5.3 (95 percent CI: 4.6, 6.2) and 0.13 (95 percent) CI: 0.06, 0.26) for a negative fFN. The high NPV, supported by this combination of results, suggests that fFN conveys an important benefit in terms of identifying women who are not an immediate risk of preterm birth and who may not require intervention.

The EVUSD literature presents special challenges to combining results in this fashion. Continuous predictors, such as cervical measurements, cannot be captured adequately from the level of detail permitted in publications. Appropriately, therefore, authors of the articles we reviewed examined their data and established categories of cervical change or dichotomous cutoff points for examining test characteristics or calculating likelihood ratios. As a result of their statistically driven analyses, the studies show greater inconsistency in the cutoff points used than was true for the fFN articles.

Of the five EVUSD studies in women with signs or symptoms of preterm labor, three evaluated the use of wedging or funneling to determine risk of preterm birth. ^111^ ^112^ ^113^ Combined, these investigators evaluated 314 women, of whom 98 delivered before 37 weeks' gestation. Of those who delivered preterm, 59 had funneling or wedging noted on ultrasound examination; 39 did not have visible funneling. In addition, 23 women had funneling and delivered at term (a total of 23 false-positives), and 171 women had normal ultrasounds and term deliveries. These figures are equivalent to the following rates: sensitivity, 60.2 percent; specificity, 79.2 percent; PPV, 56.7 percent; and NPV, 81.4 percent. The positive likelihood ratio for funneling is 2.8 (95 percent CI: 2.1, 3.9) and 0.50 (0.39, 0.65) for the absence of funneling.

Two studies ^55^ ^112^ used the cervical length of 3 cm or less as a diagnostic cutoff point to assign higher risk of preterm birth. This threshold was associated with the following rates: sensitivity, 88.5 percent; specificity, 59.3 percent; PPV, 49.5 percent; NPV, 92.0 percent; and positive likelihood ratio of 2.2 (95 percent CI: 1.7, 2.7); negative likelihood ratio of 0.19 (0.10, 0.39).

The test characteristics reviewed above are summarized in Table 12. The right portion of the table provides examples of the predictive values of these biologic markers in the studies included in this summary and for a range of hypothetical rates of preterm birth in women presenting with signs and symptoms of preterm labor. As shown in the table, as the proportion of women who gave birth preterm increases, the NPV falls, and the PPV improves. The aggregate predictive values reflect expected performance of the biologic markers in populations similar to that of the study participants with the observed incidence of preterm birth comparable to that summarized in the table.

Table 12. Predictive value of biologic markers in women with symptoms of preterm labor

| Sensitivity | Specificity | Test Characteristics by Incidence of Preterm Birth In Women Presenting for Preterm Labor
| Sensitivity | Specificity | Included Studies | | | Low Risk Example Within 7 Days = 3% Before 37 Weeks = 10% | | Medium Risk Example Within 7 Days = 10% Before 37 Weeks = 25% | | High Risk Example Within 7 Days = 15% Before 37 Weeks = 45%
| Sensitivity | Specificity | Observed Incidence | PPV | NPV | PPV | NPV | PPV | NPV | PPV | NPV
Birth within 7 days
fFN | 89.4 | 83.3 | 5.3 | 22.9 | 99.3 | 14.3 | 99.6 | 37.2 | 98.6 | 48.6 | 97.8
Birth before 37 weeks
fFN | 54.7 | 85.6 | 27.3 | 58.8 | 83.4 | 29.7 | 94.5 | 55.9 | 85.0 | 75.7 | 69.8
EVUSD: Funneling/wedging | 60.2 | 79.2 | 31.2 | 56.7 | 81.4 | 24.3 | 94.7 | 49.0 | 85.6 | 70.4 | 70.9
EVUSD: Cervical length < 3 cm | 88.5 | 59.3 | 31.1 | 49.5 | 92.0 | 19.4 | 97.8 | 42.0 | 93.9 | 64.0 | 86.2

fFv = fetal fibronectin; EVUSD = endovaginal ultrasound; PPV = positive predictive value; NPV = negative predictive value

##### Conclusions

Biologic markers supplement clinical judgment. Based on a patient's obstetric history, her description of current symptoms, and findings from physical examination and monitoring of contractions, care providers estimate the probability of preterm birth. An estimate of high probability results in further testing and/or treatment; an estimate of lower probability leads to continued observation. Thresholds for deciding whether to treat women in preterm labor or to observe them further are highly individualized and often not explicit. For example, physicians with aggressive treatment policies may favor intervention at any time that they believe that a woman has a greater than 10 percent chance that her preterm labor might result in preterm birth and will likely further adjust that judgment based on gestational age. A conservative philosophy might reserve treatment for cases in which the probability estimate of a preterm birth is greater than 30 percent, accepting that time and observation will further clarify the need to treat.

Regardless of where this threshold to treat lies for individual providers, there exists a range of probabilities between an estimated probability at which they "always" treat and an equivalent estimated probability at which they are comfortable sending a patient home with no further evaluation. When this range is relatively wide, the additional diagnostic or prognostic information provided by fFN or EVUSD testing may help the clinician to make a more sound decision.

##### Clinical applications of likelihood ratios

Imagine a provider whose threshold to treat is 20 percent and who would accept a 2 percent risk that the pregnancy would be delivered before term. Faced with a patient who is being evaluated for her second episode of preterm labor at 33 weeks' gestation and who has contractions every 8 minutes, no cervical change, and a history of a prior preterm birth at 36 weeks, the clinician may believe that the woman's current episode has a 10 percent chance of leading to progressive cervical change and delivery. This is within the clinician's range of clinical uncertainty; additional information, such as fFN or EVUSD data, can have direct decisionmaking utility.

The question is how to apply such information easily across a range of patient populations with varied prevalence of preterm birth. Likelihood ratios for categories of test results accomplish this; they can be used to modify the odds of a patient's having a specific outcome such as preterm birth or birth within the next week. Posttest odds are equal to the pretest odds multiplied by the likelihood ratio.

In this hypothetical example, the provider's pretest probability, based on clinical judgment, was 10 percent. This value can be converted to odds using this formula: [image] Pretest odds are 0.11:1 or 1:9.

From the combined analysis of fFN discussed above (with a likelihood ratio of 3.8 percent for birth before 37 weeks), if the woman's fFN test was positive, then her posttest odds would be given by the following equation: Posttest odds = Pretest odds x Likelihood ratio = 0.11 x 3.8 = 0.42

To convert this back to a probability, we use this formula: [image]

In short, with a positive fFN test, a woman's posttest odds are 0.42, which is equivalent to a probability of 30 percent. This is a value within the range of probabilities for which the hypothetical clinician would start treatment. Pocket nomograms are available to ease use of these conversions in clinical settings. ^116^

Figures 9 and 10 remove these intermediate calculations and allow direct inspection of the relationship between a clinician's initial assessment of risk of preterm birth (the X-axis) and the probability after adjustment for evaluation of biologic markers (the Y-axis). If the clinician is certain that a woman will deliver, then both probabilities are near 1.0 (in the upper right-hand corner of the figures), and the biologic marker contributes little. The lower range of clinical assessment of probability (toward the lower left-hand corner) is of greater interest. In this range, biologic markers offer additional information that can aid decisionmaking, prompting treatment or confirming the choice of expectant management.

An alternative approach to using these graphs is to acknowledge that clinical estimates of risk of spontaneous preterm birth for an individual are imprecise, whereas the prevalence of preterm birth from preterm labor in a specified population can be determined with certainty. This prevalence can serve as the prior probability. In this case, the prevalence is located on the X-axis, and the Y-axis reflects the posterior probability, in that population, adjusted for the biologic marker result. Whether interpreted as adjustment of individual risk or risk for a population, these biologic markers offer additional information that refines assessment of the probability that preterm birth will result from an episode of preterm labor.

## Tocolytics

We grouped the tocolytic strategies using two schemes. First, tocolytics were designated as either first-line or maintenance regimens. The former are used to treat acute preterm labor symptoms after the clinician decides that these symptoms are so significant that administration of a tocolytic drug to prevent preterm birth is indicated. Maintenance regimens are used after an episode of acute tocolysis with a first-line regimen. The goal of maintenance tocolysis is prolonged prevention of a preterm birth in a woman who had experienced symptoms of preterm labor.

Second, we divided the tocolytic strategies using two schemes: (1) beta-mimetics, (2) calcium channel blockers, (3) magnesium sulfate, (4) NSAIDs, and (5) a category labeled "other" that includes ethanol and atosiban. Clinicians use drugs within all five of these categories for both first-line and maintenance tocolysis. The evidence tables in correspond to these categories. Evidence Tables 3 through 7 contain first-line tocolytic studies, and Evidence Tables 8 through 11 provide information on maintenance tocolytics. Based on the available research that met our inclusion criteria, the maintenance review includes only beta-mimetics, calcium channel blockers, magnesium sulfate, and NSAIDs. Studies comparing classes of tocolytics are repeated in the evidence tables and the discussion in this chapter within each tocolytic class.

A review of the potential side effects or harms from treatment follows the discussion of the benefits of tocolytic therapy. Results are divided by the drug's mechanisms of action. Owing to time and resource limitations, we were unable to divide the studies further on the basis of whether the drugs were being used for first-line or maintenance treatment.

### Description of the Tocolytic Literature

The reports reviewed about the use of tocolytic drugs in women with preterm labor are a mixture of RCTs, nonrandomized controlled trials, and observational studies, including prospective and retrospective cohort and case series. (See the inclusion/exclusion criteria in Chapter 2, Table 2.) As is common in this literature, RCTs are susceptible to bias when clinicians, patients, or other outcome assessors are not masked to the interventions being studied. They also may be conducted for relatively short periods of time, in narrowly defined patient populations, and in exemplary settings. On the other hand, the observational studies included in this review may lack subjects randomly assigned to control groups and are susceptible to bias from sources other than the intervention being studied. Often, however, observational studies enroll a broader set of patients or are conducted in a wide variety of settings. We believe that in our review of this literature, including both RCTs (efficacy studies) and observational studies (effectiveness studies) of tocolytics provides the most comprehensive and informative picture of the efficacy and effectiveness of these substances in controlling or stopping the symptoms of preterm labor.

### First-Line Tocolytics: Beta-Mimetics

#### Description of the Beta-Mimetic Literature

For first-line tocolysis, beta-mimetics have been the most frequent class of drugs studied (Evidence Table 3). We reviewed 47 studies including 35 RCTs, 4 nonrandomized controlled trials, 3 retrospective cohort studies, and 2 prospective cohort studies. Of these, 15 studies focused on tocolytic treatment with only a beta-mimetic, and 1 study focused on treatment with magnesium sulfate; some studies also included a control group. Other studies compared treatment with a beta-mimetic and a calcium channel blocker (15 studies), magnesium sulfate (10 studies), or an NSAID (5 studies). One final study compared treatment with magnesium sulfate and an NSAID.

More than one-half of the RCTs had definitions of preterm labor that we considered adequate. They included the number of contractions, typically recorded during a specific period of time, and another measure such as level of effacement or dilation. ^117^ ^118^ ^119^ ^120^ ^121^ ^122^ ^123^ ^124^ ^125^ ^126^ ^127^ ^128^ ^129^ ^130^ ^131^ ^132^ ^133^ ^134^ ^135^ Three RCTs had no definition. ^136^ ^137^ ^138^ One of the three nonrandomized trials ^128^ and approximately one-half of the nine observational studies ^139^ ^140^ ^141^ ^142^ ^143^ had an adequate definition. In the studies that included a count of contractions, the number used as an entry criterion varied greatly.

Authors included a definition of successful tocolysis in more than 60 percent of studies, ^117^ ^120^ ^122^ ^125^ ^126^ ^127^ ^128^ ^129^ ^130^ ^131^ ^133^ ^134^ ^137^ ^138^ ^139^ ^140^ ^142^ ^144^ ^145^ ^146^ ^147^ ^148^ ^149^ ^150^ ^151^ ^152^ ^153^ ^154^ ^155^ including approximately one-half of the RCTs. As with the definition of preterm labor, definitions of successful tocolysis varied greatly. The most common definitions were delay of labor for 48 hours, 7 days, and until 34, 35, or 36 weeks' gestation.

The number of subjects included in the studies varied widely; 23 studies enrolled 100 or more women. ^96^ ^117^ ^121^ ^122^ ^123^ ^124^ ^131^ ^132^ ^133^ ^135^ ^136^ ^137^ ^141^ ^143^ ^144^ ^145^ ^149^ ^151^ ^156^ ^157^ ^158^ ^159^ Studies tended to have little or no demographic data. The mother's age was most commonly reported; nine studies also reported the mother's race. ^117^ ^123^ ^124^ ^128^ ^133^ ^138^ ^147^ ^150^ ^154^ Education levels were not reported in any of the studies.

Bias is a concern in this literature. Only six of the RCTs state that the treating physician was masked to which patients received which treatments. ^96^ ^121^ ^129^ ^137^ ^160^ None of the observational studies used regression techniques to control for confounding from factors outside the treatment.

A discussion of patient compliance with the treatment protocol is virtually nonexistent in the studies. If the patient is receiving only inpatient treatments, then compliance is not necessarily a serious concern, as it can be monitored by hospital staff; however, some studies continue treatment after discharge but do not provide information concerning compliance with these medications.

Another potential concern relating to the population of women reflected in the analyses is generally controlled in this literature; only nine studies do not either exclude women with ruptured membranes or use stratified analyses for women with intact membranes relative to ruptured membranes. ^96^ ^125^ ^135^ ^141^ ^146^ ^154^ ^160^ Patient exclusions based on the need for a medically indicated birth were not easily discernible from the literature.

#### Results of the Beta-Mimetic Literature Review

##### Beta-mimetics versus control groups

Merkatz, Peter, and Barden ^136^ reported on the only RCT comparing first-line beta-mimetic treatment with that given a control group that found the estimated gestational age at delivery to be significantly older with treatment. Some patients included in this control group, however, received ethanol treatment. Four other RCTs that compared a beta-mimetic treatment with that given a control group found no significant difference in this outcome. ^121^ ^131^ ^133^ ^151^

Both Merkatz, Peter, and Barden ^136^ and Larsen, Hansen, Hesseldahl, et al. ^121^ found a significant increase in mean prolongation of pregnancy in patients receiving beta-mimetic treatment. Two other authors found greater prolongation in the beta-mimetic group relative to no treatment controls: 1 day or less by Leveno, Klein, Guzick, et al., ^151^ and less than 24 hours and less than 48 hours by the Canadian Preterm Labor Investigators Group. ^96^ Holleboom, Merkus, van Elferen, et al. ^131^ and Guinn, Goepfert, Owen, et al., ^133^ two relatively large studies with, respectively, 201 and 179 women, did not find efficacious results in prolonging pregnancy. Although Merkatz, Peter, and Barden ^136^ also found gestation to be significantly increased to greater than or equal to 36 weeks, gestational weeks were not significantly different in five other RCTs. ^96^ ^121^ ^131^ ^133^ ^151^

Only Merkatz, Peter, and Barden ^136^ reported efficacy of tocolytics for infant outcomes, calculated in relation to a significantly higher birth weight. Other studies found no difference in measures of birth weight; Activity, Pulse, Grimace, Appearance, Respiration (APGAR) score; or neonatal intensive care unit admissions. ^121^ ^131^ ^133^ ^151^

##### Beta-mimetics versus other tocolytics

Other RCTs included in the review compared the efficacy of beta-mimetic treatment with treatment with a different class of tocolytic. With respect to older mean gestational age at birth, Jannet, Abankwa, Guyard, et al. ^134^ and Papatsonis, Van Geijn, Ader, et al. ^159^ found calcium channel blocker treatment, and Eronen, Pesonen, Kurki, et al. ^161^ found NSAID treatment, to be related significantly to older estimated mean gestational age at birth compared with beta-mimetic treatment. For the same outcome measure, Koks, Brolmann, de Kliene, et al. ^135^ and Bracero, Leikin, Kirshenbaum, et al. ^127^ found no significant difference between calcium channel blockers and beta-mimetics, and Kurki, Eronen, Lumme, et al. ^129^ found no difference between NSAIDs and beta-mimetics.

Similarly mixed results were found in RCTs that measured prolongation of pregnancy. Only in comparison to ethanol treatment was a beta-mimetic found to result in a significantly longer prolongation of pregnancy. ^148^ In several studies, beta-mimetics alone were found to result in a significantly shorter prolongation of pregnancy when compared with another class of tocolytic including calcium channel blockers, ^159^ NSAIDs, ^129^ and magnesium sulfate and beta-mimetic combination. ^138^

Other researchers found no significant differences in trials comparing beta-mimetic treatment and other classes of tocolytics using a variety of measures of prolongation, which includes five studies of calcium channel blocker treatment, ^126^ ^127^ ^130^ ^135^ ^153^ two of NSAID treatment, ^119^ ^123^ and two of magnesium sulfate treatment. ^122^ ^150^

Similarly mixed results were shown in observational studies. In no instance did beta-mimetic treatment significantly prolong pregnancy more than an alternative tocolytic. ^128^ ^140^ ^141^ ^142^ ^146^

The most common instant-related outcome in the first-line beta-mimetic RCTs was birth weight. Bracero, Leikin, Kirshenbaum, et al. ^127^ found calcium channel blocker treatment to be related to higher birth weight, but nonstatistically significant differences were not found by Meyer, Randall, Graves, et al., ^126^ Jennet, Abankwa, Guyard, et al., ^134^ Papatsonis, Van Geijn, Ader, et al., ^159^ Koks, Brolmann, de Kleine, et al., ^135^ and Garcia-Valasco, and Gonzalez. ^153^ Two studies concluded that the differences between an NSAID and a beta-mimetic were insignificant; ^123^ ^161^ another found the same insignificant differences between magnesium sulfate and a beta-mimetic. ^150^

### First-Line Tocolytics: Calcium Channel Blockers

#### Description of the Calcium Channel Blocker Literature

All of the 14 calcium channel blocker studies, except one case study, compared a calcium channel blocker with a different class of tocolytic. Of the 11 RCTs included in the review, 9 compared treatment with a calcium channel blocker and a beta-mimetic, which were discussed in the preceding section on beta-mimetics. The remaining two RCTs compared treatment with a calcium channel blocker and magnesium sulfate. ^162^ ^163^ (See Evidence Table 4.)

All calcium channel blocker studies, except for one retrospective cohort analysis, ^155^ included a definition of preterm labor. Nine of the 11 RCTs included a definition that we would consider adequate. ^125^ ^126^ ^127^ ^130^ ^134^ ^135^ ^154^ ^162^ ^163^ In addition, 8 of the 11 RCTs included a definition of successful tocolysis. Definitions vary with length of cessation of symptoms, ranging from 2 hours in the research by Smith and Woodland ^154^ to 36 completed weeks' gestation in Ferguson, Dyson, Schutz, et al. ^125^ and Jannet, Abankwa, Guyard, et al. ^134^

Generally, studies either excluded women at entry who had ruptured membranes or stratified outcome analyses. Exceptions include two RCTs ^135^ ^154^ and two of the three observational studies. ^155^ ^163^ The estimated gestational age at entry was rather broad in the study population. In seven RCTs, it is 20 to 22 weeks at the lower boundary and 34 to 36 weeks at the upper boundary. In the remaining four RCTs, it is 24 to 26 weeks at the lower boundary and 34 to 36 weeks at the upper boundary.

#### Results of the Calcium Channel Blocker Literature Review

Few statistically significant differences were found in outcomes between study arms of the calcium channel blocker studies; all were in relation to beta-mimetic treatment. As discussed in the section of this chapter concerning beta-mimetic study results, Jannet, Abankwa, Guyard, et al. ^134^ in a study with an enrollment of 90 women, an adequate definition of preterm labor, and a definition of successful tocolysis found calcium channel blockers to have greater efficacy than beta-mimetics in terms of mean estimated gestational age at delivery and delivery at term. These researchers did not find significant differences in infant outcomes. Papatsonis, Van Geijn, Ader, et al. ^159^ also reported significant findings in favor of calcium channel blockers compared with beta-mimetic treatment in terms of mean estimated gestational age at birth, mean prolongation of pregnancy, prolongation of pregnancy for specific lengths of time ranging between 24 hours and 2 weeks, and delivery at less than 34 weeks. This study had 185 women at enrollment; it included a definition of preterm labor but no definition of successful tocolysis.

Although lacking statistically significant differences in delivery outcomes, several studies found calcium channel blocker treatment relative to beta-mimetic treatment to be associated with improved infant outcomes. Bracero, Leikin, Kirshbaum, et al. ^127^ found birth weights to be higher and neonatal intensive care unit admissions to be lower; Koks, Brolmann, DeKleine, et al. ^135^ found 1-minute APGAR scores to be higher. The retrospective cohort study comparing these two classes of tocolytics also found birth weight to be significantly higher for the calcium channel blocker group.

Four additional RCTs found no significant differences between any outcome measures comparing calcium channel blocker and beta-mimetic treatment. ^126^ ^130^ ^153^ ^154^ This finding also was true for the two RCTs comparing calcium channel blockers and magnesium sulfate treatment. ^162^ ^163^

### First-Line Tocolytics: Magnesium Sulfate

#### Description of the Magnesium Sulfate Literature

The first-line magnesium sulfate literature (Evidence Table 5) includes nine RCTs and nine observational analyses (one nonrandomized control trial, two prospective studies, and six retrospective studies). As we found in studies of other classes of tocolytic pharmacotherapies, preterm labor typically was defined; one RCT was the exception. ^138^ Successful tocolysis was also defined in most studies in our review with the most common goal being delay of delivery for greater than 48 hours. ^120^ ^122^ ^128^ ^142^ ^150^ ^162^ ^164^ ^165^

Based on the information included in the articles, none of the physicians providing treatment were masked. None of the observational studies included multivariate analyses to control for confounding.

#### Results of the Magnesium Sulfate Literature Review

Three studies compared magnesium treatment to a control group; ^120^ ^124^ ^166^ the later study also included a terbutaline treatment arm. Fox, Albert, McCaul, et al. ^166^ found magnesium treatment to show efficacy in terms of delivery at less than or equal to 48 hours. On the other hand, although both measures of mean estimated gestational age at birth were greater than 36 weeks, the control group showed significantly better outcomes than the magnesium group. No statistically significant differences were shown in any infant outcome measures. Cotton, Strassner, Hill, et al. ^120^ and Cox, Sherman, and Leveno ^124^ found no significant differences in delivery or infant outcomes.

The remaining six RCTs compared magnesium treatment with beta-mimetic treatment, ^122^ ^138^ ^150^ calcium channel blocker therapy, ^162^ and treatment with an NSAID. ^167^ Of the three studies comparing magnesium to a beta-mimetic, one found statistically significant results: Hatjis, Swain, Nelson, et al. ^138^ compared treatment with ritodrine alone with treatment with ritodrine and magnesium sulfate and found the combination therapy to be significantly more likely to prolong pregnancy by 1 week or more. No significant findings were uncovered in relation to an NSAID. ^167^

A nonrandomized control rial conducted by Chau, Gabert, and Miller ^128^ supported the finding of the efficacy of magnesium treatment in relation to beta-mimetic pharmacotherapy. Significant differences were shown in mean prolongation weeks, delivery at term, and mean birth weight. A limitation of this study, however, was that patients who failed in their initial treatment were moved to the other treatment group, thus confounding the results. A retrospective cohort study of 61 women ^152^ combining terbutaline, ritodrine, and magnesium sulfate treatment found that women who were able to persist with treatment relative to those who were forced to stop because of complications were significantly less likely to give birth at less than 36 weeks and their babies had shorter hospital stays. Another retrospective study ^142^ comparing a treatment combining magnesium and a beta-mimetic with only beta-mimetic treatment found no differences in effectiveness.

One small retrospective study of 44 women conducted by Lewis, Grimshaw, Brooks, et al. ^165^ compared the combination of magnesium sulfate and indomethacin, an NSAID, with magnesium alone. They found the combination therapy to be associated with greater mean prolongation days.

### First-Line Tocolytics: Nonsteroidal Anti-Inflammatory Disease Drugs

#### Description of the NSAID Literature

As shown in Evidence Table 6, the literature meeting the inclusion criteria for NSAIDs was small: five RCTs, one nonrandomized controlled trial, one retrospective study, and two case series analyses. The only RCT that did not compare NSAID treatment with beta-mimetic treatment was conducted by Morales and Madhav ^167^ and compared NSAID and magnesium regimens. The nonrandomized trial ^146^ compared ethanol treatment with treatment with a combination of ethanol and an NSAID or treatment with a beta-mimetic. The retrospective cohort study ^165^ compared pharmacotherapy with magnesium, an NSAID, and a beta-mimetic with treatment with magnesium and a beta-mimetic. The two case series reviews ^168^ ^169^ did not include comparison groups. These were almost all small studies; all the investigations reporting statistical comparisons had sample sizes of fewer than 100 subjects.

All three RCTs defined preterm labor, but only Kurki, Eronen, Lumme, et al. ^129^ defined successful tocolysis. Women with ruptured membranes were excluded from these studies. In two of the three RCTs, the physician was masked as to which patients received the intervention treatment. ^118^ ^129^

#### Results of the NSAID Literature Review

Gamissans, Canas, Cararach, et al. ^118^ found treatment with an NSAID and a beta-mimetic relative to a beta-mimetic and a placebo to be related significantly to women being more likely to deliver at 37 or more weeks. Infants born to mothers receiving combination therapy had greater birth weights and higher APGAR scores at 1 minute. Kurki, Eronen, Lumme, et al. ^129^ also found that an NSAID showed efficacy over a beta-mimetic in relation to delaying labor 24 to 48 hours and promoting delivery at greater than or equal to 37 weeks and had fewer maternal side effects. Eronen, Pesonen, Kurki, et al. ^161^ also found the NSAID to provide a superior treatment. In contrast, Morales, Smith, Angel, et al. ^123^ found no difference between indomethacin and ritodrine in relation to prolongation of pregnancy, birth weight, APGAR scores, or neonatal death. It should be noted, however, that patients experiencing serious side effects from indomethacin were given magnesium sulfate.

The retrospective cohort study ^165^ found the combination of magnesium sulfate, an NSAID, and a beta-mimetic to be superior to a combination of magnesium sulfate and a beta-mimetic in mean prolongation days.

### First-Line Tocolytics: Other Agents

#### Description of the Literature on Other Tocolytics

In Evidence Table 7, three RCTs compared therapy with ethanol with treatment with other classes of tocolytics. The two older studies provided insufficient statistical analyses for efficacy comparisons. ^117^ ^144^ The third RCT compared ethanol with a beta-mimetic. ^148^ Two small observational studies explored tocolytic effects of ethanol ^170^ and atosiban. ^171^ Neither study enrolled more than 100 women, excluded preterm births arising from conditions other than preterm labor, or included statistical comparison allowing for conclusions about tocolytic effectiveness.

#### Results of the Other Tocolytic Literature Review

In the only analyzable efficacy study containing statistical analyses, Caritis, Carson, Greebon, et al. ^148^ found beta-mimetic treatment to be superior to ethanol in terms of mean prolongation days and for delaying birth sufficiently to allow for a full course of betamethasone for fetal lung maturation.

### Maintenance Tocolytics: Beta-Mimetics

Thirteen studies explored the benefit of maintenance therapy with a beta-mimetic tocolytic after treatment with a first-line therapy had ended (Evidence Table 8). Eleven of the studies were RCTs. All of the studies included a definition of preterm labor, and all but Brown and Tejani ^172^ had what we consider an adequate definition. None of the studies provided a definition of successful tocolysis. All but two RCTs ^173^ ^174^ excluded women with ruptured membranes at study entry.

Seven of the RCTs compared a treatment group to a control group. ^44^ ^172^ ^175^ ^175^ ^176^ ^177^ ^178^ ^179^ All except three studies masked the treating clinician to the protocol. ^173^ ^175^ ^176^ Most of the RCTs ^44^ ^174^ ^175^ ^176^ ^177^ ^179^ ^180^ ^181^ found no efficacy differences in treatment. In contrast, Brown and Tejani ^172^ in a small study found beta-mimetic treatment to show efficacy in terms of mean prolongation days and infant birth weight. In a more recent and larger study of more than 200 women, Rust, Bofill, Arriola, et al. ^178^ found no differences between groups in delivery outcomes; however, the length of hospital stay for the infant was shorter in the control group than in the group treated with magnesium or terbutaline. This was the only study to include a pill count to evaluate compliance with treatment.

A small observational study ^182^ contained no statistical analysis. Another larger cohort study compared women with and without cervical change ^172^ and found delivery and infant outcomes to be generally superior in women without cervical change. One RCT compared two beta-mimetics, ritodrine and terbutaline and found no difference. ^173^

### Maintenance Tocolytics: Calcium Channel Blockers

Only one study met the criteria for inclusion within the category of maintenance calcium channel blocker therapy (Evidence Table 9). In an RCT, El-Sayed, Holbrook, Gibson, et al. ^183^ compared treatment with two calcium channel blockers, nifedipine and diltiazem. There was no masking in this study and no definition of successful tocolysis, but it did include an adequate definition of preterm labor. They found nifedipine to show efficacy in terms of mean estimated gestational age at delivery and delivery at greater than or equal to 37 weeks, but no significant differences in infant outcomes.

### Maintenance Tocolytics: Magnesium Sulfate

All four maintenance magnesium sulfate studies included in the review (Evidence Table 10) compared magnesium and beta-mimetic treatments. The comparisons were discussed earlier in the maintenance beta-mimetic section.

### Maintenance Tocolytics: Non-Steroidal Anti Inflammatory Disease Drugs

The only study in this category (Evidence Table 11) is an RCT conducted by Bivins, Newman, Fyfe, et al. ^181^ that enrolled fewer than 100 women in a comparison of indomethacin with terbutaline treatment. The research group found no significant differences in efficacy between the two therapies.

### Tocolytic Harms

Owing to the large numbers of categories and the multiple classes of agents assessed in this evidence report, we have chosen to summarize the harms data graphically in the form of "bubble charts." Tables specifying the individual rates of the harms in each study would be unwieldy, so we believe that these figures will convey the information more readily. The articles included in this analysis appear in the tocolytic evidence tables, but we also included additional articles that had not met our inclusion criteria for the benefits analysis.

The graphs give the rates of each of the categories of harm within each class of tocolytic medication: beta-mimetics, calcium channel blockers, NSAIDs, magnesium sulfate, ethanol, and atosiban. Each circle within the graph represents a single study. The size of the circle is proportional to the number of subjects receiving the medication (or placebo) in the study. A study with 100 subjects would have a circle twice as large as a study with 50 subjects, assisting the reader in giving more "weight" to larger studies.

We listed as "harms" clinical markers and events that the authors of the individual studies considered as adverse events or "side effects." In general, these adverse events represent process measures of somewhat unclear significance for the long-term health of the mother and infant. For example, the hypokalemia that is sometimes found after treatment with beta-mimetics may have no clinical consequences but may be associated with increased risk of cardiac arrhythmia. This level of detail generally is not available in this literature. Confidence intervals are generally not provided in the articles, and statistical interpretation is often difficult. Our summary of the literature, by definition, cannot be more detailed than the detail in the studies performed.

We were unable to form synthetic estimates across studies of the rates of treatment harms. The definitions of the clinical categories often were vague or not provided at all in the source articles, which would lead to problems if we assumed that the clinical categories actually were equivalent. Not all categories of medications were represented on every graph. For example, data on "metabolic harms" (e.g., elevated blood glucose, hypokalemia) were collected only for beta-mimetics.

#### Maternal Harms

##### Serious cardiovascular harms

Cardiac side effects, including arrhythmias, heart failure, and chest pain, are well known to occur with the beta-mimetics, and these findings were confirmed by the graph in Figure 11. The estimates varied widely among the studies, and the range in the severity of the "serious harms" was substantial. Some of the variability is likely attributable to the assiduousness with which investigators assessed the cardiac effects of these agents.

Figure 11. Maternal harms - serious cardiovascular

##### Minor cardiovascular harms

The pattern for minor cardiovascular harms was similar to that for the major harms, with higher rates in patients taking the beta-mimetic class of medications (Figure 12). Again, a great deal of variability occurred within categories such as the beta-mimetics. Although these types of events are uncomfortable, they were generally not considered to be of major health consequence.

Figure 12. Maternal harms - minor cardiovascular

##### Maternal metabolic harms

As shown in Figure 13, a definite pattern of increased metabolic abnormality was seen for women who received beta-mimetic agents. The detail in the articles does not allow us to assess the clinical importance of the hyperglycemia, hypokalemia, or other adverse effects; but such abnormalities clearly were very common.

Figure 13. Maternal harms - metabolic

##### Gastrointestinal harms

Many agents, including placebo, are associated with gastrointestinal harms (Figure 14). In the case of placebo, the "harm" is the association of symptoms with the medication when, in fact, they are not caused by the medication. Moderate rates of gastrointestinal harms were found for many of the agents. Interestingly, the few studies examining NSAIDs appeared to show relatively low rates of maternal gastrointestinal effects in this literature when compared with the other agents. This result may be because of the young age of the subjects and the relatively short duration of the NSAID exposure. Overall, there appeared to be little clear relationship among class of medication and gastrointestinal side effects.

Figure 14. Maternal harms - gastrointestinal

##### Maternal psychologic harms

The category of "psychologic" harms encompasses symptoms that are relatively nonspecific (Figure 15). The beta-mimetic studies assessed this category of harms most commonly and found them more frequently when compared with studies of other agents in which it was assessed.

Figure 15. Maternal harms - psychologic

##### Overall maternal results

The overall picture for maternal harms is one of more frequent occurrence of harms in users of beta-mimetic medications, especially for the cardiac, metabolic, and psychologic categories. We note, however, that these harms also were searched for more frequently in studies of these agents.

The articles were often unclear as to whether a single patient could appear more than once within a single category of harm. For example, if a single patient had tachycardia and palpitations, she could be counted in each category. Because we saw both of these effects as belonging to "minor maternal cardiovascular harms," the summary graphs may be subject to a degree of double counting that could bias the study outcome by raising somewhat the estimate of harms. Conversely, the reviewers for this report were impressed that many of the studies did not search adequately for maternal harms associated with tocolytic treatment, which would tend to bias the study outcome by lowering the estimate of the rate of harms.

#### Fetal/Neonatal Harms

##### Ductal constriction/tricuspid regurgitation

As shown in Figure 16, premature constriction of the ductus arteriosis would be expected to be of concern with the anti-inflammatory nonsteroidal class of medications. Two studies addressed this issue, and they did appear to find somewhat increased rates of ductal constriction. The study with the highest rates used routine prepartum echocardiograms specifically to estimate ductal constriction. The study did not address the clinical significance of this ductal constriction.

Figure 16. Fetal/newborn harms - ductal constriction/tricuspid regurgitation

##### Intraventricular hemorrhage

Intraventricular hemorrhage (IVH) is an uncommon but potentially serious neonatal complication, with increased risk among premature infants (Figure 17). No pattern of increased risk appeared for any pharmacologic intervention. The studies with the highest rate of IVH were case series of premature, low-birth-weight infants, in whom one would expect higher rates of IVH in both intervention and placebo groups.

Figure 17. Fetal/newborn harms - IVH

##### Necrotizing enterocolitis

We found little evidence of a difference among the treatment groups in the risk of necrotizing enterocolitis (NEC) (Figure 18). Prior research has shown that indomethacin may be associated with an increased risk of certain neonatal adverse outcomes, including intraventricular hemorrhage and NEC. ^184^ ^185^ Moreover, indomethacin therapy in utero may cause constriction of the ductus arteriosis that may culminate in closure. ^186^ ^187^ The drug is used in neonatology as a medical treatment to close persistently patent ductuses in newborns. Given that all of these complications also are associated with preterm birth, the magnitude of additional risk posed by indomethacin is unclear.

Figure 18. Fetal/newborn harms - NEC

##### Sepsis

Estimates of sepsis in the literature were hindered by definitional problems of "sepsis." Some studies required a positive blood culture, others defined sepsis clinically, still others had categories of "possible sepsis." The study with a category of "possible sepsis" did exhibit the highest rates of this harm. Overall, we found no pattern of differential neonatal harm among these agents (Figure 19).

Figure 19. Fetal/newborn harms - sepsis

##### Tachycardia

The estimation of fetal/neonatal tachycardia is hampered by lack of a consistent definition of tachycardia, which likely contributed to the wide range of estimates. Some studies gave no specific heart rate but rather simply reported a percentage for tachycardia. As shown in Figure 20, not surprisingly the beta-mimetics appear to contribute to higher rates of rapid heart rate.

Figure 20. Fetal harms - tachycardia

##### Overall fetal/neonatal results

The fetal/neonatal harms literature provided little consistent evidence of short-term harms to the infants of women receiving tocolytic agents. Insufficient evidence was available from which to draw conclusions regarding longer term effects of tocolytic medications on the health of children.

The analysis did not address the potential harms associated with the use of multiple classes of tocolytic medications during a single pregnancy. A few studies used such regimens, generating the challenge of differentiating the effects of single agents compared with those of multiple agents. One would expect that the harms associated with the use of multiple agents would be at least as great as those of both agents used alone.

## Antibiotics

Observational studies consistently support the theory that genital tract infections are associated with preterm birth. ^188^ Histologic evidence of acute inflammation is found in up to 50 percent of placentas after delivery before term. ^189^ Up to two-thirds of women who present with preterm labor have positive amniotic fluid cultures, and their fluid harbors an array of organisms. ^190^ These empirical observations have prompted researchers to hypothesize that treating women who present with preterm labor symptoms may prevent preterm birth.

RCTs have been designed and completed to test this hypothesis. The 15 trials and 1 observational study that met the entry criteria are summarized in Evidence Table 12.

### Results of the Antibiotic Review

The articles reviewed consistently report three outcomes: (1) prolongation of pregnancy after enrollment, (2) mean gestational age at delivery, and (3) preterm delivery at a specific cutoff point, usually less than or equal to 37 weeks. Of the 15 RCTs reviewed, two consistently found improvement in all three of these outcome measures, ^191^ ^186^ but five found no improvement in any of the three measures. ^193^ ^194^ ^195^ ^196^ ^197^ Five studies found a significant increase in pregnancy prolongation, ^191^ ^192^ ^198^ ^199^ ^200^ and three studies found a diminution in the number of preterm deliveries. ^192^ ^198^ ^201^

Thus, the results of this research are mixed and definitive statements are hard to make about antibiotic efficacy in gravidas with preterm labor symptoms. This mixture of positive and negative results emphasizes the need for meta-analysis; Chapter 4 discusses the results of the meta-analysis on antibiotics conducted as part of this review.

### Issues and Limitations in the Antibiotic Literature

Of the 15 RCTs reviewed, none used the same definition of symptoms to label a woman as having preterm labor. The array of criteria used included frequency of contractions, intensity of contractions, duration of contraction, and a wide range of measures of cervical dilation. Four trials used particularly broad definitions such as "painful" contractions, ^191^ dilation greater than or equal to 4 cm with no lower limit on contraction frequency, ^201^ contractions less than 10 minutes apart for more than 60 minutes, ^192^ and "preterm labor." ^202^ Lack of a standard, reproducible definition for preterm labor detracts from our ability to compare studies.

Study enrollment was quite varied in these 15 trials. Only one trial had more than 200 subjects (n=277), ^194^ and five trials enrolled fewer than 100 women. ^196^ ^197^ ^200^ ^202^ ^203^ Smaller samples force a reader to look at surrogate outcomes (e.g., pregnancy prolongation or gestational age at delivery) because they lack the power to show statistically that antibiotic therapy improves or worsens perinatal outcome. Moreover, clinically significant findings may not be discernable when statistically insignificant results are reported from studies with small sample sizes. Romero, Mazor, Oyarzun, et al. ^188^ calculated that their multicenter study of antibiotic efficacy, the largest study we reviewed, with 277 participants, had insufficient power to detect a difference in perinatal outcome. These investigators estimated that a sample size of 2,270 subjects would be required to detect a 33 percent reduction in the event rate between the placebo group and the antibiotic group.

Complicating the interpretation of this literature further is the array of cointerventions used in the management of women with symptoms of preterm labor. All but one study used tocolytics, ^197^ and the majority of studies allowed clinicians to prescribe more than one tocolytic. Likewise, the use of corticosteroids and nonpharmacologic interventions (e.g., hydration or bed rest) was ubiquitous throughout these studies. In no instance were regression techniques included to control for the potential confounding that could be caused by the use of these cointerventions and to support the finding that the treatment effect could be attributed to antibiotic therapy.

In lieu of adequate numbers to assess perinatal outcome (which, given the rarity of perinatal death and serious morbidity, would require enrolling thousands of women), survival analysis would be an additional analytic technique for assessment of interventions in women with preterm labor. Despite the advantages of survival analysis, only three trials ^193^ ^194^ ^200^ employed the technique. One of these trials showed a treatment benefit; ^200^ the other two did not. ^193^ ^194^

A certain number of preterm births subsequent to assignment of the diagnosis of preterm labor in women with symptoms of labor will be medically indicated. Thus, treatment trials in women with preterm labor symptoms should exclude medically indicated preterm deliveries from their analysis or report on them separately. To our knowledge, none of these studies took this approach, and their failure to account for the etiologic heterogeneity of preterm birth may result in erroneous conclusions.

No two trials used the same antibiotic regimen. Beta-lactam, cephalosporin, macrolide, and metronidzole antibiotics were given to women with symptoms of preterm labor. Routes of administration and duration of use varied widely from study to study. Thus, there is insufficient consistency to determine whether any conclusions reached in relation to the results shown in this literature would apply to antibiotics in general or to the particularly convincing regimen used in an individual study.

In any study of a pharmaceutical intervention, bias is controlled by recording compliance with treatment in the study population and searching for potential confounding by recording differences in compliance. Our review of these 15 RCTs discloses only two studies that measured compliance. ^194^ ^203^

A limitation of all but two trials is gestational age at enrollment. The prevalence of positive amniotic fluid cultures-a direct measure of in utero infection-and histologic chorioamniotis-an indirect measure-vary inversely with gestational age. ^194^ ^204^ Thus, gravidas at earlier gestational ages are more likely to have infection as an etiology and, in theory, should be more likely to benefit from antibiotic treatment. The converse should be true about women who present with preterm labor symptoms at later gestational ages.

Thus, a relationship between gestational age and prevalence of in utero infection is particularly pertinent in this literature. Evidence Table 12 shows that the studies included women at a wide range of gestational ages, but only two studies had a mean gestational age at enrollment of less than 30 weeks. ^191^ ^201^ The large trial from Romero, Sibai, Caritis, et al. ^194^ enrolled one-half of its subjects at more than 32 weeks; the positive culture rate from amniotic fluid, around 6 percent, was much lower than anticipated. When McGregor, French, and Seo ^199^ stratified their results by gestational age, they saw a benefit of treatment only in women enrolled before 32 weeks.

The final limitation is generalizability of these findings to the universe of women with symptoms of preterm labor. Three studies have dropout rates of greater than 20 percent, ^191^ ^198^ ^203^ and two studies have insufficient data to assess dropout rates. ^194^ ^201^ In addition, only five studies reported the number of women with preterm labor symptoms who were screened to find the enrolled population. ^192^ ^193^ ^194^ ^195^ The rates of study participation range from 13 percent ^194^ to 50 percent. ^199^ Such low enrollment figures may result in participants' being unrepresentative of the population of women with symptoms of preterm labor.

## Home Uterine Activity Monitoring

Four studies of home uterine activity monitoring met the criteria for inclusion in this study. ^205^ ^206^ ^207^ ^208^ All four studies measured deliveries at specific dates as their primary outcomes of interest. Of these four studies, one concluded that home uterine activity monitoring with daily nursing support was effective in reducing preterm deliveries, defined in that study as those before 37 weeks. ^206^ The authors of this study reported that among women experiencing recurrent PTL, 47 percent of patients enrolled in the home uterine activity monitoring group delivered before 37 weeks, compared with 84 percent in the "standard-care" group (p=0.025). The mean gestational age for the group receiving home uterine activity monitoring plus nursing support was 36.1 weeks compared with 33.9 weeks, but that difference was not reported to be significant. Standard care did not include nursing support, so it is unclear whether the home uterine activity monitoring device or the nursing support may have been the mitigating factor in reducing preterm births. Among those patients whose preterm labor recurred, 32 percent of the group receiving standard care experienced failed tocolysis at first recurrence compared with none of the group receiving home uterine activity monitoring plus nursing care (p=0.02). The authors attributed this difference to earlier detection of preterm labor in the home uterine activity monitoring group. Neonatal outcome results are not provided in this study, so it is impossible to review the effects that either of these results had on infant health.

The other three studies we evaluated attempted to equalize non-home uterine activity monitoring interventions (e.g., nursing contact or education) in the monitored and unmonitored groups to isolate the effects of the monitoring device. None of these studies found that monitoring improved outcomes or reduced preterm births. One study compared the use of monitoring (without added nursing contact) to standard care. ^207^ This research team gave the same instructions regarding signs and symptoms of preterm labor and the circumstances under which women should contact a physician, to both study groups. All women were taking terbutaline and had weekly cervical exams. Subjects in the monitoring group monitored themselves for 1 hour per day and transmitted the results to a Tokos Monitor Center perinatal nurse. Any woman experiencing four or more contractions per hour was remonitored immediately and referred to the hospital unless the contractions subsided.

None of the outcomes collected by Nagey, Bailey-Jones, and Herman ^207^ showed any statistically significant difference between the monitored and unmonitored group, including delivery after week 37, delivery after week 34, or delivery after week 32. The risk ratio for preterm delivery for the monitored patients was 1.08 (p=0.79). Eleven women in the monitored group and five in the unmonitored groups experienced a nondelivery readmission, this difference also was insignificant. Differences in cervical examination upon admission (cervical dilation, cervical effacement, and station) were insignificant.

Iams, Johnson, and O'Shaughnessy ^205^ compared self-palpation with home uterine activity monitoring in the presence of equal education and nursing contact. Subjects in both groups called the monitoring center if they noticed symptoms of preterm labor and were asked to palpate or record uterine activity whenever they noted these symptoms or an increase in perceived contraction frequency. Again, no significant differences between the two groups were noted in outcomes (gestational age, delivery less than 36 weeks, delivery less than 36 weeks with recurrent labor, term delivery, and birth weight). The authors suggested that, although the home uterine activity monitoring device per se did not have any effect on outcomes, the relevant part of the home uterine activity monitoring system as a whole may be the nursing contact, which, in this study, was provided to both the treatment and control groups, although the sample size in this study is too small to draw this conclusion with certainty.

Finally, Brown, Britton, et al. ^208^ also compared home uterine activity monitoring to no monitoring in groups of women receiving identical care other than monitoring, including daily perinatal telephone contact by a nurse. All women in this study also received oral terbutaline. Both groups received education that included recognizing the signs and symptoms of preterm labor and instructions on prenatal followup. The monitored patients transmitted a uterine activity monitoring strip to the Tokos Monitor Center twice daily until 37 weeks' gestation or until instructed to discontinue monitoring. This research team found no significant differences in gestational age at delivery, in delivery at specific endpoints (less than 35 weeks, 35 to 37 weeks, greater than 37 weeks), or in neonatal outcomes (birth weight, admissions or days in neonatal intensive care units, or mechanical ventilation). In a logistical regression model predicting delivery at less than 35 weeks, the authors found that only cervical dilation at study entry was significantly predictive. Women with cervical dilation (2 cm at enrollment) had an odds ratio of 4.35 for delivery at less than 35 weeks' gestation compared with women with cervical dilation of less than 2 cm. Readmissions necessitating additional magnesium sulfate treatment did not differ between the groups, nor did the numbers of women with one unscheduled hospital observation lasting less than 24 hours.

Harms of home uterine activity monitoring were not studied in this analysis; however, because home uterine activity monitoring is not invasive, risks of the system are limited to interventions that might be used with it, or that might be used upon identifying an increase in contractions (i.e., tocolysis, corticosteroids). Nagey, Bailey-Jones, and Herman ^207^ studied hospital readmission, which would presumably include additional treatment, and found no significant difference between the two groups. Watson, Welch, Mariona, et al. ^206^ also found no significant difference in the numbers of patients readmitted for recurrent preterm labor.

An important limitation in much of the home uterine activity monitoring literature in general is the mixing of the effects of the device and the accompanying nursing support. As noted earlier, Watson, Welch, Mariona, et al. ^206^ did not separate out these effects, making it difficult to compare their study with others. Iams, Johnson, and O'Shaughnessy ^205^ did not compare home uterine activity monitoring to standard care; rather they specifically were interested in comparing the device to self-palpation. This design would not provide information about whether the system might provide benefit compared with general practice.

Each study used relatively small sample size, although the authors addressed this limitation adequately in their texts. We have attempted to address this issue as well by performing a meta-analysis of the three more comparable studies.

Only Nagey, Bailey-Jones, and Herman ^207^ described how they developed their randomization schedule, so we are unable to comment on the appropriateness or lack thereof of the other studies. None of the studies presented an intent-to-treat analysis, which would have been useful to evaluate fully the likely impact of home uterine activity monitoring in a clinical setting; however, because these results were generally negative, such analysis would simply have magnified that effect.

Although each study reported data for preterm births, data were provided for few maternal and neonatal outcomes. Only Brown, Britton, Brizendine, et al. ^208^ gave information beyond birth weight for neonatal outcomes: They found no significant differences in care provided to infants whose mothers had or had not received home uterine activity monitoring.