# Introduction

## Primary Objectives and Scope

Effective management strategies for identifying and treating preterm labor are required to prevent preterm birth, that is, birth before 37 full weeks of gestation. Preterm labor itself would be of little interest were it not the prelude to early births and their heavy burden of infant mortality and morbidity. Preterm birth is a factor in three-quarters of neonatal mortality and one-half of long-term neurologic impairment in children. ^1^ Table 1 summarizes the importance of preterm birth-and, by extension, management of preterm labor-as a national health concern.

Table 1. Existing Information on Preterm Labor

Area | Facts Identified (Summary)
Incidence and Prevalence | About 11% of pregnant women in the U.S. will experience a spontaneous preterm delivery. ^4^ ^5^ Of those, an estimated 40% will occur following preterm labor. About 7% of all live births will be low birth weight babies (about 6% among white and Hispanic babies, 13% among Black babies). Approximately 4 million babies are born in the U.S. each year. ^1^ ^4^ ^9^
Characteristics and Size of Population | Preterm labor afflicts pregnant women of every socioeconomic class, and ethnic group, and age. Etiologic contributions include cigarette smoking, preeclampsia, incompetent cervix, prior preterm birth, abruptio placentae, occult in utero infections, and possibly stress, anxiety, and depression. ^9^
Practice Setting | Preterm labor can be addressed in clinicians' offices, private and public inpatient and outpatient settings, free-standing birth centers, and patients' homes.
Morbidity and Developmental Milestones | For mothers, the morbidity associated with preterm labor can be related to both physical functioning and emotional stress, as well as potential harms from the side effects of diagnostic testing or use of certain drugs. (Mistaking preterm labor for certain other conditions in which drugs used to treat preterm labor can be contraindicated can create its own set of potential adverse events.) The morbidity for babies born preterm can manifest in many ways. Short-term outcomes for newborns can include acute and chronic lung disease, central nervous system hemorrhage, and blindness. Long-term outcomes can involve cerebral palsy, mental retardation, and learning disability, and other forms of developmental delay. ^11^ ^93^
Mortality | The risk of neonatal mortality inversely is associated with gestational age at birth. Approximately, three-quarters of neonatal deaths can be attributed to preterm birth. ^94^
Quality of Life | More than one-half of neurologic impairments found in children can be attributed to preterm delivery. The quality of life of women in preterm labor can be affected by stress associated with their condition, hospitalization, and need for bed rest. ^11^ ^95^
Loss of Productivity | Employed pregnant women experiencing preterm labor will have reduced economic productivity to the extent that days of bed rest and/or hospitalization are required. Although difficult to measure, individuals with handicaps caused by having been preterm babies experience increased morbidity that may adversely affect their future level of productivity and earning power. ^93^
Costs to Diagnosis and Treat | The costs to treat women in preterm labor include the costs of drugs (such as tocolytics and possibly antibiotics) and hospitalizations. To those may be added the costs of biologic marker tests to make a more precise diagnosis, the costs of diagnosing possible overt or occult infections, and possibly even amniocentesis. In addition, preterm delivery accounts for approximately 35% of all health care spending on infants and 10% of all health care spending for children. ^16^
Other Costs or Burdens | In 1988, for children younger than 15 years of age, costs for health care, education, and child care associated with having been of low birth weight (a result of preterm birth) were estimated to be $5.5 to 6 billion. ^16^
Variations in Practice | No consensus exists regarding the diagnosis or the treatment of preterm labor. Approaches range from essentially "watchful waiting" or traditional "conservative interventions" (e.g., bed rest) to complex diagnostic and therapeutic regimens involving biologic marker tests (diagnosis) and pharmacologic agents (antibiotics, tocolytic drugs and perhaps corticosteroids) and to system-wide (e.g., state or county) programs to detect and manage the condition. ^94^

In theory, early detection and management of preterm labor helps to prevent preterm birth and its potential neonatal sequelae, which include respiratory distress syndrome, sepsis, intraventricular hemorrhage, necrotizing enterocolitis, patent ductus arteriosus, and hyperbilirubinemia; ^2^ however, widespread treatment of women with signs and symptoms of preterm labor has failed to reduce the prevalence of preterm birth in the United States. Rates of preterm births has not changed meaningfully in 20 years, underscoring the need to evaluate the effectiveness of current interventions.

The reasons for the lack of progress remain undefined, although they are related in part to the rise in multiple gestations resulting from the success of assisted reproductive technologies. ^3^ Multifetal pregnancies are at higher risk for preterm birth. From 1981 to 1993, preterm births rose from 9.4 to 11 percent, ^4^ stabilizing at approximately 11 percent through 1997. ^5^ Keys to this failure to see a decline in the prevalence of preterm births may lie in how we identify, evaluate, and treat women with preterm labor.

Lack of uniform criteria for evaluating and diagnosing preterm labor presents special challenges for clinicians and perinatal researchers attempting to draw conclusions from the medical literature. This evidence report focuses in part on documenting the range, complexity, and lack of uniformity of definitions, and how this pattern influences interpretation of the scientific literature on key clinical questions. We revisit the challenge of definition at appropriate transitions throughout this report.

Care providers are anxious for tools that provide objective categorization of risk and assist diagnosis. Candidate biologic markers are numerous and offer the possibility of refining clinical estimates of the probability that a particular woman's uterine activity will continue, cause cervical change, and result in preterm birth. Nonetheless, such testing is costly and controversial. Little existing literature summarizes the utility of biologic markers in the population of women with preterm labor or compares the literature on the clinical diagnostic properties across tests.

Once a diagnosis is made, in contemporary practice, tocolytics (agents intended to stop contractions and maintain uterine quiescence) are the cornerstone of pharmacologic treatment of preterm labor and are often continued as a maintenance treatment to prevent further preterm labor episodes. Arguably, the effectiveness of these agents, as a class, to prolong gestation to term is limited. This report summarizes the literature on the effectiveness of tocolytics for preventing preterm birth. When possible, we explore the benefit expected from use of tocolytic agents with an emphasis not only on traditional dichotomous interpretations of treatment outcome (i.e., full-term versus preterm births) but also measures that take into account increments of time gained. Two factors drive this interest in additional measures: (1) the continuous improvement in infant outcomes found to be correlated with incremental increases in birth weight and gestational age, ^6^ and (2) the proven benefit of giving mothers at risk of a preterm birth corticosteroids to promote fetal lung maturation. ^2^ Therefore, understanding what are the effective, and preferable, means by which to delay preterm birth is also an objective of this work. Equally important is documenting potential harmful maternal and infant effects of treatment with tocolytics and estimating the incidence of serious adverse events.

As occult in utero infection and inflammation increasingly are thought to contribute to the risk of preterm birth, research on the use of antibiotics has proliferated. The literature is replete with studies of antibiotics of many types and doses, by several routes of administration, for differing durations, with and without the use of tocolytics or other cointerventions. This evidence report is an opportunity to consolidate data that may provide insight into the appropriate integration of antibiotics into management.

Preterm labor generally requires initial hospital-based management. The possibility of using technology, such as home uterine activity monitoring, to facilitate safe discharge from inpatient care is attractive for patients, providers, and payers. Home monitoring makes continued frequent surveillance of uterine activity feasible; its status as a management tool, however, remains unclear.

The broad scope, lack of clear clinical management imperatives, and importance of these concerns suggests that the audience for this report will be large and receptive to evidence provided to address the key clinical questions described in detail in the next subsection.

## Key Clinical Questions

Our key clinical questions focus on three important components of managing preterm labor: diagnosis, pharmacotherapy for arresting the condition, and monitoring symptoms. (See Chapter 2 for a more detailed discussion of our key questions.) First, the key questions involve the use of particular diagnostic tests, so-called biologic markers, to enhance clinical accuracy in predicting which women presenting with signs and symptoms of preterm labor are most likely (or least likely) to result in a preterm birth. These biologic markers include fetal fibronectin (fFN), endovaginal ultrasound (EVUSD), and salivary estriol (E3).

Second, we investigate pharmacotherapies for arresting the condition, including tocolytics to stop uterine contractions and antibiotics for treating possible underlying infections. Tocolytic agents will be examined by class and by whether treatment focuses on arresting current symptoms or, following an episode of preterm labor, are used to maintain uterine quiescence.

The majority of the tocolytic literature concentrates on the class of drugs known as beta-mimetics; it also includes calcium channel blockers, magnesium sulfate, and nonsteroidal anti-inflammatory drugs (NSAIDs). In addition, we review the outcomes of treatment with ethanol, a therapy no longer in accepted practice in the United States. In addition to benefits obtained from tocolytic pharmacotherapy, we also explore the harms. In contrast, antibiotics will be discussed as one group, and potential harms will not be examined.

Third, our clinical questions concern the use of home uterine activity monitoring for detecting early symptoms of preterm labor, which is intended to allow the clinician more time to administer therapies intended to stop the progression to preterm delivery or administer pharmacotherapies to aid fetal development.

## Technical Expert Advisory Group

Technical experts in the field of the management of preterm labor were identified to provide assistance throughout the project. The Technical Expert Advisory Group (TEAG) (Appendix A) was expected to contribute to advancing the Agency for Healthcare Research and Quality's (AHRQ's) broader goals of (1) creating and maintaining science partnerships as well as public-private partnerships and (2) meeting the needs of an array of potential customers and users of its products. Thus, it was both an additional resource and a sounding board during the project. The TEAG included eight members: six technical/clinical experts; one representative of organizations whose mission concerns the interests and perspectives of patients and consumers; and one potential user of the final evidence report, specifically, an American College of Obstetricians and Gynecologists (ACOG) representative, the organization originally nominating this topic.

To ensure robust, scientifically relevant work, the TEAG was called on to provide reactions to work in progress and advice on substantive issues or possibly overlooked areas of research. TEAG members participated in conference calls and discussions, periodically through e-mail, to:

- Refine the key clinical questions at the beginning of the project.
- Discuss the preliminary assessment of the literature and to provide input for the data extraction form during the project.
- Select topics and guide approaches for meta-analyses toward the end of the project.

In addition, early in the process, senior staff and TEAG members discussed the challenges of designing a literature search concerning a clinical situation that is as difficult to conceptualize as preterm labor. A particular concern potentially resulting from defining the condition based on its symptoms is that the narrowness or breadth of the criteria for enrolling women with preterm labor in research protocols would influence the outcomes of the treatment under study. For instance, in trials with broad definitions of preterm labor, an unknown fraction of the women might have been inappropriate candidates for the therapies they received because their symptoms would have resolved on their own. We decided to proceed with the literature search and data extraction as outlined in the report on the grounds that, since the authors had defined study participants as experiencing preterm labor, we had no means either to exclude studies in an unbiased way or to "adjust" results post hoc for these problems. This concern is, however, what motivates the authors of this report to advocate for future research to include using biologic markers as a means of increasing clinical confidence that an appropriate diagnosis was made for women included in a study.

Because of their extensive knowledge of the literature on preterm labor and their active involvement in professional societies, TEAG members were also asked to participate in the external peer review of the draft report.

## Background and Significance

### Overview and Burden of Disease

Although preterm labor is the most common cause of antenatal hospitalization, the number of pregnancies in which preterm labor occurs is documented inadequately. Only two studies that specifically address the natural history of preterm labor were identified. In a study designed to determine how warning signs of preterm labor relate to eventual diagnosis of preterm labor and preterm birth, Copper, Goldenberg, Davis, et al. ^7^ followed 329 indigent, high-risk patients. In this small cohort, 27 percent of the participants met the research criteria for diagnosis of preterm labor: "contractions occurring between 20 and 36 weeks' gestation at a rate of four in 20 minutes or eight in 1 hour with at least one of the following: ruptured membranes, cervical change over time, dilatation > 2.0 cm, or cervical length < 1.0 cm." Twelve percent of the cohort had spontaneous preterm births. ^7^ Also, West, Yawn, Thorp, et al. ^8^ found that the cumulative incidence of physician diagnosis of preterm labor during the late 1980s and early 1990s was 3.6 to 6.4 percent in a population-based sample of live births in Olmstead County, Minnesota.

Such prospective enumeration of populations of pregnant women is required to accurately measure incidence, the rate of new diagnoses of preterm labor in pregnant women, and prevalence, the proportion of pregnant women receiving treatment for preterm labor, at a given time. Without a denominator from an identified population at risk for developing preterm labor, the majority of existing studies provide "numerator" data that poorly capture the impact of preterm labor on the health care system or on the lives of pregnant women. Each year at least 200,000 infants are born before term after spontaneous preterm labor, ^5^ ^9^ but the number of other pregnancies in the United States affected by the occurrence of preterm labor that do not result in preterm birth has not been projected accurately.

The incidence and burden of preterm birth is comparatively well understood. Conservatively estimated, 11 percent of all live births, or approximately 440,000 births, occur before term each year in the United States. ^5^ ^9^ Preterm birth is responsible for 70 to 85 percent of fetal, neonatal, and infant deaths ^10^ and is second only to fetal deformity in causing perinatal morbidity. Up to one-half of the total burden of neurologic disability in children, including cerebral palsy, is attributable to prematurity. ^1^ ^11^ This risk of neonatal mortality and morbidity is related directly to gestational age and weight at birth: the more premature the infant, the greater the risk. Infants born before 32 weeks, 2 percent of births, experience the majority of neonatal deaths and congenital neurologic disorders. ^12^ Even late in the preterm period (35 or 36 weeks gestation), when the overall risk of mortality is modest, ^13^ an increased risk of infant mortality, ^14^ respiratory distress syndrome, ^12^ ^13^ and impaired intellectual development ^15^ can still be discerned.

The economic costs of caring for preterm infants are substantial. Total care costs are, on average, tenfold higher for preterm infants than for normal-weight infants born at term. ^16^ Preterm birth accounts for 35 percent of all health care spending on infants and 10 percent of all spending for children. ^16^ The ongoing medical, educational, and special needs of children born at low birth weights, the majority after preterm birth, are estimated to exceed $5 billion each year. ^16^ These costs reflect only the care of infants born before term. Additional personal and health care costs accrue from the evaluation and care of women who experienced preterm labor.

To narrow the focus to spontaneous preterm labor potentially preceding spontaneous preterm birth, we first consider the major routes to preterm birth. Preterm births can be classified as spontaneous or medically indicated. Spontaneous preterm births are preceded by spontaneous preterm labor or preterm premature rupture of membranes, or both. ^17^ ^18^ Medically indicated preterm births follow a decision to allow or cause delivery for maternal or fetal indications. Preeclampsia and presumed fetal growth restriction cause the majority of medically indicated preterm deliveries. ^19^ Spontaneous preterm labor precedes approximately 43 percent of preterm births; preterm premature rupture of membranes, approximately 32 percent; and medical indications for delivery, the remaining 25 percent. ^17^

The subtypes of spontaneous preterm birth, preterm labor, and preterm rupture of membranes share many risk factors. ^20^ ^21^ In fact, 15 to 20 percent of women successfully treated for preterm labor subsequently experience preterm premature rupture of membranes. ^21^ ^22^ Although this interrelationship is clear, the management of these conditions is divergent. This report focuses exclusively on the management of preterm labor.

### The Epidemiology of Preterm Birth

The epidemiologic literature focuses on preterm birth, rather than preterm labor, as an outcome. Because the majority of women presenting for care with preterm labor signs or symptoms do not have the more serious outcome of giving birth prematurely, experts believe that examining the association of factors with spontaneous preterm birth itself (i.e., a "hard" outcome) reduces misclassification bias and yields more precise estimates of the importance of specific maternal characteristics and exposures. Research on determinants of preterm birth have three dominant foci:

- Description of risk factors for individuals and populations to guide prenatal surveillance and intervention programs.
- Identification of behaviors and conditions that are amenable to change or treatment.
- Description of physiologic processes that precede preterm birth and may elucidate etiologic pathways or serve as biologic markers of impending birth.

The last category includes uterine activity, cervical change, and biologic markers such as fFN and E3, which will be reviewed later.

### Risk Factors for Preterm Birth

The first category of risk factors consists predominantly of factors for which the mechanism of risk modification is unknown or difficult to separate definitively from socioeconomic, behavioral, or nutritional factors. Many of these "exposures" are relatively fixed (i.e., not amenable to modification after a woman becomes pregnant). The most robust and consistent factor is uniquely informative: women who have had a prior spontaneous preterm birth have a threefold increase in risk of preterm birth in a subsequent pregnancy compared with women who have had only term deliveries. ^23^ This risk increases with the number of previous preterm births, and the outcome of the most recent pregnancy has the greatest influence. ^24^ Depending on the population, women with a history of preterm birth deliver before term in 15 to 80 percent of subsequent pregnancies. ^23^ Presumably this reflects the constancy of unobserved, underlying factors.

In the United States, black race is a risk factor. Adjusting for known confounders, including income and educational status, being black confers a relative risk of 2.0 to 3.5 of having a preterm baby when compared with being white. ^13^ ^25^ This divergence of risk is most pronounced at the lowest gestational ages (i.e., below 27 weeks). ^26^ The risk of other minorities in the United States is characterized too poorly to generalize.

Additional reported factors associated with increased risk include both very young and advanced maternal age, single marital status, low socioeconomic status, and some of its isolated correlates such as low income, poor access to and quality of care, and limited educational attainment. Poor nutritional status and low pre-pregnancy body weight also are related to increased risk. ^27^ ^28^ These last two examples underscore the overlap between descriptive markers of risk and the possibility that deprivation plays a role in some cases, whereas knowledge and intentional behavior factors, such as nutritional habits, play a role in others.

#### Modifiable Risk Factors

Cigarette smoking is the most "costly" preventable risk from a population perspective. Smoking contributes independently to the risk of prematurity and to decreased birth weight. Adjusting for other factors, smokers are 40 to 70 percent more likely than nonsmokers to deliver before 37 weeks gestation. ^29^ ^30^ ^31^ Other potentially remediable risks include cocaine use, poor diet, and fasting. ^32^ ^33^ Alcohol and marijuana use appear to be unrelated to spontaneous preterm birth risk. Data on the effects of stress, caffeine consumption, and physical exertion conflict.

Like behaviors, infections are risk factors that also can be modified before the window of risk for preterm labor. Alterations in vaginal flora are associated with increased risk of preterm birth. One of numerous possible infections is bacterial vaginosis (BV), a disruption of normal vaginal flora characterized by a superabundance of Gardnerella vaginalis , mixed anaerobes, and/or genital mycoplasmas. Its presence during pregnancy is associated with a 1.5- to 4.0-fold increased risk of preterm birth ^34^ ^35^ ^36^ ^37^ ^38^ ^39^ and approximately twice the likelihood of preterm labor. ^37^ ^38^ ^40^ ^41^ Black women are more likely than white women to have BV, ^36^ ^39^ ^42^ ^43^ a finding that might help to explain the higher rate of preterm births in black women. Research regarding both pregnant and nonpregnant women has suggested that BV in the lower genital tract is associated with increased risk of infection in the upper genital tract; the latter may be one mechanism by which infection incites inflammation, uterine contractions, and subsequent preterm labor. Urinary tract infection also has been linked variably to increased risk. ^20^

Aggressive screening and treatment for genital and urinary tract infections have varied effectiveness for reducing preterm births; some studies demonstrate decreased rates and others fail to find benefit. ^20^ The physiologic mechanisms that may link infection, inflammation, and preterm labor are addressed in a subsequent discussion concerning the rationale for antibiotic use in the management of preterm labor.

#### Evaluation of Risk

Although the etiologic pathways to preterm birth are uncharted, substantial heterogeneity exists in the factors that contribute to the likelihood that any individual woman will experience preterm labor or deliver before term as a result of preterm labor. Conflicting results of studies assessing risk factors for preterm birth should not be viewed as irreconcilable. The distribution of fixed and modifiable risk factors in selected populations of pregnant women is sure to vary. As a result, synergy among risk factors-for instance, race and smoking and diet, or age and multiple gestation and socioeconomic status-also will vary. It is precisely the many permutations of risk factors and the complexity of their interactions that have thwarted efforts to use this knowledge in care settings to identify women at risk of preterm labor and spontaneous preterm birth.

With rare exceptions, risk scoring systems are empirically derived from what we know about the fixed and modifiable risks described above. Despite statistical refinements, they are neither sufficiently sensitive nor specific to guide care. The most successful tool, developed by Creasy, Golbud, Laros, et al. ^44^ had a sensitivity of 64 percent and specificity of 90 percent, with a positive predictive value of 30 percent when evaluated in a general obstetric population for prediction of preterm birth.

More than one-half of spontaneous preterm births occur in women with no apparent risk factors. ^45^ The limited utility of predictive tools, therefore, is less an indictment of the literature than it is a reflection of the lack of a gold standard, other than preterm birth, against which to measure the usefulness of prediction tools.

## Clinical Management of Preterm Labor

### Problems in the Diagnosis of Preterm Labor

Labor at term occurs when uterine contractions lead to progressive cervical dilation and effacement. By extension, the hallmarks of preterm labor are uterine activity and cervical change; however, uniformly accepted standards for defining preterm labor do not exist. Therefore, diagnosis of preterm labor invokes an essential circularity: this patient has the kind of uterine activity that may lead to preterm birth if not treated. Thus, intervention precludes definitive diagnosis. As a surrogate, operational definitions of preterm labor seek to quantify how many contractions over what period of time are occurring (e.g., more than four contractions in 20 minutes or five to eight contractions in 1 hour) they also often require documentation of change in dilation or effacement of the cervix.

In practice, clinicians weigh many highly individual factors not captured in formal definitions: Are the contractions painful? Does the mother recognize the contractions? Does she report other symptoms of labor such as back pain, pelvic pressure, vaginal bleeding, or vaginal discharge? What is her individual risk profile? Has she had prior preterm births? Are other processes at work that may be provoking uterine activity, such as a urinary tract infection, substance use, or placental compromise, including abruption (premature separation of the placenta)?

Once other explanations are excluded, two factors drive intervention for preterm labor: (1) estimates of the probability of progressive labor and (2) the degree of immaturity of the fetus. Higher probability and younger gestational age may lead to intervention based on less strict criteria than would otherwise be used. For example, allowing a mother at 28 weeks' gestation to continue to contract with the goal of documenting cervical change simply to meet diagnostic criteria is problematic at best. Because (in theory) achieving uterine quiescence is easier earlier in the cascade of labor events, early intervention is believed to be desirable.

Symptoms, including regular contractions before term, are common; hence, their presence is not highly predictive for discerning who will have progressive cervical change or go on to have a preterm delivery. In a study of 763 women who made unscheduled visits for symptoms suggestive of preterm labor, only 18 percent delivered before 37 weeks; moreover, only 3 percent delivered within the next 2 weeks. ^46^ Early detection of symptoms ^47^ ^48^ ^49^ ^50^ ^51^ and actual measurement of uterine contractions with home monitors ^49^ ^50^ ^51^ ^52^ have failed to lower preterm delivery rates.

These findings suggest that women with contractions and symptoms that will lead to preterm birth are indistinguishable from the larger group who has incidental uterine activity, making it difficult to target surveillance and treatment efficiently. As the studies presented in the evidence tables show, the great majority of women diagnosed with preterm labor will not deliver before term.

### Physiology of Preterm Labor

The cervical changes caused by labor (either term or preterm) reflect the culmination of a complex set of molecular changes in cervical connective tissue clinically known as "ripening" or "softening." ^53^ ^54^ Although the sequence of events leading to cervical change, especially the triggers, is less clear for preterm labor than for term labor, the basic physiology is considered to be similar. The uterine wall consists primarily of smooth muscle or myometrium. Contractions result from shortening of the muscle fibers provoked by a stimulus, such as oxytocin or prostaglandins. At the cellular level, regulated release of intracellular calcium is required to set in motion the cascade that allows myosin and actin filaments within the muscle cell to generate force by shortening. To convert from the irregular, disorganized contractions common throughout pregnancy to coordinated contractions, the cells in the uterus create new channels called gap junctions to facilitate the flow of calcium and other intercellular signals. This process results in contractions in which the upper segment of the uterus provides downward expulsive force, pressing the presenting part of the infant against the cervix.

In addition to the mechanical force of uterine contractions, structural changes take place in the cervical tissue itself. White blood cells infiltrate the cervix and release various enzymes (proteases, collagenases, and elastases) that weaken the collagen and protein matrix of the cervix. This weakening allows the stretching and distortion of the cervix required for dilation and effacement.

Many types of stimuli may contribute to the initiation and perpetuation of contractions and to recruitment of inflammatory factors required for cervical change, which potentially provides multiple potential points for therapeutic intervention. In the discussion of management, we review how biologic markers can be used to detect important physiologic changes associated with preterm labor, the mechanism of action for each category of pharmacologic agents, potential harms associated with the use of tocolytics, and the rationale for use of home uterine activity monitoring.

### Treatment Mechanisms

Clinicians frequently use a combination of treatments in caring for women with preterm labor. As noted earlier, the chief focus of this report centers on tocolytics and antibiotics. We do not review combinations of treatment that might be employed because the number of different combinations of pharmaceutical and nonpharmaceutical interventions is very large. In addition, frequent cointerventions that are not reviewed specifically in this report are bed rest and hydration.

### Biologic Markers to Assess Risk in Women with Preterm Labor Symptoms

Over the past decade, two biologic markers-fFN in cervicovaginal secretions and EVUSD of the cervix have been investigated extensively. When used as tests to assess women with symptoms of preterm labor, these biologic markers have been shown to increase the precision by which clinicians can assess the likelihood of preterm birth. Our third marker, E3, has not been evaluated in a study restricted to women in preterm labor.

The value of these biologic markers lies in their ability to add predictive value (either positive or negative) to the clinician's diagnostic abilities. In other words, their purpose is to predict more accurately which patients presenting with signs and symptoms of preterm labor are likely to deliver prematurely. If biologic markers have strong positive predictive value, a positive test would indicate which women are more likely to deliver. The converse is equally valuable: if biologic markers have strong negative predictive value, a negative test predicts which women are likely not to progress to delivery and, thereby, enable women and their clinicians to avoid unnecessary treatment.

In clinical practice, when any of the three biologic markers is used in a group of women with preterm labor symptoms to predict the likelihood of spontaneous preterm birth, fFN, ^46^ ^51^ EVUSD, ^55^ ^56^ and E3 ^40^ demonstrate moderate positive predictive value (20 to 40 percent) and good negative predictive value (85 to 95 percent). In logistic regression models, the presence or absence of these biologic markers explains significantly more of the variability in preterm birth in women with preterm labor symptoms than do traditional clinical assessment tools, such as cervical dilation by digital assessment or uterine contraction frequency.

#### Fetal Fibronectin

The fFN is a glycoprotein with high molecular weight that is expressed only during fetal life and oncogenesis. This molecule serves an adhesive function, helping to anchor the placenta to the uterine lining. With either labor or intrauterine infection, ^57^ fFN is released into the lower genital tract (cervix and vagina). Putative release mechanisms include placental shearing, cytokine-induced overproduction by the decidua, and occult leakage of amniotic fluid. The presence of fFN in the cervix or vagina precedes the onset of both term and preterm births. ^46^ The fetal isoform of fibronectin can be detected in lower genital secretions using a specific monoclonal antibody and enzyme-linked assay techniques.

#### Endovaginal Ultrasound

Before the development of ultrasound transducers that could be inserted vaginally, the cervix in women with preterm labor symptoms was assessed by either digital examination or transabdominal ultrasound. The former technique is less precise and subject to intraobserver variation; however, it is sufficient to clinically categorize degree of risk. ^58^ The latter technique is limited by the abdominal wall and the symphisis pubis. EVUSD provides reliable and reproducible views of the cervix that are easily obtained. The rationale for use rests on the ability to see and measure changes in cervical dimensions that may be associated with cervical ripening and/or the prior influence of contractile activity.

Prospective studies in women with preterm labor symptoms have demonstrated that EVUSD assessment of cervical length (distance between internal and external cervical openings) and dilation of the internal os (labeled dynamic change, beaking, funneling) is superior to digital assessment in assigning risk of preterm birth in women with preterm labor symptoms. ^59^

#### Salivary Estriol

The placenta in humans produces corticotropin-releasing hormone (CRH), and CRH levels gradually increase with gestational age. Unlike the pituitary-adrenal axis, in which cortisol has a negative feedback effect on CRH production, cortisol exerts positive feedback increasing placental CRH production. Placenta production of CRH increases dramatically just before both term and preterm labor.

CRH produced in the placenta enters both the maternal and fetal circulatory systems. ^60^ In the fetus, CRH induces the production of steroid precursors in the adrenal gland that are further synthesized by the fetal liver and placenta, culminating in the production of E3. The E3 freely enters the maternal circulatory system after it is synthesized by the fetus. Thus, maternal E3 is a byproduct of placental CRH production. A surge in maternal E3 blood levels occurs before labor.

Researchers have assessed the materno-placental-fetal CRH axis indirectly by measuring E3 in maternal saliva to predict preterm delivery risk in women at increased risk of preterm labor. ^61^ Relevant to this report, studies assessing its utility in symptomatic women were not identified.

### Mechanisms of Tocolytic Drugs

Tocolytic drugs decrease the uterine muscle's ability to contract; the goal is to diminish the force and frequency of contractions and preferably bring them to a halt. Many agents have been used, including ethanol, magnesium sulfate, calcium channel blockers, oxytocin antagonists, NSAIDs, and beta-mimetic agonists. Tocolytics can be administered in two ways: (1) those used at initial presentation grouped under the rubric "first-line therapy", and (2) those given to maintain uterine quiescence after first-line tocolysis are labeled "maintenance therapy." The same classes of drugs are used in both therapeutic approaches, although parenteral administration predominates in first-line treatment and oral administration is the delivery route of choice for maintenance therapy.

#### Beta-Mimetic Agents

Two types of beta receptors are described in humans. ^62^ Beta-one receptors predominate in the heart and adipose tissue, whereas beta-two receptors are localized in the smooth muscle of the uterus, blood vessels, and bronchioles. Beta-mimetics, also called beta-adrenergic agonists, bind to beta receptors in these cells, activating the enzyme adenylate cyclase and causing an increase in intracellular cyclic adenosine monophosphate (cAMP). ^63^ Increases in cAMP initiates reduction in intracellular calcium and reduces the ability of the myosin-actin interactions to generate contractile force. ^64^ Thus, interactions between beta-mimetics and the beta-two receptor can inhibit uterine muscle activity.

Unfortunately, molecules with absolute selectivity for beta-two receptors have not been discovered, and even agonists with some degree of beta-two selectivity interact with beta-one receptors. This interaction explains the characteristic pattern of cardiovascular side effects (hypotension, tachycardia, arrhythmia, heart failure) and metabolic side effects (hyperglycemia, hypokalemia) seen in clinical attempts to block beta-two receptors and achieve tocolysis. ^65^ Beta-mimetic drugs include ritodrine, terbutaline, isoxuprine, salbutamol, fenoterol, hexoprenaline, and nylidrin.

#### Calcium Channel Blockers

Calcium channel blockers prevent the entry of calcium into smooth muscle cells, which occurs by two mechanisms: (1) blockage of calcium channels ^66^ and (2) suppression of calcium release from the intracellular stores. ^67^ The end result is smooth muscle relaxation, including the muscular activity of the uterus. This smooth muscle relaxation is nonspecific and can lead to peripheral vasodilation with hypotension. Calcium channel blockers used for tocolysis include nifedipine, nicardipine, and verapamil.

#### Magnesium Sulfate

Magnesium is a bivalent cation, as is calcium. Magnesium exerts its muscle-relaxing properties by competing with calcium rather than by interacting with receptors. The primary site for this competition is the intracellular stores within the sarcoplasmic reticulum. ^68^ At sufficiently high levels, magnesium displaces some of the calcium molecules that would otherwise have been held in store to drive actin and myosin interaction. Because magnesium cannot play the same role as calcium in facilitating contraction, a relative local shortage of calcium within intracellular stores lengthens the time required between contractions to repolarize the contractile units thereby decreasing the force of contractions. Serum magnesium concentrations of 4 to 8 mEq/L, which are roughly 2 to 4 times normal physiologic values, inhibit uterine activity in humans. ^69^

#### Nonsteroidal Anti-Inflammatory Drugs

NSAIDs inhibit production of prostaglandins, which are potent uterine muscle stimulants at and before term. ^70^ Because prostaglandins enhance uterine contractility, inhibition of prostaglandin formation depresses uterine activity. ^71^ ^72^ ^73^ Examples of NSAIDs used for tocolysis include aspirin, indomethacin, naproxen, ketorlac, and ibuprofen.

#### Oxytocin Antagonists

Oxytocin is a pituitary hormone thought to be critical in human parturition. ^74^ Its physiologic role is to stimulate uterine contractility. Uterine muscle has specific cell membrane receptors for the molecule. ^75^ Antagonists have been synthesized by altering the eight-amino-acid sequence of oxytocin.

Atosiban is a selective oxytocin antagonist molecule that binds to the uterine receptors in place of oxytocin. Because it does not initiate the cascade of events that lead to contractions and it blocks oxytocin from binding by occupying its place on the receptors, atosiban is capable of inhibiting uterine contractions in women with preterm labor. ^76^ ^77^ ^78^

#### Alcohol

Alcohol was the first tocolytic agent used for prevention of preterm birth in women with signs and symptoms of preterm labor. ^79^ It inhibits uterine contractility by diminishing secretion of two neurohypopheseal hormones: antidiuretic hormone and oxytocin. ^80^ Ethanol reduces the pulsatile excretion of oxytocin from the pituitary seen in normal labor, thereby causing a tocolytic effect. ^81^ Although alcohol is no longer used in the management of preterm labor, we mention it here primarily for historical comparison.

#### Harms of Tocolytics

The examination of the efficacy and effectiveness of treatments for any condition must be balanced against the harms caused by that treatment; in this case, the harms associated with tocolytic treatment. Such ill effects of treatments may be described by a number of terms, such as side effects, harms, untoward events, and adverse events. For ease of description, we will refer to them as "harms."

Every treatment has harms associated with its use. The harm may be associated directly with the therapeutic effect of the agent, as in myelosuppression related to the effect of chemotherapeutic agents. Harms may also relate to the effects of medications on organ systems distant from the target organ intended for the therapeutic effect, such as the gastric toxicity of NSAIDs. Finally, idiosyncratic reactions may occur, such as serious allergic reactions.

The level of harmful effect considered tolerable in the literature is variable. The tolerance level for harms may be somewhat greater if the condition under treatment is very severe or has a poor prognosis, if the harms are very transient and of little consequence other than patient inconvenience, or if the effect size of the efficacy of the treatment under consideration is very great.

The identification of harms in the medical literature is hindered by several issues, as follows:

- The description of the efficacy of the treatment is often much more detailed and complete than the description of harms.
- Attention is often not paid to the detailed issues of assessment of harms. Variables often are described poorly, making comparison of rates of harms among studies difficult. For example, articles may describe a side effect of beta-mimetic agents as "arrhythmia." No detail is given as to the definition of arrhythmia, which technically may include disturbances such as sinus tachycardia, supraventricular tachycardias, and more serious disturbances such as atrial fibrillation and the potentially lethal ventricular tachycardia. Combining these various cardiac disturbances under "arrhythmia" may lose a great deal of information.
- Serious adverse events may be rare, but important. Most randomized controlled trials (RCTs) in the treatment of preterm labor have fewer than 100 subjects in the treatment group. Low frequency but serious adverse events with rates of 1 percent or less may not be detected at all in a trial of this size, or they may be ascribed to chance alone.
- Followup of children born to women who have received therapy with tocolytic agents generally lasts only until the end of the child's hospitalization. No information is available on issues such as late cognitive development. Such issues could be resolved only by conducting very large RCTs with a long followup period, because children whose mothers have undergone premature labor may have been born prematurely with low birth weight, placing them at risk for adverse developmental outcomes. Developmental diseases may be subtle or appear long after delivery. In utero exposure to diethylstilbestrol is a classic example of such.
- Controversy also exists concerning the potential benefits and harms that might affect the central nervous system of a neonate exposed in utero to magnesium sulfate. Observational studies suggest two important, yet contradictory, findings: (1) Magnesium has been found to have a neuroprotective effect in the development of cerebral palsy, ^82^ a potentially serious morbidity associated with preterm birth; (2) conversely, researchers have found that magnesium may increase the risk of perinatal death. ^83^ Given the disparity of findings and the dual roles of magnesium as a tocolytic and antiseizure medicine in preeclampsia, these differences can be resolved only through large RCTs.

Of the management tools for preterm labor, tocolytics carry the greatest potential for minor and serious side effects. The minor side effects are common; beta-mimetics are potent cardiovascular stimulants associated with disconcerting, but generally benign, signs and symptoms, including tachycardia, palpitations, or chest tightness. In rare instances, beta-mimetic cardiovascular stimulation can cause serious complications such as maternal myocardial ischemia or fetal cardiac effects. They also have metabolic effects including increasing glucose availability and decreasing potassium levels in the blood.

Magnesium when given per strict protocol to women with normal urine output has a wide margin of safety. Its side effect profile is medically minor, but it may cause significant maternal distress side effects, including lethargy, drowsiness, double vision, nausea, and vomiting. Beta-mimetics, magnesium, and calcium channel blockers are all associated with increased risk of pulmonary edema, a serious and potentially lethal maternal complication. NSAIDs have the fewest maternal risks; fetal effects include diminished production of urine with oligohydramnios and premature closure of the ductus arteriosis. These effects usually are transient, but cases of sustained diminished renal capacity and pulmonary hypertension have been reported. Calcium channel blockers as a single agent are thought to have a good safety profile for both mother and fetus. Concomitant use of calcium channel blockers with magnesium sulfate, which some describe as a "primitive" calcium channel blocker, is potentially harmful and has resulted in cardiovascular collapse.

The oxytocin antagonist atosiban, at least within the context of clinical trials, has minimal side effects. Clinicians could not distinguish atosiban from placebo. This cannot be said of other tocolytics because their characteristic side effect profiles are unmaskable for the knowledgeable clinician.

In addressing harms, the report seeks to describe and, when possible, estimate the types and frequency of major and minor harms associated with each class of tocolytics. Such information coupled with estimates of the efficacy of the agents will improve the ability to manage preterm labor in a way that maximizes benefit and minimizes risk.

### Mechanisms of Antibiotics for Treatment of Preterm Labor

Women who present with preterm labor symptoms often have occult infections of their upper genital tract that can be detected by amniocentesis and subsequent culture of their amniotic fluid. ^84^ ^85^ Women in the group who have occult infections are more likely to experience preterm birth than women without evidence of infection. ^84^ This association of infections of the upper genital tract and preterm birth in women with preterm labor symptoms provides the rationale for using antibiotics in the management of women with preterm labor. Antibiotic administration may cure occult infections, thereby lowering the risk of spontaneous preterm birth. ^84^

Organisms cultured from the amniotic fluid or placental-decidual interface of women who give birth before term include enteric gram negatives, gram-positive cocci, anaerobic cocci, and mycoplasma species-a mix of genital flora. Given the variety of potential pathogenic organisms, clinicians have empirically chosen broad spectrum antibiotics in an attempt to eradicate these organisms from the upper genital tract in women with preterm labor. Antibiotics used include second- and third-generation cephalosporins, beta-lactam antibiotics with beta-lactamase inhibitors, synthetic penicillins, metronidazole, and combinations of agents such as "triple coverage" (beta-lactam antibiotics, aminoglycoside, and clindamycin).

It is important to distinguish between antibiotics intended to treat occult in utero infection and those intended to prevent early-onset group B streptococcal sepsis in newborns. Preterm infants are particularly susceptible to acquiring group B streptococcal infections at birth from their mothers whose vaginas may be colonized with this organism and may be developing sepsis. The goal of early-onset sepsis prevention can be readily accomplished with single-agent beta-lactam antibiotic treatment during labor.

### Home Uterine Activity Monitoring

The goal of home uterine activity monitoring is to detect early labor symptoms in women deemed to be at high risk of preterm delivery, with the assumption that early detection provides an opportunity for successful treatment. Thus, home monitoring proponents do not claim that monitoring in and of itself can prevent preterm birth, but rather that the technology helps clinicians target preventive therapies earlier for women with preterm labor symptoms who are at risk of preterm birth and who may not recognize their early symptoms. This report focuses exclusively on the use of this technology in the management of women who have been diagnosed with preterm labor and released home for monitoring, generally after some treatment.

Home uterine activity monitoring uses a tocodynamometer to record uterine contractions in conjunction with daily telephone calls from a health care provider, usually a nurse, to offer patient support and advice. ^86^ ^87^ The biologic hypothesis underlying the use of the device is that women will have an identifiable increase in uterine contractions before preterm delivery (i.e., a "crescendo" effect in contractions) and that many women are unable to recognize this prodromal uterine activity. ^88^ ^89^ The premise on which the usefulness of home uterine activity monitoring rests is that by detecting early contractions, health care providers can treat preterm labor and prevent or decrease the likelihood of preterm birth. ^87^

Patients attach the external tocodynamometer over the uterus twice each day for 30 to 60 minutes while they are recumbent. ^90^ Digitized tracings from the tocodynamometer are transmitted over telephone lines for immediate interpretation by a health care provider. The Food and Drug Administration (FDA) has approved a portable tocodynamometer for use in the homes of women with high-risk pregnancies, whose fetuses are of more than 24 weeks' gestation, and who have a history of preterm birth. ^91^ The device has been shown to record uterine contractions with precision in both hospitalized and ambulatory gravidas. ^92^

## Organization of this Report

The remainder of this evidence report is organized in the following sections. Chapter 2 provides details about the literature search and review methodology. Specifically included are the causal pathways for our key clinical questions; our approaches to conducting the systematic review, abstracting data from articles, maintaining quality control, and applying a quality rating system for individual articles and similar details. In addition, we comment briefly on the external peer review process. Chapter 3 provides our results on the four main topics covered by this report: biologic markers, tocolytics, antibiotics, and home uterine activity monitoring. Results of our supplemental meta-analysis concerning tocolytics, antibiotics, and home uterine activity monitoring are found in Chapter 4. Chapter 5 provides conclusions, and Chapter 6 offers recommendations for a research agenda on management of preterm labor.

The references cited in the body of the report follow Chapter 6. The complete list of literature considered and used in developing the evidence report appears in the bibliography. Appendix A includes acknowledgments, information on the TEAG, and the peer reviewers for this report. The data extraction forms appear in Appendix B, and a list of acronyms and abbreviations is in Appendix C. The Evidence Tables are contained in their entirety in Volume 2 of this report.