# Appendix C. Acronyms and Abbreviations

ACOG: American College of Obstetricians and Gynecologists

add.: additional

AHRQ: Agency for Healthcare Research and Quality

AoT: aim of treatment

APGAR: Activity, Pulse, Grimace, Appearance, Respiration

assoc: association

BP: blood pressure

bpm: beats per minute

BV: bacterial vaginosis

C: clinician reviewer

cAMP: cyclic adenosine monophosphate

CI: confidence interval

corr: correlation, correlated with

CoT: commencement of treatment

CRH: corticotropin-releasing hormone

Cx: control group

dk: don't know, not stated in article

DoT: duration of treatment

E3: salivary estriol

ECG: electrocardiogram

EGA: estimated gestational age

EVUSD: endovaginal ultrasound

FDA: Food and Drug Administration

fFN: fetal fibronectin

HEED: Health Economic Evaluations Database

HMD: hyaline memebrane disease

HUAM: home uterine activity monitoring

IUGR: intrauterine growth retardation

IV: intravenous

IVH: intraventricular hemorrhage

M: methods reviewer

mcg, µg: microgram

MeSH: Medical Subject Headings

NEC: necrotising enterocoitis

NICHHD: National Institute of Child Health and Human Development

NICU: neonatal intensive care unit

NLM: National Library of Medicine

NPV: negative predictive value

NRDS: neonatal respiratory distress syndrome

NS: not significant

NSAID: nonsteroidal anti-inflammatory disease drugs

OR: odds ratio

path: pathologist

pd: time period

PDA: patent ductus arteriosus

pharm: pharmacist

PPV: positive predictive value

PROM: premature rupture of membrane

prov: providers

PTL: preterm labor

PVC: premature vehicular contraction

Q: quartile

RCT: randomized controlled trial

Rh: blood group type

ROC: receiver-operator characteristic curve

RR: risk ratio

RTI-UNC EPC: Research Triangle Institute-University of North Carolina Evidence-based Practice Center

SD: standard deviation

SEM: standard error of the mean

sens: sensitivity

SGA: small for gestational age

sig: significant

spec: s1pecificity

SVT: suproventricular tachycardia

TEAG: Technical Expert Advisory Group

TVUSD: transvaginal ultrasound

tx: treatment group

UTI: urinary tract infection

wk(s): week(s)

wkly: weekly