# Appendix B. Extraction Forms

## Article Identification, Eligibility Screen & Abstract:BIOMARKERS FOR PRETERM LABOR

Initials of Reviewer __ __ __ Date__ __/__ __ (Mo/Day) Unique Article Identifier __ __ __

### Screen

(If any response is "No" then STOP. If any response is "Can't Tell," bring to the attention of the Research Coordinator.

Preterm labor, preterm birth or time to delivery an outcome? | [image] Yes | [image] No | [image] Can't Tell
40 or more subjects at completion? | [image] Yes | [image] No | [image] Can't Tell
Population of women with signs/symptoms of PTL? | [image] Yes | [image] No | [image] Can't Tell

### Abstract

(Note that numeric values in many instances need to be preceded by <, > , < or >.)

1. Main Objectives (described by author, typically in the introduction). _____________________________________________________________________________ _____________________________________________________________________________

2. Study Design. (Record as stated by the author. Typically found in the abstract, end of the introduction or beginning of the methods section. If you think the author has misstated the study design, record the discrepancy in the comments section.)

[image] Diagnostic;
[image] Randomized controlled trial
[image] Non-randomized controlled trial
[image] Prospective cohort study
[image] Retrospective cohort study
[image] Case-control study
[image] Cross-over study
[image] Case series
[image] Cross-sectional survey
[image] Cost-benefit/cost-effectiveness study
[image] Other (describe in space to right) _________________________________

3. Subanalysis. Are there any subgroup or stratified analyses in this article?

[image] Yes [image] No

4. Country in which study was conducted: ______________________________ STUDY POPULATION

5. Inclusion Criteria

[image] Gestational age: __________ to __________ completed weeks
[image] Intact membranes
[image] Fetal weight estimate: __________
[image] Maternal age: __________ (lower limit) __________ (upper limit)
[image] Singleton gestation
[image] Multiple gestation
[image] Signs and symptoms of active labor
[image] High risk of preterm labor/delivery
If yes, how was "high risk" defined? _____________________________________________________
_________________________________________________________________________________
[image] Other: ______________________________

6. Exclusion Criteria

[image] Abnormal fetus | [image] Maternal age __________ (upper limit)
| [image] Maternal age __________ (lower limit)
[image] Antibiotic therapy, current or recent | [image] Maternal fever/Pyrexia: T _____
[image] Cerclage/Need for cerclage | [image] Maternal White Blood Cells (WBC) _____
[image] Chorioamnionitis | [image] Multiple gestation
[image] Chronic disease | [image]No prior prenatal care
[image] Current bleeding/hemorrhage | [image]Placenta previa
[image] Current illegal substance abuse | [image] Rupture of membranes
[image] Dilation __________cm | [image] Singleton gestation
[image] Fetal distress | [image] Uterine anomaly
[image] Failure to give informed consent | [image] Other maternal/fetal indication for delivery
[image] Group B Strep (GBS) Positive | [image] Other Positive Cultures ( ______________ )
[image] Hypertensive disorders (incl. Pre-eclampsia) | [image] Signs/Symptoms of labor
[image] High risk of preterm delivery
[image] If yes, how was "high risk" defined? ________________________________________________
_____________________________________________________________________________
[image] Other: ________________________________________________________________________
[image] Other: ________________________________________________________________________
[image] Other: ________________________________________________________________________
[image] Other: ________________________________________________________________________

7. Gestational age assignment. (Circle either and/or as appropriate.)

[image] Not determined/not measured/can't tell
[image] Last Menstrual Period (LMP)
[image] And/or clinical sizing, including serial fundal heights
[image] And/or ultrasound When was ultrasound conducted? _________________________________

8. Population Size:

Screened __________ [image] Cannot Determine
Eligible __________ [image] Cannot Determine
Enrolled __________ [image] Cannot Determine
Completed __________ [image] Cannot Determine
Included in analysis __________ [image] Cannot Determine

8a. Reasons for exclusion from analysis:

[image] Loss to follow-up (n= )
[image] Other ____________________ (n= )
[image] Other ____________________ (n= )
[image] Other ____________________ (n= )
[image] Other ____________________ (n= )

9. MASKING LEVEL

Were treating physicians masked to the results of the diagnostic tests? | Yes | No | Can't Tell
Were patients masked to the results of the diagnostic tests? | Yes | No | Can't Tell

## Definition of Diagnostic Test

10. What screening test or tests was/were used?

10a. How are the test result groups compared in the analysis defined (e.g., positive fFN test; positive fFN test + some cervical length)?

Group A: _____________________________________________________________________
Group B: _____________________________________________________________________
Group C: _____________________________________________________________________
Group D: _____________________________________________________________________

11. Diagnostic testing

11a. Diagnostic Test 1 When initiated: Frequency Performed: Did the result of the test influence the frequency with which it was subsequently performed? Yes No Can't Tell

Diagnostic Test 2 When initiated: Frequency Performed: Did the result of the test influence the frequency with which it was subsequently performed? Yes No Can't Tell

12. If cervical length was measured, how was it measured?

13. Was wedging or funneling or breaking considered?

14. How were they defined? Wedging: ________________________________________________ Funneling: _______________________________________________ Breaking: ________________________________________________

15. Non-Pharmaceutical Co-Interventions.

15a. Under what circumstances were non-pharmaceutical co-interventions administered?

15b. Which ones were used?

[image] Bedrest | [image] Routine Observation
[image] Fetal Monitoring | [image] Uterine Monitoring
[image] IV Fluids
[image] Other:______________________________________________________________________________

15c. Were non-pharmaceutical co-interventions administered in both the test positive and test negative group? Yes No If not, in which group were they administered? ___________________________________

16. Pharmaceutical Co-Interventions.

16a. Under what circumstances were co-interventions administered?

16b. What pharmaceutical co-interventions were administered? tocolysis specify drug _______________ antibiotics specify drug _______________ other _______________________

16c. Were pharmaceutical co-interventions administered in the same fashion in the test positive and test negative groups? Yes No

17. What evaluations other than the test being studied (i.e., fFN or E3) were performed? a. Periodic pelvic examination _____ frequency specify by speculum or digital cervical evaluation __________________ b. Periodic ultrasound _____ frequency c. Cultures for infection d. HUAM _____ frequency e. Others _____________ _____ frequency _____________ _____ frequency

18. Participant Characteristics. (Record as number and/or percent as presented in article. Follow percent with %.)

| Group A | Group B | Group C | Group D | Total
Age (±SD)
Race:
White
Black
Hispanic
Other
High School Grads
Married
Gravidity
Parity

19. OUTCOME MEASURES.

19a. Definition of Preterm Labor. (Record each definition separately. Provide the letters corresponding to each symptom. Fill in any necessary data describing a particular symptom.) [image] Can't tell Def. 1: ____________________ Def. 2: ____________________ Def. 3: ____________________ a. Contractions: __________/__________ b. History of contractions c. Dilation: __________ cm d. Change in dilation from baseline e. Effacement: __________% f. Cervical change g. Length of cervix: __________ cm h. Contractions unresolved with: __________ i. Other: ______________________________ j. Other: ______________________________

19b. Rates of outcomes Specify mean or median. Numeric values may be preceded by <, >, <, or >. Record as number and/or percent as presented in article. Follow percent with "%". In the last column, if a difference between the groups is statistically significant, record the relevant p value. If it is not significant, state, "n.s." If statistical adjustments were performed (i.e., stratified analyses or multivariate modeling) report the adjusted results, the strata, and any variable used for adjustment in #.

Outcome | Group A (N = ) | Group B (N = ) | Group C (N = ) | Group D (N= ) | Sig. Level
DELIVERY
Mean/Median Est. Gestational Age (EGA) at Delivery (SD)
Time to delivery
Occurrence of Contractions
PTL Only Group
Delivered at: __________ weeks
Delivered at: __________ weeks
Delivered at: __________ weeks
Delivered at: __________ weeks
Combined PPROM + PTL
Delivered at: __________ weeks
Delivered at: __________ weeks
Delivered at: __________ weeks
Delivered at: __________ weeks
Delivery at Term
MATERNAL OUTCOMES
Maternal Length of Stay (SD)
Chorioamnionitis
Endometritis/Post-partum febrile morbidity
INFANT OUTCOMES
Mean/Median Birthweight (SD)
_____ gms
_____ gms
_____ gms
Apgar ______ at ______ min
Apgar ______ at ______ min
Mean/Neonatal Hospital Days
Mean/Median Neonatal Deaths
Fetal Mortality
Neonatal Respiratory Distress Syndrome (NRDS), Hyaline Membrane Disease (HMD)
Bronchio Pulmonary Dysplasia (BPD)
Intraventricular Hemorrhage
Neonatal Sepsis
Necrotizing Enterocolitis
Neonatal Morbidity
Pneumonia
Neonatal Infection
OTHER

20. Sensitvity/Specificity Analysis for Test ____________ for Outcome: _________________________ NOTE: You may use as many of these pages as is necessary to capture the information provided by test/outcome. The table below is designed to capture rates associated with a given test and outcome by the groups into which participants were divided for analysis (i.e., those defined in question 11). If results are provided for different outcomes, use a different page for each outcome.

| Overall | Group A: ( ) Numeric Value CI | Group B: ( ) Numeric Value CI | Group C: ( ) Numeric Value CI | Group D: ( ) Numeric Value CI
Sensitivity
Specificity
Positive Predictive Value
Negative Predictive Value
Likelihood Ratio (positive/negative)
Odds Ratio or Relative Risk

20b. Were these results based on one-time testing or repeated testing?

20c. Numbers provided for sensitivity/specificity calculations: Overall:

| Had Outcome | Did not have outcome
Test positive
Test negative

Group A:

| Had Outcome | Did not have outcome
Test positive
Test negative

Group B:

| Had Outcome | Did not have outcome
Test positive
Test negative

Group C:

| Had Outcome | Did not have outcome
Test positive
Test negative

Group D:

| Had Outcome | Did not have outcome
Test positive
Test negative

21. Were ROC curves presented? [image] Yes [image] No If so, on what page? _____

22. Describe any multivariate analysis performed. Include statistical technique, model description, and result highlights.

23. Was cost data collected? [image] Yes [image] No

24. Was information on harms collected? [image] Yes [image] No

25. Describe any additional analyses and/or subgroup analyses:

26. Limitations. (Distinguish between limitations stated by the author and those found by the reviewer.) a) State limitations noted by the author. b) State any other limitations you found in the article.

27. Conclusions: [image] Test effective at predicting the following outcome: _________________________________________ _________________________________________________________________________________ [image] Test effective at predicting relevant outcomes in the following subgroup(s) _________________________________________________________________________________ _________________________________________________________________________________

28. Comments. (Provide any additional information that you believe needs to be captured concerning this study.)

## Article Identification, Eligibility Screen & Abstract: TOCOLYTIC USE FOR PRETERM LABOR

Initials of Reviewer __ __ __ Date __ __/__ __ Unique Article Identifier __ __ __

### SCREEN

(If any response is "No" then STOP. If any response is "Can't Tell," bring to the attention of the Research Coordinator.

Preterm birth an outcome | [image] Yes | [image] No | [image] Can't Tell
40 or more subjects at completion? | [image] Yes | [image] No | [image] Can't Tell
Intervention used as part of treating subjects with signs/symptoms of preterm labor (not a preventive intervention used among asymptomatic patients) | [image] Yes | [image] No | [image] Can't Tell

### ABSTRACT

(Note that numeric values in many instances need to be preceded by <, >, < or >.)

1. Main Objectives (described by author, typically in the introduction). _____________________________________________________________________________ _____________________________________________________________________________ _____________________________________________________________________________

2. Study Design. (Record as stated by the author. Typically found in the abstract, end of the introduction or beginning of the methods section. If you think the author has misstated the study design, record the discrepancy in the comments section.)

[image] Randomized controlled trial
[image] Non-randomized controlled trial
[image] Prospective cohort study
[image] Retrospective cohort study
[image] Case-control study
[image] Cross-over study
[image] Case series
[image] Cross-sectional survey
[image] Cost-benefit/cost-effectiveness study
[image] Other (describe in space to right) _________________________________

3. PPROM. Are women with preterm premature rupture of membrane included in this analysis as an entry criteria? Yes No

4. Subanalysis. Are there any subgroup analyses in this article? Yes No

5. Country in which study was conducted: ______________________________

6. Definition of Preterm Labor. (Record each definition separately. Provide the letters corresponding to each symptom. Fill in any necessary data describing a particular symptom.) Can't tell Def. 1: ____________________ Def. 2: ____________________ Def. 3: ____________________ c. Bio-marker(s) used (list: ______________________________) d. Contractions: __________/__________ e. History of contractions f. Dilation: __________ cm g. Change in dilation from baseline h. Effacement: __________% i. Cervical change j. Length of cervix: __________ cm k. Contractions unresolved with: __________ l. Other: ______________________________ m. Other: ______________________________

7. Inclusion Criteria (Record criteria other than was stated within definition of preterm labor) Gestational age: __________ to __________ completed weeks Intact membranes Fetal weight estimate: __________ Maternal age: __________ (lower limit) __________ (upper limit) Singleton gestation Other: ______________________________ Other: ______________________________

8. Exclusion Criteria

[image] Abnormal fetus | [image] Maternal age __________ (upper limit)
[image] Allergy to protocol drug | [image] Maternal age __________ (lower limit)
[image] Antibiotic therapy, current or recent | [image] Maternal fever/Pyrexia: T _____
[image] Cerclage/Need for cerclage | [image] Maternal White Blood Cells (WBC) _____
[image] Chorioamnionitis | [image] Multiple gestation
[image] Chronic disease | [image] No prior prenatal care
[image] Current bleeding/hemorrhage | [image] Placenta previa
[image] Current illegal substance abuse | [image] Rupture of membranes
[image] Dilation __________cm | [image] Singleton gestation
[image] Fetal distress | [image] Uterine anomaly
[image] Failure to give informed consent | [image] Other maternal/fetal indication for delivery
[image] Group B Strep (GBS) Positive | [image] Other Positive Cultures ( ______________ )
[image] Hypertensive disorders (incl. Pre-eclampsia)
[image] Other: ________________________________________________________________________
[image] Other: ________________________________________________________________________
[image] Other: ________________________________________________________________________
[image] Other: ________________________________________________________________________

9. Gestational age assignment. (Circle either and/or as appropriate.) Not determined/not measured/can't tell Last Menstrual Period (LMP) And/or clinical sizing, including serial fundal heights And/or ultrasound When was ultrasound conducted? _________________________________

10. Population Size: Screened __________ Cannot Determine Eligible __________ Cannot Determine Enrolled __________ Cannot Determine Completed __________ Cannot Determine

11. MASKING LEVEL

Subject masked to treatment assignment | [image] Yes | [image] No | [image] Can't Tell
Treating physician(s) masked to treatment assignment | [image] Yes | [image] No | [image] Can't Tell
Other direct care providers masked to treatment assignment | [image] Yes | [image] No | [image] Can't Tell | [image] N/A
Pharmacist masked to treatment assignment | [image] Yes | [image] No | [image] Can't Tell | [image] N/A
Pathologist masked to treatment assignment | [image] Yes | [image] No | [image] Can't Tell | [image] N/A

12. Costs and cost effectiveness. Is any cost information included in this study? Yes No

13. Participant Characteristics. (Record as number and/or percent as presented in article. Follow percent with %.)

| Treatment Group A | Treatment Group B | Comparison Group | Total
Age (±SD)
Race:
White
Black
Hispanic
Other
High School Grads
Married

14. Dominant Mechanisms(s) of Loss. (Provide the reason for discontinuation and if available, the number of patients). [image] None lost [image] Can't tell [image] Loss to follow-up __________ [image] Side effects of treatment __________ [image] Other: _________________________________________ [image] Other: _________________________________________ [image] Other: _________________________________________

15. Timing of intervention: [image] Within _____ hrs of evaluation/admission [image] Other: ____________________________ [image] Cannot tell

16. Intervention Compliance Assessment. (State what action(s) was taken to ensure that subject completed treatment.) [image] None reported [image] Mechanism: ______________________________

17. Intention to treat analysis provided? [image] Yes, list exclusions below and if available, number of subjects. [image] No [image] Developed allergy or did not tolerate intervention drug: __________ [image] Positive cultures - urine: __________ [image] Positive cultures - group B strep: __________ [image] Positive cultures - amniotic fluid: __________ [image] Positive cultures - other cervico-vaginal: __________ [image] Did not comply with protocol for use of intervention drug: __________ [image] Did not comply with follow-up: __________ [image] Other: _____________________________________________ [image] Other: _____________________________________________ [image] Other: _____________________________________________ Were exclusions from analysis after Treatment Assignment? [image] Yes [image] No [image] Can't Tell

18. Care Setting(s). List all settings where treatment was provided. [image] Hospital [image] Perinatal center [image] Home [image] Other: _______________________________ [image] Other: _______________________________

19. Were harms or side effects of treatment included in the study?[image] Yes, [image] _____ page # (s) [image] No

20. Is successful tocolysis defined? [image] Yes [image] No If yes, define: __________________________________________________________________________ 21. Definition of Treatment and Comparison Groups. How are the groups defined? Treatment Group A: _____________________________________________________________________ Treatment Group B: _____________________________________________________________________ Comparison Group: _____________________________________________________________________

22. TOCOLYTIC DRUG REGIMEN BY GROUPS (If treatment includes a separate loading and maintenance dose of the same drug, i.e., the route and/or duration of treatment changes, list these as different drugs.)

| Treatment Group A | Treatment Group B | Comparison Group
Number of Subjects per group | N = | N = | N =
DRUG 1
Dose
Route
Commencement of Treatment
Duration of Treatment
DRUG 2
Dose
Route
Commencement of Treatment
Duration of Treatment
DRUG 3
Dose
Route
Commencement of Treatment
Duration of Treatment
DRUG 4
Dose
Route
Commencement of Treatment
Duration of Treatment

23. Non-Pharmaceutical Co-Interventions. Did comparison group receive co-interventions? [image] Yes [image] No

[image] Bedrest | [image] Routine Observation
[image] Fetal Monitoring | [image] Uterine Monitoring
[image] IV Fluids
[image] Other: ______________________________________________________________________________

24. CO-INTERVENTION DRUG REGIMEN BY GROUPS

| Treatment Group A | Treatment Group B | Comparison Group
Number of Subjects per group | N = | N = | N =
DRUG 1
Dose
Route
Aim of Treatment
Commencement of Treatment
Duration of Treatment
DRUG 2
Dose
Route
Aim of Treatment
Commencement of Treatment
Duration of Treatment
DRUG 3
Dose
Route
Aim of Treatment
Commencement of Treatment
Duration of Treatment
DRUG 4
Dose
Route
Aim of Treatment
Commencement of Treatment
Duration of Treatment

25a). OUTCOME MEASURES. Specify mean or median. Numeric values may be preceded by <, >, <, or >. Record as number and/or percent as presented in article. Follow percent with "%". In the last column, if a difference between the groups is statistically significant, record the relevant p value. If it is not significant, state, "n.s." If statistical adjustments were performed (i.e., stratified analyses or multivariate modeling) report the adjusted results, the strata, and any variable used for adjustment in #24.

Outcome | Intervention Group A (N = ) | Intervention Group B (N = ) | Comparison Group (N = ) | Sig. Level
DELIVERY
Mean/Median Est. Gestation Age (EGA) at Delivery (SD)
Mean/Median Prolongation (SD) Days
PTL Only Group
Delivered at: __________ weeks
Delivered at: __________ weeks
Delivered at: __________ weeks
Delivered at: __________ weeks
Combined PPROM + PTL
Delivered at: __________ weeks
Delivered at: __________ weeks
Delivered at: __________ weeks
Delivered at: __________ weeks
Delivery at Term
PROM OR PPROM Outcome
MATERNAL OUTCOMES
Maternal Length of Stay (SD)
Chorioamnionitis
Endometritis/Post-partum
Adverse Drug Reactions
INFANT OUTCOMES
Mean/Median Birthweight (SD)
_____ gms
_____ gms
_____ gms
Apgar ______ at ______ min
Apgar ______ at ______ min
Mean/Neonatal Hospital Days
Mean/MedianNeonatal Deaths
Fetal Mortality
Neonatal Respiratory Distress Syndrome (NRDS), Hyaline Membrane Disease (HMD)
Bronchio Pulmonary Dysplasia (BPD)
Intraventricular Hemorrhage
Neonatal Sepsis
Necrotizing Enterocolitis
Neonatal Morbidity
Pneumonia
Neonatal Infection
OTHER

26. Describe any additional analyses and/or subgroup analyses:

27. Limitations. (Distinguish between limitations stated by the author and those found by the reviewer.)

28. Conclusions: [image] Intervention ineffective in altering outcomes detailed above. [image] Intervention effectively alters the following outcomes: ______________________________________ ________________________________________________________________________________ [image] Intervention effectively alters the following outcomes in the following subgroup(s) ________________________________________________________________________________ ________________________________________________________________________________

29. Comments. (Provide any additional information that you believe needs to be captured concerning this study.) Unique Article Identifier: Study Type: Sample Size:

[image] | Maternal Harms | Treatment Grp1 | Treatment Grp2 | Control Grp
| Death
| Heart Failure
| Arrhythmia
| Abnormal glucose tolerance
| Elevated liver functions/hepatitis
| Renal failure
| Headache
| Tremor
| Hypotension
| Skin rash
| Stress, emotional distress or other mental health issues
| Discontinuations due to side effects
| Other:
| Other:
| Other
| Death
| Intraventricular hemorrhage
| Necrotizing enterocolitis
| Ductal constriction
| Bardycardia
| Cerebral Palsy
| Other neurologic effects
| Other:
| Other:
| Other:
| Other:
* Statistical significance: if nonsignificant note NS, otherwise provide p number.

Method of Ascertaining Harms: Interviewer-administered side-effect checklist Self-administered side-effect checklist Open-ended question asked at each visit Investigator observed at each visit Spontaneous reporting by patient Not otherwise specified

## Article Identification, Eligibility Screen & Abstract:HOME UTERINE ACTIVITY MOINTORING

Initials of Reviewer __ __ __ Date __ __/__ __ (Mo/Day) Unique Article Identifier __ __ __

### SCREEN

(If any response is "No" then STOP. If any response is "Can't Tell," bring to the attention of the Research Coordinator.

Preterm birth an outcome | [image] Yes | [image]No | [image] Can't Tell
40 or more subjects at completion? | [image] Yes | [image] No | [image] Can't Tell
Intervention used as part of managing subjects with signs/symptoms of preterm labor or who have been treated for preterm labor (not a preventive intervention used among asymptomatic patients)? | [image] Yes | [image] No | [image] Can't Tell
Study design RCT? | [image] Yes | [image] No | [image] Can't Tell

### ABSTRACT

(Note that numeric values in many instances need to be preceded by <, > , < or >.) 25. Main Objectives (described by author, typically in the introduction). _____________________________________________________________________________ _____________________________________________________________________________ _____________________________________________________________________________

2. Study Design. (Record as stated by the author. Typically found in the abstract, end of the introduction or beginning of the methods section. If you think the author has misstated the study design, record the discrepancy in the comments section.) Randomized controlled trial Non-randomized controlled trial Prospective cohort study Retrospective cohort study Case-control study Cross-over study Case series Cross-sectional survey Cost-benefit/cost-effectiveness study Other (describe in space to right) _________________________________

3. Country in which study was conducted: ______________________________

4. Definition of Preterm Labor. (Record each definition separately. Provide the letters corresponding to each symptom. Fill in any necessary data describing a particular symptom.) Can't tell Def. 1: ____________________ Def. 2: ____________________ Def. 3: ____________________ n. Bio-marker(s) used (list: ______________________________) o. Contractions: __________/__________ p. History of contractions q. Dilation: __________ cm r. Change in dilation from baseline s. Effacement: __________% t. Cervical change u. Length of cervix: __________ cm v. Contractions unresolved with: __________ w. Other: ______________________________ x. Other: ______________________________

5. Inclusion Criteria (Record criteria other than was stated within definition of preterm labor) Gestational age: __________ to __________ completed weeks Intact membranes Fetal weight estimate: __________ Maternal age: __________ (lower limit) __________ (upper limit) Singleton gestation Signs and symptoms of preterm labor in the current pregnancy Treatment for preterm labor in the current pregnancy Other: ______________________________ Other: ______________________________

6. Exclusion Criteria

[image] Abnormal fetus | [image] Maternal age __________ (upper limit)
[image] Allergy to protocol drug | [image] Maternal age __________ (lower limit)
[image] Antibiotic therapy, current or recent | [image] Maternal fever/Pyrexia: T _____
[image] Cerclage/Need for cerclage | [image] Maternal White Blood Cells (WBC) _____
[image] Chorioamnionitis | [image] Multiple gestation
[image] Chronic disease | [image] No prior prenatal care
[image] Current bleeding/hemorrhage Placenta previa | [image] Current illegal substance abuse Rupture of membranes
[image] Dilation __________cm | [image] Singleton gestation
[image] Fetal distress | [image] Uterine anomaly
[image] Failure to give informed consent | [image] Other maternal/fetal indication for delivery
[image] Group B Strep (GBS) | [image]Positive Other Positive Cultures ( ______________ )
[image] Hypertensive disorders (incl. Pre-eclampsia)
[image] Other: ________________________________________________________________________
[image] Other: ________________________________________________________________________
[image] Other: ________________________________________________________________________
[image] Other: ________________________________________________________________________

7. Gestational age assignment. (Circle either and/or as appropriate.) Not determined/not measured/can't tell Last Menstrual Period (LMP) And/or clinical sizing, including serial fundal heights And/or ultrasound When was ultrasound conducted? _________________________________

8. Population Size: Screened__________ Cannot Determine Eligible__________ Cannot Determine Enrolled__________ Cannot Determine Completed__________ Cannot Determine

9. MASKING LEVEL

Subject masked to intervention assignment | [image] Yes | [image] No | [image] Can't Tell
Treating physician(s) masked to intervention assignment | [image] Yes | [image] No | [image] Can't Tell
Other direct care providers masked to intervention assignment | [image] Yes | [image] No | [image] Can't Tell | [image] N/A
Pharmacist masked to intervention assignment | [image] Yes | [image] No | [image] Can't Tell | [image] N/A
Pathologist masked to intervention assignment | [image] Yes | [image] No | [image] Can't Tell | [image] N/A

10. Definition of Treatment and Comparison Groups. How are the groups defined? Group A: _____________________________________________________________________ Group B: _____________________________________________________________________ Group C: _____________________________________________________________________

11. Participant Characteristics. (Record as number and/or percent as presented in article. Follow percent with %.)

| Group A (N= ) | Group B (N= ) | Group C (N= ) | Total
Age (±SD)
Race:
White
Black
Hispanic
Other
PTL in a previous pregnancy
Previous PTD
Gravidity
Parity
High School Grads
Married

12. Dominant Mechanisms(s) of Loss. (Provide the reason for discontinuation and if available, the number of patients). [image] None lost [image] Can't tell [image] Loss to follow-up __________ [image] Side effects of treatment __________ [image] Other: _________________________________________ [image] Other: _________________________________________ [image] Other: _________________________________________

13. Intervention Compliance Assessment. (State what action(s) was taken to ensure that subject completed treatment.) [image] None reported [image] Mechanism: ______________________________

14. Intention to treat analysis provided? [image] Yes, list exclusions below and if available, number of subjects. [image] No [image] Positive cultures - urine: __________ [image] Positive cultures - group B strep: __________ [image] Positive cultures - amniotic fluid: __________ [image] Positive cultures - other cervico-vaginal: __________ [image] Did not comply with protocol for use of intervention: __________ [image] Did not comply with follow-up: __________ [image] Other: _____________________________________________ [image] Other: _____________________________________________ [image] Other: _____________________________________________ Were exclusions from analysis after Treatment Assignment? [image] Yes [image] No [image] Can't Tell

15. Non-Pharmaceutical Co-Interventions.

15a. Under what circumstances were non-pharmaceutical co-interventions (other than HUAM) administered?

15b. Which ones were used? [image] Bedrest [image] Routine Observation [image] Fetal Monitoring [image] IV Fluids [image] Other:______________________________________________________________________________

15c. Were non-pharmaceutical co-interventions administered in both/all groups? [image] Yes [image] No

If not, in which group(s) were they administered? ___________________________________

Under what circumstances were they administered?_____________________________________

16. Pharmaceutical Co-Interventions.

16a. Under what circumstances were co-interventions administered?

16b. What pharmaceutical co-interventions were administered? [image] tocolysis specify drug _______________ [image] antibiotics specify drug________________ [image] other ________________________

16c. Were pharmaceutical co-interventions administered in the same fashion in both/all groups? [image] Yes [image] No If not, describe the differences in administration.________________________________________________

18a). OUTCOME MEASURES. Specify mean or median. Numeric values may be preceded by <, >, <, or >. Record as number and/or percent as presented in article. Follow percent with "%". In the last column, if a difference between the groups is statistically significant, record the relevant p value. If it is not significant, state, "n.s." If statistical adjustments were performed (i.e., stratified analyses or multivariate modeling) report the adjusted results, the strata, and any variable used for adjustment)

Outcome | Group A (N = ) | Group B (N = ) | Group C (N = ) | Sig. Level
DELIVERY
Mean/Median Est. Gestation Age (EGA) at Delivery (SD)
Mean/Median Prolongation (SD) Days
PTL Only Group
Delivered at: __________ weeks
Delivered at: __________ weeks
Delivered at: __________ weeks
Delivered at: __________ weeks
MATERNAL OUTCOMES
Hospital admissions
Any non-delivery admissions
Chorioamnionitis
Endometritis/Post-partum
Adverse Drug Reactions
INFANT OUTCOMES
Mean/Median Birthweight (SD)
_____ gms
_____ gms
_____ gms
Apgar ______ at ______ min
Apgar ______ at ______ min
Mean/Neonatal Hospital Days
Mean/MedianNeonatal Deaths
Fetal Mortality
Neonatal Respiratory Distress Syndrome (NRDS), Hyaline Membrane Disease (HMD)
Bronchio Pulmonary Dysplasia (BPD)
Intraventricular Hemorrhage
Neonatal Sepsis
Necrotizing Enterocolitis
Neonatal Morbidity
Pneumonia
Neonatal Infection
OTHER

19. Describe any multivariate analysis performed. Include statistical technique, model description, and result highlights. :

20. Describe any additional analyses and/or subgroup analyses:

21. Was cost data collected? [image] Yes [image] No

22. Limitations. (Distinguish between limitations stated by the author and those found by the reviewer.) a) State limitations noted by the author. b) State any other limitations you found in the article.

23. Conclusions: [image] Intervention ineffective in altering outcomes detailed above. [image] Intervention effectively alters the following outcomes: ______________________________________ ________________________________________________________________________________ [image] Intervention effectively alters the following outcomes in the following subgroup(s) ________________________________________________________________________________ ________________________________________________________________________________

24. Comments. (Provide any additional information that you believe needs to be captured concerning this study.)