# Appendix A. Acknowledgments

This study was supported by Contract No. 290-97-0011 from the Agency for Healthcare Research and Quality (AHRQ). We acknowledge the assistance of Jacqueline Besteman, J.D., M.A., the AHRQ Task Order Officer for the Evidence-based Practice Center Program, and Ernestine Murray, R.N., M.A.S., the AHRQ Task Order Officer for this project. The investigators appreciate the considerable help of the data abstractors including clinicians: Alexander Allaire, M.D., Jennifer Bailit M.D., Muge Calikoglu M.D., Tara Gustillo-Ahby, M.D., Martin Fielder, M.D., Gil Reid, M.D., and Paul Whiteacre, M.D. and methodologists: Tracy Bouchard-Cyr, M.P.H., Kathryn Anderson Clark, M.S., Eric Finch, B.A., and Erdal Tekin, B.A. We also thank Patricia Ann Payne, B.S.N., C.N.M., M.P.H., and Rukmini Bagchee, M.S. for their work in developing the analysis of tocolytic harms. We thank the following individuals from the University of North Carolina at Chapel Hill: Gordon DeFriese, Ph.D., Co-Director of the RTI-UNC Evidence-based Practice Center and Lynn Whitener, Dr.P.H., M.S.L.S. We also thank the following individuals from the Research Triangle Institute: Suzanne L. West, Ph.D., M.P.H., and Linda J. Lux, M.P.A. for their valuable insights into the methods and substance of this evidence report, Linda Fonville for her outstanding secretarial support, and Nicole Walker and Richard Strowd, J.D. for exceptional contracting support.

## Technical Expert Advisory Group

We gratefully acknowledge the substantial involvement of and assistance from the Technical Expert Advisory Group (TEAG). TEAG members are listed at the end of this section. The TEAG was meant in part to contribute to (a) advancing AHRQ's broader goals of creating and maintaining "science partnerships" and "public-private partnerships" and (b) meeting the needs of a broad array of potential customers and users of its products. Thus, it was both a substantive resource and a sounding board throughout the study, and it is the body from whom "expert inputs" were formally sought at several points through the project.

We constituted our TEAG from three types of technical experts and other partners. These types are (1) technical/clinical experts; (2) patients or representatives of organizations whose mission concerns the interests and perspectives of patients and consumers; and (3) potential users of the final evidence report or other materials, including explicitly a representative of the organization that nominated the topic (in this case, the American College of Obstetrics and Gynecology. All in all, we had six clinical/technical experts, one individual representing patient populations, and one individual representing potential user groups, for a total of eight on the TEAG.

The final decision about TEAG membership was based on candidates' availability for scheduled conference calls and other input, willingness to review materials and provide advice and assistance within a short turnaround time, and approval by the AHRQ Task Order Officer.

The RTI-UNC Center team solicited the views of TEAG members from the start of the project. Among other issues, TEAG members provided insights and reactions to key clinical questions, input to the literature review process by ensuring that we included all known published research meeting our inclusion criteria, review of our data extraction forms and view of our approach to meta-analysis. TEAG members have also provided valuable input concerning problems of focusing a literature search on treatments, and specifying appropriate outcomes, for a clinical topic as difficult to conceptualize as preterm labor.

In keeping with AHRQ's standards for employing a multidisciplinary approach to the development of evidence reports, we called on our TEAG for inputs at two key points during this task. First, the group was asked to comment on the literature synthesis and to give us feedback on our overall plans at that stage of the analysis, which included approaches to developing evidence tables and to summarizing information about patient outcomes associated with the treatment options being studied for the management of preterm labor.

Technical Expert Advisory Group

TEAG Members
Haywood Brown, MD Department of Obstetrics and Gynecology St. Vincents Hospital (FLC) | Carol Sakala, PhD, MSPH Center for Applied Ethics and Professional Practice Education Development Center, Inc.
Jan French, CNM Denver Health Medical Center | Susan Smarr, MD Department of Obstetrics and Gynecology Permanente Medical Group, Inc.
Jay Iams, MD Ohio State University Dept of OB/GYN | Barbara Yawn, MD MS MSPH Department of Research and Education Olmstead Medical Center
Dwight Rouse, MD University of Alabama, Birmingham Dept OB/GYN | Stanley Zinberg, MD, MS American College of Obstetricians and Gynecologists

## Peer Reviewers

An important first step in the identification of potential peer reviewers was to determine the appropriate constituencies from which our reviewers should be approached. The categories we finally settled on, and the number of reviewers asked to participate in this effort, are shown in Table A. Although the categories are fairly self-explanatory, we note the following details for clarification. Individual experts engaged in related research (as contrasted with medical practice per se) were included in Category I (clinical practice and health care delivery) because they are based in health care delivery organizations and, we judged, likely to be involved to some extent in patient care. We assigned organizations that appear to be engaged chiefly in information dissemination (clearinghouses and the like) to Category IV (quality-of-care and consumer groups) on the grounds that much quality of care activity today assumes some effort to provide consumer information. We believe that these four categories represent the full range of health care experts, users, and patient groups that should be involved in reviewing this particular evidence report on the management of preterm labor; the specific peer reviewers are listed at the end of this appendix.

We selected 19 organizations or independent peer reviewers from the four categories noted in Table A. The individuals included the eight members of the TEAG because they played a major role throughout the project in conceptualizing the work and reviewing materials; moreover, as active professionals in the field, the RTI/UNC EPC believed that their comments at this stage would be very valuable. The remainder of the peer reviewer group were identified by issuing an invitation to the organization's executive officer/director (e.g., President, CEO) or to a public sector agency head asking them to nominate a peer reviewer or by soliciting nominations from the TEAG. A preliminary (and longer) list of organizations, agencies, or individuals was submitted to the AHRQ Task Order Officer for this project for review, comment, and approval. We then contacted all potential peer reviewers to determine their willingness to serve as peer reviewers, alerting them to the fact that this service would require them to prepare formal written reviews according to the checklist developed for this evidence report. Their comments and suggestions formed the basis of our revisions to the evidence report.

The peer reviewers who were selected for this Evidence Report are predominantly involved in clinical practice or research, professional associations, and public sector quality of care organizations.

### Table A. Categories of Peer Reviewers

Category | Number of Peer Reviewers
I. Clinical Practice Experts and Health Care Delivery Organizations | 3
II. Professional Associations/Guidelines Developers/Other Users of Evidence Report | 5
III. Public Sector/ Quasi Public and Regulatory Agencies | 1
IV. Quality of Care and Consumer Groups | 2

### Peer Reviewer List

Gina Burns President Group B Strep Association | Jan M. Kriebs, CNM MSN FACNM American College of Nurse Midwives
Nancy Cuddihy Health Care Consultant | Brian Mercer, MD Society for Maternal Fetal Medicine University of Tennessee at Memphis
Calvin Hobel, MD Cedars Sinai Medical Center Deptarment of OB/GYN | Michael O'Shea, MD Wake Forest University School of Medicine Department of Pediatrics
William Heuston, MD American Association of Family Practice | Kathleen Rice Simpson, PhD, RNC, FAAN Association of Women's Health, Obstetric and Neonatal Nurses
Ann Koontz, DrPH, CNM Maternal and Child Health Bureau Health Resources and Services Administration | Pat Venus Center for Health Care Policy and Evaluation United Health Group