# Appendixes

Appendix A. Acknowledgments

Appendix B. Extraction Forms

Appendix C. Acronyms and Abbreviations