# Reference List

1 Yoon PW, Scheuner MT, Peterson-Oehlke KL, et al. Can family history be used as a tool for public health and preventive medicine?. Genetic medicine. 2002;4(4):304-10.
2 Hariri S, Yoon PW, Moonesinghe R, et al. Evaluation of family history as a risk factor and screening tool for detecting undiagnosed diabetes in a nationally representative survey population. Genet Med. 2006;8(12):752-9. [pmid: 17172938].
3 Butterworth A. Family history as a risk factor for common, complex disease. Public Health Genetics Unit (now the PHG Foundation), Cambridge, U.K.; 2007. www.phgfoundation.org/pages/family_history.htm.
4 Kardia SLR, Modell SM, Peyser PA. Family-centered approaches to understanding and preventing coronary heart disease. Am J Prev Med. 2003;24(2):143-51. [pmid: 12568820].
5 Qureshi N, Wilson B, Santaguida P et al. Collection and use of cancer family history in primary care. Evid Rep Technol Assess No.159, AHRQ Publication No. 08-E001 (prepared by the McMaster University Evidence-based Practice Center under Contract No. 290-02-0020). Rockville, MD: Agency for Health Care Research and Quality; 2007 Oct. Available at: http://www.ahrq.gov/clinic/tp/famhisttp.htm
6 Rich EC, Burke W, Heaton CJ, et al. Reconsidering the family history in primary care. J Gen Intern Med. 2004;19(3):273-80. [pmid: 15009784].
7 Gail MH, Costantino JP, Pee D, et al. Projecting individualized absolute invasive breast cancer risk in African American women. J Natl Cancer Inst. 2007;99(23):1782-92. [pmid: 18042936].
8 Spiegelman D, Colditz GA, Hunter D, et al. Validation of the Gail et al. model for predicting individual breast cancer risk. J Natl Cancer Inst. 1994;86(8):600-7. [pmid: 8145275].
9 Rockhill B, Spiegelman D, Byrne C, et al. Validation of the Gail et al. model of breast cancer risk prediction and implications for chemoprevention. J Natl Cancer Inst. 2001;93(5):358-66. [pmid: 11238697].
10 Adams-Campbell LL, Makambi KH, Palmer JR, et al. Diagnostic accuracy of the Gail model in the Black Women's Health Study. Breast J. 2007;13(4):332-6. [pmid: 17593036].
11 Boyle P, Mezzetti M, La Vecchia C, et al. Contribution of three components to individual cancer risk predicting breast cancer risk in Italy. Eur J Cancer Prev. 2004;13(3):183-91. [pmid: 15167217].
12 Decarli A, Calza S, Masala G, et al. Gail model for prediction of absolute risk of invasive breast cancer: independent evaluation in the Florence-European Prospective Investigation Into Cancer and Nutrition cohort. J Natl Cancer Inst. 2006;98(23):1686-93. [pmid: 17148770].
13 Chlebowski RT, Anderson GL, Lane DS, et al. Predicting risk of breast cancer in postmenopausal women by hormone receptor status. J Natl Cancer Inst. 2007;99(22):1695-705. [pmid: 18000216].
14 Kim DJ, Rockhill B, Colditz GA. Validation of the Harvard Cancer Risk Index: a prediction tool for individual cancer risk. J Clin Epidemiol. 2004;57(4):332-40. [pmid: 15135833].
15 Gail MH, Brinton LA, Byar DP, et al. Projecting individualized probabilities of developing breast cancer for white females who are being examined annually. J Natl Cancer Inst. 1989;81(24):1879-86. [pmid: 2593165].
16 Colditz GA, Atwood KA, Emmons K, et al. Harvard report on cancer prevention volume 4: Harvard Cancer Risk Index. Risk Index Working Group, Harvard Center for Cancer Prevention. Cancer Causes Control. 2000;11(6):477-88. [pmid: 10880030].
17 Whitlock EP, Lin JS, Chou R, et al. Using existing systematic reviews in complex systematic reviews. Ann Intern Med. 2008;148(10):776-82. [pmid: 18490690].
18 Bardia A, Tleyjeh IM, Cerhan JR, et al. Efficacy of antioxidant supplementation in reducing primary cancer incidence and mortality: systematic review and meta-analysis. [Review] [73 refs]. Mayo Clin Proc. 2008;83(1):23-34. [pmid: 18173999].
19 Alkhenizan A, Hafez K. The role of vitamin E in the prevention of cancer: a meta-analysis of randomized controlled trials. Ann Saudi Med. 2007;27(6):409-14. [pmid: 18059122].
20 Browning DR, Martin RM. Statins and risk of cancer: A systematic review and metaanalysis. Int J Cancer. 2007;120(4):833-43. [pmid: 17131313].
21 Kosters JP, Gotzsche PC. Regular self-examination or clinical examination for early detection of breast cancer [Review][24 refs]. Cochrane Database Syst Rev 2003;(2):CD003373
22 Gotzsche PC, Nielsen M. Screening for breast cancer with mammography. Cochrane Database Syst Rev 2006;(4):CD001877
23 Dube C, Rostom A, Lewin G, et al. The use of aspirin for primary prevention of colorectal cancer: a systematic review prepared for the U.S. Preventive Services Task Force. Ann Intern Med. 2007;146(5):365-75. [pmid: 17339622].
24 Hewitson P, Glasziou P, Irwig L, et al. Screening for colorectal cancer using the faecal occult blood test, Hemoccult.[update of Cochrane Database Syst Rev. 2000;(2):CD001216; PMID: 10796760]. [Review][46 refs]. Cochrane Database Syst Rev 2007;(1):CD001216
25 Kerr J, Day P, Broadstock M, et al. Systematic review of the effectiveness of population screening for colorectal cancer. [Review] [28 refs]. N Z Medl Jl. 2007;120(1258):U2629.
26 Bristol SLR Team 2006. Systematic Literature Review Report. The associations between food, nutrition, physical activity and the risk of prostate cancer and underlying mechanisms. World Cancer Research Fund/American Institute for Cancer Research, Food, Nutrition, Physical Activity, and the Prevention of Cancer: a Global Perspective. Washington, DC: AICR 2007, 2006 Jun 30.
27 Ilic D, O'Connor D, Green S, et al. Screening for prostate cancer. Cochrane Database Syst Rev 2006; Issue 3, Art.No.: CD004720.DOI:10.1002/14651858.CD004720.pub2:
28 Huang HY, Caballero B, Chang S, et al. The efficacy and safety of multivitamin and mineral supplement use to prevent cancer and chronic disease in adults: a systematic review for a National Institutes of Health state-of-the-science conference. [Review] [44 refs]. Ann Intern Med. 2006;145(5):372-85. [pmid: 16880453].
29 Moayyedi P, Achkar E. Does fecal occult blood testing really reduce mortality? A reanalysis of systematic review data.[Review] [25 refs]. Am J Gastroenterol. 2006;101(2):380-4. [pmid: 16454847].
30 Walsh JM, Terdiman JP. Colorectal cancer screening: scientific review.[Review] [105 refs]. JAMA. 2003;289(10):1288-96. [pmid: 12633191].
31 Bonovas S, Filioussi K, Flordellis CS, et al. Statins and the risk of colorectal cancer: a meta-analysis of 18 studies involving more than 1.5 million patients. J Clin Oncol. 2007;25(23):3462-8. [pmid: 17687150].
32 Hoffmeister M, Chang-Claude J, Brenner H. Do older adults using NSAIDs have a reduced risk of colorectal cancer?. Drugs Aging. 2006;23(6):513-23. [pmid: 16872234].
33 Asano TK, McLeod RS. Nonsteroidal anti-inflammatory drugs and aspirin for the prevention of colorectal adenomas and cancer: a systematic review. [Review] [45 refs]. Dis Colon Rectum. 2004;47(5):665-73. [pmid: 15054679].
34 Coulter ID, Hardy ML, Morton SC, et al. Antioxidants Vitamin C and Vitamin E for the Prevention and Treatment of Cancer. J Gen Intern Med. 2006;21(7):735-44. [pmid: 16808775].
35 Dale KM, Coleman CI, Henyan NN, et al. Statins and cancer risk: a meta-analysis. JAMA. 2006;295(1):74-80. [pmid: 16391219].
36 Heresbach D, Manfredi S, D'halluin PN, et al. Review in depth and meta-analysis of controlled trials on colorectal cancer screening by faecal occult blood test. [Review] [61 refs]. Eur J Gastroenterol Hepatol. 2006;18(4):427-33. [pmid: 16538116].
37 Hackshaw AK, Paul EA. Breast self-examination and death from breast cancer: a meta-analysis. Br J Cancer. 2003;88(7):1047-53. [pmid: 12671703].
38 Huang HY, Caballero B, Chang S et al. Multivitamin/mineral supplements and prevention of chronic disease. Evid Rep Technol Assess No.139, AHRQ Publication No.06-E012. (Prepared by The Johns Hopkins University Evidence-based Practice Center under Contract No.290-02-0018). Rockville, MD: Agency for Healthcare Research and Quality; 2006 May. [underlined: PM:17764205]
39 Bonovas S, Filioussi K, Tsavaris N, et al. Use of statins and breast cancer: A meta-analysis of seven randomized clinical trials and nine observational studies. J Clin Oncol. 2005;23(34):8606-12. [pmid: 16260694].
40 Mahmud S, Franco E, Aprikian A. Prostate cancer and use of nonsteroidal anti-inflammatory drugs: systematic review and meta-analysis. [Review] [43 refs]. Br J Cancer. 2004;90(1):93-9. [pmid: 14710213].
41 Rostom A, Dube C, Lewin G, et al. Nonsteroidal anti-inflammatory drugs and cyclooxygenase-2 inhibitors for primary prevention of colorectal cancer: a systematic review prepared for the U.S. Preventive Services Task Force. Ann Intern Med. 2007;146(5):376-89. [pmid: 17339623].
42 Weingarten MA, Zalmanovici A, Yaphe J. Dietary calcium supplementation for preventing colorectal cancer and adenomatous polyps.[update of Cochrane Database Syst Rev. 2005;(3):CD003548; PMID: 16034903]. [Review][38 refs]. Cochrane Database Syst Rev 2008;(1):CD003548
43 Brett J, Bankhead C, Henderson B, et al. The psychological impact of mammographic screening. A systematic review. [Review] [74 refs]. Psychooncology. 2005;14(11):917-38. [pmid: 15786514].
44 Watson EK, Henderson BJ, Brett J, et al. The psychological impact of mammographic screening on women with a family history of breast cancer—a systematic review. [Review] [26 refs]. Psychooncology. 2005;14(11):939-48. [pmid: 15744777].
45 Dutch Review Team 2006. Systematic Literature Review Report. The associations between food, nutrition and physical activity and the risk of colorectal cancer and underlying mechanisms. World Cancer Research Fund/American Institute for Cancer Research, Food, Nutrition, Physical Activity, and the Prevention of Cancer: a Global Perspective. Washington, DC: AICR 2007, 2007.
46 Italian Review Team 2005. Systematic Literature Review Report. The Associations between Food, Nutrition and Physical Activity and the Risk of Breast Cancer and Underlying Mechanisms. World Cancer Research Fund/American Institute for Cancer Research, Food, Nutrition, Physical Activity, and the Prevention of Cancer: a Global Perspective. Washington, DC: AICR 2007, 2007.
47 Baron JA, Beach M, Wallace K, et al. Risk of prostate cancer in a randomized clinical trial of calcium supplementation. Cancer Epidemiol Biomarkers Prev. 2005;14(3):586-9. [pmid: 15767334].
48 Giles JT, Kennedy DT, Dunn EC, et al. Results of a community pharmacy-based breast cancer risk-assessment and education program. Pharmacotherapy. 2001;21(2):243-53. [pmid: 11213861].
49 Curry SJ, Taplin SH, Anderman C, et al. A randomized trial of the impact of risk assessment and feedback on participation in mammography screening. Prev Med. 1993;22(3):350-60. [pmid: 8327418].
50 Bastani R, Maxwell AE, Bradford C, et al. Tailored risk notification for women with a family history of breast cancer. Prev Med. 1999;29(5):355-64. [pmid: 10564627].
51 Leggatt V, Mackay J, Marteau TM, et al. The psychological impact of a cancer family history questionnaire completed in general practice. J Med Genet. 2000;37(6):470-2. [pmid: 10928860].
52 Khoury MJ, Yang Q, Gwinn M, et al. An epidemiologic assessment of genomic profiling for measuring susceptibility to common diseases and targeting interventions. Genet Med. 2004;6(1):38-47. [pmid: 14726808].
53 Collins FS. Shattuck lecture—medical and societal consequences of the Human Genome Project. N Engl J Med. 1999;341(1):28-37. [pmid: 10387940].
54 Levy S, Sutton G, Ng PC, et al. The diploid genome sequence of an individual human. PLoS Biol. 2007;5(10):e254. [pmid: 17803354].
55 Pharoah PD, Antoniou AC, Easton DF, et al. Polygenes, risk prediction, and targeted prevention of breast cancer. N Engl J Med. 2008;358(26):2796-803. [pmid: 18579814].
56 Rodriguez-Bigas MA, Boland CR, Hamilton SR, et al. A National Cancer Institute Workshop on Hereditary Nonpolyposis Colorectal Cancer Syndrome: meeting highlights and Bethesda guidelines. J Natl Cancer Inst. 1997;89(23):1758-62. [pmid: 9392616].
57 Cleeman JI, Grundy SM, Becker D, et al. Executive summary of the Third Report of the National Cholesterol Education Program (NCEP) expert panel on detection, evaluation, and treatment of high blood cholesterol in adults (Adult Treatment Panel III). JAMA. 2001;285(19):2486-97. [pmid: 11368702].
58 Haddow J, Palomaki G. Human Genome Epidemiology. Oxford: Oxford University Press; 2003. ACCE: A model process for evaluating data on emerging genetic tests.
59 Yoon PW, Scheuner MT, Khoury MJ. Research priorities for evaluating family history in the prevention of common chronic diseases. Am J Prev Med. 2003;24(2):128-35. [pmid: 12568818].
60 Scheuner MT, Wang SJ, Raffel LJ, et al. Family history: a comprehensive genetic risk assessment method for the chronic conditions of adulthood. Am J Med Genet. 1997;71(3):315-24. [pmid: 9268102].
61 Houlston RS, Murday V, Harocopos C, et al. Screening and genetic counselling for relatives of patients with colorectal cancer in a family cancer clinic.[erratum appears in BMJ 1990 Sep 1;301(6749):446]. BMJ. 1990;301(6748):366-8. [pmid: 2169322].
62 Houlston RS, McCarter E, Parbhoo S, et al. Family history and risk of breast cancer. J Med Genet. 1992;29(3):154-7. [pmid: 1552556].
63 Houlston R, Bourne TH, Davies A, et al. Use of family history in a screening clinic for familial ovarian cancer. Gynecol Oncol. 1992;47(2):247-52. [pmid: 1468703].
64 Steinberg GD, Carter BS, Beaty TH, et al. Family history and the risk of prostate cancer. Prostate. 1990;17(4):337-47. [pmid: 2251225].
65 Carter BS, Bova GS, Beaty TH, et al. Hereditary prostate cancer: epidemiologic and clinical features. J Urol. 1993;150(3):797-802. [pmid: 8345587].
66 Colditz GA, Willett WC, Hunter DJ, et al. Family history, age, and risk of breast cancer. Prospective data from the Nurses' Health Study. JAMA. 1993;270(3):338-43. [pmid: 8123079].
67 Slattery ML, Kerber RA. A comprehensive evaluation of family history and breast cancer risk. The Utah Population Database. JAMA. 1993;270(13):1563-8. [pmid: 8371466].
68 Claus EB, Risch N, Thompson WD. Autosomal dominant inheritance of early-onset breast cancer. Implications for risk prediction. Cancer. 1994;73(3):643-51. [pmid: 8299086].
69 Fuchs CS, Giovannucci EL, Colditz GA, et al. A prospective study of family history and the risk of colorectal cancer. N Engl J Med. 1994;331(25):1669-74. [pmid: 7969357].
70 Spitz MR, Currier RD, Fueger JJ, et al. Familial patterns of prostate cancer: a case-control analysis. J Urol. 1991;146(5):1305-7. [pmid: 1942282].
71 Colditz GA, Branch LG, Lipnick RJ, et al. Increased green and yellow vegetable intake and lowered cancer deaths in an elderly population. Am J Clin Nutr. 1985;41(1):32-6. [pmid: 3966422].
72 Hertog MG, Bueno-de-Mesquita HB, Fehily AM, et al. Fruit and vegetable consumption and cancer mortality in the Caerphilly Study. Cancer Epidemiol Biomarkers Prev. 1996;5(9):673-7. [pmid: 8877056].
73 Steinmetz KA, Potter JD. Vegetables, fruit, and cancer prevention: a review. J Am Diet Assoc. 1996;96(10):1027-39. [pmid: 8841165].
74 Alpha-Tocopherol Beta-Carotene Cancer Prevention Study Group. The effect of vitamin E and beta carotene on the incidence of lung cancer and other cancers in male smokers. N Engl J Med. 1994;330(15):1029-35. [pmid: 8127329].
75 Marteau TM, Lerman C. Genetic risk and behavioural change. BMJ. 2001;322(7293):1056-9. [pmid: 11325776].
76 Heshka JT, Palleschi C, Howley H, et al. A systematic review of perceived risks, psychological and behavioral impacts of genetic testing. Genet Med. 2008;10(1):19-32. [pmid: 18197053].
77 Sheldon TA, Cullum N, Dawson D, et al. What's the evidence that NICE guidance has been implemented? Results from a national evaluation using time series analysis, audit of patients' notes, and interviews. BMJ. 2004;329(7473):999-1003. [pmid: 15514342].
78 Lynch HT. Cancer family history and genetic testing: are malpractice adjudications waiting to happen?. Am J Gastroenterol. 2002;97(3):518-20. [pmid: 11922540].
79 Kelly KM, Shedlosky-Shoemaker R, Porter K, et al. Cancer family history reporting: impact of method and psychosocial factors. J Genet Couns. 2007;16(3):373-82. [pmid: 17318453].
80 Task Force on Community Preventive Services. The Guide to Community Preventive Services: What Works to Promote Health? The Community Guide 2005. http://www.thecommunityguide.org/methods/.
81 World Cancer Research Fund / American Institute for Cancer Research. Food, Nutrition, Physical Activity and the Prevention of Cancer: a Global Perspective. 2nd Expert Report. United Kingdom: World Cancer Research Fund International; 2007 Jan 1.
82 Thoma A, Veltri K, Haines T, et al. A systematic review of reviews comparing the effectiveness of endoscopic and open carpal tunnel decompression. Plast Reconstr Surg. 2004;113(4):1184-91. [pmid: 15083019].
83 Jadad AR, Moore RA, Carroll D, et al. Assessing the quality of reports of randomized clinical trials: is blinding necessary?. Control Clin Trials. 1996;17(1):1-12. [pmid: 8721797].
84 Costantino JP, Gail MH, Pee D, et al. Validation studies for models projecting the risk of invasive and total breast cancer incidence. J Natl Cancer Inst. 1999;91(18):1541-8. [pmid: 10491430].
85 Willett WC, Hunter DJ, Stampfer MJ, et al. Dietary fat and fiber in relation to risk of breast cancer. An 8-year follow-up. JAMA. 1992;268(15):2037-44. [pmid: 1328696].
86 Colditz GA. The nurses' health study: a cohort of US women followed since 1976. J Am Med Womens Assoc. 1995;50(2):40-4. [pmid: 7722205].
87 Anderson GL, Manson J, Wallace R, et al. Implementation of the Women's Health Initiative study design. Ann Epidemiol. 2003;13(9 Suppl):S5-17. [pmid: 14575938].
88 Russell C, Palmer JR, Adams-Campbell LL, et al. Follow-up of a large cohort of Black women. Am J Epidemiol. 2001;154(9):845-53. [pmid: 11682367].
89 Baker LH. Breast Cancer Detection Demonstration Project: Five-Year Summary Report. CA Cancer J Clin. 1982;32(4):194-225. [pmid: 6805867].
90 Marchbanks PA, McDonald JA, Wilson HG, et al. The NICHD Women's Contraceptive and Reproductive Experiences Study: methods and operational results. Ann Epidemiol. 2002;12(4):213-21. [pmid: 11988408].
91 Demierre MF, Higgins PD, Gruber SB. Statins and cancer prevention. Nat Rev Cancer. 2005;5(12):930-42. [pmid: 16341084].
92 Kim KP, Whitehead C, Piazza G, et al. Combinatorial chemoprevention: efficacy of lovostatin and exisulind on the formation and progression of aberrant crypt foci. Anticancer Res. 2004;24(3a):1805-11. [pmid: 15274359].
93 Agarwal B, Rao CV, Bhendwal S, et al. Lovastatin augments sulindac-induced apoptosis in colon cancer cells and potentiates chemopreventive effects of sulindac. Gastroenterology. 1999;117(4):838-47. [pmid: 10500066].
94 Narisawa T, Fukaura Y, Terada K, et al. Prevention of 1,2-dimethylhydrazine-induced colon tumorigenesis by HMG-CoA reductase inhibitors, pravastatin and simvastatin, in ICR mice. Carcinogenesis. 1994;15(9):2045-8. [pmid: 7923600].
95 Chan KK, Oza AM, Siu LL. The statins as anticancer agents. Clin Cancer Res. 2003;9(1):10-9. [pmid: 12538446].
96 Graaf MR, Beiderbeck AB, Egberts AC, et al. The risk of cancer in users of statins. J Clin Oncol. 2004;22(12):2388-94. [pmid: 15197200].
97 Poynter JN, Gruber SB, Higgins PDR, et al. Statins and the risk of colorectal cancer. N Engl J Med. 2005;352(21):2184-92. [pmid: 15917383].
98 Shannon J, Tewoderos S, Garzotto M, et al. Statins and prostate cancer risk: a case-control study. Am J Epidemiol. 2005;162(4):318-25. [pmid: 16014776].
99 Newman TB, Hulley SB. Carcinogenicity of lipid-lowering drugs. JAMA. 1996;275(1):55-60. [pmid: 8531288].
100 Coogan PF, Rosenberg L, Palmer JR, et al. Statin use and the risk of breast and prostate cancer. Epidemiology. 2002;13(3):262-7. [pmid: 11964926].
101 Pfeffer MA, Keech A, Sacks FM, et al. Safety and tolerability of pravastatin in long-term clinical trials: prospective Pravastatin Pooling (PPP) Project. Circulation. 2002;105(20):2341-6. [pmid: 12021218].
102 Setoguchi S, Glynn RJ, Avorn J, et al. Statins and the risk of lung, breast, and colorectal cancer in the elderly. Circulation. 2007;115(1):27-33. [pmid: 17179016].
103 Boyle P, Veronesi U, Tubiana M, et al. European School of Oncology Advisory report to the European Commission for the “Europe Against Cancer Programme” European Code Against Cancer. Eur J Cancer. 1995;31A(9):1395-405. [pmid: 7577062].
104 Shapiro S, Coleman EA, Broeders M, et al. Breast cancer screening programmes in 22 countries: current policies, administration and guidelines. International Breast Cancer Screening Network (IBSN) and the European Network of Pilot Projects for Breast Cancer Screening. Int J Epidemiol. 1998;27(5):735-42. [pmid: 9839727].
105 WHO. IARC Handbook of Cancer Prevention. Volume 7. Breast Cancer Screening. Lyon, France: IARC Press; 2002. Efficacy of screening by self-examination.
106 Gotzsche PC, Olsen O. Is screening for breast cancer with mammography justifiable?. Lancet. 2000;355(9198):129-34. [pmid: 10675181].
107 Blamey RW, Wilson AR, Patnick J. ABC of breast diseases: screening for breast cancer. BMJ. 2000;321(7262):689-93. [pmid: 10987778].
108 Cox B. Variation in the effectiveness of breast screening by year of follow-up. J Natl Cancer Inst Monogr 1997;(22):69–72.
109 Elwood JM, Cox B, Richardson AK. The effectiveness of breast cancer screening by mammography in younger women. Online J Curr Clin Trials 1993;Doc No 32:23,227.
110 Glasziou PP. Meta-analysis adjusting for compliance: the example of screening for breast cancer. J Clin Epidemiol. 1992;45(11):1251-6. [pmid: 1432006].
111 Glasziou PP, Woodward AJ, Mahon CM. Mammographic screening trials for women aged under 50. A quality assessment and meta-analysis. Med J Aust. 1995;162(12):625-9. [pmid: 7603372].
112 Glasziou P, Irwig L. The quality and interpretation of mammographic screening trials for women ages 40–49. J Natl Cancer Inst Monogr 1997;(22):73–7.
113 Hendrick RE, Smith RA, Rutledge JH, III, et al. Benefit of screening mammography in women aged 40–49: a new meta-analysis of randomized controlled trials. J Natl Cancer Inst Monogr 1997;(22):87–92.
114 Humphrey LL, Helfand M, Chan BK, et al. Breast cancer screening: a summary of the evidence for the U.S. Preventive Services Task Force. Ann Intern Med. 2002;137(5 Part 1):347-60. [pmid: 12204020].
115 Kerlikowske K, Grady D, Rubin SM, et al. Efficacy of screening mammography. A meta-analysis. JAMA. 1995;273(2):149-54. [pmid: 7799496].
116 Larsson LG, Nystrom L, Wall S, et al. The Swedish randomised mammography screening trials: analysis of their effect on the breast cancer related excess mortality. J Med Screen. 1996;3(3):129-32. [pmid: 8946307].
117 Larsson LG, Andersson I, Bjurstam N, et al. Updated overview of the Swedish Randomized Trials on Breast Cancer Screening with Mammography: age group 40–49 at randomization. J Natl Cancer Inst Monogr 1997;(22):57–61.
118 Nystrom L, Rutqvist LE, Wall S, et al. Breast cancer screening with mammography: overview of Swedish randomised trials. Lancet. 1993;341(8851):973-8. [pmid: 8096941].
119 Nystrom L, Larsson LG, Wall S, et al. An overview of the Swedish randomised mammography trials: total mortality pattern and the representivity of the study cohorts. J Med Screen. 1996;3(2):85-7. [pmid: 8849766].
120 Nystrom L, Andersson I, Bjurstam N, et al. Long-term effects of mammography screening: updated overview of the Swedish randomised trials. Lancet. 2002;359(9310):909-19. [pmid: 11918907].
121 Smart CR, Hendrick RE, Rutledge JH III, et al. Benefit of mammography screening in women ages 40 to 49 years. Current evidence from randomized controlled trials. Cancer. 1995;75(7):1619-26. [pmid: 8826919].
122 Kerlikowske K. Efficacy of screening mammography among women aged 40 to 49 years and 50 to 69 years: comparison of relative and absolute benefit. J Natl Cancer Inst Monogr 1997;(22):79–86.
123 Report of the Organizing Committee and Collaborators Falun Meeting. Breast-cancer screening with mammography in women aged 40–49 years. Int J Cancer 1996;68(6):693–9.
124 Nyström L. Assessment of population screening: the case of mammography [thesis] Umeå: Umeå University Medical Dissertations. 2000.
125 Wald NJ, Chamberlain J, Hackshaw A. Report of the European Society for Mastology Breast Cancer Screening Evaluation Committee (1993). The Breast. 1993;2:209-16.
126 WHO. IARC Handbooks of Cancer Prevention. Volume 7. Breast Cancer Screening. Lyon: IARC Press; 2002.
127 Nyström L. Update of the overview of the Swedish randomized trials on breast cancer screening with mammography. NIH Consensus Development Conference on Breast Cancer Screening for Women Ages 40–49. Nat 1997;65–9.
128 Olsen O, Gotzsche PC. Cochrane review on screening for breast cancer with mammography. Lancet. 2001;358(9290):1340-2. [pmid: 11684218].
129 Rosenberg L, Palmer JR, Zauber AG, et al. A hypothesis: nonsteroidal anti-inflammatory drugs reduce the incidence of large-bowel cancer. J Natl Cancer Inst. 1991;83(5):355-8. [pmid: 1759994].
130 Thun MJ, Namboodiri MM, Heath CW Jr. Aspirin use and reduced risk of fatal colon cancer. N Engl J Med. 1991;325(23):1593-6. [pmid: 1669840].
131 Sandler RS. Aspirin and other nonsteroidal anti-inflammatory agents in the prevention of colorectal cancer. Important Adv Oncol 1996;123–37.
132 Friedman GD, Coates AO, Potter JD, et al. Drugs and colon cancer. Pharmacoepidemiol Drug Saf. 1998;7(2):99-106. [pmid: 15073733].
133 Rosenberg L, Louik C, Shapiro S. Nonsteroidal antiinflammatory drug use and reduced risk of large bowel carcinoma. Cancer. 1998;82(12):2326-33. [pmid: 9635524].
134 Giovannucci E. The prevention of colorectal cancer by aspirin use. Biomed Pharmacother. 1999;53(7):303-8. [pmid: 10472428].
135 Kune GA. Colorectal cancer chemoprevention: aspirin, other NSAID and COX-2 inhibitors. Aust N Z J Surg. 2000;70(6):452-5. [pmid: 10843404].
136 Garcia-Rodriguez LA, Huerta-Alvarez C. Reduced risk of colorectal cancer among long-term users of aspirin and nonaspirin nonsteroidal antiinflammatory drugs. Epidemiology. 2001;12(1):88-93. [pmid: 11138826].
137 Baron JA, Cole BF, Sandler RS, et al. A randomized trial of aspirin to prevent colorectal adenomas. N Engl J Med. 2003;348(10):891-9. [pmid: 12621133].
138 Sandler RS, Halabi S, Baron JA, et al. A randomized trial of aspirin to prevent colorectal adenomas in patients with previous colorectal cancer. N Engl J Med. 2003;348(10):883-90. [pmid: 12621132].
139 Willett W. The search for the causes of breast and colon cancer. Nature. 1989;338(6214):389-94. [pmid: 2648156].
140 Fearon ER, Vogelstein B. A genetic model for colorectal tumorigenesis. Cell. 1990;61(5):759-67. [pmid: 2188735].
141 Potter JD. Reconciling the epidemiology, physiology, and molecular biology of colon cancer. JAMA. 1992;268(12):1573-7. [pmid: 1518112].
142 Winawer SJ, Zauber AG, Ho MN, et al. Prevention of colorectal cancer by colonoscopic polypectomy. The National Polyp Study Workgroup. N Engl J Med. 1993;329(27):1977-81. [pmid: 8247072].
143 Young GP, St John DJ, Winawer SJ, et al. Choice of fecal occult blood tests for colorectal cancer screening: recommendations based on performance characteristics in population studies: a WHO (World Health Organization) and OMED (World Organization for Digestive Endoscopy) report. Am J Gastroenterol. 2002;97(10):2499-507. [pmid: 12385430].
144 Black WC, Haggstrom DA, Welch HG. All-cause mortality in randomized trials of cancer screening. J Natl Cancer Inst. 2002;94(3):167-73. [pmid: 11830606].
145 Levin TR, Conell C, Shapiro JA, et al. Complications of screening flexible sigmoidoscopy. Gastroenterology. 2002;123(6):1786-92. [pmid: 12454834].
146 Segnan N, Senore C, Andreoni B, et al. Baseline findings of the Italian multicenter randomized controlled trial of “once-only sigmoidoscopy”—SCORE. J Natl Cancer Inst. 2002;94(23):1763-72. [pmid: 12464648].
147 Gondal G, Grotmol T, Hofstad B, et al. Grading of distal colorectal adenomas as predictors for proximal colonic neoplasia and choice of endoscope in population screening: experience from the Norwegian Colorectal Cancer Prevention study (NORCCAP). Gut. 2003;52(3):398-403. [pmid: 12584223].
148 Atkin WS, Cuzick J, Northover JM, et al. Prevention of colorectal cancer by once-only sigmoidoscopy. Lancet. 1993;341(8847):736-40. [pmid: 8095636].
149 Lieberman DA, Weiss DG, Bond JH, et al. Use of colonoscopy to screen asymptomatic adults for colorectal cancer. Veterans Affairs Cooperative Study Group 380. N Engl J Med. 2000;343(3):162-8. [pmid: 10900274].
150 Schoenfeld P, Cash B, Flood A, et al. Colonoscopic screening of average-risk women for colorectal neoplasia. N Engl J Med. 2005;352(20):2061-8. [pmid: 15901859].
151 Clark LC, Combs GF Jr, Turnbull BW, et al. Effects of selenium supplementation for cancer prevention in patients with carcinoma of the skin. A randomized controlled trial. Nutritional Prevention of Cancer Study Group. JAMA. 1996;276(24):1957-63. [pmid: 8971064].
152 Giovannucci E, Rimm EB, Wolk A, et al. Calcium and fructose intake in relation to risk of prostate cancer. Cancer Res. 1998;58(3):442-7. [pmid: 9458087].
153 Kristal AR, Cohen JH, Qu P, et al. Associations of energy, fat, calcium, and vitamin D with prostate cancer risk. Cancer Epidemiol Biomarkers Prev. 2002;11(8):719-25. [pmid: 12163324].
154 Rodriguez C, McCullough ML, Mondul AM, et al. Calcium, dairy products, and risk of prostate cancer in a prospective cohort of United States men. Cancer Epidemiol Biomarkers Prev. 2003;12(7):597-603. [pmid: 12869397].
155 Chan JM, Stampfer MJ, Ma J, et al. Dairy products, calcium, and prostate cancer risk in the Physicians' Health Study. AM J Clin Nutr. 2001;74(4):549-54. [pmid: 11566656].
156 Vlajinac HD, Marinkovic JM, Ilic MD, et al. Diet and prostate cancer: a case-control study. Eur J Cancer. 1997;33(1):101-7. [pmid: 9071908].
157 Hayes RB, Ziegler RG, Gridley G, et al. Dietary factors and risks for prostate cancer among blacks and whites in the United States. Cancer Epidemiol Biomarkers Prev. 1999;8(1):25-34. [pmid: 9950236].
158 Kristal AR, Stanford JL, Cohen JH, et al. Vitamin and mineral supplement use is associated with reduced risk of prostate cancer. Cancer Epidemiol Biomarkers Prev. 1999;8(10):887-92. [pmid: 10548317].
159 Schuurman AG, van den Brandt PA, Dorant E, et al. Animal products, calcium and protein and prostate cancer risk in The Netherlands Cohort Study. Br J Cancer. 1999;80(7):1107-13. [pmid: 10362125].
160 Chan JM, Pietinen P, Virtanen M, et al. Diet and prostate cancer risk in a cohort of smokers, with a specific focus on calcium and phosphorus (Finland). Cancer Causes Control. 2000;11(9):859-67. [pmid: 11075876].
161 Tavani A, Gallus S, Franceschi S, et al. Calcium, dairy products, and the risk of prostate cancer. Prostate. 2001;48(2):118-21. [pmid: 11433421].
162 Berndt SI, Carter HB, Landis PK, et al. Calcium intake and prostate cancer risk in a long-term aging study: the Baltimore Longitudinal Study of Aging. Urology. 2002;60(6):1118-23. [pmid: 12475694].
163 Gambert SR. Screening for prostate cancer. Int Urol Nephrol. 2001;33(2):249-57. [pmid: 12092637].
164 Holmberg L, Bill-Axelson A, Helgesen F, et al. A randomized trial comparing radical prostatectomy with watchful waiting in early prostate cancer. N Engl J Med. 2002;347(11):781-9. [pmid: 12226148].
165 Albertsen PC, Hanley JA, Fine J. 20-year outcomes following conservative management of clinically localized prostate cancer. JAMA. 2005;293(17):2095-101. [pmid: 15870412].
166 Johansson JE, Andren O, Andersson SO, et al. Natural history of early, localized prostate cancer. JAMA. 2004;291(22):2713-9. [pmid: 15187052].
167 Coley C, Barry M, Mulley A. Clinical Guideline, Part III: Screening for Prostate Cancer. Ann Intern Med. 1997;126(6):480-4. [pmid: 9072936].
168 Ferrini R, Woolf SH. American College of Preventive Medicine practice policy. Screening for prostate cancer in American men. Am J Prev Med. 1998;15(1):81-4. [pmid: 9651646].
169 Harris R, Lohr KN. Screening for prostate cancer: an update of the evidence for the U.S. Preventive Services Task Force. Ann Intern Med. 2002;137(11):917-29. [pmid: 12458993].
170 Smith RA, Cokkinides V, Eyre HJ. American Cancer Society guidelines for the early detection of cancer, 2003. CA Cancer J Clin. 2003;53(1):27-43. [pmid: 12568442].
171 Taplin SH, Thompson RS, Schnitzer F, et al. Revisions in the risk-based Breast Cancer Screening Program at Group Health Cooperative. Cancer. 1990;66(4):812-8. [pmid: 2386908].
172 Veronesi U, Maisonneuve P, Rotmensz N, et al. Italian randomized trial among women with hysterectomy: tamoxifen and hormone-dependent breast cancer in high-risk women. J Natl Cancer Inst. 2003;95(2):160-5. [pmid: 12529349].
173 Scheuner MT, Whitworth WC, McGruder H, et al. Familial risk assessment for early-onset coronary heart disease. Genet Med. 2006;8(8):525-31. [pmid: 16912584].
174 Centers for Disease Control and Prevention. Family Healthware. National Office of Public Health Genomics.December 11 2007. www.cdc.gov/genomics/activities/famhx.htm.
175 Grodstein F, Stampfer MJ, Manson JE, et al. Postmenopausal estrogen and progestin use and the risk of cardiovascular disease. N Engl J Med. 1996;335(7):453-61. [pmid: 8672166].
176 Rossouw JE, Anderson GL, Prentice RL, et al. Risks and benefits of estrogen plus progestin in healthy postmenopausal women: principal results From the Women's Health Initiative randomized controlled trial. JAMA. 2002;288(3):321-33. [pmid: 12117397].
177 Shaukat A, Scouras N, Schunemann HJ. Role of supplemental calcium in the recurrence of colorectal adenomas: a metaanalysis of randomized controlled trials. Am J Gastroenterol. 2005;100(2):390-4. [pmid: 15667497].
178 Jacobs EJ, Mondul AM, Connell CJ. A large cohort study of aspirin and other nonsteroidal anti-inflammatory drugs and prostate cancer incidence. J Natl Cancer Inst. 2005;97(13):975-80. [pmid: 15998950].
179 Haiman CA, Le Marchand L, Yamamato J, et al. A common genetic risk factor for colorectal and prostate cancer. Nat Genet. 2007;39(8):954-6. [pmid: 17618282].
180 Flossmann E, Rothwell PM. British Doctors Aspirin Trial and the UK-TIA Aspirin Trial. Effect of aspirin on long-term risk of colorectal cancer: consistent evidence from randomised and observational studies. Lancet. 2007;369(9573):1603-13. [pmid: 17499602].
181 Peto R. Randomised trial of prophylactic daily aspirin in british male doctors. BMJ. 1988;296(6618):313-6. [pmid: 3125882].
182 Farrell B. The United Kingdom transient ischaemic attack (UK-TIA) aspirin trial: Final results. J Neurol Neurosurg Psychiatry. 1991;54(12):1044-54. [pmid: 1783914].
183 Burton PR. Size matters: just how big is BIG? Quantifying realistic sample size requirements for human genome epidemiology. Int J Epidemiol 2008;1–11.
184 Austoker J. Breast self-examination. BMJ. 2003;326:1-2. [pmid: 12511431].
185 U.S.Preventive Services Task Force. Screening for Breast Cancer. Agency for Healthcare Research and Quality, Rockville, MD.November 2003. http://www.ahrq.gov/clinic/uspstf/uspsbrca.htm (http://http://www.ahrq.gov/clinic/uspstf/uspsbrca.htm).
186 Baker S, Wall M, Bloomfield A. What is the most appropriate breast-cancer screening interval for women aged 45 to 49 years in New Zealand?. [Review] [52 refs]. N Z Med J. 2005;118(1221):U1636. [pmid: 16138174].
187 U.S.Preventive Services Task Force. Screening for Colorectal Cancer. Agency for Healthcare Research and Quality, Rockville, MD.October 2008. http://www.ahrq.gov/clinic/uspstf/uspscolo.htm#related.
188 Whitlock EP, Lin J, Liles E, Beil T, Fu R, O'Connor E, Thompson RN, Cardenas T. Screening for Colorectal Cancer: An Updated Systematic Review. Health Services/Technology Assessment Text. (HSTAT. http://www.ncbi.nlm.nih.gov/books/bv.fcgi?rid=hstat3.chapter.54428).
189 Lin K, Lipsitz R. Benefits and harms of prostate-specific antigen screening for prostate cancer: an evidence update for the U.S. Preventive Services Task Force. Ann Intern Med. 2008;149:192-9. [pmid: 18678846].
190 U.S.Preventive Services Task Force. Screening for Ovarian Cancer. Agency for Healthcare Research and Quality, Rockville, MD.May 2004. http://www.ahrq.gov/clinic/uspstf/uspsovar.htm.
191 Scheuner MT, Rotter JI. Quantifying the health benefits of genetic tests: a clinical perspective. Genet Med. 2006;8(3):141-2. [pmid: 16540747].
192 Mandelson MT. Colorectal cancer screening participation by older women. Am J Prev Med. 2000;19:149-54. [pmid: 11020590].
193 Slattery ML, Edwards SL, Ma KN, et al. Colon cancer screening, lifestyle, and risk of colon cancer. Cancer Causes Control. 2000;11(6):555-63. [pmid: 10880038].
194 Madlensky L, Esplen MJ, Gallinger S, et al. Relatives of colorectal cancer patients: factors associated with screening behavior. Am J Prev Med. 2003;25(3):187-94. [pmid: 14507524].
195 Jacobsen PB, Lamonde LA, Honour M, et al. Relation of family history of prostate cancer to perceived vulnerability and screening behavior. Psychooncology. 2004;13(2):80-5. [pmid: 14872526].
196 Slattery ML, Kinney AY, Levin TR. Factors associated with colorectal cancer screening in a population-based study: the impact of gender, health care source, and time. Prev Med. 2004;38(3):276-83. [pmid: 14766109].
197 Ramji F, Cotterchio M, Manno M, et al. Association between subject factors and colorectal cancer screening participation in Ontario, Canada. Cancer Detect Prev. 2005;29(3):221-6. [pmid: 15896925].
198 Bloom JR, Stewart SL, Oakley-Girvans I, et al. Family history, perceived risk, and prostate cancer screening among African American men. Cancer Epidemiol Biomarkers Prev. 2006;15(11):2167-73. [pmid: 17119042].
199 Beresford SA, Johnson KC, Ritenbaugh C, et al. Low-fat dietary pattern and risk of colorectal cancer: the Women's Health Initiative Randomized Controlled Dietary Modification Trial. JAMA. 2006;295(6):643-54. [pmid: 16467233].