# Executive Summary

Family history reflects the combined influences of genetics, environmental exposures, and behaviors within families, ^1^ and is a risk factor for some clinically important chronic diseases such as cardiovascular disease, diabetes mellitus, stroke, and several cancers. ^2,^ ^3^ Family history reflects genomic, social and environmental risk which is shared between relatives. This ‘compressed information’ ^4^ may provide predictive information independent of other known risk factors.

Individual risk stratification systems based on family history may carry valuable predictive information for individual patients, but they need to be validated for application in routine practice. The usefulness of family history-based risk stratification systems in disease prevention depends on (a) accurate reporting and capture of family history information, (b) valid methods of risk classification, (c) effective preventive interventions to manage disease risk, and (d) evidence that the use of family history information provides incremental net benefit over and above non-family history-based alternative approaches. With the exception of accuracy of reporting, this systematic review is designed to inform all of these issues.

## Scope and Purpose of the Systematic Review

This report, which builds on a previous evidence report ^5^ on the topic of tools for collecting and interpreting family history information, addresses the clinical utility of routinely using family history information in risk assessment and prevention for breast, ovarian, colorectal, and prostate cancers in primary care. The specific research questions are:

1 Which risk stratification algorithms or guidelines delineate risk accurately, and in a clinically meaningful way?
2 For which behaviors and clinical preventive services (‘interventions’) is there evidence of benefits in terms of actual reduction in disease risk, and what harms, if any, have been identified?
3 For those interventions identified as being based on reasonable evidence, what is the evidence that providing information on risk status results in behavior change or increased uptake of services on the part of individual patients?
4 What are the harms or risks to individual patients that may result from the collection of family history information in itself, and/or the provision of family history-based risk information?

These questions represent the links in the chain between taking family history and producing benefit: Does family history predict future risk of cancer? If so, are there interventions to reduce this risk, and do they also carry their own risks? Does a family history-based approach lead to higher uptake of preventive interventions? Are there any direct harms which arise from a family history-based approach?

This review's focus is therefore firmly on the application of family history taking from general populations under the care of primary care providers such as family physicians, internists, nurse practitioners, and obstetricians. We sought to examine the capture and use of family history information as an activity practiced in primary care, where patients are not pre-selected for risk, and where the approach to capturing information is heavily influenced (often constrained) by contextual factors, ^6^ and where the preventive interventions available are those that can be recommended by a primary care practitioner. This is distinctly different from clinical genetics assessment, where the central focus is on extensive family history capture, validation, and assessment, where the patient population is usually pre-selected for high risk status.

## Methods

Standard systematic review methodology was employed. MEDLINE^®^, EMBASE^®^, CINAHL^®^, Cochrane Central^®^, Cochrane Database of Systematic Reviews, and PsycINFO were searched from 1990 to June 2008 inclusive. Cancer guidelines and recommendations were searched from 2002 forward and systematic reviews from 2003 to June 2008.

Eligibility criteria included English studies evaluating breast, colorectal, ovarian, or prostate cancers. Study designs varied by question, but were restricted to systematic reviews of effectiveness (Question 2), and experimental (Questions 3 and 4) and diagnostic evaluation (Question 1) types. Populations were limited to those unselected for cancer risk. Interventions were the structured/systematic collection of family history (Questions 1, 3, and 4) and primary or secondary cancer prevention (screening) interventions (Question 2). The outcomes were disease incidence or proxy (Questions 1 and 2), uptake of recommended preventive interventions (Question 3), and harms (e.g., psychological distress) (Question 4).

## Results

Our comprehensive search yielded 10,644 unique citations; from these 9,765 were excluded as they were not an English language publication, not on the cancers of interest, or on topic for any of the four research questions. The remaining 879 citations were screened at full text and from these a total of 12 primary studies and 29 systematic reviews were eligible.

## Research Q1: Which Risk Stratification Algorithms or Guidelines, Delineate Risk Accurately and in a Clinically Meaningful Way?

General approach. The purpose of this question was to establish whether family history-based risk stratification systems (of any kind) could accurately predict risk in individual patients. We reviewed published studies that examined the discriminatory accuracy of models (algorithms, guidelines) that used family history information to predict individual risk of breast, ovarian, colorectal or prostate cancer. To be eligible, a model had to incorporate specified family history information (either alone or with other personal or clinical information which would be routinely available on all patients to a primary care practitioner), and validation data in a defined general population had to be presented. The main outcome of interest was discriminatory accuracy, which reflects the proportion of individuals correctly classified by the tool with respect to actual disease incidence. This was variously presented as a concordance statistic, the area under the curve in receiver operating characteristic (ROC) analyses, or correlation coefficient, and reflects the usefulness of the model for use in the assessment of individual patients.

Findings. Eight evaluation studies were identified as eligible after full text review. ^7^ – ^14^ All tools except one were designed for breast cancer risk assessment. The breast cancer tools were all generally related to the original Gail model, ^15^ including the model developed from the Contraceptive and Reproductive Experiences Study (the CARE model ^7^ ). The Harvard Cancer Risk Index ^16^ (HCRI) was developed for application to a number of cancers, but an eligible validation study was identified only for colon cancer. No eligible studies were identified of tools based strictly on family history information alone.

The original evaluation of the Gail model was conducted in a predominantly white U.S. female population, ^8^ and reported discriminatory accuracy in terms of a Pearson correlation coefficient (0.67). The other breast cancer models were evaluated in white, ^9^ “diverse”, ^13^ African American, ^7,^ ^10^ and Italian ^11,^ ^12^ populations. These studies reported concordance statistics in the range of 0.55–0.59, indicating very modest discriminatory accuracy.

The HCRI was evaluated for prediction of colon cancer ^14^ in secondary analyses of cohort data, and reported concordance statistics of 0.67 and 0.71 for women and men, respectively. This suggests moderate discriminatory accuracy (67 and 71 percent correct prediction of eventual cancer status respectively, 50 percent being that expected by chance alone).

## Research Q2: For Which Behaviors and Clinical Preventive Services is There Evidence of Benefit in Terms of Actual Reduction in Disease Risk, and What Harms, if any, Have Been Identified?

General approach. The purpose of this question was to establish the link between stratifying cancer risk and being able to intervene to alter that risk, and not to conduct an exhaustive review of the extensive literature around cancer risk factors. We therefore evaluated published systematic reviews on a range of interventions which are generally recommended as part of cancer risk reduction strategies in primary care settings. Where multiple reviews addressing the same intervention were identified, we selected the most recent or most comprehensive for reporting, and considered differences in methodological quality. ^17^

Findings. Twenty-nine systematic reviews were retained after full text review, addressing four chemoprevention interventions (antioxidant supplementation, calcium supplementation, non-steroidal anti-inflammatory drugs (NSAIDS), but not COX-2 inhibitors and statins) and five screening interventions (breast self-examination (BSE), screening mammography, fecal occult blood testing (FOBT), flexible sigmoidoscopy (FS), and prostate specific antigen (PSA) for three cancers (breast, colorectal, prostate). No reviews were identified for several interventions of interest, and none were relevant to ovarian cancer prevention.

Data were extracted from the 10 reviews that represented the most comprehensive, up-to-date, and high quality evidence. ^18^ – ^27^ Of the remainder where data were not abstracted, 12 reported overlapping data, ^28^ – ^39^ five did not identify primary intervention studies despite these being designed to do so, ^40^ – ^44^ and two did not report usable data. ^45,^ ^46^

Overall quality assessment suggested low risk for bias, the main area of weakness being failure to describe adequate control of bias in study selection. ^18^ – ^20,^ ^22,^ ^23,^ ^27^ Other issues were incomplete description of search methods, ^23,^ ^27^ failure to describe criteria for assessing the validity of primary studies, ^20,^ ^25,^ ^26^ and failure to cite the validity assessments of included studies. ^20,^ ^26^

### Breast Cancer

Five systematic reviews synthesized evidence on chemoprevention (antioxidants and statins) and screening (breast self-examination (BSE) and screening mammography).

Antioxidants. One review ^18^ evaluated supplements that contained any combination of ß-carotene, vitamin C, vitamin E, selenium, zinc, and other antioxidants, and concluded no evidence of a protective effect of any combination against breast cancer (RR 1.00, 95 percent CI 0.90–1.09) at one year followup. A second review ^19^ examined vitamin E alone or in any combination in three high quality randomized controlled trials (RCT) and concluded no evidence of a reduction in breast cancer incidence (RR 0.99, 95 percent CI 0.90–1.10).

Statins. One review, ^20^ suggested that statins appeared to confer neither a protective nor a harmful effect on breast cancer incidence (RR 1.01, 95 percent CI 0.79–1.30).

BSE. One review ^21^ showed no impact of BSE on breast cancer mortality (RR 1.05, 95 percent 0.98–1.14).

Screening mammography. The most recent comprehensive review, ^22^ suggested that screening mammography was associated with reduced breast cancer mortality at 13 years (RR 0.80, 95 CI 0.73–0.88), although concerns were raised about inadequate bias control in some primary trials. No effect on overall mortality was noted (RR 1.00, 95 percent CI 0.96–1.04).

### Colorectal Cancer

Six reviews evaluated interventions in colorectal cancer (CRC) prevention, four on chemoprevention (antioxidants, NSAIDS, statins) and two on screening (fecal occult blood testing (FOBT) and flexible sigmoidoscopy (FS)).

Antioxidants. One review ^18^ evaluated supplements which contained any combination of ß-carotene, vitamin C, vitamin E, selenium, zinc, and showed no evidence of a protective effect against CRC incidence (RR 1.00, 95 percent CI 0.90–1.10). A second review ^19^ evaluated vitamin E given in any combination and found no evidence of an effect on CRC incidence (RR 0.95, 95 percent CI 0.81–1.12).

NSAIDS. One review evaluated low dose ASA, ^23^ and found no evidence of an effect on CRC incidence (RR 1.02, 95 percent CI 0.84–1.25), CRC mortality (RR not reported) or adenoma incidence (RR 0.85, 95 percent CI 0.68–1.1) at 5 years.

Statins. One review ^20^ showed neither a protective nor harmful effect of statins on CRC incidence (pooled RR 1.02, 95 percent CI 0.89–1.16) or CRC mortality (RR 0.33, 95 percent CI 0.07–1.63).

FOBT. One review ^24^ examined FOBT (guaiac or immunochemical) in studies of at least two rounds of screening were compared with no screening. A statistically significant effect of screening on CRC mortality was observed (RR 0.84, 95 percent CI 0.78–0.90), and no effect on all-cause mortality (RR 1.00, 95 percent CI 0.99–1.01).

FS. A single review ^25^ examined the evidence for FS in CRC screening, identifying a single RCT comparing FS plus FOBT against FOBT alone. No statistically significant effect was found on CRC mortality or incidence (RR 0.78, 95 percent CI 0.36–1.73 and 1.37, 95 percent CI 0.88–2.15, respectively).

### Prostate Cancer

Five reviews synthesized evidence in relation to prostate cancer prevention: four relating to chemoprevention (antioxidants, calcium, and statins) and one relating to screening (prostate-specific antigen (PSA) with digital rectal examination (DRE) and trans-urethral ultrasound (TRUS) biopsy).

Antioxidants. One review ^18^ evaluated supplements that contained any combination of ß-carotene, vitamin C, vitamin E, selenium, zinc, and other antioxidants. The pooled analysis of all antioxidants showed no effect on prostate cancer incidence (RR 0.87, 95 percent CI 0.74–1.02), and a reduced risk associated with vitamin E specifically (RR 0.82, 95 percent CI 0.67–0.99). A second review ^19^ of vitamin E in any combination showed a negative association with prostate cancer incidence (RR 0.85, 95 percent CI 0.74, 0.96).

Calcium. One review evaluated calcium supplementation and prostate cancer risk, ^26^ where this was a secondary outcome in a single colorectal adenoma prevention trial. ^47^ It suggested a statistically significantly lower incidence of prostate cancer in the supplement group until 2 years after supplementation was discontinued (rate ratio 0.52, 95 percent CI 0.28–0.98), at which point the risk in both groups converged.

Statins. One review ^20^ examined the effectiveness of statins on prostate cancer. The results indicated that statins appeared to neither increase nor decrease the risk of prostate cancer incidence or mortality (RR 1.00, 95 percent CI 0.85–1.17 and RR 0.99, 95 percent CI 0.14–7.01, respectively).

PSA-based screening. One review ^27^ examined the effectiveness of PSA-based population screening (with DRE and TRUS biopsy) in two trials, one with an annual and the other a three times yearly, screening cycle. No statistically significant impact of screening on prostate cancer mortality was found (RR 1.01, 95 percent CI 0.80–1.29).

## Research Q3: For Those Interventions Identified as Being Based on Reasonable Evidence, What is the Evidence That Providing Information on Risk Status, Results in Behavior Change or Increased Uptake of Services on the Part of Individual Patients?

General approach. The focus of this question was behavior: whether giving people personalized risk advice based on their family history would lead to a higher adherence with preventive recommendations. We evaluated intervention studies in which the outcomes were actual risk-reduction behavior, focusing on interventions that were considered standard of care when the primary study was conducted.

Findings. Three studies ^48^ – ^50^ were eligible, all focusing on uptake of screening interventions for breast cancer as the target behavior. Two were randomized controlled trials ^49,^ ^50^ and examined different levels of personalization of risk information. The third ^48^ was an uncontrolled before-after study.

One trial ^48^ showed a borderline statistically significant difference (P = 0.05) in mammography uptake (about 8 percent) between intervention and control groups. The other two studies were null. The community pharmacy study ^46^ was the only one to examine other behaviors, and showed a statistically significant increase in self-reported BSE, but not CBE.

## Research Q4: What are the Harms or Risks to Individual Patients That may Result From the Collection of Family History Information in Itself, and/or the Provision of Family History-Based Risk Information?

General approach. The purpose of this question was to identify whether the process of capturing family history and feeding back personalized risk, in and of itself, was associated with identifiable harms. We reviewed published intervention studies which examined the direct impact of family history-based risk information on quality of life, psychological, and social impact, where these could be directly attributed to this intervention and not subsequent investigations or preventive activities.

Findings. One eligible study was identified, ^51^ an uncontrolled before-after study designed to evaluate the psychological impact of providing family history information and receiving a personalized risk assessment for breast cancer. In all participants, no statistically significant change in anxiety or cancer worry between baseline and followup was observed. In participants whose risk assessment indicated “population risk”, a small reduction in self-perceived risk was observed (P<0.01). In participants who required further assessment (‘true’ high risk and ‘false positive’ groups), higher baseline cancer risk perception scores were observed compared with the group assessed as population risk (P<0.001 for ‘higher risk’ group and P=0.003 for ‘false positive’ group).

## Discussion and Conclusions

The purpose of this review was to establish the evidence base to answer the question, “In primary care settings, and in relation to breast, ovarian, colorectal or prostate cancers, would the routine use of family history-based risk assessment be likely to lead to net health benefits?” We identified a very limited evidence base for all four of the research questions.

While there are a number of FHx-based cancer risk stratification systems, no evaluations have been published of any based only on FHx information. Of those models which include FHx information along with other clinical variables, published validations suggest good epidemiological calibration but no more than modest individual discriminatory accuracy. The models evaluated were not necessarily developed for general clinical use.

The experimental evidence base, represented in published systematic reviews, for primary and secondary cancer prevention in general populations is very limited. The most consistent evidence supports screening mammography and FOBT-based colorectal screening strategies, with equivocal evidence for vitamin E and calcium in reducing the risk of prostate cancer. The review likely did not include some experimental evidence for interventions which have not been examined in systematic reviews, but which would be relevant to the main study questions.

There is insufficient evidence to assess the effect of FHx-based risk assessment on preventive behaviors. Very few trials have been conducted, and none in settings resembling routine primary care practice. There is also insufficient evidence to assess definitively whether FHx-based personalized risk assessment directly causes adverse outcomes; the results of the single study available indicate the need to take into account baseline psychological status and risk perception in assessing the impact of FHx-based risk information.

### Conclusions

1 The evidence for the predictive accuracy of algorithms in primary care populations was very limited. Although many tools were identified that incorporated some family history information, no evaluations of solely family history-based tools. The tools on which it was possible to comment related mainly to breast cancer.
  Recommendations for future research:
  - The actual performance of tools based only on family history should be formally examined in primary prospective studies, and/or in secondary analysis of large cohort studies.
  - The performance of individual family history components of different risk stratification models which use a wider range of factors (including those examined in this report) should be examined separately from the non-family history components, in order to determine whether they provide sufficient predictive power in the absence of the non-family history factors.
  - For clinical relevance, the focus of validation should be discriminatory accuracy at the individual patient level.
  - More definitive evaluation should examine the effect on health outcomes when risk stratification systems are used in combination with preventive interventions, in actual practice settings. This cannot be done with secondary analyses of observational data and requires well-designed intervention studies.
2 The evidence establishing the efficacy of interventions for primary and secondary prevention based on systematic reviews of randomized or controlled clinical studies in unselected populations is very limited. Interventions for which there were reviews include chemoprevention (antioxidants, calcium, NSAIDS, and statins) and screening interventions (BSE, mammography, FBOT, FS, and PSA) for breast, colorectal and prostate cancers. No reviews were found for ovarian cancer. It is likely that this review excluded effectiveness data available from RCTs of interventions which have not yet been the subject of systematic reviews.
  Recommendations for future research:
  - The large amount of evidence on potential primary cancer preventive interventions obtained from observational studies of cancer risk factors should continue to be further evaluated in well-designed randomized controlled trials.
  - Further systematic reviews should be conducted to examine the full range of potentially preventive interventions
3 Within primary care populations, there is very limited evidence to support or refute the effect on risk-reducing behavior changes (e.g., lifestyle changes or uptake of recommended clinical interventions) of taking a family history and using it to personalize risk of breast, ovarian, colorectal or prostate cancer.
  Recommendations for future research:
  - Well-designed trials are required that compare family history-based, personalized risk advice with standard of care on risk reducing behaviors in populations at different risk levels (including population risk).
4 In primary care populations, there is very limited information to evaluate direct harm incurred from the routine practice of taking family history and using it to personalize risk information.
  Recommendations for future research:
  - Trials of family history taking as an intervention should include capture of data to examine the full range of potential impacts on individuals. Baseline data on psychological status should be captured so that this can formally be adjusted for in outcome analyses.
5 Research on the use of family history tools, risk stratification systems, and family history-based personalized prevention advice should take into account evidence on the factors likely to promote their effective use in practice, such as the educational needs of primary care practitioners and issues which act as barriers or constraints to their implementation in practice.