# Acknowledgments

The researchers at the Evidence-based Practice Center would like to acknowledge the following people for their contributions.

We are grateful to Gurvaneet Randhawa, Supriya Janakiraman and members of the technical expert panel who were instrumental in developing the questions and defining the scope of this review: Robert German, Rodolfo Valdez, Lisa Madlensky, and Louise Acheson.

We would also like to thank Maureen Rice for developing and running the search strategies; Catherine Salmon, Connie Freeborn, Robert Stevens, Lynda Booker, Solina Yoo, Kate Walker, Sara Kaffashian, and Maureen Rice for screening the citations; and Sara Shepley for managing the references in RefMan and SRS and for assistance in article retrieval.

Thank you to Rachel Morris for the many hours of screening and data abstraction.

We would like to thank Valery L'Heureux and Silvia Visentin at the University of Ottawa for their administrative assistance to the investigators.

Finally we would like to say thank you to Mary Gauld, Maureen Rice, Roxanne Cheeseman, and Cecile Royer for their invaluable input in the editing and formatting of this report.