# Methods

## Analytic framework

The analytic framework is a schematic representation of the strategy for showing the relationships between the primary exposure, which is the collection of cancer family history, and the outcomes of interest for each research question. Figure 2 shows the inter-relationships among the four research questions being addressed in this systematic review. Cancer family history is an important component of algorithms, models, and guidelines used to predict risk of cancer or gene mutation; we evaluated predictive accuracy outcomes of eligible algorithms, models, or guidelines in the first research question (Q1). A large number of interventions have been implemented to address primary and secondary prevention of the cancers of interest; our second research question evaluated the evidence from systematic reviews and evaluated outcomes of benefit and harm from these interventions (Q2). Following the collection of cancer family history, the uptake of these prevention and screening interventions was the outcome of interest for our third research question (Q3). Our final research question focused on the potential for harmful outcomes as a result of collecting family history (Q4).

Figure 2. Analytic framework for the research questions evaluated in this review

### Search Strategy

Bibliographic databases searched for this review included: MEDLINE®, EMBASE®, CINAHL®, Cochrane Controlled Trials Register (CCTR)® (Q1, Q3, Q4), Cochrane Database of Systematic Reviews (Q2), and PsycINFO (Q3). Years searched were 1990 to June 2008 inclusive (Q1, Q3, and Q4). We searched for cancer guidelines and recommendations from 2002 forward to ensure that the guidelines were reasonably current. We also searched the grey literature, including the National Clearing House for guidelines. Based on input from our Technical Expert Panel we searched the Guide to Community Preventive Services published by the CDC ^80^ and other appropriate guidelines (e.g., U. S. Preventive Services Task Force recommendations for the prevention and screening interventions for the cancers of interest).

Finally, we restricted the search for systematic reviews (Q2), from 2003 to June 2008 (Q2). As per the recommendations of our content experts, we reviewed the methods and content of the report “Food, Nutrition, Physical Activity, and the Prevention of Cancer: a Global Perspective” published by World Cancer Research Fund’ from American Institute for Cancer Research (updated for breast cancer only in Spring 2008). ^81^ This report reflects an international initiative that has systematically reviewed the literature to evaluate the cancer prevention evidence for a range of interventions broadly including exercise and related behaviors, food and food supplements (including vitamins), and screening interventions for different types of cancer (including breast, ovarian, colorectal, and prostate cancers). Since this World Cancer Review comprehensively captured and evaluated the literature on these interventions from root to the end of 2006), we did not include any reviews on these particular interventions for this time period.

In addition we retrieved and evaluated references from eligible articles. Hand searching was not undertaken, but we reviewed the publication type “letters” (normally excluded from reviews); the investigators suggested that, within the content area of cancer genetics, primary data information might be published as letters in some journals. Finally, we formally reviewed all articles suggested by peer reviewers of the draft evidence report and incorporated those which met eligibility criteria. Detailed search strategies are listed in Appendix A.

### Eligibility Criteria

A list of eligibility criteria was determined and standardized forms were developed in Systematic Review Software (SRS, 3.0, TrialStat Corporation, Ottawa, Ontario Canada) and Microsoft Excel for the purposes of this systematic review.

#### Publication Year, Type, and Language

##### Inclusion

Language: Only English language studies were eligible. (Q1, Q2, Q3, Q4)

Publication Date: 1990 to June 2008. (Q1, Q3, Q4)

2003 to June 2008 (Q1 guidelines/recommendations and Q2)

##### Exclusion

Publications that were editorials, comments, opinions, or abstract only (Q1, Q2, Q3, Q4)

### Eligibility Criteria for Research Q1

#### Population

Any patient or general populations not selected for known or suspected pre-existing elevated risk of breast, ovarian, colorectal, and/or prostate cancer

##### Inclusion

- populations sampled from clinical settings, including population screening programs
- participants in analytical epidemiological research studies

##### Exclusion

- people with a personal history of breast, ovarian, colorectal, or prostate cancer
- people at high risk of cancer, as estimated by an existing risk assessment system
- populations sampled from specialist genetic clinics or cancer family clinics
- people who have had a genetic test for a mutation related to one of the cancers of interest (irrespective of result)

#### Intervention

##### Inclusion

Any system designed

- to use family history information alone, or in combination with other information typically and universally available to primary care practitioners (i.e., personal/demographic factors, past medical history, clinical observations that do not require specialist referral)
- to stratify people into two or more risk categories OR to provide a numerical point estimate of risk of developing breast, ovarian, colorectal, and/or prostate cancer, over any time period
- for application in risk assessment of individual patients
- in which the model validation is tested on a patient sample different than the one used to develop the model

##### Exclusion

- Systems which do not incorporate family history information
- Systems which include data from specialist investigations which are typically unavailable in primary care settings

#### Design

##### Inclusion

1 Analytical studies examining disease risk categorization as the ‘exposure’ and cancer incidence or proxy as the ‘outcome’
  - cohort (prospective or historical)
  - case control
2 Diagnostic studies examining disease risk categorization using the algorithm as the ‘test’ and cancer incidence or proxy as the ‘reference’
3 Intervention studies examining disease risk classification system as the ‘intervention’ and correct prediction of cancer incidence or proxy as the ‘outcome’
  - randomized controlled trials (cancer risk classification system compared with any other system, or no system)
  - non-randomized controlled trials (cancer risk classification system compared with any other system, or no system)
  - uncontrolled before-after studies (data on prediction of patients' cancer risk before and after the introduction of a cancer risk classification system)

##### Exclusion

None

#### Outcome

##### Inclusion

1 Model calibration, expressed as observed versus expected cases
2 Model discriminatory accuracy, expressed as sensitivity, specificity, predictive value, likelihood ratio, concordance statistic, receiver operator characteristics (ROC), area under the curve (AUC), or other appropriate summary statistic
  For the outcomes of
  - incidence of breast, ovarian, colorectal, or prostate cancer
  - breast-, ovarian-, colorectal-, or prostate-specific mortality
  - proxies - incidence of known precancerous states, such as colorectal adenomatous polyps
  Over any defined time period

##### Exclusion

None

### Eligibility Criteria for Research Q2

#### Population

##### Inclusion

Reviews where eligibility criteria include AND outcome data are presented separately for:

General population, primary care patients or participants in population screening programs who may or may not have been selected by age and sex criteria but not on the basis of a priori higher risk, such as:

- personal history of cancer
- known precancerous condition
- known disorder which increases cancer risk
- known or suspected familial cancer syndrome

Participants may have had relatives with cancer, but they are not selected specifically on the basis of suspected [underlined: genetic] risk

##### Exclusion

Reviews where the eligibility criteria focus specifically on people eligible for, or who have had, a genetic test for a cancer-associated mutation (irrespective of result)

#### Intervention

##### Inclusion

Breast

- breast self-examination
- clinical examination
- screening mammography
- chemoprevention
- magnetic resonance imaging breast screening (MRI)
- referral for genetic counseling +/- genetic testing, where criteria are met

Colorectal

- fecal occult blood (FOB) test
- screening colonoscopy
- screening sigmoidoscopy
- chemoprevention
- referral for genetic counseling +/- genetic testing, where criteria are met

Ovarian

- ultrasound screening
- referral for genetic counseling +/- genetic testing, where criteria are met

Prostate

- prostate-specific antigen (PSA) screening
- digital rectal examination
- chemoprevention
- referral for genetic counseling +/- genetic testing, where criteria are met

General behaviors for all four cancers

- vitamins, minerals, micronutrient supplementation
- regular exercise/physical activity
- high fiber diet
- increased fruit and vegetable consumption or specific food intake
- low fat diet
- smoking cessation
- reduction in alcohol intake
- seeking healthcare advice
- participation in recommended screening/surveillance

##### Exclusion

None

### Comparator/Study Design

#### Inclusion

Systematic reviews of primary studies which seek to identify studies with the following designs

- randomized controlled trials
- non-randomized controlled trials
- uncontrolled before-after studies (or non-controlled trials)

Comparators:

- as reported in primary studies

##### Exclusion

Systematic reviews of primary studies which focus solely on the following designs

- cohort studies
- case-control studies
- case series and case reports

#### Outcomes

##### Inclusion

- cancer incidence
- cancer-related mortality
- all cause mortality
- incidence of known precancerous conditions
- complications of diagnosis, complications or side effects of treatment, psychosocial sequelae

##### Exclusion

All other outcomes

### Eligibility Criteria for Research Q3

Population

Any patient or general populations not specifically selected for known or suspected pre-existing elevated risk of breast, ovarian, colorectal, and/or prostate cancer

#### Inclusion

- populations sampled from population or clinical settings, including population screening programs

#### Exclusion

- populations selected entirely on the basis of a personal history of breast, ovarian, colorectal, or prostate cancer
- populations selected entirely on the basis of having a high risk of cancer, as estimated by an existing risk assessment system or a genetics specialist
- populations sampled from specialist genetics clinics or cancer family clinics
- populations selected entirely because they have had a genetic test for a mutation related to one of the cancers of interest (irrespective of the result)

#### Intervention

##### Inclusion

Systematic provision of personal risk of breast, colorectal, prostate and/or ovarian cancer based on family history, alone or combined with individual advice on appropriate risk reduction behaviors and/or services

##### Exclusion

- family history taking without provision of personal risk information
- advice on risk reduction not accompanied by, or based on, family history information
- provision of general risk information
- genetic counseling

#### Comparator/Study Design

##### Inclusion

Primary studies of the following study designs:

- randomized controlled trials
- non-randomized controlled trials
- uncontrolled before-after studies (or non-controlled trials)

Comparators:

- no comparator group
- comparator group with no intervention
- comparator group receiving preventive advice without provision of family history-based information

##### Exclusion

- cohort studies
- case-control studies
- case series and case reports

#### Outcomes

##### Inclusion

- change in target behaviors related to cancer prevention, considered standard advice at the time of the primary study
- uptake of services identified in (Q2) or considered current/standard of care at the time of the primary study

##### Exclusion

None

### Eligibility Criteria for Research Q4

#### Population

Any patient or general populations not specifically selected for known or suspected pre-existing elevated risk of breast, ovarian, colorectal, and/or prostate cancer

##### Inclusion

- populations sampled from population or clinical settings, including population screening programs

##### Exclusion

- populations selected entirely on the basis of a personal history of breast, ovarian, colorectal, or prostate cancer
- populations selected entirely on the basis of having a high risk of cancer, as estimated by an existing risk assessment system or a genetics specialist
- populations sampled from specialist genetics clinics or cancer family clinics
- populations selected entirely because they have had a genetic test for a mutation related to one of the cancers of interest (irrespective of the result)

#### Intervention

##### Inclusion

Systematic collection of family history information and/or the provision of family history-based personal risk of breast, colorectal, prostate, and/or ovarian cancer

##### Exclusion

- advice on risk reduction not based on family history information
- provision of general risk information
- genetic counseling

#### Comparator/Study Design

##### Inclusion

Primary studies of the following study designs:

- randomized controlled trials
- non-randomized controlled trials
- uncontrolled before-after studies (non-controlled trials)

Comparators:

- no comparator group
- comparator group with no intervention
- comparator group with intervention not based on family history collection or family history-based preventive advice

##### Exclusion

- cohort studies
- case-control studies
- case series and case reports

#### Outcome

##### Inclusion

- psychological status
  - anxiety/distress
  - cancer worry
  - depression
  - inaccurate risk perception
  - other psychological outcome
- quality of life
- social impacts
  - family functioning including dynamics/communication, etc.
  - insurance or employment discrimination
  - other

##### Exclusion

- outcomes not listed above

Figure 3 illustrates the flow of studies based on the eligibility criteria described.

FIgure 3. Flow of studies to final number of eligible studies

### Study Selection

A team of study assistants was trained to apply the eligibility criteria for screening the title and abstract lists and the full text papers. All levels of screening were done in web-based Systematic Review Software (SRS) (TrialStat Corporation, Ottawa, Ontario Canada). Standardized forms and a training manual explaining the criteria were developed and reviewed with the screeners (Appendix B). For the title and abstract phase, two reviewers evaluated each citation for eligibility. Articles were retrieved if either one of the reviewers judged it as meeting eligibility criteria or if there was insufficient information to determine eligibility. For screening of full text articles, two screeners came to consensus on the identification, selection, and abstraction of information. Disagreements that could not be resolved by consensus were resolved by one of our McMaster research team members.

### Data Extraction

Appropriate data collection forms were developed for use in the SRS (Appendix B). All eligible studies from the selection phase (full text screening) were abstracted onto a data form according to predetermined criteria. One data extractor transferred the data onto these forms, and another checked the answers for accuracy before they were entered into SRS. Data entries were verified by the investigators responsible for summarizing the different report results sections.

### Quality Assessment and Peer Review

Quality assessment of studies was undertaken in varying forms. Studies eligible for (Q1) were evaluated for potential bias in relation to the model variables and selection bias. For the systematic reviews identified for (Q2), a modified version of the Oxman-Guyatt Overview Quality Assessment Questionnaire, a validated, 10-item assessment scale was used. ^82^ Studies for (Q3 and Q4) were evaluated using the Jadad scale for randomized trials. ^83^

A draft version of this report was circulated to 14 peer reviewers (see Appendix E). Where possible, comments and suggestions were incorporated.

## Summarizing our Findings: Descriptive and Analytic Approaches

A qualitative descriptive approach was used to summarize study characteristics and outcomes. Multiple publications on the same study cohort were grouped together and treated as a single study with the most current data reported for presentation of summary results. Standardized summary tables explaining important study population and population characteristics, as well as study results, were created. Meta-analysis was not undertaken for eligible studies for (Q1, Q3, or Q4) as the clinical heterogeneity between studies was considerable.