# Appendix E - Partners, Technical Expert Panel, and Peer Reviewers

## Task Order Officer

Supriya Janakiraman, M.D., M.P.H.

Staff Service Fellow, Center for Outcomes and Evidence AHRQ

Rockville, MD

## Partners

Robert German, Dr.P.H., M.P.H.

Associate Director for Science, Division of Cancer Prevention and Control,

Centers for Disease Control and Prevention

Atlanta, GA

Rodolfo Valdez, Ph.D., M.Sc.

National Office of Public Health Genomics

Centers for Disease Control and Prevention

Atlanta, GA

## Members of the Technical Expert Panel

Lisa Madlensky, Ph.D.

Assistant Professor, Cancer Prevention & Control Program

University of San Diego

San Diego, CA

Louise Acheson, M.D., M.S.

Professor of Family Medicine and Oncology

Associate Professor of Reproductive Biology

Case Western Reserve University and University Hospitals Case Medical Center

Euclid, OH

## Peer Reviewers

Louise Acheson, M.D., M.S.

Professor of Family Medicine and Oncology

Associate Professor of Reproductive Biology

Case Western Reserve University and University Hospitals Case Medical Center

Euclid, OH, U.S.A

George Browman, M.D., M.Sc.

Senior Scientist, BC Cancer Agency

Chair of the Cancer Guidelines Action Group of the Canadian Partnership Against Cancer

Victoria, BC, C.A.

W.Greg Feero, M.D., Ph.D.

Senior Advisor for Genomic Medicine

National Human Genome Research Institute

National Institutes of Health

Bethesda, MD, U.S.A.

Andrew Freedman, M.D., M.Sc.

National Cancer Institute, Epidemiologist

Bethesda, MD, U.S.A.

Joy Larsen Haidle, M.S., C.G.C.

Genetic Counselor

Hubert H. Humphrey Cancer Center

Robbinsdale, MN, U.S.A.

Lisa Madlensky, Ph.D.

Assistant Professor, Cancer Prevention & Control Program

University of San Diego

San Diego, CA. U.S.A.

Phuong Mai, M.D.

Staff Clinical, Clinical Genetics Branch

Division of Cancer Epidemiology and Genetics

National Cancer Institute, National Institutes of Health

Rockville, MD, U.S.A.

Harvey J.Murff, M.D., M.P.H.

Vanderbilt Epidemiology Center

Institute for Medicine and Public Health

Nashville, TN, U.S.A.

Suzanne O'Neill, Ph.D., C.G.C.

Associate Director, Northwestern University Graduate Program in Genetic Counseling

Assistant Professor, Northwestern University Feinberg School of Medicine

Chicago, IL, U.S.A.

Nancie Petrucelli, M.S., C.G.C.

Senior Genetic Counselor/Coordinator

Cancer Genetic Counseling Service

Barbara Ann Karmanos Cancer Institute

Detroit, MI, U.S.A.