# Appendix D - Excluded Studies

## References

1 Abbadessa G, Santoro A, Claudio PP. 42nd Annual Meeting of the American Society of Clinical Oncology (ASCO) (June 2–6, Atlanta) 2006. Drugs of the Future. 2006;31(7):617-23. Excluded: Not an eligible study design, OVID-Embase.
2 Abdel-Fattah M, Zaki A, Bassili A, et al. Breast self-examination practice and its impact on breast cancer diagnosis in Alexandria, Egypt. East Mediterr Health J. 2000;6(1):34-40. Excluded: Family history not systematically collected, OVID-Medline. [pmid: 11370338].
3 Absetz P, Aro AR, Sutton SR. Experience with breast cancer, pre-screening perceived susceptibility and the psychological impact of screening. Psychooncology. 2003;12(4):305-18. Excluded: Family history not systematically collected, OVID-Medline. [pmid: 12748969].
4 Abu-Rustum NR, Herbolsheimer H. Breast cancer risk assessment in indigent women at a public hospital. Gynecol Oncol. 2001;81(2):287-90. Excluded: Model does not categorize risk or validate, OVID-Medline. [pmid: 11330964].
5 ACOG: American College of Obstetricians and Gynecologists. ACOG practice bulletin. Clinical management guidelines for obstetrician-gynecologists. Number 42, April 2003. Breast cancer screening. Obst Gynecol. 2003;101(4):821-31. Excluded: Model does not categorize risk or validate, OVID-Medline. [pmid: 12685457].
6 ACOG: American College of Obstetricians and Gynecologists. ACOG practice bulletin. Breast cancer screening. Number 42, April 2003. Int J Gynaecol Obstet. 2003;81(3):313-23. Excluded: Model does not categorize risk or validate, OVID-Medline. [pmid: 12828183].
7 ACOG: American College of Obstetricians and Gynecologists. ACOG committee opinion. Routine cancer screening. Number 247, December 2000. Int J Gynaecol Obstet. 2003;82(2):241-5. Excluded: Model does not categorize risk or validate, OVID-Medline. [pmid: 12926412].
8 ACOG: American College of Obstetricians and Gynecologists. ACOG Committee on Gynecologic Practice. Committee opinion no. 356: Routine cancer screening. Obstet Gynecol. 2006;108(6):1611-3. Excluded: Model does not categorize risk or validate, OVID-Embase. [pmid: 17138803].
9 Agrawal A, Fentiman IS. NSAIDs and breast cancer: A possible prevention and treatment strategy. Int J Clin Pract. 2008;62(3):444-9. Excluded: Not an eligible study design, OVID-Embase. [pmid: 18194278].
10 Ahmed NU, Fort JG, Elzey JD, et al. Empowering factors in repeat mammography: insights from the stories of underserved women. J Ambulatory Care Manage. 2004;27(4):348-55. Excluded: Family history not systematically collected, OVID-Medline. [pmid: 15495747].
11 Ahmed NU, Fort JG, Elzey JD, et al. Empowering factors for regular mammography screening in under-served populations: pilot survey results in Tennessee.[see comment]. Ethn Dis. 2005;15(3):387-94. Excluded: Family history not systematically collected, OVID-Medline. [pmid: 16108297].
12 Aiken LS, Fenaughty AM, West SG, et al. Perceived determinants of risk for breast cancer and the relations among objective risk, perceived risk, and screening behavior over time. Womens Health. 1995;1(1):27-50. Excluded: Family history not systematically collected, OVID-Medline. [pmid: 9373372].
13 Ainsworth PJ, Koscinski D, Fraser BP, et al. Family cancer histories predictive of a high risk of hereditary non-polyposis colorectal cancer associate significantly with a genomic rearrangement in hMSH2 or hMLH1. Clin Genet. 2004;66(3):183-8. Excluded: Family history not systematically collected, OVID-Medline. [pmid: 15324316].
14 Aktan-Collan K, Mecklin JP, Jarvinen H, et al. Predictive genetic testing for hereditary non-polyposis colorectal cancer: uptake and long-term satisfaction. Int J Cancer. 2000;89(1):44-50. Excluded: Not an eligible population, OVID-Medline. [pmid: 10719730].
15 Aktan-Collan K, Haukkala A, Pylvanainen K, et al. Direct contact in inviting high-risk members of hereditary colon cancer families to genetic counselling and DNA testing. J Med Genet. 2007;44(11):732-8. Excluded: Not an eligible population, OVID-Medline. [pmid: 17630403].
16 Alamian A, Rouleau I, Simard J, et al. Use of dietary supplements among women at high risk of hereditary breast and ovarian cancer (HBOC) tested for cancer susceptibility. Nutr Cancer. 2006;54(2):157-65. Excluded: Not an eligible population, OVID-Medline. [pmid: 16898859].
17 American Cancer Society. American Cancer Society issues redefined breast cancer screening guidelines. Iowa Med 93(5):27-Oct. Excluded: Model does not categorize risk or validate, OVID-Medline.
18 American College of Obstetricians and Gynecologists. ACOG Committee Opinion No. 384 November 2007: colonoscopy and colorectal cancer screening and prevention. Obstet Gynecol. 2007;110(5):1199-202. Excluded: Model does not categorize risk or validate, OVID-Medline. [pmid: 17978144].
19 American Gastroenterological Association. American Gastroenterological Association medical position statement: hereditary colorectal cancer and genetic testing. Gastroenterology. 2001;121(1):195-7. Excluded: Model does not categorize risk or validate, OVID-Medline. [pmid: 11438508].
20 American Society of Clinical Oncology. Statement of the American Society of Human Genetics on genetic testing for breast and ovarian cancer predisposition. Am J Hum Genet. 1994;55(5):i-iv. Excluded: Model does not categorize risk or validate, OVID-Medline. [pmid: 7977337].
21 American Society of Clinical Oncology. American Society of Clinical Oncology policy statement update: genetic testing for cancer susceptibility. J Clin Oncol. 2003;21(12):2397-406. Excluded: Model does not categorize risk or validate, OVID-Medline. [pmid: 12692171].
22 Amir E, Evans DG, Shenton A, et al. Evaluation of breast cancer risk assessment packages in the family history evaluation and screening programme. J Med Genet. 2003;40(11):807-14. Excluded: Model does not categorize risk or validate, OVID-Medline. [pmid: 14627668].
23 Andersen MR, Peacock S, Nelson J, et al. Worry about ovarian cancer risk and use of ovarian cancer screening by women at risk for ovarian cancer.[see comment]. Gynecol Oncol. 2002;85(1):3-8. Excluded: Family history not systematically collected, OVID-Medline. [pmid: 11925113].
24 Andersen MR, Bowen D, Yasui Y, et al. Awareness and concern about ovarian cancer among women at risk because of a family history of breast or ovarian cancer. Am J Obstet Gynecol. 2003;189(4:Suppl):Suppl-7. Excluded: Family history not systematically collected, OVID-Medline.
25 Andersen MR, Smith R, Meischke H, et al. Breast cancer worry and mammography use by women with and without a family history in a population-based sample. Cancer Epidemiol Biomarkers Prev. 2003;12(4):314-20. Excluded: Family history not systematically collected, OVID-Medline. [pmid: 12692105].
26 Andersen MR, Nelson J, Peacock S, et al. Worry about ovarian cancer risk and use of screening by high-risk women: how you recruit affects what you find. Am J Med Genet 2004;Part(2):130–5. Excluded: Family history not systematically collected, OVID-Medline.
27 Anderson BO. Global Summit Consensus Conference on International Breast Health Care: Guidelines for countries with limited resources. Breast J. 2003;9(SUPPL. 2):S40-S41. Excluded: Not an eligible study design, OVID-Embase.
28 Andreeva VA, Unger JB, Pentz MA. Breast cancer among immigrants: A systematic review and new research directions. J Immigr Minor Health. 2007;9(4):307-22. Excluded: Not an eligible population, OVID-Embase. [pmid: 17431785].
29 Andrykowski MA, Zhang M, Pavlik EJ, et al. Factors associated with return for routine annual screening in an ovarian cancer screening program. Gynecol Oncol. 2007;104(3):695-701. Excluded: Not an eligible study design, OVID-Medline. [pmid: 17145075].
30 Anonymous. Colonoscopy in the screening and surveillance of individuals at increased risk for colorectal cancer. American Society for Gastrointestinal Endoscopy. Gastrointest Endosc 1998;48(6):676–8. Excluded: Model does not categorize risk or validate, OVID-Medline.
31 Anonymous. Bilateral prophylactic mastectomy in women with an increased risk of breast cancer. Tecnologica MAP 1999;Suppl:3–6. Excluded: Family history not systematically collected, OVID-Medline.
32 Anonymous. Assessing hereditary breast cancer risk. Cancer Pract 1999;7(6):279–84. Excluded: Family history not systematically collected, OVID-Medline.
33 Anonymous. Cancer predisposition genetic testing and risk assessment counseling. Oncology Nursing Society. Oncol Nurs Forum 2000;27(9):1349 Excluded: Not an eligible study design, OVID-Medline.
34 Anonymous. Anxiety, depression in women at high risk for breast Cancer. Oncology News International 2002;11(5):50 Excluded: Not an eligible study design, OVID-Cinahl.
35 Anonymous. Colorectal cancer screening: New recommendations. Consultant 2003;43(3):318–20. Excluded: Not an eligible intervention or outcome, OVID-Embase.
36 Anonymous. Simple programme predicts who is most at risk of breast cancer. S Afr Med J 2004;Suid-Afrikaanse(5):337–8. Excluded: Not an eligible study design, OVID-Medline.
37 Anonymous. The management of colorectal cancers. Eff Health Care 2004;8(3):1–11. Excluded: Model does not categorize risk or validate, OVID-Cinahl.
38 Anonymous. Diseases: Management of patients presenting the first signs or a history of solid malignancy? Joint Bone Spine 2005;72(Suppl. 1):S31–S38 Excluded: Not an eligible intervention or outcome, OVID-Embase.
39 Anonymous. Vitamins, minerals, supplements and dietary approaches. Focus on Alternative and Complementary Therapies 2005;10(3):227–32. Excluded: Not an eligible study design, OVID-Embase.
40 Anonymous. Updated guideline provides recommendations for surveillance after colorectal cancer. ASCO News & Forum 2006;1(1):20–1. Excluded: Not an eligible intervention or outcome, OVID-Cinahl.
41 Anonymous. American Cancer Society guidelines still advise yearly mammography for women aged 40 to 49 years. CA Cancer J Clinic 2007;57(4):187–8. Excluded: Not an eligible study design, OVID-Embase.
42 Anonymous. Europe against colorectal cancer: Declaration of Brussels 9 May 2007. Z Gastroenterol 2008;46(SUPPL. 1):S2–S3 Excluded: Not an eligible publication type, OVID-Embase.
43 Antill Y, Reynolds J, Young MA, et al. Risk-reducing surgery in women with familial susceptibility for breast and/or ovarian cancer. Eur J Cancer. 2006;42(5):621-8. Excluded: Family history not systematically collected, OVID-Medline. [pmid: 16434187].
44 Antill YC, Reynolds J, Young MA, et al. Screening behavior in women at increased familial risk for breast cancer. Fam Cancer. 2006;5(4):359-68. Excluded: Not an eligible study design, OVID-Medline. [pmid: 16817030].
45 Antoniou AC, Durocher F, Smith P, et al. BRCA1 and BRCA2 mutation predictions using the BOADICEA and BRCAPRO models and penetrance estimation in high-risk French-Canadian families. Breast Cancer Res. 2006;8(1):R3. Excluded: Model does not categorize risk or validate, OVID-Medline. [pmid: 16417652].
46 Apicella C, Dowty JG, Dite GS, et al. Validation study of the LAMBDA model for predicting the BRCA1 or BRCA2 mutation carrier status of North American Ashkenazi Jewish women. Clin Genet. 2007;72(2):87-97. Excluded: Model does not categorize risk or validate, OVID-Medline. [pmid: 17661812].
47 Armstrong C. ACS recommendations on MRI and mammography for breast cancer screening. Am Fam Physician. 2007;75(11):1712. Excluded: Model does not categorize risk or validate, OVID-Embase.
48 Armstrong K, Moye E. What is the evidence on screening mammography for women in their 40s?. J Fam Pract. 2007;56(7):530. Excluded: Model does not categorize risk or validate, OVID-Embase. [pmid: 17612034].
49 Armstrong K, Calzone K, Stopfer J, et al. Factors associated with decisions about clinical BRCA1/2 testing. Cancer Epidemiol Biomarkers Prev. 2000;9(11):1251-4. Excluded: Not an eligible study design, OVID-Medline. [pmid: 11097234].
50 Armstrong K, Weber B, FitzGerald G, et al. Life insurance and breast cancer risk assessment: adverse selection, genetic testing decisions, and discrimination. Am J Med Genet 2003;Part(3):359–64. Excluded: Family history not systematically collected, OVID-Medline.
51 Armstrong K, Weber B, Stopfer J, et al. Early use of clinical BRCA1/2 testing: associations with race and breast cancer risk. Am J Med Genet 2003;Part(2):154–60. Excluded: Not an eligible population, OVID-Medline.
52 Armstrong K, Micco E, Carney A, et al. Racial differences in the use of BRCA1/2 testing among women with a family history of breast or ovarian cancer. JAMA. 2005;293(14):1729-36. Excluded: Family history not systematically collected, OVID-Medline. [pmid: 15827311].
53 Armstrong K, Moye E, Williams S, et al. Screening mammography in women 40 to 49 years of age: a systematic review for the American College of Physicians. Ann Intern Med. 2007;146(7):516-26. Excluded: Not an eligible population, OVID-Medline. [pmid: 17404354].
54 Asano, TK, McLeod, et al. Vitamins and minerals for the prevention of colorectal adenomas and carcinomas [Protocol]. Cochrane Database Syst Rev 2008;(1): Excluded: Not an eligible study design, OVID-Cochrane.
55 Asano, TK, McLeod, et al. Dietary fibre for the prevention of colorectal adenomas and carcinomas [Systematic Review]. Cochrane Database Syst Rev 2008;(1): Excluded: Not an eligible intervention or outcome, OVID-Cochrane.
56 ASCO clinical practice guidelines highlight new strategies for breast cancer surveillance, HER-2 testing. ASCO News Forum 2007;2(1):32–3. Excluded: Not an eligible intervention or outcome, OVID-Cinahl.
57 Association of Breast Surgery @ BASO Royal College of Surgeons of England. Guidelines for the management of symptomatic breast disease. Eur J Surg Oncol. 2005;31(SUPPL.):S1-S21. Excluded: Not an eligible intervention or outcome, OVID-Embase.
58 Astorg P. Dietary n - 6 and n - 3 polyunsaturated fatty acids and prostate cancer risk: A review of epidemiological and experimental evidence. Cancer Causes Control. 2004;15(4):367-86. Excluded: Not an eligible intervention or outcome, OVID-Embase. [pmid: 15141138].
59 Audrain J, Schwartz MD, Lerman C, et al. Psychological distress in women seeking genetic counseling for breast-ovarian cancer risk: the contributions of personality and appraisal. Ann Behav Med. 1997;19(4):370-7. Excluded: Family history not systematically collected, OVID-Medline. [pmid: 9706364].
60 Aus G, Abbou CC, Bolla M, et al. EAU guidelines on prostate cancer. Eur Urol. 2005;48(4):546-51. Excluded: Model does not categorize risk or validate, OVID-Embase. [pmid: 16046052].
61 Azaiza F, Cohen M. Health beliefs and rate of breast cancer screening among Arab women. J Womens Health. 2006;15(5):520-30. Excluded: Family history not systematically collected, OVID-Embase.
62 Aziz O, Athanasiou T, Fazio VW, et al. Meta-analysis of observational studies of ileorectal versus ileal pouch-anal anastomosis for familial adenomatous polyposis. Br J Surg. 2006;93(4):407-17. Excluded: Not an eligible intervention or outcome, OVID-Medline. [pmid: 16511903].
63 Azzarello,L.M. Psychological factors associated with skin cancer detection behaviors in individuals with a family history of melanoma Azzarello. 2006 Excluded: Not an eligible intervention or outcome, OVID-PsycInfo.
64 Badger TM, Ronis MJJ, Simmen RCM, et al. Soy protein isolate and protection against cancer. J Am Coll Nutr. 2005;24(2):146S-9S. Excluded: Not an eligible intervention or outcome, OVID-Embase. [pmid: 15798082].
65 Baider L, Ever-Hadani P, Kaplan De-Nour A. Psychological distress in healthy women with familial breast cancer: like mother, like daughter?. Int J Psychiatry Med. 1999;29(4):411-20. Excluded: Family history not systematically collected, OVID-Medline. [pmid: 10782424].
66 Baker S, Wall M, Bloomfield A. Breast cancer screening for women aged 40 to 49 years—what does the evidence mean for New Zealand?. N Z Med J. 2005;118(1221):U1628. Excluded: Not an eligible study design, OVID-Medline. [pmid: 16138166].
67 Balmana J, Stoffel EM, Emmons KM, et al. Comparison of motivations and concerns for genetic testing in hereditary colorectal and breast cancer syndromes. J Med Genet. 2004;41(4):e44. Excluded: Not an eligible study design, OVID-Medline. [pmid: 15060120].
68 Banerjee S, Van Dam J. CT colonography for colon cancer screening. Gastrointest Endosc. 2006;63(1):121-33. Excluded: Not an eligible population, OVID-Cinahl. [pmid: 16377329].
69 Bankhead CR, Brett J, Bukach C, et al. The impact of screening on future health-promoting behaviours and health beliefs: a systematic review. [Review] [264 refs]. Health Technol Assess. 2003;7(42):1-92. Excluded: Not an eligible intervention or outcome, OVID-Medline.
70 Barcenas CH, Hosain GM, Arun B, et al. Assessing BRCA carrier probabilities in extended families. J Clin Oncol. 2006;24(3):354-60. Excluded: Model does not categorize risk or validate, OVID-Medline. [pmid: 16421416].
71 Barkun AN, Jobin G, Cousineau G, et al. The Quebec Association of Gastroenterology position paper on colorectal cancer screening - 2003.[erratum appears in Can J Gastroenterol. 2004 Sep;18(9):591]. Can J Gastroenterol. 2004;18(8):509-19. Excluded: Model does not categorize risk or validate, OVID-Medline. [pmid: 15372115].
72 Barlow WE, White E, Ballard-Barbash R, et al. Prospective breast cancer risk prediction model for women undergoing screening mammography. J Natl Cancer Inst. 2006;98(17):1204-14. Excluded: Model does not categorize risk or validate, OVID-Medline. [pmid: 16954473].
73 Barnsley GP, Grunfeld E, Coyle D, et al. Surveillance mammography following the treatment of primary breast cancer with breast reconstruction: a systematic review. Plast Reconstr Surg. 2007;120(5):1125-32. Excluded: Not an eligible intervention or outcome, OVID-Medline. [pmid: 17898585].
74 Basch E, Bent S, Foppa I, et al. Marigold (Calendula officinalis L.): An evidence-based systematic review by the natural standard research collaboration. J Herb Pharmacother. 2006;6(34):135-59. Excluded: Not an eligible intervention or outcome, OVID-Embase. [pmid: 17317655].
75 Bassil KL, Vakil C, Sanborn M, et al. Cancer health effects of pesticides: systematic review. Can Fam Physician. 2007;53(10):1704-11. Excluded: Not an eligible population, OVID-Medline. [pmid: 17934034].
76 Becker,S.T. Breast cancer screening patterns related to mammography adherence among Northern Plains Tribes American Indian women 2006 Excluded: Not an eligible publication type, OVID-Cinahl.
77 Beebe-Dimmer JL, Wood J, Gruber SB, et al. Use of complementary and alternative medicine in men with family history of prostate cancer: A pilot study. Urology. 2004;63(2):282-7. Excluded: Family history not systematically collected, OVID-Embase. [pmid: 14972472].
78 Beery TA, Williams JK. Risk reduction and health promotion behaviors following genetic testing for adult-onset disorders. Genet Test. 2007;11(2):111-23. Excluded: Family history not systematically collected, OVID-Medline. [pmid: 17627380].
79 Bellentani S, Baldoni P, Petrella S, et al. A simple score for the identification of patients at high risk of organic diseases of the colon in the family doctor consulting room. Fam Pract. 1990;7(4):307-12. Excluded: Not an eligible intervention or outcome, OVID-Embase. [pmid: 2289644].
80 Benedict S, Goon G, Hoomani J, et al. Breast cancer detection by daughters of women with breast cancer.[see comment]. Cancer Pract. 1997;5(4):213-9. Excluded: Family history not systematically collected, OVID-Medline. [pmid: 9250077].
81 Benichou J, Gail MH, Mulvihill JJ. Graphs to estimate an individualized risk of breast cancer. J Clin Oncol. 1996;14(1):103-10. Excluded: Not an eligible study design, OVID-Medline. [pmid: 8558184].
82 Benjamin,O. The role of dispositional optimism, cancer specific fatalism, and psychological distress in patients participation in the brca1 and brca2 genetic testing Benjamin. 1998 Excluded: Not an eligible publication type, OVID-PsycInfo.
83 Berg AO, U.S.Preventive Services Task Force. Screening for prostate cancer: recommendations and rationale. Am J Nurs 111;103(3):107–10. Excluded: Model does not categorize risk or validate, OVID-Medline.
84 Berg AO. U.S.Preventive Services Task Force. Screening for prostate cancer: recommendations and rationale. The American Journal for Nurse Practitioners. 2003;7(1):24-6. Excluded: Not an eligible intervention or outcome, OVID-Cinahl.
85 Berg AO. U.S.Preventive Services Task Force. Chemoprevention of breast cancer: recommendations and rationale. Am J Nurs. 2003;103(5):107. Excluded: Not an eligible intervention or outcome, OVID-Cinahl.
86 Bergmann M, Wolf B, Karner-Hanusch J. Hereditary colorectal cancer - Guidelines for clinical routine. European Surgery - Acta Chirurgica Austriaca. 2006;38(1):59-62. Excluded: Model does not categorize risk or validate, OVID-Embase.
87 Bermejo-Perez MJ, Marquez-Calderon S, Llanos-Mendez A. Effectiveness of preventive interventions in BRCA1/2 gene mutation carriers: a systematic review. Int J Cancer. 2007;121(2):225-31. Excluded: Not an eligible intervention or outcome, OVID-Medline. [pmid: 17471565].
88 Bermejo-Perez MJ, Marquez-Calderon S, Llanos-Mendez A. Cancer surveillance based on imaging techniques in carriers of BRCA1/2 gene mutations: a systematic review. Br J Radiol. 2008;81(963):172-9. Excluded: Not an eligible study design, OVID-Medline. [pmid: 18208856].
89 Bermejo JL, Eng C, Hemminki K. Cancer characteristics in Swedish families fulfilling criteria for hereditary nonpolyposis colorectal cancer. Gastroenterology. 2005;129(6):1889-99. Excluded: Model does not categorize risk or validate, OVID-Medline. [pmid: 16344057].
90 Berry DA, Parmigiani G, Sanchez J, et al. Probability of carrying a mutation of breast-ovarian cancer gene BRCA1 based on family history. J Natl Cancer Inst. 1997;89(3):227-38. Excluded: Model does not categorize risk or validate, OVID-Medline. [pmid: 9017003].
91 Berry DA, Iversen ES Jr, Gudbjartsson DF, et al. BRCAPRO validation, sensitivity of genetic testing of BRCA1/BRCA2, and prevalence of other breast cancer susceptibility genes. J Clin Oncol. 2002;20(11):2701-12. Excluded: Model does not categorize risk or validate, OVID-Medline. [pmid: 12039933].
92 Bertaccini A, Fandella A, Prayer-Galetti T, et al. Systematic development of clinical practice guidelines for prostate biopsies: A 3-year Italian project. Anticancer Res. 2007;27(1 B):659-66. Excluded: Not an eligible intervention or outcome, OVID-Embase. [pmid: 17348457].
93 Bevers TB, Anderson BO, Bonaccio E, et al. Breast cancer screening and diagnosis: Clinical practice guidelines in oncology[trademark]. J Natl Compr Cancer Netw. 2006;4(5):480-508. Excluded: Not an eligible publication type, OVID-Embase.
94 Bianchi F, Galizia E, Bracci R, et al. Effectiveness of the CRCAPRO program in identifying patients suspected for HNPCC. Clin Genet. 2007;71(2):158-64. Excluded: Model does not categorize risk or validate, OVID-Medline. [pmid: 17250665].
95 Biswas S, Berry DA. Determining joint carrier probabilities of cancer-causing genes using Markov chain Monte Carlo methods. Genet Epidemiol. 2005;29(2):141-54. Excluded: Model does not categorize risk or validate, OVID-Medline. [pmid: 16025444].
96 Bjelakovic G, Nikolova D, Simonetti RG, et al. Antioxidant supplements for prevention of gastrointestinal cancers: A systematic review and meta-analysis. Lancet. 2004;364(9441):1219-28. Excluded: Not an eligible intervention or outcome, OVID-Embase. [pmid: 15464182].
97 Bjelakovic G. Antioxidants don't prevent GI cancers, increase overall mortality. South African Family Practice. 2005;47(1):18. Excluded: Not an eligible study design, OVID-Embase.
98 Bjelakovic G, Nikolova D, Simonetti RG, et al. High-dose antioxidants to prevent cancer: Hype or hoax?. Focus on Alternative and Complementary Therapies. 2005;10(1):29-31. Excluded: Not an eligible study design, OVID-Embase.
99 Bjelakovic G, Nikoloval D. Antioxidants do not prevent colorectal cancer. J Fam Pract. 2006;55(10):849. Excluded: Not an eligible study design, OVID-Embase. [pmid: 17089474].
100 Bjelakovic G, Nagorni A, Nikolova D, et al. Meta-analysis: antioxidant supplements for primary and secondary prevention of colorectal adenoma. Aliment Pharmacol Ther. 2006;24(2):281-91. Excluded: Not an eligible intervention or outcome, OVID-Medline. [pmid: 16842454].
101 Bjelakovic G, Nikolova D, Gluud LL, et al. Mortality in randomized trials of antioxidant supplements for primary and secondary prevention: Systematic review and meta-analysis. JAMA. 2007;297(8):842-57. Excluded: Not an eligible intervention or outcome, OVID-Embase. [pmid: 17327526].
102 Blalock SJ, DeVellis BM, Afifi RA, et al. Risk perceptions and participation in colorectal cancer screening. Health Psychol. 1990;9(6):792-806. Excluded: Not an eligible study design, OVID-PsycInfo. [pmid: 2286186].
103 Bleiker EM, Menko FH, Taal BG, et al. Screening behavior of individuals at high risk for colorectal cancer. Gastroenterology. 2005;128(2):280-7. Excluded: Not an eligible study design, OVID-Medline. [pmid: 15685539].
104 Blom J, Yin L, Liden A, et al. Toward understanding nonparticipation in sigmoidoscopy screening for colorectal cancer. Int J Cancer. 2008;122(7):1618-23. Excluded: Not an eligible study design, OVID-Medline. [pmid: 18064580].
105 Bloom JR, Stewart SL, Chang S, et al. Effects of a telephone counseling intervention on sisters of young women with breast cancer. Prev Med. 2006;43(5):379-84. Excluded: Family history not systematically collected, OVID-Medline. [pmid: 16916540].
106 Bloom JR, Stewart SL, Oakley-Girvans I, et al. Family history, perceived risk, and prostate cancer screening among African American men. Cancer Epidemiol Biomarkers Prev. 2006;15(11):2167-73. Excluded: Family history not systematically collected, OVID-Medline. [pmid: 17119042].
107 Bock CH, Peyser PA, Gruber SB, et al. Prostate cancer early detection practices among men with a family history of disease. Urology. 2003;62(3):470-5. Excluded: Not an eligible population, OVID-Medline. [pmid: 12946749].
108 Bodd TL, Reichelt J, Heimdal K, et al. Uptake of BRCA1 genetic testing in adult sisters and daughters of known mutation carriers in Norway. J Genet Couns. 2003;12(5):405-17. Excluded: Not an eligible population, OVID-Medline. [pmid: 14758817].
109 Bodmer D, Ligtenberg MJ, Van Der Hout AH, et al. Optimal selection for BRCA1 and BRCA2 mutation testing using a combination of ‘easy to apply’ probability models. Br J Cancer. 2006;95(6):757-62. Excluded: Model does not categorize risk or validate, OVID-Medline. [pmid: 16909138].
110 Boggs BD, Stephens MM, Wallace R. How does colonoscopy compare with fecal occult blood testing as a screening tool for colon cancer?. J Fam Pract. 2005;54(11):996-7. Excluded: Not an eligible study design, OVID-Embase. [pmid: 16266608].
111 Bondy ML, Vogel VG, Halabi S, et al. Identification of women at increased risk for breast cancer in a population-based screening program. Cancer Epidemiol Biomarkers Prev. 1992;1(2):143-7. Excluded: Model does not categorize risk or validate, OVID-Medline. [pmid: 1306097].
112 Bondy ML, Lustbader ED, Halabi S, et al. Validation of a breast cancer risk assessment model in women with a positive family history. J Natl Cancer Inst. 1994;86(8):620-5. Excluded: Model does not categorize risk or validate, OVID-Medline. [pmid: 8003106].
113 Bondy ML, Newman LA. Assessing breast cancer risk: evolution of the Gail Model. J Natl Cancer Inst. 2006;98(17):1172-3. Excluded: Not an eligible study design, OVID-Medline. [pmid: 16954464].
114 Bonovas S, Filioussi K, Sitaras NM. Do nonsteroidal anti-inflammatory drugs affect the risk of developing ovarian cancer? A meta-analysis. Br J Clin Pharmacol. 2005;60(2):194-203. Excluded: Not an eligible population, OVID-Embase. [pmid: 16042673].
115 Borry P, Stultiens L, Nys H, et al. Attitudes towards predictive genetic testing in minors for familial breast cancer: a systematic review. Crit Rev Oncol Hematol. 2007;64(3):173-81. Excluded: Not an eligible intervention or outcome, OVID-Medline. [pmid: 17553690].
116 Bosserman LD, Smith JA, Hellerstedt B, et al. Hereditary cancer testing in community oncology practices. Community Oncology. 2007;4(11 SUPPL.):2-8. Excluded: Not an eligible study design, OVID-Embase.
117 Botkin JR, Smith KR, Croyle RT, et al. Genetic testing for a BRCA1 mutation: prophylactic surgery and screening behavior in women 2 years post testing. Am J Med Genet 2003;Part(3):201–9. Excluded: Not an eligible population, OVID-Medline.
118 Bouvier AM, Faivre J, Lejeune C. Screening strategy of colorectal cancers in high risk cases. Acta Endoscopica. 2002;32(4):623-31. Excluded: Not an eligible study design, OVID-Embase.
119 Bowen D, McTiernan A, Burke W, et al. Participation in breast cancer risk counseling among women with a family history. Cancer Epidemiol Biomarkers Prev. 1999;8(7):581-5. Excluded: Family history not systematically collected, OVID-Medline. [pmid: 10428194].
120 Bowen DJ, Morasca AA, Meischke H. Measures and correlates of resilience. Women Health. 2003;38(2):65-76. Excluded: Family history not systematically collected, OVID-Medline. [pmid: 14655795].
121 Bowen DJ, Alfano CM, McGregor BA, et al. The relationship between perceived risk, affect, and health behaviors. Cancer Detect Prev. 2004;28(6):409-17. Excluded: Family history not systematically collected, OVID-Medline. [pmid: 15582264].
122 Bradbury AR, Ibe CN, Dignam JJ, et al. Uptake and timing of bilateral prophylactic salpingo-oophorectomy among BRCA1 and BRCA2 mutation carriers. Genetics in Medicine. 2008;10(3):161-6. Excluded: Not an eligible population, OVID-Embase. [pmid: 18344704].
123 Brain K, Norman P, Gray J, et al. Anxiety and adherence to breast self-examination in women with a family history of breast cancer. Psychosom Med. 1999;61(2):181-7. Excluded: Not an eligible study design, OVID-Medline. [pmid: 10204971].
124 Braithwaite D, Emery J, Walter F, et al. Psychological impact of genetic counseling for familial cancer: a systematic review and meta-analysis. J Natl Cancer Inst. 2004;96(2):122-33. Excluded: Family history not systematically collected, OVID-Medline. [pmid: 14734702].
125 Braithwaite D, Sutton S, Mackay J, et al. Development of a risk assessment tool for women with a family history of breast cancer. Cancer Detect Prev. 2005;29(5):433-9. Excluded: Model does not categorize risk or validate, OVID-Medline. [pmid: 16055276].
126 Braithwaite RS, Chlebowski RT, Lau J, et al. Meta-analysis of vascular and neoplastic events associated with tamoxifen. J Gen Intern Med. 2003;18(11):937-47. Excluded: Not an eligible intervention or outcome, OVID-Medline. [pmid: 14687281].
127 Bratt O, Damber JE, Emanuelsson M, et al. Risk perception, screening practice and interest in genetic testing among unaffected men in families with hereditary prostate cancer. Eur J Cancer. 2000;36(2):235-41. Excluded: Not an eligible study design, OVID-Medline. [pmid: 10741283].
128 Bratt O, Emanuelsson M, Gronberg H. Psychological aspects of screening in families with hereditary prostate cancer. Scand J Urol Nephrol. 2003;37(1):5-9. Excluded: Family history not systematically collected, OVID-Medline. [pmid: 12745735].
129 Braun L. There's no doubt: Soy protects and promotes health. Australian Journal of Pharmacy. 2007;88(1044):52-3. Excluded: Not an eligible study design, OVID-Embase.
130 Brenneman AE. Colon cancer: an update on screening. JAAPA J Am Acad Physician Assist. 2008;21(3):17-8. Excluded: Model does not categorize risk or validate, OVID-Cinahl.
131 Brewer NT, Salz T, Lillie SE. Systematic review: the long-term effects of false-positive mammograms. Ann Intern Med. 2007;146(7):502-10. Excluded: Not an eligible population, OVID-Medline. [pmid: 17404352].
132 Broadstock M, Michie S, Marteau T. Psychological consequences of predictive genetic testing: a systematic review. Eur J Hum Genet. 2000;8(10):731-8. Excluded: Family history not systematically collected, OVID-Medline. [pmid: 11039571].
133 Brooks DD, Winawer SJ, Rex DK, et al. Colonoscopy surveillance after polypectomy and colorectal cancer resection. Am Fam Physician. 2008;77(7):995-1002. Excluded: Model does not categorize risk or validate, OVID-Medline. [pmid: 18441865].
134 Brosnan CA. Review: colorectal cancer screening with the faecal occult blood test reduced colorectal cancer mortality. Evid Based Nurs. 2007;10(4):112. Excluded: Not an eligible study design, OVID-Cinahl. [pmid: 17905764].
135 Brown SR, Baraza W, Hurlstone P. Chromoscopy versus conventional endoscopy for the detection of polyps in the colon and rectum. Cochrane Database of Syst Rev 2007;(4):CD006439 Excluded: Not an eligible intervention or outcome, OVID-Medline.
136 Bruner DW, Baffoe-Bonnie A, Miller S, et al. Prostate cancer risk assessment program. A model for the early detection of prostate cancer. ONCOLOGY. 1999;13(3):325-34. PM:10204154 Excluded: not an eligible study design. [pmid: 10204154].
137 Brunton M, Jordan C, Campbell I. Anxiety before, during, and after participation in a population-based screening mammography programme in Waikato Province, New Zealand. N Z Med J. 2005;118(1209):U1299. Excluded: Family history not systematically collected, OVID-Medline. [pmid: 15711632].
138 Bryant RJ, Hamdy FC. Screening for prostate cancer: an update. Eur Urol. 2008;53(1):37-44. Excluded: Not an eligible study design, OVID-Medline. [pmid: 17826892].
139 Buchalter,A.J. Effects of coping on distress related to family history of breast cancer Buchalter. 2002 Excluded: Not an eligible publication type, OVID-PsycInfo.
140 Bujanda L, Sarasqueta C, Zubiaurre L, et al. Low adherence to colonoscopy in the screening of first-degree relatives of patients with colorectal cancer. Gut. 2007;56(12):1714-8. Excluded: Not an eligible study design, OVID-Medline. [pmid: 17400596].
141 Bunn JY, Bosompra K, Ashikaga T, et al. Factors influencing intention to obtain a genetic test for colon cancer risk: a population-based study. Prev Med. 2002;34(6):567-77. Excluded: Family history not systematically collected, OVID-Medline. [pmid: 12052015].
142 Burch JA, Soares-Weiser K, St John DJ, et al. Diagnostic accuracy of faecal occult blood tests used in screening for colorectal cancer: a systematic review. J Med Screen. 2007;14(3):132-7. Excluded: Not an eligible population, OVID-Medline. [pmid: 17925085].
143 Burt RW. Impact of family history on screening and surveillance. Gastrointest Endosc. 1999;49(3:Pt 2):t-4. Excluded: Not an eligible study design, OVID-Medline.
144 Bushnell CD, Goldstein LB. Risk of ischemic stroke with tamoxifen treatment for breast cancer: a meta-analysis. Neurology. 2004;63(7):1230-3. Excluded: Not an eligible intervention or outcome, OVID-Medline. [pmid: 15477543].
145 Butow P, Meiser B, Price M, et al. Psychological morbidity in women at increased risk of developing breast cancer: a controlled study. Psychooncology. 2005;14(3):196-203. Excluded: Not an eligible study design, OVID-Medline. [pmid: 15386776].
146 Cairns S, Scholefield JH. Guidelines for colorectal cancer screening in high risk groups. Gut. 2002;51:Suppl-2. Excluded: Not an eligible study design, OVID-Medline.
147 Calonge N. Screening for ovarian cancer: Recommendation statement. Am Fam Physician. 2005;71(4):759-62. Excluded: Model does not categorize risk or validate, OVID-Embase. [pmid: 15756773].
148 Calonge N. U.S. preventive services task force - Genetic risk assessment and BRCA mutation testing for breast and ovarian cancer susceptibility: Recommendation statement. Am Fam Physician. 2006;73(5):869-77. Excluded: Model does not categorize risk or validate, OVID-Embase.
149 Calvocoressi L, Kasl SV, Lee CH, et al. A prospective study of perceived susceptibility to breast cancer and nonadherence to mammography screening guidelines in African American and White women ages 40 to 79 years. Cancer Epidemiol Biomarkers Prev. 2004;13(12):2096-105. Excluded: Family history not systematically collected, OVID-Medline. [pmid: 15598767].
150 Capalbo C, Ricevuto E, Vestri A, et al. Improving the accuracy of BRCA1/2 mutation prediction: validation of the novel country-customized IC software. Eur J Hum Genet. 2006;14(1):49-54. Excluded: Model does not categorize risk or validate, OVID-Medline. [pmid: 16288312].
151 Capalbo C, Ricevuto E, Vestri A, et al. BRCA1 and BRCA2 genetic testing in Italian breast and/or ovarian cancer families: mutation spectrum and prevalence and analysis of mutation prediction models. Ann Oncol. 2006;17:Suppl-40. Excluded: Family history not systematically collected, OVID-Medline.
152 Cappelli M, Surh L, Humphreys L, et al. Psychological and social determinants of women's decisions to undergo genetic counseling and testing for breast cancer. Clin Genet. 1999;55(6):419-30. Excluded: Family history not systematically collected, OVID-Medline. [pmid: 10450858].
153 Cappelli M, Hunter AGW, Stern H, et al. Participation rates of Ashkenazi Jews in a colon cancer community-based screening/prevention study. Clin Genet. 2002;61(2):104-14. Excluded: Family history not systematically collected, OVID-Embase. [pmid: 11940085].
154 Carlson RW, Moench SJ, Hammond ME, et al. HER2 testing in breast cancer: NCCN Task Force report and recommendations. J Natl Compr Cancer Netw. 2004;4:Suppl-22. Excluded: Not an eligible intervention or outcome, OVID-Medline.
155 Carlsson AH, Bjorvatn C, Engebretsen LF, et al. Psychosocial factors associated with quality of life among individuals attending genetic counseling for hereditary cancer. J Genet Couns. 2004;13(5):425-45. Excluded: Family history not systematically collected, OVID-Medline. [pmid: 15604640].
156 Carpentieri DF, Qualman SJ, Bowen J, et al. Protocol for the examination of specimens from pediatric and adult patients with osseous and extraosseous Ewing sarcoma family of tumors, including peripheral primitive neuroectodermal tumor and Ewing sarcoma. Arch Pathol Lab Med. 2005;129(7):866-73. Excluded: Not an eligible intervention or outcome, OVID-Embase. [pmid: 15974809].
157 Ceber E, Soyer MT, Ciceklioglu M, et al. Breast cancer risk assessment and risk perception on nurses and midwives in Bornova Health District in Turkey. Cancer Nurs. 2006;29(3):244-9. Excluded: Family history not systematically collected, OVID-Medline. [pmid: 16783126].
158 Chalmers K, Thomson K. Coming to terms with the risk of breast cancer: perceptions of women with primary relatives with breast cancer. Qual Health Res. 1996;6(2):256-82. Excluded: Family history not systematically collected, OVID-Cinahl.
159 Chalmers KI, Luker KA. Breast self-care practices in women with primary relatives with breast cancer. J Adv Nurs. 1996;23(6):1212-20. Excluded: Family history not systematically collected, OVID-Medline. [pmid: 8796471].
160 Champion VL. Compliance with guidelines for mammography screening. Cancer Detect Prev. 1992;16(4):253-8. Excluded: Family history not systematically collected, OVID-Medline. [pmid: 1458516].
161 Chan SC. Practice of breast self-examination amongst women attending a Malaysian Well Person's Clinic. Med J Malaysia. 1999;54(4):433-7. Excluded: Not an eligible study design, OVID-Medline. [pmid: 11072459].
162 Chao A, Connell CJ, Cokkinides V, et al. Underuse of screening sigmoidoscopy and colonoscopy in a large cohort of US adults. Am J Public Health. 2004;94(10):1775-81. Excluded: Family history not systematically collected, OVID-Cinahl. [pmid: 15451749].
163 Chatterjee N, Wacholder S. A marginal likelihood approach for estimating penetrance from kin-cohort designs. Biometrics. 2001;57(1):245-52. Excluded: Model does not categorize risk or validate, OVID-Medline. [pmid: 11252606].
164 Chen J, Pee D, Ayyagari R, et al. Projecting absolute invasive breast cancer risk in white women with a model that includes mammographic density. J Natl Cancer Inst. 2006;98(17):1215-26. Excluded: Model does not categorize risk or validate, OVID-Medline. [pmid: 16954474].
165 Chen K, Qiu JL, Zhang Y, et al. Meta analysis of risk factors for colorectal cancer. World J Gastroenterol. 2003;9(7):1598-600. Excluded: Not an eligible intervention or outcome, OVID-Embase. [pmid: 12854172].
166 Chen S, Wang W, Lee S, et al. Prediction of germline mutations and cancer risk in the Lynch syndrome.[see comment]. JAMA. 2006;296(12):1479-87. Excluded: Model does not categorize risk or validate, OVID-Medline. [pmid: 17003396].
167 Chen S, Parmigiani G. Meta-analysis of BRCA1 and BRCA2 penetrance. J Clin Oncol. 2007;25(11):1329-33. Excluded: Not an eligible intervention or outcome, OVID-Medline. [pmid: 17416853].
168 Chiao EY, Giordano TP, Palefsky JM, et al. Screening HIV-infected individuals for anal cancer precursor lesions: a systematic review. Clin Infect Dis. 2006;43(2):223-33. Excluded: Family history not systematically collected, OVID-Medline. [pmid: 16779751].
169 Chikhaoui Y, Gelinas H, Joseph L, et al. Cost-minimization analysis of genetic testing versus clinical screening of at-risk relatives for familial adenomatous polyposis. Int J Technol Assess Health Care. 2002;18(1):67-80. Excluded: Not an eligible intervention or outcome, OVID-Medline. [pmid: 11987443].
170 Cho E, Smith-Warner SA, Ritz J, et al. Alcohol intake and colorectal cancer: a pooled analysis of 8 cohort studies. Ann Intern Med. 2004;140(8):603-13. Excluded: Not an eligible intervention or outcome, OVID-Medline. [pmid: 15096331].
171 Christman LK, Abdulla R, Jacobsen PB, et al. Colorectal cancer screening among a sample of community health center attendees. J Health Care Poor & Underserved. 2004;15(2):281-93. Excluded: Not an eligible study design, OVID-Medline. [pmid: 15253379].
172 Church J, Lowry A, Simmang C, et al. Practice parameters for the identification and testing of patients at risk for dominantly inherited colorectal cancer—supporting documentation. Dis Colon Rectum. 2001;44(10):1404-12. Excluded: Model does not categorize risk or validate, OVID-Medline. [pmid: 11598466].
173 Ciliska D, Robinson P, Armour T, et al. Diffusion and dissemination of evidence-based dietary strategies for the prevention of cancer. Nutr J. 2005;4:13. Excluded: Not an eligible intervention or outcome, OVID-Medline. [pmid: 15819991].
174 Claes E, Evers-Kiebooms G, Decruyenaere M, et al. Surveillance behavior and prophylactic surgery after predictive testing for hereditary breast/ovarian cancer. Behav Med. 2005;31(3):93-105. Excluded: Family history not systematically collected, OVID-Medline. [pmid: 16252621].
175 Clark MA, Rakowski W, Bonacore LB. Repeat mammography: prevalence estimates and considerations for assessment. Ann Behav Med. 2003;26(3):201-11. Excluded: Not an eligible intervention or outcome, OVID-Medline. [pmid: 14644696].
176 Clarke M. Tamoxifen for early breast cancer. Cochrane Database Syst Rev 2001;(1):CD000486 Excluded: Not an eligible intervention or outcome, OVID-Cinahl.
177 Clarke M. Tamoxifen for early breast cancer [Systematic Review]. Cochrane Database of Syst Rev 2008;(1) 2008;(1): Excluded: Not an eligible intervention or outcome, OVID-Cochrane.
178 Claus EB, Risch N, Thompson WD. The calculation of breast cancer risk for women with a first degree family history of ovarian cancer. Breast Cancer Res Treat. 1993;28(2):115-20. Excluded: Model does not categorize risk or validate, OVID-Medline. [pmid: 8173064].
179 Claus EB, Risch N, Thompson WD. Autosomal dominant inheritance of early-onset breast cancer. Implications for risk prediction. Cancer. 1994;73(3):643-51. [underlined: PM:8299086] Excluded: Model does not categorize risk or validate, OVID-Medline. [pmid: 8299086].
180 Clavel-Chapelon F, Joseph R, Goulard H. Surveillance behavior of women with a reported family history of colorectal cancer. Prev Med. 1999;28(2):174-8. Excluded: Not an eligible study design, OVID-Medline. [pmid: 10048109].
181 Codori AM, Petersen GM, Miglioretti DL, et al. Health beliefs and endoscopic screening for colorectal cancer: potential for cancer prevention. Prev Med. 2001;33(2:Pt 1):t-36. Excluded: Family history not systematically collected, OVID-Medline.
182 Cohen M. First-degree relatives of breast-cancer patients: cognitive perceptions, coping, and adherence to breast self-examination. Behav Med. 2002;28(1):15-22. Excluded: Family history not systematically collected, OVID-Medline. [pmid: 12244641].
183 Cohen M. Breast cancer early detection, health beliefs, and cancer worries in randomly selected women with and without a family history of breast cancer. Psychooncology. 2006;15(10):873-83. Excluded: Family history not systematically collected, OVID-Embase. [pmid: 16374894].
184 Collins KS, Collins SK. Professional issues. Cancer screening recommendations. Radiat Therapist. 2004;13(2):137-9. Excluded: Not an eligible intervention or outcome, OVID-Cinahl.
185 Collins V, Meiser B, Gaff C, et al. Screening and preventive behaviors one year after predictive genetic testing for hereditary nonpolyposis colorectal carcinoma. Cancer. 2005;104(2):273-81. Excluded: Not an eligible population, OVID-Medline. [pmid: 15948171].
186 Colomer R, Vinas G, Beltran M, et al. Validation of the 2001 St Gallen risk categories for node-negative breast cancer using a database from the Spanish Breast Cancer Research Group (GEICAM). J Clin Oncol. 2004;22(5):961-2. Excluded: Family history not systematically collected, OVID-Medline. [pmid: 14990656].
187 Cormier L, Valeri A, Azzouzi R, et al. Worry and attitude of men in at-risk families for prostate cancer about genetic susceptibility and genetic testing. Prostate. 2002;51(4):276-85. Excluded: Not an eligible study design, OVID-Medline. [pmid: 11987156].
188 Cormier L, Reid K, Kwan L, et al. Screening behavior in brothers and sons of men with prostate cancer. J Urol. 2003;169(5):1715-9. Excluded: Family history not systematically collected, OVID-Medline. [pmid: 12686816].
189 Corpet DE, Pierre F. How good are rodent models of carcinogenesis in predicting efficacy in humans? A systematic review and meta-analysis of colon chemoprevention in rats, mice and men. Eur J Cancer. 2005;41(13):1911-22. Excluded: Not an eligible intervention or outcome, OVID-Medline. [pmid: 16084718].
190 Costantino JP, Gail MH, Pee D, et al. Validation studies for models projecting the risk of invasive and total breast cancer incidence. J Natl Cancer Inst. 1999;91(18):1541-8. Excluded: Model does not categorize risk or validate, OVID-Medline. [pmid: 10491430].
191 Costanza ME, Stoddard A, Gaw VP, et al. The risk factors of age and family history and their relationship to screening mammography utilization. J Am Geriatr Soc. 1992;40(8):774-8. Excluded: Family history not systematically collected, OVID-Medline. [pmid: 1634720].
192 Costanza ME, Luckmann R, Stoddard AM, et al. Applying a stage model of behavior change to colon cancer screening. Prev Med. 2005;41(34):707-19. Excluded: Family history not systematically collected, OVID-Medline. [pmid: 16171854].
193 Cottet V, Pariente A, Nalet B, et al. Low compliance with colonoscopic screening in first-degree relatives of patients with large adenomas. Aliment Pharmacol Ther. 2006;24(1):101-9. Excluded: Family history not systematically collected, OVID-Medline. [pmid: 16803608].
194 Coughlin L. American Cancer Society releases annual guidelines for the early detection of cancer. Am Fam Physician. 2005;71(11):2202-5. Excluded: Model does not categorize risk or validate, OVID-Embase.
195 Coulson AS, Glasspool DW, Fox J, et al. RAGs: A novel approach to computerized genetic risk assessment and decision support from pedigrees. Methods Inf Med. 2001;40(4):315-22. Excluded: Model does not categorize risk or validate, OVID-Medline. [pmid: 11552344].
196 Coyne JC, Kruus L, Racioppo M, et al. What do ratings of cancer-specific distress mean among women at high risk of breast and ovarian cancer? Am J Med Genet 2003;Part(3):222–8. Excluded: Not an eligible study design, OVID-Medline.
197 Cravo ML, Fidalgo PO, Lage PA, et al. Validation and simplification of Bethesda guidelines for identifying apparently sporadic forms of colorectal carcinoma with microsatellite instability. Cancer. 1999;85(4):779-85. Excluded: Model does not categorize risk or validate, OVID-Medline. [pmid: 10091754].
198 Cui Y, Peterson NB, Hargreaves M, et al. Mammography use in the Southern Cohort Study (United States). J Health Care Poor Underserved. 2007;18(4):Supplement-17. Excluded: Family history not systematically collected, OVID-Cinahl.
199 Cull A, Fry A, Rush R, et al. Cancer risk perceptions and distress among women attending a familial ovarian cancer clinic. Br J Cancer. 2001;84(5):594-9. Excluded: Not an eligible study design, OVID-Medline. [pmid: 11237377].
200 Cullen J, Schwartz MD, Lawrence WF, et al. Short-term impact of cancer prevention and screening activities on quality of life. J Clin Oncol. 2004;22(5):943-52. Excluded: Not an eligible intervention or outcome, OVID-Medline. [pmid: 14990651].
201 Culver J, Burke W, Yasui Y, et al. Participation in breast cancer genetic counseling: the influence of educational level, ethnic background, and risk perception. J Genetic Couns. 2001;10(3):215-31. Excluded: Family history not systematically collected, OVID-Cinahl.
202 Dai Z, Xu YC, Niu L. Obesity and colorectal cancer risk: a meta-analysis of cohort studies. World J Gastroenterol. 2007;13(31):4199-206. Excluded: Not an eligible population, OVID-Medline. [pmid: 17696248].
203 Daly MB, Lerman CL, Ross E, et al. Gail model breast cancer risk components are poor predictors of risk perception and screening behavior. Breast Cancer Res Treat. 1996;41(1):59-70. Excluded: Family history not systematically collected, OVID-Medline. [pmid: 8932877].
204 Davila RE, Rajan E, Baron TH, et al. ASGE guideline: colorectal cancer screening and surveillance.[erratum appears in Gastrointest Endosc. 2006 May;63(6):892 Note: Adler, Douglas G [added]; Egan, James V [added]; Faigel, Douglas O [added]; Gan, Seng-Ian [added]; Hirota, William K [added]; Leighton, Jonathan A [added]; Lichtenstein, David [added]; Qureshi, Waqar A [added]; Shen, Bo [added]; Zuckerman, Marc J [added]; VanGuilder, Trina [added]; Fanelli, Robert D [added]]. Gastrointest Endosc. 2006;63(4):546-57. Excluded: Model does not categorize risk or validate, OVID-Medline. [pmid: 16564851].
205 Dawson SJ, Price MA, Jenkins MA, et al. Cancer risk management practices of noncarriers within BRCA1/2 mutation positive families in the Kathleen Cuningham Foundation Consortium for Research into Familial Breast Cancer. J Clin Oncol. 2008;26(2):225-32. Excluded: Not an eligible population, OVID-Medline. [pmid: 18040054].
206 De Bock GH, van Asperen CJ, de Vries JM, et al. How women with a family history of breast cancer and their general practitioners act on genetic advice in general practice: prospective longitudinal study. BMJ. 2001;322(7277):26-7. Excluded: Not an eligible study design, OVID-Medline. [pmid: 11141149].
207 De Bock GH, Bonnema J, Van Der Hage J, et al. Effectiveness of routine visits and routine tests in detecting isolated locoregional recurrences after treatment for early-stage invasive breast cancer: A meta-analysis and systematic review. J Clin Oncol. 2004;22(19):4010-8. Excluded: Not an eligible intervention or outcome, OVID-Embase. [pmid: 15459225].
208 de la Hoya M, Diez O, Perez-Segura P, et al. Pre-test prediction models of BRCA1 or BRCA2 mutation in breast/ovarian families attending familial cancer clinics. J Med Genet. 2003;40(7):503-10. Excluded: Model does not categorize risk or validate, OVID-Medline. [pmid: 12843322].
209 Dearnaley DP, Kirby RS, Kirk D, et al. Diagnosis and management of early prostate cancer. Report of a British Association of Urological Surgeons Working Party. BJU Int. 1999;83(1):18-33. Excluded: Model does not categorize risk or validate, OVID-Embase. [pmid: 10233447].
210 Deligeoroglou E, Michailidis E, Creatsas G. Oral contraceptives and reproductive system cancer. Ann N Y Acad Sci. 2003;997:199-208. Excluded: Not an eligible study design, OVID-Embase. [pmid: 14644827].
211 Desch CE, Benson AB III, Somerfield MR, et al. Colorectal cancer surveillance: 2005 update of an American Society of Clinical Oncology practice guideline.[erratum appears in J Clin Oncol. 2006 Mar 1;24(7):1224]. J Clin Oncol. 2005;23(33):8512-9. Excluded: Model does not categorize risk or validate, OVID-Medline. [pmid: 16260687].
212 Dettenborn L, James GD, Berge-Landry H, et al. Heightened cortisol responses to daily stress in working women at familial risk for breast cancer. Biol Psychol. 2005;69(2):167-79. Excluded: Not an eligible study design, OVID-Medline. [pmid: 15804544].
213 Digianni LM, Kim HT, Emmons K, et al. Complementary medicine use among women enrolled in a genetic testing program. Cancer Epidemiol Biomarkers Prev. 2003;12(4):321-6. Excluded: Not an eligible population, OVID-Medline. [pmid: 12692106].
214 Digianni LM, Rue M, Emmons K, et al. Complementary medicine use before and 1 year following genetic testing for BRCA1/2 mutations. Cancer Epidemiol Biomarkers Prev. 2006;15(1):70-5. Excluded: Not an eligible population, OVID-Medline. [pmid: 16434589].
215 DiLorenzo TA, Schnur J, Montgomery GH, et al. A model of disease-specific worry in heritable disease: the influence of family history, perceived risk and worry about other illnesses. J Behav Med. 2006;29(1):37-49. Excluded: Not an eligible study design, OVID-Medline. [pmid: 16470344].
216 Dimella, L.F. The relationship between beliefs about god's control over health and adherence to breast cancer screening guidelines following genetic testing Dimella. 2003 Excluded: Not an eligible intervention or outcome, OVID-PsycInfo.
217 Dominguez FJ, Jones JL, Zabicki K, et al. Prevalence of hereditary breast/ovarian carcinoma risk in patients with a personal history of breast or ovarian carcinoma in a mammography population. Cancer. 2005;104(9):1849-53. Excluded: Model does not categorize risk or validate, OVID-Medline. [pmid: 16136597].
218 Driver JA, Gaziano JM, Gelber RP, et al. Development of a risk score for colorectal cancer in men. Am J Med. 2007;120(3):257-63. PM:17349449 Excluded: not an eligible study design. [pmid: 17349449].
219 Drossaert CC, Boer H, Seydel ER. Perceived risk, anxiety, mammogram uptake, and breast self-examination of women with a family history of breast cancer: the role of knowing to be at increased risk. Cancer Detect Prev. 1996;20(1):76-85. Excluded: Family history not systematically collected, OVID-Medline. [pmid: 8907207].
220 Drossaert CHC, Boer H, Seydel ER. Prospective study on the determinants of repeat attendance and attendance patterns in breast cancer screening using the theory of planned behaviour. Psychol Health. 2003;18(5):551-65. Excluded: Not an eligible study design, OVID-Cinahl.
221 DudokdeWit AC, Tibben A, Duivenvoorden HJ, et al. Distress in individuals facing predictive DNA testing for autosomal dominant late-onset disorders: comparing questionnaire results with in-depth interviews. Rotterdam/Leiden Genetics Workgroup. Am J Med Genet. 1998;75(1):62-74. Excluded: Not an eligible intervention or outcome, OVID-Medline. [pmid: 9450860].
222 Duffy MJ, Bonfrer JM, Kulpa J, et al. CA125 in ovarian cancer: European Group on Tumor Markers guidelines for clinical use. Int J Gynecol Cancer. 2005;15(5):679-91. Excluded: Model does not categorize risk or validate, OVID-Embase. [pmid: 16174214].
223 Duffy MJ, van Dalen A, Haglund C, et al. Tumour markers in colorectal cancer: European Group on Tumour Markers (EGTM) guidelines for clinical use. Eur J Cancer. 2007;43(9):1348-60. Excluded: Model does not categorize risk or validate, OVID-Embase. [pmid: 17512720].
224 Eastham JA, May R, Robertson JL, et al. Development of a nomogram that predicts the probability of a positive prostate biopsy in men with an abnormal digital rectal examination and a prostate-specific antigen between 0 and 4 ng/mL. Urology. 1999;54(4):709-13. PM:10510933 Excluded: Not an eligible study design. [pmid: 10510933].
225 Eccles DM, Evans DG, Mackay J. Guidelines for a genetic risk based approach to advising women with a family history of breast cancer. UK Cancer Family Study Group (UKCFSG). J Med Genet. 2000;37(3):203-9. Excluded: Model does not categorize risk or validate, OVID-Medline. [pmid: 10699057].
226 Edwards A, Unigwe S, Elwyn G, et al. Effects of communicating individual risks in screening programmes: Cochrane systematic review. Br Med J. 2003;327(7417):703-7. Excluded: Family history not systematically collected, OVID-Embase. [pmid: 14512475].
227 Edwards A, Gray J, Clarke A, et al. Interventions to improve risk communication in clinical genetics: Systematic review. Patient Educ Couns. 2008;71(1):4-25. Excluded: Family history not systematically collected, OVID-Embase. [pmid: 18207694].
228 Edwards AG, Evans R, Dundon J, et al. Personalised risk communication for informed decision making about taking screening tests. Cochrane Database Syst Rev 2006;(4):CD001865 Excluded: Family history not systematically collected, OVID-Medline.
229 Eisinger F, Tarpin C, Huiart L, et al. Behavioral and economic impact of a familial history of cancers. Fam Cancer. 2005;4(4):307-11. Excluded: Family history not systematically collected, OVID-Medline. [pmid: 16341808].
230 Elit L. Familial ovarian cancer. Can Fam Physician. 2001;47:778-84. Excluded: Model does not categorize risk or validate, OVID-Medline. [pmid: 11340759].
231 Ellis P, Robinson P, Ciliska D, et al. A systematic review of studies evaluating diffusion and dissemination of selected cancer control interventions. Health Psychol. 2005;24(5):488-500. Excluded: Not an eligible intervention or outcome, OVID-Medline. [pmid: 16162043].
232 Elmore JG, Armstrong K, Lehman CD, et al. Screening for breast cancer. JAMA. 2005;293(10):1245-56. Excluded: Not an eligible intervention or outcome, OVID-Medline. [pmid: 15755947].
233 Emery J. The GRAIDS Trial: the development and evaluation of computer decision support for cancer genetic risk assessment in primary care. Ann Hum Biol. 2005;32(2):218-27. Excluded: Model does not categorize risk or validate, OVID-Medline. [pmid: 16096220].
234 Emery J, Morris H, Goodchild R, et al. The GRAIDS Trial: a cluster randomised controlled trial of computer decision support for the management of familial cancer risk in primary care. Br J Cancer. 2007;97(4):486-93. Excluded: Model does not categorize risk or validate, OVID-Medline. [pmid: 17700548].
235 Engstrom PF, Benson AB III, Chen YJ, et al. Colon cancer clinical practice guidelines in oncology. J Natl Compr Cancer Netw. 2005;3(4):468-91. Excluded: Not an eligible intervention or outcome, OVID-Medline.
236 Epstein SA, Lin TH, Audrain J, et al. Excessive breast self-examination among first-degree relatives of newly diagnosed breast cancer patients. High-Risk Breast Cancer Consortium. Psychosomatics. 1997;38(3):253-61. Excluded: Family history not systematically collected, OVID-Medline. [pmid: 9136254].
237 Erblich J, Bovbjerg DH, Valdimarsdottir HB. Looking forward and back: distress among women at familial risk for breast cancer. Ann Behav Med. 2000;22(1):53-9. Excluded: Family history not systematically collected, OVID-Medline. [pmid: 10892528].
238 Erlick RG, Rosen BP, Bradley LN, et al. Psychological impact of screening for familial ovarian cancer: reactions to initial assessment. Gynecol Oncol. 1997;65(2):197-205. Excluded: Not an eligible population, OVID-Medline. [pmid: 9159325].
239 Esplen MJ, Toner B, Hunter J, et al. A supportive-expressive group intervention for women with a family history of breast cancer: results of a phase II study. Psychooncology. 2000;9(3):243-52. Excluded: Not an eligible population, OVID-Medline. [pmid: 10871720].
240 Esplen MJ, Hunter J, Leszcz M, et al. A multicenter study of supportive-expressive group therapy for women with BRCA1/BRCA2 mutations. Cancer. 2004;101(10):2327-40. Excluded: Not an eligible population, OVID-Embase. [pmid: 15478194].
241 Etminan M, FitzGerald JM, Gleave M, et al. Intake of selenium in the prevention of prostate cancer: a systematic review and meta-analysis. Cancer Causes Control. 2005;16(9):1125-31. Excluded: Not an eligible intervention or outcome, OVID-Medline. [pmid: 16184479].
242 Euhus DM, Leitch AM, Huth JF, et al. Limitations of the Gail model in the specialized breast cancer risk assessment clinic. Breast J. 2002;8(1):23-7. Excluded: Model does not categorize risk or validate, OVID-Medline. [pmid: 11856157].
243 Euhus DM, Smith KC, Robinson L, et al. Pretest prediction of BRCA1 or BRCA2 mutation by risk counselors and the computer model BRCAPRO. J Natl Cancer Inst. 2002;94(11):844-51. Excluded: Model does not categorize risk or validate, OVID-Medline. [pmid: 12048272].
244 Evans D, Lalloo F, Shenton A, et al. Uptake of screening and prevention in women at very high risk of breast cancer. Lancet. 2001;358(9285):889-90. Excluded: Not an eligible study design, OVID-Medline. [pmid: 11567707].
245 Evans DG, Maher ER, Macleod R, et al. Uptake of genetic testing for cancer predisposition. J Med Genet. 1997;34(9):746-8. Excluded: Not an eligible population, OVID-Medline. [pmid: 9321761].
246 Evans DG, Eccles DM, Rahman N, et al. A new scoring system for the chances of identifying a BRCA1/2 mutation outperforms existing models including BRCAPRO. J Med Genet. 2004;41(6):474-80. Excluded: Model does not categorize risk or validate, OVID-Medline. [pmid: 15173236].
247 Evans R, Edwards A, Brett J, et al. Reduction in uptake of PSA tests following decision aids: systematic review of current aids and their evaluations. Patient Educ Couns. 2005;58(1):13-26. Excluded: Not an eligible intervention or outcome, OVID-Medline. [pmid: 15950832].
248 Fabian CJ, Kimler BF. Selective estrogen-receptor modulators for primary prevention of breast cancer. J Clin Oncol. 2005;23(8):1644-55. Excluded: Not an eligible study design, OVID-Embase. [pmid: 15755972].
249 Faccenda,K.A. Factors affecting the decision to have genetic testing for breast cancer Faccenda. 1999 Excluded: Not an eligible publication type, OVID-PsycInfo.
250 Fajardo LL. Screening mammography. Imaging Decisions MRI. 2005;9(2):23-34. Excluded: Not an eligible study design, OVID-Embase.
251 Fang CY, Daly MB, Miller SM, et al. Coping with ovarian cancer risk: The moderating effects of perceived control on coping and adjustment. Br J Health Psychol. 2006;11(4):561-80. Excluded: Not an eligible population, OVID-Embase. [pmid: 17032484].
252 Fasching PA, Bani MR, Nestle-Kramling C, et al. Evaluation of mathematical models for breast cancer risk assessment in routine clinical use. Eur J Cancer Prev. 2007;16(3):216-24. Excluded: Model does not categorize risk or validate, OVID-Medline. [pmid: 17415092].
253 Fernandez E, Vecchia CL, Balducci A, et al. Oral contraceptives and colorectal cancer risk: a meta-analysis. Br J Cancer. 2001;84(5):722-7. Excluded: Not an eligible population, OVID-Cochrane. [pmid: 11237397].
254 Figueredo A, Rumble RB, Maroun J, et al. Follow-up of patients with curatively resected colorectal cancer: A practice guideline. BMC Cancer. 2003;3:26. Excluded: Model does not categorize risk or validate, OVID-Embase. [pmid: 14529575].
255 Finne P, Auvinen A, Aro J, et al. Estimation of prostate cancer risk on the basis of total and free prostate-specific antigen, prostate volume and digital rectal examination. Eur Urol. 2002;41(6):619-26. Excluded: Not an eligible intervention or outcome, OVID-Cochrane. [pmid: 12074779].
256 Finney Rutten LJ, Iannotti RJ. Health beliefs, salience of breast cancer family history, and involvement with breast cancer issues: adherence to annual mammography screening recommendations. Cancer Detect Prev. 2003;27(5):353-9. Excluded: Family history not systematically collected, OVID-Medline. [pmid: 14585322].
257 Finney,L.J. Health beliefs, message framing, and mammography screening compliance: Measurement development and theory testing Finney. 2001 Excluded: Not an eligible publication type, OVID-PsycInfo.
258 Fisher TJ, Kirk J, Hopper JL, et al. A simple tool for identifying unaffected women at a moderately increased or potentially high risk of breast cancer based on their family history. Breast. 2003;12(2):120-7. Excluded: Model does not categorize risk or validate, OVID-Medline. [pmid: 14659341].
259 Flamm CR, Ziegler KM, Aronson N. Technology evaluation center assessment synopsis: Use of magnetic resonance imaging to avoid a biopsy in women with suspicious primary breast lesions. J Am Coll Radiol. 2005;2(6):485-7. Excluded: Not an eligible population, OVID-Embase. [pmid: 17411864].
260 Fletcher JW, Djulbegovic B, Soares HP, et al. Recommendations on the use of PET in oncology. J Nucl Med. 2008;49(3):480-508. Excluded: Model does not categorize risk or validate, OVID-Embase. [pmid: 18287273].
261 Fletcher KE, Clemow L, Peterson BA, et al. A path analysis of factors associated with distress among first-degree female relatives of women with breast cancer diagnosis. Health Psychol. 2006;25(3):413-24. Excluded: Family history not systematically collected, OVID-Medline. [pmid: 16719614].
262 Fletcher RH, Lobb R, Bauer MR, et al. Screening patients with a family history of colorectal cancer. J Gen Intern Med. 2007;22(4):508-13. Excluded: Family history not systematically collected, OVID-Medline. [pmid: 17372801].
263 Fletcher SW, Elmore JG. Mammographic screening for breast cancer. N Engl J Med. 2003;348(17):1672-80. Excluded: Not an eligible study design, OVID-Embase. [pmid: 12711743].
264 Flook N. Colorectal cancer. Summary of Canadian screening guidelines. Can Fam Physician. 2004;50:592-3. Excluded: Model does not categorize risk or validate, OVID-Medline. [pmid: 15116806].
265 Flossmann E, Rothwell PM. British Doctors Aspirin Trial and the UK-TIA Aspirin Trial. Effect of aspirin on long-term risk of colorectal cancer: consistent evidence from randomised and observational studies. Lancet. 2007;369(9573):1603-13. Excluded: Not an eligible population, OVID-Medline. [pmid: 17499602].
266 Fornasarig M, Viel A, Bidoli E, et al. Amsterdam criteria II and endometrial cancer index cases for an accurate selection of HNPCC families. Tumori. 2002;88(1):18-20. Excluded: Not an eligible intervention or outcome, OVID-Embase. [pmid: 12004844].
267 Frazier TG, Cummings PD. Motivational factors for participation in breast cancer screening. J Cancer Educ. 1990;5(1):51-4. Excluded: Not an eligible study design, OVID-Medline. [pmid: 2400671].
268 Friebel TM, Domchek SM, Neuhausen SL, et al. Bilateral prophylactic oophorectomy and bilateral prophylactic mastectomy in a prospective cohort of unaffected BRCA1 and BRCA2 mutation carriers. Clin Breast Cancer. 2007;7(11):875-82. Excluded: Not an eligible population, OVID-Embase. [pmid: 18269778].
269 Friedman LC, Webb JA, Richards CS, et al. Psychological and behavioral factors associated with colorectal cancer screening among Ashkenazim. Prev Med. 1999;29(2):119-25. Excluded: Family history not systematically collected, OVID-Medline. [pmid: 10446038].
270 Friedman LC, Everett TE, Peterson L, et al. Compliance with fecal occult blood test screening among low-income medical outpatients: a randomized controlled trial using a videotaped intervention. J Cancer Educ. 2001;16(2):85-8. Excluded: Family history not systematically collected, OVID-Medline. [pmid: 11440068].
271 Friedman LC, Webb JA, Everett TE. Psychosocial and medical predictors of colorectal cancer screening among low-income medical outpatients. J Cancer Educ. 2004;19(3):180-6. Excluded: Family history not systematically collected, OVID-Medline. [pmid: 15458875].
272 Fries MH, Holt C, Carpenter I, et al. Diagnostic criteria for testing for BRCA1 and BRCA2: the experience of the Department of Defense Familial Breast/Ovarian Cancer Research Project. Mil Med. 2002;167(2):99-103. Excluded: Model does not categorize risk or validate,OVID-Cinahl. [pmid: 11873550].
273 Fries MH, Holt C, Carpenter I, et al. Guidelines for evaluation of patients at risk for inherited breast and ovarian cancer: recommendations of the Department of Defense Familial Breast/Ovarian Cancer Research Project. Mil Med. 2002;167(2):93-8. Excluded: Model does not categorize risk or validate, OVID-Medline.
274 Frost MH, Vockley CW, Suman VJ, et al. Perceived familial risk of cancer: Health concerns and psychosocial adjustment. J Psychosoc Oncol. 2000;18(1):63-82. Excluded: Family history not systematically collected, OVID-Embase.
275 Fuerst ML. Genetic testing plus Bethesda guidelines help screen for Lynch syndrome. Oncol Times. 2005;27(18):13-4. Excluded: Not an eligible study design, OVID-Cinahl.
276 Fung MF, Bryson P, Johnston M, et al. Screening postmenopausal women for ovarian cancer: a systematic review. J Obstet Gynaecol Can. 2004;26(8):717-28. Excluded: Not an eligible intervention or outcome, OVID-Medline. [pmid: 15307976].
277 Furukawa T, Konishi F, Shitoh K, et al. Evaluation of screening strategy for detecting hereditary nonpolyposis colorectal carcinoma. Cancer. 2002;94(4):911-20. Excluded: Model does not categorize risk or validate, OVID-Medline. [pmid: 11920458].
278 Gagnon P, Massie MJ, Kash KM, et al. Perception of breast cancer risk and psychological distress in women attending a surveillance program. Psychooncology. 1996;5(3):259-69. Excluded: Family history not systematically collected, OVID-Cochrane.
279 Gao X, LaValley MP, Tucker KL. Prospective studies of dairy product and calcium intakes and prostate cancer risk: a meta-analysis. J Natl Cancer Inst. 2005;97(23):1768-77. Excluded: Not an eligible intervention or outcome, OVID-Cinahl. [pmid: 16333032].
280 Garrett MM, Fisher DA. Strategies to improve colorectal cancer screening rates. Journal of Clinical Outcomes Management. 2006;13(9):512-7. Excluded: Not an eligible intervention or outcome, OVID-Embase.
281 Gately ST. Targeting cyclooxygenase-2 for cancer prevention and treatment. Prog Drug Res. 2005;63:207-25. Excluded: Not an eligible study design, OVID-Embase. [pmid: 16265882].
282 Geelen A, Schouten JM, Kamphuis C, et al. Fish consumption, n-3 fatty acids, and colorectal cancer: a meta-analysis of prospective cohort studies. Am J Epidemiol. 2007;166(10):1116-25. Excluded: Not an eligible population, OVID-Medline. [pmid: 17823383].
283 Geirdal AO, Reichelt JG, Dahl AA, et al. Psychological distress in women at risk of hereditary breast/ovarian or HNPCC cancers in the absence of demonstrated mutations. Fam Cancer. 2005;4(2):121-6. Excluded: Not an eligible population, OVID-Medline. [pmid: 15951962].
284 Geirdal AO, Maehle L, Heimdal K, et al. Quality of life and its relation to cancer-related stress in women of families with hereditary cancer without demonstrated mutation. Qual Life Res. 2006;15(3):461-70. Excluded: Not an eligible study design, OVID-Medline. [pmid: 16547785].
285 Geirdal AO, Dahl AA. The relationship between coping strategies and anxiety in women from families with familial breast-ovarian cancer in the absence of demonstrated mutations. Psychooncology. 2008;17(1):49-57. Excluded: Not an eligible population, OVID-Medline. [pmid: 17385192].
286 Geller G, Doksum T, Bernhardt BA, et al. Participation in breast cancer susceptibility testing protocols: influence of recruitment source, altruism, and family involvement on women's decisions. Cancer Epidemiol Biomarkers Prev. 1999;8(4:Pt 2):t-83. Excluded: Not an eligible study design, OVID-Medline.
287 Gerdes AM, Cruger DG, Thomassen M, et al. Evaluation of two different models to predict BRCA1 and BRCA2 mutations in a cohort of Danish hereditary breast and/or ovarian cancer families. Clin Genet. 2006;69(2):171-8. Excluded: Model does not categorize risk or validate, OVID-Embase. [pmid: 16433698].
288 Giardiello FM, Brensinger JD, Petersen GM. AGA technical review on hereditary colorectal cancer and genetic testing. Gastroenterology. 2001;121(1):198-213. Excluded: Model does not categorize risk or validate, OVID-Medline. [pmid: 11438509].
289 Giarelli E. Self-surveillance for genetic predisposition to cancer: behaviors and emotions. Oncol Nurs Forum. 2006;Online(2):221-31. Excluded: Not an eligible population, OVID-Medline.
290 Gil F, Mendez I, Sirgo A, et al. Perception of breast cancer risk and surveillance behaviours of women with family history of breast cancer: a brief report on a Spanish cohort. Psychooncology. 2003;12(8):821-7. Excluded: Family history not systematically collected, OVID-Medline. [pmid: 14681955].
291 Gil KM, von Gruenigen VE. Nutrition and ovarian carcinogenesis: A critical review. Women's Oncology Review. 2005;5(2):81-94. Excluded: Not an eligible intervention or outcome, OVID-Embase.
292 Gilbar O. Women with high risk for breast cancer: psychological symptoms. Psychol Rep. 1997;80(3:Pt 1):t-2. Excluded: Family history not systematically collected, OVID-Medline.
293 Gilbar O. Coping with threat. Implications for women with a family history of breast cancer. Psychosomatics. 1998;39(4):329-39. Excluded: Family history not systematically collected, OVID-Medline. [pmid: 9691702].
294 Gilpin CA, Carson N, Hunter AG. A preliminary validation of a family history assessment form to select women at risk for breast or ovarian cancer for referral to a genetics center. Clin Genet. 2000;58(4):299-308. Excluded: Model does not categorize risk or validate, OVID-Medline. [pmid: 11076055].
295 Giuliano AE, Boolbol S, Degnim A, et al. Society of Surgical Oncology: Position statement on prophylactic mastectomy. Ann Surg Oncol. 2007;14(9):2425-7. Excluded: Not an eligible intervention or outcome, OVID-Embase. [pmid: 17597344].
296 Glicksman AS. Colorectal Cancer Care Task Force. Colorectal algorithm guidelines for screening. Med Health R I. 2006;89(4):149. Excluded: Not an eligible study design, OVID-Medline. [pmid: 16676913].
297 Goelen G, Teugels E, Sermijn E, et al. Comparing the performance of family characteristics and predictive models for germline BRCA1/2 mutations in breast cancer families. Archives of Public Health. 2003;61(6):297-312. Excluded: Model does not categorize risk or validate, OVID-Embase.
298 Gologan A, Krasinskas A, Hunt J, et al. Performance of the revised Bethesda guidelines for identification of colorectal carcinomas with a high level of microsatellite instability. Arch Pathol Lab Med. 2005;129(11):1390-7. Excluded: Model does not categorize risk or validate, OVID-Medline. [pmid: 16253017].
299 Gonzalez-Perez A, Garcia Rodriguez LA, Lopez-Ridaura R. Effects of non-steroidal anti-inflammatory drugs on cancer sites other than the colon and rectum: a meta-analysis. BMC Cancer. 2003;3:28. Excluded: Not an eligible population, OVID-Medline. [pmid: 14588079].
300 Gorham ED, Garland CF, Garland FC, et al. Optimal vitamin D status for colorectal cancer prevention: a quantitative meta analysis. Am J Prev Med. 2007;32(3):210-6. Excluded: Not an eligible population, VID-Medline. [pmid: 17296473].
301 Gorin SS, Albert SM. The meaning of risk to first degree relatives of women with breast cancer. Women Health. 2003;37(3):97-114. Excluded: Family history not systematically collected, OVID-Embase. [pmid: 12839310].
302 Goyal S, Bennett P, Sweetland HM, et al. Are surgeons effective counsellors for women with a family history of breast cancer?. Eur J Surg Oncol. 2002;28(5):501-4. Excluded: Not an eligible study design, VID-Medline. [pmid: 12217301].
303 Gradishar WJ, Cella D. Selective estrogen receptor modulators and prevention of invasive breast cancer. JAMA. 2006;295(23):2784-6. Excluded: Not an eligible study design, OVID-Embase. [pmid: 16754726].
304 Gramling R, Anthony D, Lowery J, et al. Association between screening family medical history in general medical care and lower burden of cancer worry among women with a close family history of breast cancer. Genet Med. 2005;7(9):640-5. Excluded: Not an eligible study design, OVID-Medline. [pmid: 16301866].
305 Gramling R, Anthony D, Frierson G, et al. The cancer worry chart: a single-item screening measure of worry about developing breast cancer. Psychooncology. 2007;16(6):593-7. Excluded: Not an eligible population, OVID-Medline. [pmid: 17096453].
306 Greco K, Nail L, Kendall J, et al. Breast cancer screening decisions in older high-risk women. Oncol Nurs Forum. 2007;34(1):205. Excluded: Not an eligible publication type, OVID-Cinahl.
307 Greco,K.E. Mammography decision-making in women age 65 or older with a family history of breast cancer. Excluded: Not an eligible publication type, OVID-Cinahl.
308 Green BB, Taplin SH. Breast cancer screening controversies. J Am Board Fam Pract. 2003;16(3):233-41. Excluded: Not an eligible population, OVID-Medline. [pmid: 12755251].
309 Green RC, McLaughlin JR, Younghusband HB. SISE matters: the sum of information on seventy-yr-old equivalents measures pedigree information content when assessing the risk of HNPCC in a family. Familial Cancer. 2005;4(2):169-75. Excluded: Model does not categorize risk or validate, OVID-Medline. [pmid: 15951969].
310 Gronwald J, Byrski T, Huzarski T, et al. A survey of preventive measures among BRCA1 mutation carriers from Poland. Clin Genet. 2007;71(2):153-7. Excluded: Not an eligible population, OVID-Medline. [pmid: 17250664].
311 Gross CP, Filardo G, Singh HS, et al. The relation between projected breast cancer risk, perceived cancer risk, and mammography use: Results from the national health interview survey. J Gen Intern Med. 2006;21(2):158-64. Excluded: Family history not systematically collected, OVID-Embase. [pmid: 16390511].
312 Gross RE. Utilization of Breast Cancer Anxiety Scale in women at high risk for breast cancer. 18th Annual SGNO Symposium. J Gynecol Oncol Nurs. 2001;11(1):24-5. Excluded: Not an eligible study design, OVID-Cinahl.
313 Grube BJ. Barriers to diagnosis and treatment of breast cancer in the older woman. J Am Coll Surg. 2006;202(3):495-508. Excluded: Not an eligible study design, OVID-Embase. [pmid: 16500255].
314 Guerrero-Preston R, Chan C, Vlahov D, et al. Previous cancer screening behavior as predictor of endoscopic colon cancer screening among women aged 50 and over, in NYC 2002. J Community Health. 2008;33(1):10-21. Excluded: Family history not systematically collected, OVID-Medline. [pmid: 18080204].
315 Guevarra,J.S. Psychological distress, African American acculturation and family history of breast cancer: Effects on breast self-examination frequency Guevarra. 2000 Excluded: Not an eligible publication type, OVID-PsycInfo.
316 Gullini S, Matarese V, Pezzoli A, et al. Screening colonoscopy in asymptomatic increased-risk subjects. Eur J Cancer Prev. 2001;10(2):175-6. Excluded: Family history not systematically collected, OVID-Medline. [pmid: 11330462].
317 Haas JS, Kaplan CP, Des JG, et al. Perceived risk of breast cancer among women at average and increased risk. J Womens Health (Larchmt). 2005;14(9):845-51. Excluded: Family history not systematically collected, OVID-Medline. [pmid: 16313212].
318 Hackshaw A. EUSOMA review of mammography screening. Ann Oncol. 2003;14(8):1193-5. Excluded: Not an eligible study design, OVID-Medline. [pmid: 12881375].
319 Hadley DW, Jenkins J, Dimond E, et al. Genetic counseling and testing in families with hereditary nonpolyposis colorectal cancer. Arch Intern Med. 2003;163(5):573-82. Excluded: Not an eligible population, OVID-Medline. [pmid: 12622604].
320 Hadley DW, Jenkins JF, Dimond E, et al. Colon cancer screening practices after genetic counseling and testing for hereditary nonpolyposis colorectal cancer. J Clin Oncol. 2004;22(1):39-44. Excluded: Not an eligible population, OVID-Medline. [pmid: 14701766].
321 Hadley DW, Jenkins JF, Steinberg SM, et al. Perceptions of cancer risks and predictors of colon and endometrial cancer screening in women undergoing genetic testing for Lynch syndrome. J Clin Oncol. 2008;26(6):948-54. Excluded: Family history not systematically collected, OVID-Medline. [pmid: 18281669].
322 Hagoel L, Dishon S, Almog R, et al. Proband family uptake of familial-genetic counselling. Psychooncology. 2000;9(6):522-7. Excluded: Not an eligible population, OVID-Medline. [pmid: 11180587].
323 Hailey BJ, Carter CL, Burnett DR. Breast cancer attitudes, knowledge, and screening behavior in women with and without a family history of breast cancer. Health Care Women Int. 2000;21(8):701-15. Excluded: Family history not systematically collected, OVID-Medline. [pmid: 11813762].
324 Halbert CH, Lynch H, Lynch J, et al. Colon cancer screening practices following genetic testing for hereditary nonpolyposis colon cancer (HNPCC) mutations. Arch Intern Med. 2004;164(17):1881-7. Excluded: Not an eligible population, OVID-Medline. [pmid: 15451763].
325 Halbert CH, Brewster K, Collier A, et al. Recruiting African American women to participate in hereditary breast cancer research. J Clin Oncol. 2005;23(31):7967-73. Excluded: Family history not systematically collected, OVID-Cinahl. [pmid: 16258097].
326 Halbert CH, Kessler L, Wileyto EP, et al. Breast cancer screening behaviors among African American women with a strong family history of breast cancer. Prev Med. 2006;43(5):385-8. Excluded: Family history not systematically collected, OVID-Medline. [pmid: 16860380].
327 Halbert C, Kessler L, Collier A, et al. Psychological functioning in African American women at an increased risk of hereditary breast and ovarian cancer. Clin Genet. 2005;68(3):222-7. Excluded: Not an eligible study design, OVID-Medline. [pmid: 16098010].
328 Hall MJ, Neugut AI. Review: only women with specific family histories should be referred for counseling or evaluation for BRCA breast and ovarian cancer susceptibility. ACP J Club. 2006;144(2):37. Excluded: Not an eligible study design, OVID-Cinahl. [pmid: 16539352].
329 Hallowell N, Jacobs I, Richards M, et al. Surveillance or surgery? A description of the factors that influence high risk premenopausal women's decisions about prophylactic oophorectomy. J Med Genet. 2001;38(10):683-91. Excluded: Not an eligible study design, OVID-Medline. [pmid: 11594337].
330 Hamann HA, Somers TJ, Smith AW, et al. Posttraumatic stress associated with cancer history and BRCA1/2 genetic testing. Psychosom Med. 2005;67(5):766-72. Excluded: Not an eligible population, OVID-Medline. [pmid: 16204436].
331 Hampton T. Breast cancer prevention strategies explored. JAMA. 2006;295(18):2128-9. Excluded: Not an eligible study design, OVID-Embase. [pmid: 16684975].
332 Hannemann M, Fox R, James M. Ovarian cancer death reduction for women at high risk: workload implications for gynaecology services. J Obstet Gynaecol. 2006;26(1):42-4. Excluded: Not an eligible study design, OVID-Medline. [pmid: 16390709].
333 Harmon AL, Westerberg AL, Bond DS, et al. Cancer prevention among rural youth: building a “Bridge” to better health with genealogy. J Cancer Educ. 2005;20(2):103-7. Excluded: Family history not systematically collected, OVID-Cinahl. [pmid: 16083374].
334 Harris L, Fritsche H, Mennel R, et al. American Society of Clinical Oncology 2007 update of recommendations for the use of tumor markers in breast cancer. J Clin Oncol. 2007;25(33):5287-312. Excluded: Not an eligible intervention or outcome, OVID-Medline. [pmid: 17954709].
335 Haug U, Brenner H. New stool tests for colorectal cancer screening: a systematic review focusing on performance characteristics and practicalness. Int J Cancer. 2005;117(2):169-76. Excluded: Not an eligible population, OVID-Medline. [pmid: 15880368].
336 Hay JL, McCaul KD, Magnan RE. Does worry about breast cancer predict screening behaviors? A meta-analysis of the prospective evidence. Prev Med. 2006;42(6):401-8. Excluded: Not an eligible intervention or outcome, OVID-Medline. [pmid: 16626796].
337 Heatley MK. Immunohistochemical and functional biomarkers of value in female genital tract lesions: A systematic review with statistical meta-analysis. Int J Gynecol Pathol. 2007;26(2):177-9. Excluded: Not an eligible study design, OVID-Embase. [pmid: 17413986].
338 Heikkila K, Ebrahim S, Lawlor DA. A systematic review of the association between circulating concentrations of C reactive protein and cancer. J Epidemiol Community Health. 2007;61(9):824-32. Excluded: Not an eligible intervention or outcome, OVID-Embase. [pmid: 17699539].
339 Henderson BJ, Tyndel S, Brain K, et al. Factors associated with breast cancer-specific distress in younger women participating in a family history mammography screening programme. Psychooncology. 2008;17(1):74-82. Excluded: Not an eligible study design, OVID-Medline. [pmid: 17410528].
340 Hendriks YMC, De Jong AE, Morreau H, et al. Diagnostic approach and management of Lynch syndrome (Hereditary Nonpolyposis Colorectal Carcinoma): A guide for clinicians. CA Cancer J Clin. 2006;56(4):213-25. Excluded: Model does not categorize risk or validate, OVID-Embase. [pmid: 16870997].
341 Hensley ML, Robson ME, Kauff ND, et al. Pre- and postmenopausal high-risk women undergoing screening for ovarian cancer: anxiety, risk perceptions, and quality of life. Gynecol Oncol. 2003;89(3):440-6. Excluded: Not an eligible study design, OVID-Medline. [pmid: 12798709].
342 Herendeen JM, Lindley C. Use of NSAIDs for the chemoprevention of colorectal cancer. Ann Pharmacother. 2003;37(11):1664-74. Excluded: Not an eligible study design, OVID-Medline. [pmid: 14565811].
343 Heshka JT, Palleschi C, Howley H, et al. A systematic review of perceived risks, psychological and behavioral impacts of genetic testing. Genet Med. 2008;10(1):19-32. Excluded: Family history not systematically collected, OVID-Medline. [pmid: 18197053].
344 Hill J, Hanstock Z, Lockwood B. Keeping cancer at bay the natural way. Pharmaceutical Journal 2006;(7416):277–84. Excluded: Not an eligible study design, OVID-Embase.
345 Hirota WK, Zuckerman MJ, Adler DG, et al. ASGE guideline: The role of endoscopy in the surveillance of premalignant conditions of the upper GI tract. Gastrointest Endosc. 2006;63(4):570-80. Excluded: Not an eligible intervention or outcome, OVID-Embase. [pmid: 16564854].
346 Hlavaty T, Lukac L, Huorka M, et al. Positive family history promotes participation in colorectal cancer screening. Bratisl Lek Listy. 2005;106(10):318-23. Excluded: Not an eligible population, OVID-Medline. [pmid: 16541612].
347 Ho SM, Ho JW, Chan CL, et al. Decisional consideration of hereditary colon cancer genetic test results among Hong Kong chinese adults. Cancer Epidemiol Biomarkers Prev. 2003;12(5):426-32. Excluded: Not an eligible population, OVID-Medline. [pmid: 12750237].
348 Ho V, Yamal JM, Atkinson EN, et al. Predictors of breast and cervical screening in Vietnamese women in Harris County, Houston, Texas. Cancer Nurs 130;28(2):119–29. Excluded: Family history not systematically collected, OVID-Medline.
349 Hodgson SV, Bishop DT, Dunlop MG, et al. Suggested screening guidelines for familial colorectal cancer. J Med Screen. 1995;2(1):45-51. Excluded: Not an eligible publication type, OVID-Medline. [pmid: 7497146].
350 Hofferbert S, Worringen U, Backe J, et al. Simultaneous interdisciplinary counseling in German breast/ovarian cancer families: first experiences with patient perceptions, surveillance behavior and acceptance of genetic testing. Genet Couns. 2000;11(2):127-46. Excluded: Not an eligible population, OVID-Medline. [pmid: 10893664].
351 Holloway S, Porteous M, Cetnarskyj R, et al. Long-term attendance at follow-up of women assessed as being at increased risk of developing breast cancer in south-east Scotland. Community Genet. 2007;10(4):252-60. Excluded: Not an eligible population, OVID-Medline. [pmid: 17895631].
352 Horsman D, Wilson BJ, Avard D, et al. Clinical management recommendations for surveillance and risk-reduction strategies for hereditary breast and ovarian cancer among individuals carrying a deleterious BRCA1 or BRCA2 mutation. J Obstet Gynaecol Can. 2007;29(1):45-60. Excluded: Model does not categorize risk or validate, OVID-Medline. [pmid: 17346477].
353 Hoskins KF, Zwaagstra A, Ranz M. Validation of a tool for identifying women at high risk for hereditary breast cancer in population-based screening. Cancer. 2006;107(8):1769-76. Excluded: Model does not categorize risk or validate, OVID-Medline. [pmid: 16967460].
354 Houlston RS, Murday V, Harocopos C, et al. Screening and genetic counselling for relatives of patients with colorectal cancer in a family cancer clinic.[erratum appears in BMJ 1990 Sep 1;301(6749):446]. BMJ. 1990;301(6748):366-8. Excluded: Not an eligible study design, OVID-Medline. [pmid: 2169322].
355 Hsia J, Kemper E, Kiefe C, et al. The importance of health insurance as a determinant of cancer screening: evidence from the Women's Health Initiative. Prev Med. 2000;31(3):261-70. Excluded: Family history not systematically collected, OVID-Medline. [pmid: 10964640].
356 Hughes KS, Roche CA, Whitney T, et al. The management of women at high risk of experiencing hereditary breast and ovarian cancer: The lahey guidelines. Disease Management and Health Outcomes. 2000;7(4):201-15. Excluded: Model does not categorize risk or validate, OVID-Embase.
357 Humpel N, Magee C, Jones SC. The impact of a cancer diagnosis on the health behaviors of cancer survivors and their family and friends. Support Care Cancer. 2007;15(6):621-30. Excluded: Family history not systematically collected, OVID-Medline. [pmid: 17205274].
358 Humphrey LL, Helfand M, Chan BK. Review: Mammography reduces breast cancer mortality rates. Evid Based Med. 2003;8(2):45. Excluded: Not an eligible study design, OVID-Embase.
359 Hundt S, Haug U, Brenner H. Blood markers for early detection of colorectal cancer: A systematic review. Cancer Epidemiol Biomarkers Prev. 2007;16(10):1935-53. Excluded: Not an eligible population, OVID-Embase. [pmid: 17932341].
360 Hunter A, Humphries SE. Family history of breast cancer and cost of life assurance: a test case comparison of current UK industry practice. BMJ. 2005;331(7530):1438-9. Excluded: Not an eligible study design, OVID-Medline. [pmid: 16356979].
361 Hurt GJ, McQuellon RP, Michielutte R, et al. Risk assessment of first-degree relatives of women with breast cancer: a feasibility study. Oncol Nurs Forum. 2001;28(7):1097-104. Excluded: Family history not systematically collected, OVID-Medline. [pmid: 11517843].
362 Husaini BA, Sherkat DE, Bragg R, et al. Predictors of breast cancer screening in a panel study of African American women. Women Health. 2001;34(3):35-51. Excluded: Family history not systematically collected, OVID-Embase. [pmid: 11708686].
363 Hyman RB, Baker S, Ephraim R, et al. Health Belief Model variables as predictors of screening mammography utilization. J Behav Med. 1994;17(4):391-406. Excluded: Family history not systematically collected, OVID-Medline. [pmid: 7966260].
364 Iannuzzi-Sucich M, Kenny AM. Preventive medicine for older women: gynecologic screening guidelines. Fam Pract Recertif. 2004;26(6):53-60. Excluded: Not an eligible intervention or outcome, VID-Cinahl.
365 Ingraham BA, Bragdon B, Nohe A. Molecular basis of the potential of vitamin D to prevent cancer. Curr Med Res Opin. 2008;24(1):139-49. Excluded: Not an eligible study design, OVID-Medline. [pmid: 18034918].
366 Irani S, Krevsky B. Colorectal cancer screening: Which tests, how often?. Consultant. 2007;47(2):138-45. Excluded: Not an eligible intervention or outcome, OVID-Embase.
367 Irmejs A, Borosenko V, Melbarde-Gorkusa I, et al. Nationwide study of clinical and molecular features of hereditary non-polyposis colorectal cancer (HNPCC) in Latvia. Anticancer Res. 2007;27(1 B):653-8. Excluded: Not an eligible intervention or outcome, OVID-Embase. [pmid: 17348456].
368 Irwig L, Houssami N, van Vliet C. New technologies in screening for breast cancer: a systematic review of their accuracy. Br J Cancer. 2004;90(11):2118-22. Excluded: Not an eligible intervention or outcome, OVID-Medline. [pmid: 15150556].
369 Isaacs C, Peshkin BN, Schwartz M, et al. Breast and ovarian cancer screening practices in healthy women with a strong family history of breast or ovarian cancer. Breast Cancer Res Treat. 2002;71(2):103-12. Excluded: Not an eligible study design, OVID-Medline. [pmid: 11881908].
370 Italian Review Team 2006. Systematic Literature Review Report. The Associations between Food, Nutrition and Physical Activity and the Risk of Ovarian Cancer and Underlying Mechanisms. World Cancer Research Fund/American Institute for Cancer Research, Food, Nutrition, Physical Activity, and the Prevention of Cancer: a Global Perspective. Washington, DC: AICR, 2007. Excluded: Not an eligible population
371 Ito H, Matsuo K, Wakai K, et al. An intervention study of smoking cessation with feedback on genetic cancer susceptibility in Japan. Prev Med. 2006;42(2):102-8. Excluded: Not an eligible intervention or outcome, OVID-Medline. [pmid: 16325899].
372 Itzkowitz SH, Present DH, Binder V, et al. Consensus conference: Colorectal cancer screening and surveillance in inflammatory bowel disease. Inflamm Bowel Dis. 2005;11(3):314-21. Excluded: Model does not categorize risk or validate, OVID-Embase. [pmid: 15735438].
373 Jacobi CE, Jonker MA, Nagelkerke NJ, et al. Prevalence of family histories of breast cancer in the general population and the incidence of related seeking of health care. J Med Genet. 2003;40(7):e83. Excluded: Family history not systematically collected, OVID-Medline. [pmid: 12843332].
374 Jacobs ET, Jiang R, Alberts DS, et al. Selenium and colorectal adenoma: results of a pooled analysis.[see comment]. J Natl Cancer Inst. 2004;96(22):1669-75. Excluded: Family history not systematically collected, OVID-Medline. [pmid: 15547179].
375 Jacobsen PB, Lamonde LA, Honour M, et al. Relation of family history of prostate cancer to perceived vulnerability and screening behavior. Psychooncology. 2004;13(2):80-5. Excluded: Family history not systematically collected, OVID-Medline. [pmid: 14872526].
376 James GD, Berge-Landry HH, Valdimarsdottir HB, et al. Urinary catecholamine levels in daily life are elevated in women at familial risk of breast cancer. Psychoneuroendocrinology. 2004;29(7):831-8. Excluded: Family history not systematically collected, OVID-Medline. [pmid: 15177698].
377 James TM, Greiner KA, Ellerbeck EF, et al. Disparities in colorectal cancer screening: a guideline-based analysis of adherence. Ethn Dis. 2006;16(1):228-33. Excluded: Family history not systematically collected, OVID-Medline. [pmid: 16599375].
378 Janda M, Obermair A, Haidinger G, et al. Austrian women's attitudes toward and knowledge of breast self-examination. J Cancer Educ. 2000;15(2):91-4. Excluded: Not an eligible study design, VID-Cinahl. [pmid: 10879898].
379 Jasperson KW, Lowstuter K, Weitzel JN. Assessing the predictive accuracy of hMLH1 and hMSH2 mutation probability models. J Genet Couns. 2006;15(5):339-47. Excluded: Model does not categorize risk or validate, OVID-Medline. [pmid: 16969708].
380 Jeffery, M, Hickey, et al. Follow-up strategies for patients treated for non-metastatic colorectal cancer. Cochrane Database Syst Rev 2008;(1): Excluded: Not an eligible intervention or outcome, OVID-Cochrane.
381 Johnson KA, Trimbath JD, Petersen GM, et al. Impact of genetic counseling and testing on colorectal cancer screening behavior. Genet Test. 2002;6(4):303-6. Excluded: Not an eligible population, OVID-Medline. [pmid: 12537654].
382 Johnson PM, Gallinger S, McLeod RS. Surveillance colonoscopy in individuals at risk for hereditary nonpolyposis colorectal cancer: an evidence-based review. Dis Colon Rectum. 1994;49(1):80-93. Excluded: Not an eligible intervention or outcome, OVID-Medline.
383 Joint Test and Technology Transfer Committee Working Group ACoMG. Genetic testing for colon cancer: joint statement of the American College of Medical Genetics and American Society of Human Genetics. Joint Test and Technology Transfer Committee Working Group. Genet Med. 2000;2(6):362-6. Excluded: Model does not categorize risk or validate, OVID-Medline. [pmid: 11339660].
384 Jones JL, Hughes KS, Kopans DB, et al. Evaluation of hereditary risk in a mammography population. Clin Breast Cancer. 2005;6(1):38-44. Excluded: Model does not categorize risk or validate, OVID-Medline. [pmid: 15899071].
385 Jordan SJ, Whiteman DC, Purdie DM, et al. Does smoking increase risk of ovarian cancer? A systematic review. Gynecol Oncol. 2006;103(3):1122-9. Excluded: Not an eligible population, OVID-Medline. [pmid: 17005245].
386 Julian-Reynier C, Sobol H, Sevilla C, et al. Uptake of hereditary breast/ovarian cancer genetic testing in a French national sample of BRCA1 families.The French Cancer Genetic Network. Psychooncology. 2000;9(6):504-10. Excluded: Not an eligible study design, OVID-Medline. [pmid: 11180585].
387 Kadison P, Pelletier EM, Mounib EL, et al. Improved screening for breast cancer associated with a telephone-based risk assessment. Prev Med. 1998;27(3):493-501. Excluded: Not an eligible intervention or outcome, OVID-Embase. [pmid: 9612841].
388 Kamidono S, Ohshima S, Hirao Y, et al. Evidence-based clinical practice guidelines for prostate cancer (summary - JUA 2006 edition). Int J Urol. 2008;15(1):1-18. Excluded: Model does not categorize risk or validate, OVID-Embase. [pmid: 18184166].
389 Kang HH, Williams R, Leary J, et al. Evaluation of models to predict BRCA germline mutations. Br J Cancer. 2006;95(7):914-20. Excluded: Model does not categorize risk or validate, OVID-Medline. [pmid: 17016486].
390 Kanik EA, Canbaz H, Colak T, et al. Chemopreventive effect of nonsteroidal anti-inflammatory drugs on the development of a new colorectal polyp or adenoma in a high-risk population: A meta-analysis. Current Therapeutic Research - Clinical and Experimental. 2004;65(4):345-52. Excluded: Not an eligible intervention or outcome, OVID-Embase.
391 Kaplan KM, Weinberg GB, Small A, et al. Breast cancer screening among relatives of women with breast cancer. Am J Public Health. 1991;81(9):1174-9. Excluded: Family history not systematically collected, OVID-Medline. [pmid: 1951830].
392 Karazanashvili G, Abrahamsson PA. Prostate specific antigen and human glandular kallikrein 2 in early detection of prostate cancer. J Urol. 2003;169(2):445-57. Excluded: Not an eligible study design, OVID-Medline. [pmid: 12544286].
393 Karliner LS, Napoles-Springer A, Kerlikowske K, et al. Missed opportunities: family history and behavioral risk factors in breast cancer risk assessment among a multiethnic group of women. J Gen Intern Med. 2007;22(3):308-14. Excluded: Family history not systematically collected, OVID-Medline. [pmid: 17356960].
394 Kash KM, Holland JC, Halper MS, et al. sychological distress and surveillance behaviors of women with a family history of breast cancer. J Natl Cancer Inst. 1992;84(1):24-30. Excluded: Not an eligible study design, OVID-Medline. [pmid: 1738170].
395 Kash KM, Holland JC, Osborne MP, et al. Psychological counseling strategies for women at risk of breast cancer. J Natl Cancer Inst. 1995;Monographs(17):73-9. Excluded: Not an eligible publication type, OVID-Medline.
396 Kataja VV, Bergh J. ESMO Minimum Clinical Recommendations for diagnosis, treatment and follow-up of prostate cancer. Ann Oncol. 2005;16:Suppl-6. Excluded: Model does not categorize risk or validate, OVID-Medline.
397 Kataja VV, Colleoni M, Bergh J, et al. ESMO Minimum Clinical Recommendations for diagnosis, treatment and follow-up of locally recurrent or metastatic breast cancer (MBC). Ann Oncol. 2005;16:Suppl-2. Excluded: Model does not categorize risk or validate, OVID-Medline.
398 Katapodi MC, Lee KA, Facione NC, et al. Predictors of perceived breast cancer risk and the relation between perceived risk and breast cancer screening: a meta-analytic review. Prev Med. 2004;38(4):388-402. Excluded: Family history not systematically collected, OVID-Medline. [pmid: 15020172].
399 Katki HA. Effect of misreported family history on Mendelian mutation prediction models. Biometrics. 2006;62(2):478-87. Excluded: Model does not categorize risk or validate, OVID-Medline. [pmid: 16918912].
400 Katki HA. Incorporating medical interventions into carrier probability estimation for genetic counseling. BMC Medical Genetics. 2007;8:13. Excluded: Model does not categorize risk or validate, OVID-Medline. [pmid: 17378937].
401 Kaur JS, Roubidoux MA, Sloan J, et al. Can the Gail model be useful in American Indian and Alaska Native populations?. Cancer. 2004;100(5):906-12. Excluded: Model does not categorize risk or validate, OVID-Medline. [pmid: 14983484].
402 Kavanaugh CJ, Trumbo PR, Ellwood KC. The U.S. food and drug administration's evidence-based review for qualified health claims: Tomatoes, lycopene, and cancer. J Natl Cancer Inst. 2007;99(14):1074-85. Excluded: Not an eligible population, OVID-Embase. [pmid: 17623802].
403 Keinan-Boker L, Baron-Epel O, Garty N, et al. Family history of breast cancer and compliance with mammography in Israel: findings of the National Health Survey 2003-2004 (EUROHIS). Eur J Cancer Prev. 2007;16(1):43-9. Excluded: Family history not systematically collected, OVID-Medline. [pmid: 17220703].
404 Keller M, Jost R, Haunstetter CM, et al. Comprehensive genetic counseling for families at risk for HNPCC: impact on distress and perceptions. Genet Test. 2002;6(4):291-302. Excluded: Family history not systematically collected, OVID-Medline. [pmid: 12537653].
405 Kelly K, Leventhal H, Toppmeyer D, et al. Subjective and objective risks of carrying a BRCA1/2 mutation in individuals of Ashkenazi Jewish descent. J Genetic Couns. 2003;12(4):351-71. Excluded: Not an eligible intervention or outcome, OVID-Embase.
406 Kelly K, Leventhal H, Andrykowski M, et al. The decision to test in women receiving genetic counseling for BRCA1 and BRCA2 mutations. J Genetic Couns. 2004;13(3):237-57. Excluded: Family history not systematically collected, OVID-Medline.
407 Kelly,K.M. Subjective and objective risk in individuals testing for BRCA1 and BRCA2 mutations Kelly. 2000 Excluded: Not an eligible publication type, OVID-PsycInfo.
408 Kelly RB, Shank JC. Adherence to screening flexible sigmoidoscopy in asymptomatic patients. Med Care. 1992;30(11):1029-42. Excluded: Family history not systematically collected, OVID-Medline. [pmid: 1434956].
409 Kenen R, Ardern-Jones A, Eeles R. Living with chronic risk: Healthy women with a family history of breast/ovarian cancer. ealth, Risk and Society. 2003;5(3):315-31. Excluded: Not an eligible study design, OVID-Embase.
410 Kerber RA, Neklason DW, Samowitz WS, et al. Frequency of familial colon cancer and hereditary nonpolyposis colorectal cancer (Lynch syndrome) in a large population database. Fam Cancer. 2005;4(3):239-44. Excluded: Model does not categorize risk or validate, OVID-Medline. [pmid: 16136384].
411 Key J, Hodgson S, Omar RZ, et al. Meta-analysis of studies of alcohol and breast cancer with consideration of the methodological issues. Cancer Causes Control. 2006;17(6):759-70. Excluded: Not an eligible population, OVID-Medline. [pmid: 16783604].
412 Key TJ, Spencer EA. Carbohydrates and cancer: an overview of the epidemiological evidence. Eur J Clin Nutr. 2007;61:Suppl-21. Excluded: Not an eligible study design, OVID-Medline.
413 Khan NF, Ward A, Watson E, et al. Long-term survivors of adult cancers and uptake of primary health services: A systematic review. Eur J Cancer. 2008;44(2):195-204. Excluded: Not an eligible intervention or outcome, OVID-Embase. [pmid: 18035534].
414 Khatcheressian JL, Wolff AC, Smith TJ, et al. American Society of Clinical Oncology 2006 update of the breast cancer follow-up and management guidelines in the adjuvant setting. J Clin Oncol. 2006;24(31):5091-7. Excluded: Model does not categorize risk or validate, OVID-Medline. [pmid: 17033037].
415 Kievit W, de Bruin JH, Adang EM, et al. Current clinical selection strategies for identification of hereditary non-polyposis colorectal cancer families are inadequate: a meta-analysis. Clin Genet. 2004;65(4):308-16. Excluded: Not an eligible intervention or outcome, OVID-Medline. [pmid: 15025724].
416 Kim SE, Perez-Stable EJ, Wong S, et al. Association between cancer risk perception and screening behavior among diverse women. Arch Intern Med. 2008;168(7):728-34. Excluded: Family history not systematically collected, OVID-Medline. [pmid: 18413555].
417 Kim Y, Valdimarsdottir HB, Bovbjerg DH. Family histories of breast cancer, coping styles, and psychological adjustment. J Behav Med. 2003;26(3):225-43. Excluded: Family history not systematically collected, OVID-Medline. [pmid: 12845936].
418 Kim Y, Duhamel KN, Valdimarsdottir HB, et al. Psychological distress among healthy women with family histories of breast cancer: effects of recent life events. Psychooncology. 2005;14(7):555-63. Excluded: Family history not systematically collected, OVID-Medline. [pmid: 15543540].
419 Kinney AY, Choi YA, DeVellis B, et al. Interest in genetic testing among first-degree relatives of colorectal cancer patients. Am J Prev Med. 2000;18(3):249-52. Excluded: Family history not systematically collected, OVID-Medline. [pmid: 10722992].
420 Kinney AY, Simonsen SE, Baty BJ, et al. Risk reduction behaviors and provider communication following genetic counseling and BRCA1 mutation testing in an African American kindred. J Genetic Couns. 2006;15(4):293-305. Excluded: Not an eligible population, OVID-Medline.
421 Kinney AY, Hicken B, Simonsen SE, et al. Colorectal cancer surveillance behaviors among members of typical and attenuated FAP families. Am J Gastroenterol. 2007;102(1):153-62. Excluded: Not an eligible study design, OVID-Medline. [pmid: 17266693].
422 Klimberg VS, Galandiuk S, Singletary ES, et al. Society of Surgical Oncology: statement on genetic testing for cancer susceptibilty. Committee on Issues and Governmental Affairs of the Society of Surgical Oncology. Ann Surg Oncol. 1999;6(5):507-9. Excluded: Model does not categorize risk or validate, OVID-Medline. [pmid: 10458691].
423 Ko C, Hyman NH. Standards Committee of The American Society of Colon and Rectal Surgeons. Practice parameter for the detection of colorectal neoplasms: an interim report (revised). Dis Colon Rectum. 2006;49(3):299-301. Excluded: Model does not categorize risk or validate, OVID-Medline. [pmid: 16421663].
424 Kokuer M, Naguib RN, Jancovic P, et al. Cancer risk analysis in families with hereditary nonpolyposis colorectal cancer. IEEE Trans Inf Technol Biomed. 2006;10(3):581-7. Excluded: Model does not categorize risk or validate, OVID-Medline. [pmid: 16871728].
425 Koo BC, Ng CS, King-Im J, et al. Minimal preparation CT for the diagnosis of suspected colorectal cancer in the frail and elderly patient. Clin Radiol. 2006;61(2):127-39. Excluded: Not an eligible population, OVID-Embase. [pmid: 16439217].
426 Koushik A, Hunter DJ, Spiegelman D, et al. Fruits, vegetables, and colon cancer risk in a pooled analysis of 14 cohort studies. J Natl Cancer Inst. 2007;99(19):1471-83. Excluded: Not an eligible population, OVID-Medline. [pmid: 17895473].
427 Kubik-Huch RA. Imaging the young breast. Breast. 2006;15(Suppl 2):S35-S40. Excluded: Model does not categorize risk or validate, OVID-Embase. [pmid: 17382861].
428 Kubo A, Corley DA. Meta-analysis of antioxidant intake and the risk of esophageal and gastric cardia adenocarcinoma. Am J Gastroenterol. 2007;102(10):2323-30. Excluded: Not an eligible intervention or outcome, OVID-Embase. [pmid: 17581269].
429 Kuhl CK. Screening of women with hereditary risk of breast cancer. Clin Breast Cancer. 2004;5(4):269-71. Excluded: Not an eligible intervention or outcome, OVID-Cinahl.
430 Kumar AS, Esserman LJ. Statins: Health-promoting agents show promise for breast cancer prevention. Clin Breast Cancer. 2005;6(5):455-9. Excluded: Not an eligible study design, OVID-Embase. [pmid: 16381630].
431 Kuschel B, Hauenstein E, Kiechle M, et al. Hereditary breast and ovarian cancer - Current clinical guidelines in Germany. Breast Care. 2006;1(1):8-14. Excluded: Model does not categorize risk or validate, OVID-Embase.
432 Lagerros YT, Hsieh SF, Hsieh CC. Physical activity in adolescence and young adulthood and breast cancer risk: A quantitative review. Eur J Cancer Prev. 2004;13(1):5-12. Excluded: Not an eligible intervention or outcome, OVID-Embase. [pmid: 15075782].
433 Lancaster DR. Development and psychometric testing of the coping with breast cancer threat instrument. J Nurs Meas. 2004;12(1):33-46. Excluded: Family history not systematically collected, OVID-Medline. [pmid: 15916318].
434 Lancaster,D.R.N. Coping with appraised threat of breast cancer: primary prevention coping behaviors utilized by women at increased risk. Excluded: Not an eligible publication type, OVID-Cinahl.
435 Lancaster JM, Powell CB, Kauff ND, et al. Society of Gynecologic Oncologists Education Committee statement on risk assessment for inherited gynecologic cancer predispositions. Gynecol Oncol. 2007;107(2):159-62. Excluded: Model does not categorize risk or validate, OVID-Medline. [pmid: 17950381].
436 Lane DS, Zapka J, Breen N, et al. A systems model of clinical preventive care: the case of breast cancer screening among older women. For the NCI Breast Cancer Screening Consortium. Prev Med. 2000;31(5):481-93. Excluded: Family history not systematically collected, OVID-Medline. [pmid: 11071828].
437 Larsson SC, Wolk A. Meat consumption and risk of colorectal cancer: a meta-analysis of prospective studies. Int J Cancer. 2006;119(11):2657-64. Excluded: Not an eligible population, OVID-Medline. [pmid: 16991129].
438 Larsson SC, Giovannucci E, Wolk A. Folate and risk of breast cancer: a meta-analysis. J Natl Cancer Inst. 2007;99(1):64-76. Excluded: Not an eligible population, OVID-Medline. [pmid: 17202114].
439 Lauver D, Nabholz S, Scott K, et al. Testing theoretical explanations of mammography use. Nurs Res. 1997;46(1):32-9. Excluded: Family history not systematically collected, OVID-Medline. [pmid: 9024422].
440 Lawlor DA, Juni P, Ebrahim S, et al. Systematic review of the epidemiologic and trial evidence of an association between antidepressant medication and breast cancer. J Clin Epidemiol. 2003;56(2):155-63. Excluded: Not an eligible population, OVID-Embase. [pmid: 12654410].
441 Leddin D, Hunt R, Champion M, et al. Canadian Association of Gastroenterology and the Canadian Digestive Health Foundation: Guidelines on colon cancer screening. Can J Gastroenterol. 2004;18(2):93-9. Excluded: Model does not categorize risk or validate, OVID-Medline. [pmid: 14997217].
442 Lee-Lin F, Menon U, Pett M, et al. Breast cancer beliefs and mammography screening practices among Chinese American immigrants. J Obstet Gynecol Neonatal Nurs. 2007;36(3):212-21. Excluded: Family history not systematically collected, OVID-Cinahl.
443 Lee-Lin,F.F. Mammography and Pap testing screening among first generation Chinese Americans DIssertation Abstract. 2006 Excluded: Not an eligible publication type, OVID-Cinahl.
444 Lee EO, Ahn SH, You C, et al. Determining the main risk factors and high-risk groups of breast cancer using a predictive model for breast cancer risk assessment in South Korea. Cancer Nurs. 2004;27(5):400-6. Excluded: Model does not categorize risk or validate, OVID-Medline. [pmid: 15525868].
445 Lee JR, Vogel VG. Who uses screening mammography regularly?. Cancer Epidemiol Biomarkers Prev. 1995;4(8):901-6. Excluded: Family history not systematically collected, OVID-Medline. [pmid: 8634664].
446 Lee R, Localio AR, Armstrong K, et al. A meta-analysis of the performance characteristics of the free prostate-specific antigen test. Urology. 2006;67(4):762-8. Excluded: Not an eligible population, OVID-Medline. [pmid: 16600352].
447 Lee SC, Bernhardt BA, Helzlsouer KJ. Utilization of BRCA1/2 genetic testing in the clinical setting: report from a single institution. Cancer. 2002;94(6):1876-85. Excluded: Not an eligible population, OVID-Medline. [pmid: 11920551].
448 Legg JS. Genetic testing for inheritable cancers. Radiat Therapist. 2004;13(2):99-105. Excluded: Family history not systematically collected, OVID-Cinahl.
449 Leggatt V, Mackay J, Yates JR. Evaluation of questionnaire on cancer family history in identifying patients at increased genetic risk in general practice. BMJ. 1999;319(7212):757-8. Excluded: Family history not systematically collected, OVID-Medline. [pmid: 10488003].
450 Lemon S, Zapka J, Puleo E, et al. Colorectal cancer screening participation: comparisons with mammography and prostate-specific antigen screening. Am J Public Health. 2001;91(8):1264-72. Excluded: Family history not systematically collected, OVID-Medline. [pmid: 11499116].
451 Lemon SC, Zapka JG, Clemow L. Health behavior change among women with recent familial diagnosis of breast cancer. Prev Med. 2004;39(2):253-62. Excluded: Family history not systematically collected, OVID-Medline. [pmid: 15226033].
452 Lerman C, Rimer B, Trock B, et al. Factors associated with repeat adherence to breast cancer screening. Prev Med. 1990;19(3):279-90. Excluded: Family history not systematically collected, OVID-Medline. [pmid: 2377590].
453 Lerman C, Daly M, Sands C, et al. Mammography adherence and psychological distress among women at risk for breast cancer. Natl Cancer Inst. 1993;85(13):1074-80. Excluded: Family history not systematically collected, OVID-Medline.
454 Lerman C, Kash K, Stefanek M. Younger women at increased risk for breast cancer: perceived risk, psychological well-being, and surveillance behavior. J Natl Cancer Inst. 1994;Monographs(16):171-6. Excluded: Not an eligible publication type, OVID-Medline.
455 Lerman C, Narod S, Schulman K, et al. BRCA1 testing in families with hereditary breast-ovarian cancer. A prospective study of patient decision making and outcomes. JAMA. 1996;275(24):1885-92. Excluded: Family history not systematically collected, OVID-Medline. [pmid: 8648868].
456 Lerman C, Schwartz MD, Miller SM, et al. A randomized trial of breast cancer risk counseling: interacting effects of counseling, educational level, and coping style. Health Psychol. 1996;15(2):75-83. Excluded: Not an eligible population, OVID-Medline. [pmid: 8681923].
457 Lerman C, Schwartz MD, Lin TH, et al. The influence of psychological distress on use of genetic testing for cancer risk. J Consult Clin Psychol. 1997;65(3):414-20. Excluded: Not an eligible population, OVID-Medline. [pmid: 9170764].
458 Lerman C, Hughes C, Trock BJ, et al. Genetic testing in families with hereditary nonpolyposis colon cancer. JAMA. 1999;281(17):1618-22. Excluded: Not an eligible study design, OVID-Medline. [pmid: 10235155].
459 Lerman C, Hughes C, Croyle RT, et al. Prophylactic surgery decisions and surveillance practices one year following BRCA1/2 testing. Prev Med. 2000;31(1):75-80. Excluded: Not an eligible population, OVID-Medline. [pmid: 10896846].
460 Lesniak,K.T. Psychological and sociodemographic predictors of psychological distress in BRCA1 and BRAC2 genetic testing participants within a community based genetic screening program Lesniak. 2001 Excluded: Not an eligible publication type, OVID-PsycInfo.
461 Levin B, Barthel JS, Burt RW, et al. Colorectal Cancer Screening Clinical Practice Guidelines. J Natl Compr Cancer Netw. 2006;4(4):384-420. Excluded: Not an eligible intervention or outcome, OVID-Medline.
462 Levin B, Lieberman DA, McFarland B, et al. Screening and surveillance for the early detection of colorectal cancer and adenomatous polyps, 2008: a joint guideline from the American Cancer Society, the US Multi-Society Task Force on Colorectal Cancer, and the American College of Radiology. Gastroenterology. 2008;134(5):1570-95. Excluded: Model does not categorize risk or validate, OVID-Medline. [pmid: 18384785].
463 Levin TR, Farraye FA, Schoen RE, et al. Quality in the technical performance of screening flexible sigmoidoscopy: Recommendations of an international multi-society task group. Gut. 2005;54(6):807-13. Excluded: Not an eligible intervention or outcome, OVID-Embase. [pmid: 15888789].
464 Levine M, Moutquin JM, Walton R, et al. Chemoprevention of breast cancer. A joint guideline from the Canadian Task Force on Preventive Health Care and the Canadian Breast Cancer Initiative's Steering Committee on Clinical Practice Guidelines for the Care and Treatment of Breast Cancer. CMAJ. 2001;164(12):1681-90. Excluded: Model does not categorize risk or validate, VID-Medline. [pmid: 11450210].
465 Levy BT, Dawson J, Hartz AJ, et al. Colorectal cancer testing among patients cared for by Iowa family physicians. Am J Prev Med. 2006;31(3):193-201. Excluded: Not an eligible study design, OVID-Medline. [pmid: 16905029].
466 Lewis JD, Ng K, Hung KE, et al. Detection of proximal adenomatous polyps with screening sigmoidoscopy: a systematic review and meta-analysis of screening colonoscopy. Arch Intern Med. 2003;163(4):413-20. Excluded: Not an eligible intervention or outcome, OVID-Medline. [pmid: 12588199].
467 Lewis SJ, Harbord RM, Harris R, et al. Meta-analyses of observational and genetic association studies of folate intakes or levels and breast cancer risk. J Natl Cancer Inst. 2006;98(22):1607-22. Excluded: Not an eligible population, OVID-Medline. [pmid: 17105984].
468 Liberman M, Sampalis F, Mulder DS, et al. Breast cancer diagnosis by scintimammography: a meta-analysis and review of the literature. Breast Cancer Res Treat. 2003;80(1):115-26. Excluded: Not an eligible population, OVID-Medline. [pmid: 12889605].
469 Liede A, Metcalfe K, Hanna D, et al. Evaluation of the needs of male carriers of mutations in BRCA1 or BRCA2 who have undergone genetic counseling. Am J Hum Genet. 2000;67(6):1494-504. Excluded: Not an eligible population, OVID-Medline. [pmid: 11063672].
470 Lim J, Macluran M, Price M, et al. Short- and long-term impact of receiving genetic mutation results in women at increased risk for hereditary breast cancer. J Genet Couns. 2004;13(2):115-33. Excluded: Family history not systematically collected, OVID-Medline. [pmid: 15612172].
471 Lin, O, Roy, et al. Screening sigmoidoscopy and colonoscopy for reducing colorectal cancer mortality in asymtomatic persons. Cochrane Database Syst Rev 2008;(1): Excluded: Not an eligible study design, OVID-Cochrane.
472 Lin CJ, Block B, Nowalk MP, et al. Breast cancer risk assessment in socioeconomically disadvantaged urban communities. J Natl Med Assoc. 2007;99(7):752-6. Excluded: Model does not categorize risk or validate, OVID-Medline. [pmid: 17668640].
473 Lin OS. Clinical update: postpolypectomy colonoscopy surveillance. Lancet. 2007;370(9600):1674-6. Excluded: Model does not categorize risk or validate, OVID-Embase. [pmid: 18022025].
474 Lindberg NM, Wellisch D. Anxiety and compliance among women at high risk for breast cancer. Ann Behav Med. 2001;23(4):298-303. Excluded: Not an eligible study design, OVID-Medline. [pmid: 11761347].
475 Lindberg NM, Wellisch DK. Identification of traumatic stress reactions in women at increased risk for breast cancer. Psychosomatics. 2004;45(1):7-16. Excluded: Not an eligible study design, OVID-Medline. [pmid: 14709756].
476 Lindor NM, Petersen GM, Hadley DW, et al. Recommendations for the care of individuals with an inherited predisposition to Lynch syndrome: a systematic review. JAMA. 2006;296(12):1507-17. Excluded: Not an eligible intervention or outcome, OVID-Medline. [pmid: 17003399].
477 Lippert MT, Eaker ED, Vierkant RA, et al. Breast cancer screening and family history among rural women in Wisconsin. Cancer Detect Prev. 1999;23(3):265-72. Excluded: Family history not systematically collected, OVID-Medline. [pmid: 10337006].
478 Lipton LR, Johnson V, Cummings C, et al. Refining the Amsterdam Criteria and Bethesda Guidelines: testing algorithms for the prediction of mismatch repair mutation status in the familial cancer clinic.[erratum appears in J Clin Oncol. 2005 May 20;23(15):3652]. J Clin Oncol. 2004;22(24):4934-43. Excluded: Not an eligible intervention or outcome, OVID-Medline. [pmid: 15611508].
479 Lise M, Zavagno G, Meggiolaro F. Prophylactic mastectomy in women at high risk of breast cancer. FORUM - Trends in Experimental and Clinical Medicine. 1997;7(1 Suppl. 2):112-6. Excluded: Not an eligible study design, OVID-Embase.
480 Little MP, Muirhead CR, Charles MW. Describing time and age variations in the risk of radiation-induced solid tumour incidence in the Japanese atomic bomb survivors using generalized relative and absolute risk models. Stat Med. 1999;18(1):17-33. Excluded: Not an eligible intervention or outcome, OVID-Medline. [pmid: 9990690].
481 Liu M, Guo YM, Guo XJ, et al. Evaluation of scintimammorgraphy in the diagnosis of primary breast cancer: A meta-analysis. Chinese Journal of Evidence-Based Medicine. 2005;5(7):536-42. Excluded: Not an eligible intervention or outcome, OVID-Embase.
482 Liu X, Sennett C, Legorreta AP. Mammography utilization among California women age 40–49 in a managed care environment. Breast Cancer Res Treat. 2001;67(2):181-6. Excluded: Family history not systematically collected, OVID-Medline. [pmid: 11519867].
483 Loader S, Shields C, Rowley PT. Impact of genetic counseling and DNA testing on individuals with colorectal cancer with a positive family history: a population-based study. Genet Test. 2005;9(4):313-9. Excluded: Not an eligible population, OVID-Medline. [pmid: 16379545].
484 Locker GY, Hamilton S, Harris J, et al. ASCO 2006 update of recommendations for the use of tumor markers in gastrointestinal cancer. J Clin Oncol. 2006;24(33):5313-27. Excluded: Not an eligible intervention or outcome, OVID-Medline. [pmid: 17060676].
485 Lodder L, Frets PG, Trijsburg RW, et al. Attitudes and distress levels in women at risk to carry a BRCA1/BRCA2 gene mutation who decline genetic testing. Am J Med Genet 2003;(Part 3):266–72. Excluded: Not an eligible study design, OVID-Medline.
486 Loescher LJ. Cancer worry in women with hereditary risk factors for breast cancer. Oncol Nurs Forum. 2003;Online(5):767-72. Excluded: Family history not systematically collected, OVID-Medline.
487 Loescher LJ, Lim K, Leitner O, et al. Risk control behaviors following BRCA genetic predisposition testing. Oncol Nurs Forum. 2007;34(1):226. Excluded: Not an eligible publication type, OVID-Cinahl.
488 Longacre AV, Cramer LD, Gross CP. Screening colonoscopy use among individuals at higher colorectal cancer risk. J Clin Gastroenterol. 2006;40(6):490-6. Excluded: Family history not systematically collected, OVID-Medline. [pmid: 16825930].
489 Lopez ML, Iglesias JM, del Valle MO, et al. Impact of a primary care intervention on smoking, drinking, diet, weight, sun exposure, and work risk in families with cancer experience. Cancer Causes Control. 2007;18(5):525-35. Excluded: Family history not systematically collected, OVID-Medline. [pmid: 17450417].
490 Lord SJ, Lei W, Craft P, et al. A systematic review of the effectiveness of magnetic resonance imaging (MRI) as an addition to mammography and ultrasound in screening young women at high risk of breast cancer. Eur J Cancer. 2007;43(13):1905-17. Excluded: Family history not systematically collected, OVID-Medline. [pmid: 17681781].
491 Lostumbo L, Carbine N, Wallace J, et al. Prophylactic mastectomy for the prevention of breast cancer. Cochrane Database Syst Rev 2004;(4):CD002748 Excluded: Not an eligible intervention or outcome, OVID-Medline.
492 Love RR, Brown RL, Davis JE, et al. Frequency and determinants of screening for breast cancer in primary care group practice. Arch Intern Med. 1993;153(18):2113-7. Excluded: Family history not systematically collected, OVID-Embase. [pmid: 8379802].
493 Lubish L, Greenberg S, Friger M, et al. Breast cancer screening in two multicultural family practice teaching clinics. Isr Med Assoc J. 2001;3(8):579-83. Excluded: Family history not systematically collected, OVID-Medline. [pmid: 11519382].
494 Lunet N, Valbuena C, Vieira AL, et al. Fruit and vegetable consumption and gastric cancer by location and histological type: Case-control and meta-analysis. Eur J Cancer Prev. 2007;16(4):312-27. Excluded: Not an eligible intervention or outcome, OVID-Embase. [pmid: 17554204].
495 Lux MP, Ackermann S, Bani MR, et al. Age of uptake of early cancer detection facilities by low-risk and high-risk patients with familial breast and ovarian cancer. Eur J Cancer Prev. 2005;14(6):503-11. Excluded: Not an eligible study design, OVID-Medline. [pmid: 16284494].
496 Lux MP, Ackermann S, Nestle-Kramling C, et al. Use of intensified early cancer detection in high-risk patients with familial breast and ovarian cancer. Eur J Cancer Prev. 2005;14(4):399-411. Excluded: Not an eligible population, OVID-Medline. [pmid: 16030432].
497 Lynch HT, Snyder C, Lynch JF, et al. Patient responses to the disclosure of BRCA mutation tests in hereditary breast-ovarian cancer families. Cancer Genet Cytogenet. 2006;165(2):91-7. Excluded: Not an eligible population, OVID-Medline. [pmid: 16527602].
498 MacDonald DJ, Sarna L, Uman GC, et al. Cancer screening and risk-reducing behaviors of women seeking genetic cancer risk assessment for breast and ovarian cancers. Oncol Nurs Forum. 2006;Online(2):E27-E35. Excluded: Not an eligible population, OVID-Medline.
499 MacInnis RJ, English DR. Body size and composition and prostate cancer risk: systematic review and meta-regression analysis. Cancer Causes Control. 2006;17(8):989-1003. Excluded: Not an eligible population, OVID-Medline. [pmid: 16933050].
500 Maciosek MV, Coffield AB, Edwards NM, et al. Priorities among effective clinical preventive services: results of a systematic review and analysis. Am J Prev Med. 2006;31(1):52-61. Excluded: Family history not systematically collected, OVID-Medline. [pmid: 16777543].
501 MacKarem G, Roche CA, Hughes KS. The effectiveness of the Gail model in estimating risk for development of breast cancer in women under 40 years of age. Breast J. 2001;7(1):34-9. Excluded: Model does not categorize risk or validate, OVID-Medline. [pmid: 11348413].
502 MacLean CH, Newberry SJ, Mojica WA, et al. Effects of omega-3 fatty acids on cancer risk: a systematic review. 2006 Apr 26;295(16):1900]. JAMA. 2006;295(4):403-15. Excluded: Not an eligible population, OVID-Medline. [pmid: 16434631].
503 Madalinska JB, Van Beurden M, Bleiker EM, et al. Predictors of prophylactic bilateral salpingo-oophorectomy compared with gynecologic screening use in BRCA1/2 mutation carriers. J Clin Oncol. 2007;25(3):301-7. Excluded: Not an eligible population, OVID-Cinahl. [pmid: 17235045].
504 Madlensky L. Screening behaviors in relatives of Ontario colorectal cancer patients: a social-ecological approach. Excluded: Not an eligible publication type, OVID-Cinahl.
505 Madlensky L, Esplen MJ, Gallinger S, et al. Relatives of colorectal cancer patients: factors associated with screening behavior. Am J Prev Med. 2003;25(3):187-94. Excluded: Family history not systematically collected, OVID-Medline. [pmid: 14507524].
506 Madlensky L, Flatt SW, Bardwell WA, et al. Is family history related to preventive health behaviors and medical management in breast cancer patients?. Breast Cancer Res Treat. 2005;90(1):47-54. Excluded: Family history not systematically collected, OVID-Medline. [pmid: 15770526].
507 Madlensky L, Vierkant RA, Vachon CM, et al. Preventive health behaviors and familial breast cancer. Cancer Epidemiol Biomarkers Prev. 2005;14(10):2340-5. Excluded: Family history not systematically collected, OVID-Medline. [pmid: 16214914].
508 Mahon SM, Casperson DS. Hereditary cancer syndrome: Part 2.—Psychosocial issues, concerns, and screening—results of a qualitative study. Oncol Nurs Forum. 1995;22(5):775-82. Excluded: Not an eligible study design, OVID-Medline. [pmid: 7675684].
509 Mahon SM. From research to clinical practice. Evidence-based practice: recommendations for the early detection of breast cancer. Clin J Oncol Nurs. 2003;7(6):693-6. Excluded: Model does not categorize risk or validate, OVID-Cinahl. [pmid: 14705491].
510 Mangiapane S, Blettner M, Schlattmann P. Aspirin use and breast cancer risk: A meta-analysis and meta-regression of observational studies from 2001 to 2005. Pharmacoepidemiol Drug Saf. 2008;17(2):115-24. Excluded: Not an eligible population, OVID-Embase. [pmid: 17955496].
511 Manheimer,J. Medical risk, perceived risk, and body anxiety in women attending a high-risk breast surveillance clinic Manheimer. 1993 Excluded: Not an eligible publication type, OVID-PsycInfo.
512 Mann GJ, Thorne H, Balleine RL, et al. Analysis of cancer risk and BRCA1 and BRCA2 mutation prevalence in the kConFab familial breast cancer resource. Breast Cancer Res. 2006;8(1):R12. Excluded: Model does not categorize risk or validate, OVID-Medline. [pmid: 16507150].
513 Marques-Vidal P, Ravasco P, Ermelinda CM. Foodstuffs and colorectal cancer risk: a review. [Review] [66 refs]. Clin Nutr. 2006;25(1):14-36. Excluded: Not an eligible population, OVID-Medline. [pmid: 16290272].
514 Marroni F, Aretini P, D'Andrea E, et al. Penetrances of breast and ovarian cancer in a large series of families tested for BRCA1/2 mutations. Eur J Hum Genet. 2004;12(11):899-906. Excluded: Model does not categorize risk or validate, OVID-Medline. [pmid: 15340362].
515 Marroni F, Aretini P, D'Andrea E, et al. Evaluation of widely used models for predicting BRCA1 and BRCA2 mutations. J Med Genet. 2004;41(4):278-85. Excluded: Model does not categorize risk or validate, OVID-Medline. [pmid: 15060102].
516 Marteau TM, Lerman C. Genetic risk and behavioural change. BMJ. 2001;322(7293):1056-9. Excluded: Not an eligible study design, OVID-Embase. [pmid: 11325776].
517 Martin RM, Middleton N, Gunnell D, et al. Breast-feeding and cancer: The Boyd Orr cohort and a systematic review with meta-analysis. J Natl Cancer Inst. 2005;97(19):1446-57. Excluded: Not an eligible intervention or outcome, OVID-Embase. [pmid: 16204694].
518 Martin W, Degner L. Perception of risk and surveillance practices of women with a family history of breast cancer. Cancer Nurs. 2006;29(3):227-35. Excluded: Family history not systematically collected, OVID-Medline. [pmid: 16783123].
519 Masi CM, Blackman DJ, Peek ME. Interventions to enhance breast cancer screening, diagnosis, and treatment among racial and ethnic minority women. Med Care Res Rev. 2007;64(5:Suppl):Suppl-242S. Excluded: Not an eligible intervention or outcome, OVID-Medline.
520 Matthews BA, Nattinger AB, Venkatesan T, et al. Objective risk, subjective risk, and colorectal cancer screening among a clinic sample. Psychol Health Med. 2007;12(2):135-47. Excluded: Family history not systematically collected, OVID-Medline. [pmid: 17365894].
521 Mayo MS, Kimler BF, Fabian CJ. Evaluation of models for the prediction of breast cancer development in women at high risk. J Appl Res. 2001;1(1):37-44. Excluded: Model does not categorize risk or validate, OVID-Cinahl.
522 McCarthy BD, Moskowitz MA. Screening flexible sigmoidoscopy: Patient attitudes and compliance. J Gen Intern Med. 1993;8(3):120-5. Excluded: Family history not systematically collected, OVID-Embase. [pmid: 8455106].
523 McCaul KD, Branstetter AD, O'Donnell SM, et al. A descriptive study of breast cancer worry. J Behav Med. 1998;21(6):565-79. Excluded: Family history not systematically collected, OVID-Medline. [pmid: 9891255].
524 McCormack VA, SS I dos. Breast density and parenchymal patterns as markers of breast cancer risk: a meta-analysis. Cancer Epidemiol Biomarkers Prev. 2006;15(6):1159-69. Excluded: Not an eligible intervention or outcome, OVID-Medline. [pmid: 16775176].
525 McCullum M. Hereditary cancer risk assessment. Can Oncol Nurs J. 1997;7(4):236-7. Excluded: Not an eligible study design, OVID-Medline. [pmid: 9450422].
526 McDonald L. Soy food and soy supplements may not do the same thing in terms of breast cancer risk reduction. Cancer Biol Ther. 2006;5(5):458-9. Excluded: Not an eligible study design, OVID-Embase.
527 McInerney-Leo A, Hadley D, Kase RG, et al. BRCA1/2 testing in hereditary breast and ovarian cancer families III: risk perception and screening. Am J Med Genet 2006;(20):2198–206. Excluded: Not an eligible population, OVID-Medline.
528 McKinley JM, Weideman PC, Jenkins MA, et al. Prostate screening uptake in Australian BRCA1 and BRCA2 carriers. Hereditary Cancer in Clinical Practice. 2007;5(3):161-3. Excluded: Not an eligible population, OVID-Embase. [pmid: 19725993].
529 McKinnon W, Naud S, Ashikaga T, et al. Results of an intervention for individuals and families with BRCA mutations: a model for providing medical updates and psychosocial support following genetic testing. J Genetic Couns. 2007;16(4):433-56. Excluded: Not an eligible population, OVID-Medline.
530 McMurrick P, Dorien S, Shapiro J. Bowel cancer - guide for the GP. Aust Fam Physician. 2006;35(4):192-7. Excluded: Model does not categorize risk or validate, OVID-Cinahl. [pmid: 16642233].
531 McTiernan A, Kuniyuki A, Yasui Y, et al. Comparisons of two breast cancer risk estimates in women with a family history of breast cancer. Cancer Epidemiol Biomarkers Prev. 2001;10(4):333-8. Excluded: Model does not categorize risk or validate, OVID-Medline. [pmid: 11319173].
532 Meijers-Heijboer H, Brekelmans CT, Menke-Pluymers M, et al. Use of genetic testing and prophylactic mastectomy and oophorectomy in women with breast or ovarian cancer from families with a BRCA1 or BRCA2 mutation. J Clin Oncol. 2003;21(9):1675-81. Excluded: Not an eligible population, OVID-Medline. [pmid: 12721241].
533 Meiser B, Butow P, Barratt A, et al. Attitudes toward prophylactic oophorectomy and screening utilization in women at increased risk of developing hereditary breast/ovarian cancer. Gynecol Oncol. 1999;75(1):122-9. Excluded: Family history not systematically collected, OVID-Medline. [pmid: 10502438].
534 Meiser B, Butow P, Barratt A, et al. Breast cancer screening uptake in women at increased risk of developing hereditary breast cancer. Breast Cancer Res Treat. 2000;59(2):101-11. Excluded: Not an eligible study design, OVID-Medline. [pmid: 10817345].
535 Meiser B, Butow P, Schnieden V, et al. Psychological adjustment of women at increased risk of developing hereditary breast cancer. Psychol Health Med. 2000;5(4):377-88. Excluded: Family history not systematically collected, OVID-Embase.
536 Meiser B, Halliday JL. What is the impact of genetic counselling in women at increased risk of developing hereditary breast cancer? A meta-analytic review. Soc Sci Med. 2002;54(10):1463-70. Excluded: Not an eligible intervention or outcome, OVID-Medline. [pmid: 12061481].
537 Meiser B, Butow P, Price M, et al. Attitudes to prophylactic surgery and chemoprevention in Australian women at increased risk for breast cancer. J Womens Health (Larchmt). 2003;12(8):769-78. Excluded: Not an eligible study design, OVID-Medline. [pmid: 14588127].
538 Meiser B, Cowan R, Costello A, et al. Prostate cancer screening in men with a family history of prostate cancer: the role of partners in influencing men's screening uptake. Urology. 2007;70(4):738-42. Excluded: Not an eligible study design, OVID-Medline. [pmid: 17991547].
539 Meiser B, Butow P, Schnieden V, et al. Psychological adjustment of women at increased risk of developing hereditary breast cancer. Psychol Health Med. 2000;5(4):377-88. Excluded: Not an eligible population, OVID-PsycInfo.
540 Menon U, Skates SJ, Lewis S, et al. Prevalence screening for ovarian cancer using risk of ovarian cancer algorithm. Int J Gynecol Cancer. 2003;13(suppl 1):1. Excluded: Not an eligible intervention or outcome, OVID-Cochrane.
541 Menon U, Skates SJ, Lewis S, et al. Prospective study using the risk of ovarian cancer algorithm to screen for ovarian cancer. J Clin Oncol. 2005;23(31):7919-26. Excluded: Not an eligible intervention or outcome, OVID-Cochrane. [pmid: 16258091].
542 Mertens WC, Katz D, Quinlan M, et al. Effect of oncologist-based counseling on patient-perceived breast cancer risk and psychological distress. Community Oncology. 2008;5(2):108-14. Excluded: Not an eligible population, OVID-Embase.
543 Metcalfe KA, Foulkes WD, Kim-Sing C, et al. Family history as a predictor of uptake of cancer preventive procedures by women with a BRCA1 or BRCA2 mutation. Clin Genet. 2008;73(5):474-9. Excluded: Family history not systematically collected, OVID-Embase. [pmid: 18341607].
544 Metcalfe KA, Birenbaum-Carmeli D, Lubinski J, et al. International variation in rates of uptake of preventive options in BRCA1 and BRCA2 mutation carriers. Int J Cancer. 2008;122(9):2017-22. Excluded: Family history not systematically collected, OVID-Medline. [pmid: 18196574].
545 Miller D, Livingstone V, Herbison P. Interventions for relieving the pain and discomfort of screening mammography. Cochrane Database Syst Rev 2008;(1):CD002942 Excluded: Not an eligible intervention or outcome, OVID-Medline.
546 Mistry K, Cable G. Meta-analysis of prostate-specific antigen and digital rectal examination as screening tests for prostate carcinoma. J Am Board Fam Pract. 2003;16(2):95-101. Excluded: Not an eligible population, OVID-Medline. [pmid: 12665174].
547 Mizoue T, Tanaka K, Tsuji I, et al. Alcohol drinking and colorectal cancer risk: an evaluation based on a systematic review of epidemiologic evidence among the Japanese population. Jpn J Clin Oncol. 2006;36(9):582-97. Excluded: Not an eligible population, OVID-Medline. [pmid: 16870695].
548 Modan B, Hartge P, Hirsh-Yechezkel G, et al. Parity, oral contraceptives, and the risk of ovarian cancer among carriers and noncarriers of a BRCA1 or BRCA2 mutation. N Engl J Med. 2001;345(4):235-40. PM:11474660 Excluded: Not an eligible study design. [pmid: 11474660].
549 Moghaddam AA, Woodward M, Huxley R. Obesity and risk of colorectal cancer: a meta-analysis of 31 studies with 70,000 events. Cancer Epidemiol Biomarkers Prev. 2007;16(12):2533-47. Excluded: Not an eligible population, OVID-Medline. [pmid: 18086756].
550 Moja L, Moschetti I, Liberati A, et al. Understanding systematic reviews: the meta-analysis graph (also called ‘forest plot’). Intern Emerg Med. 2007;2(2):140-2. Excluded: Not an eligible study design, OVID-Medline. [pmid: 17634820].
551 Moller P, Evans G, Haites N, et al. Guidelines for follow-up of women at high risk for inherited breast cancer: consensus statement from the Biomed 2 Demonstration Programme on Inherited Breast Cancer. Dis Markers. 1999;15(13):207-11. Excluded: Model does not categorize risk or validate, OVID-Medline. [pmid: 10595280].
552 Moller P, Evans DG, Haites NE, et al. Women at risk for inherited breast or ovarian cancer: Guidelines for follow-up. CME Journal of Gynecologic Oncology. 2000;5(3):269-71. Excluded: Model does not categorize risk or validate, OVID-Embase.
553 Monninkhof EM, Elias SG, Vlems FA, et al. Physical activity and breast cancer: a systematic review. Epidemiology. 2007;18(1):137-57. Excluded: Not an eligible population, OVID-Medline. [pmid: 17130685].
554 Montgomery DA, Krupa K, Cooke TG. Follow-up in breast cancer: does routine clinical examination improve outcome? A systematic review of the literature. Br J Cancer. 2007;97(12):1632-41. Excluded: Not an eligible intervention or outcome, OVID-Medline. [pmid: 18000508].
555 Morantz C. American Cancer Society. ACS guidelines for early detection of cancer. Am Fam Physician. 2004;69(8):2013. Excluded: Model does not categorize risk or validate, OVID-Medline. [pmid: 15117023].
556 Morris KT, Johnson N, Krasikov N, et al. Genetic counseling impacts decision for prophylactic surgery for patients perceived to be at high risk for breast cancer. Am J Surg. 2001;181(5):431-3. Excluded: Not an eligible population, OVID-Medline. [pmid: 11448436].
557 Moskal A, Norat T, Ferrari P, et al. Alcohol intake and colorectal cancer risk: a dose-response meta-analysis of published cohort studies. Int J Cancer. 2007;120(3):664-71. Excluded: Not an eligible population, OVID-Medline. [pmid: 17096321].
558 Moss S. Overdiagnosis in randomised controlled trials of breast cancer screening. Breast Cancer Res. 2005;7(5):230-4. Excluded: Not an eligible study design, OVID-Embase. [pmid: 16168145].
559 Mpofu C, Watson AJ, Rhodes JM. Strategies for detecting colon cancer and/or dysplasia in patients with inflammatory bowel disease.[update in Cochrane Database Syst Rev. 2006;(2):CD000279; PMID: 16625534]. Cochrane Database Syst Rev 2004;(2):CD000279 Excluded: Not an eligible intervention or outcome, OVID-Medline.
560 Mulhall BP, Veerappan GR, Jackson JL. Meta-analysis: computed tomographic colonography. Summary for patients in Ann Intern Med. Apr 19. 2005;142(8):I74. PMID: 15838063. Ann Intern Med 2005; Excluded: Not an eligible population, OVID-Medline.
561 Murabito JM, Evans JC, Larson MG, et al. Family breast cancer history and mammography: Framingham Offspring Study. Am J Epidemiol. 2001;154(10):916-23. Excluded: Family history not systematically collected, OVID-Medline. [pmid: 11700246].
562 Murff HJ, Spigel DR, Syngal S. Does this patient have a family history of cancer? An evidence-based analysis of the accuracy of family cancer history. JAMA. 2004;292(12):1480-9. Excluded: Not an eligible intervention or outcome, OVID-Medline. [pmid: 15383520].
563 Murff HJ, Peterson NB, Greevy RA, et al. Early initiation of colorectal cancer screening in individuals with affected first-degree relatives. J Gen Intern Med. 2007;22(1):121-6. Excluded: Family history not systematically collected, OVID-Medline. [pmid: 17351851].
564 Murff HJ, Peterson NB, Fowke JH, et al. Colonoscopy screening in African Americans and whites with affected first-degree relatives. Arch Intern Med. 2008;168(6):625-31. Excluded: Family history not systematically collected, OVID-Embase. [pmid: 18362255].
565 Myers,M.F. Decision making regarding prophylactic mastectomy and breast cancer susceptibility testing among women at increased risk of breast cancer. Dissertation Abstract. 2000 Excluded: Not an eligible publication type, OVID-PsycInfo.
566 Myers RE, Weinberg DS, Manne SL, et al. Genetic and environmental risk assessment for colorectal cancer risk in primary care practice settings: a pilot study. Genet Med. 2007;9(6):378-84. Excluded: Not an eligible intervention or outcome, OVID-Medline. [pmid: 17575504].
567 Nam RK, Toi A, Klotz LH, et al. Nomogram prediction for prostate cancer and aggressive prostate cancer at time of biopsy: utilizing all risk factors and tumor markers for prostate cancer. Can J Urol. 2006;13(Suppl 2):2-10. PM:16672122 Excluded: Not an eligible study design.
568 Nanda R, Schumm LP, Cummings S, et al. Genetic testing in an ethnically diverse cohort of high-risk women: a comparative analysis of BRCA1 and BRCA2 mutations in American families of European and African ancestry. JAMA. 2005;294(15):1925-33. Excluded: Model does not categorize risk or validate, OVID-Medline. [pmid: 16234499].
569 Narod SA, Offit K. Prevention and management of hereditary breast cancer. J Clin Oncol. 2005;23(8):1656-63. Excluded: Not an eligible study design, OVID-Embase. [pmid: 15755973].
570 Negri E, Decarli A, La Vecchia C, et al. Identification of high risk groups for breast cancer by means of logistic models. J Clin Epidemiol. 1990;43(5):413-8. Excluded: Model does not categorize risk or validate, OVID-Medline. [pmid: 2324782].
571 Neilson AR, Whynes DK. Determinants of persistent compliance with screening for colorectal cancer. Soc Sci Med. 1995;41(3):365-74. Excluded: Not an eligible study design, OVID-Embase. [pmid: 7481930].
572 Neise C, Rauchfuss M, Paepke S, et al. Risk perception and psychological strain in women with a family history of breast cancer. Onkologie. 2001;24(5):470-5. Excluded: Not an eligible study design, OVID-Medline. [pmid: 11694774].
573 Nelson HD, Huffman LH, Fu R, et al. Genetic risk assessment and BRCA mutation testing for breast and ovarian cancer susceptibility: Systematic evidence review for the U.S. Preventive Services Task Force. Ann Intern Med. 2005;143(5):362-47. Excluded: Not an eligible intervention or outcome, OVID-Embase. [pmid: 16144895].
574 Ng KK, Fung SY, Chow LW. Practice of breast self-examination among high risk Chinese women in Hong Kong. Chin Med J (Engl). 2000;113(12):1100-3. Excluded: Family history not systematically collected, OVID-Medline. [pmid: 11776145].
575 Ngo SN, Williams DB, Cobiac L, et al. Does garlic reduce risk of colorectal cancer? A systematic review. J Nutr. 2007;137(10):2264-9. Excluded: Not an eligible intervention or outcome, OVID-Medline. [pmid: 17885009].
576 Norman P, Brain K. An application of an extended health belief model to the prediction of breast self-examination among women with a family history of breast cancer. Br J Health Psychol. 2005;10(Pt:1):1-16. Excluded: Not an eligible study design, OVID-Medline. [pmid: 15826330].
577 Novotny J, Pecen L, Petruzelka L, et al. Breast cancer risk assessment in the Czech female population—an adjustment of the original Gail model. Breast Cancer Res Treat. 2006;95(1):29-35. Excluded: Model does not categorize risk or validate, OVID-Medline. [pmid: 16319995].
578 Ohori M, Swindle P. Nomograms and instruments for the initial prostate evaluation: the ability to estimate the likelihood of identifying prostate cancer. Semin Urol Oncol. 2002;20(2):116-22. PM:12012297 Excluded: Not an eligible study design. [pmid: 12012297].
579 Okasha M, McCarron P, Gunnell D, et al. Exposures in childhood, adolescence and early adulthood and breast cancer risk: a systematic review of the literature. [Review] [243 refs]. Breast Cancer Res Treat. 2003;78(2):223-76. Excluded: Not an eligible intervention or outcome, OVID-Medline. [pmid: 12725422].
580 Oleske DM, Galvez A, Cobleigh MA, et al. Are tri-ethnic low-income women with breast cancer effective teachers of the importance of breast cancer screening to their first-degree relatives? Results from a randomized clinical trial. Breast J. 2007;13(1):19-27. Excluded: Family history not systematically collected, OVID-Medline. [pmid: 17214789].
581 Olsen CM, Green AC, Whiteman DC, et al. Obesity and the risk of epithelial ovarian cancer: a systematic review and meta-analysis. Eur J Cancer. 2007;43(4):690-709. Excluded: Not an eligible population, OVID-Medline. [pmid: 17223544].
582 Olsen CM, Bain CJ, Jordan SJ, et al. Recreational physical activity and epithelial ovarian cancer: A case-control study, systematic review, and meta-analysis. Cancer Epidemiol Biomarkers Prev. 2007;16(11):2321-30. Excluded: Not an eligible population, OVID-Embase. [pmid: 18006921].
583 Optenberg SA, Clark JY, Brawer MK, et al. Development of a decision-making tool to predict risk of prostate cancer: the Cancer of the Prostate Risk Index (CAPRI) test. Urology. 1997;50(5):665-72. PM:9372872 Excluded: Not an eligible study design. [pmid: 9372872].
584 Ormondroyd E, Moynihan C, Watson M, et al. Disclosure of genetics research results after the death of the patient participant: a qualitative study of the impact on relatives. J Genet Couns. 2007;16(4):527-38. Excluded: Family history not systematically collected, OVID-Medline. [pmid: 17492498].
585 Otto SJ, Fracheboud J, Looman CW, et al. Initiation of population-based mammography screening in Dutch municipalities and effect on breast-cancer mortality: a systematic review. Lancet. 2003;361(9367):1411-7. Excluded: Not an eligible population, OVID-Medline. [pmid: 12727393].
586 Palmer RC, Emmons KM, Fletcher RH, et al. Familial risk and colorectal cancer screening health beliefs and attitudes in an insured population. Prev Med. 2007;45(5):336-41. Excluded: Not an eligible study design, OVID-Medline. [pmid: 17804048].
587 Palomares MR, Machia JR, Lehman CD, et al. Mammographic density correlation with Gail model breast cancer risk estimates and component risk factors. Cancer Epidemiol Biomarkers Prev. 2006;15(7):1324-30. Excluded: Model does not categorize risk or validate, OVID-Medline. [pmid: 16835331].
588 Papagrigoriadis S. Follow-up of patients with colorectal cancer: The evidence is in favour but we are still in need of a protocol. Int J Surg. 2007;5(2):120-8. Excluded: Not an eligible study design, OVID-Embase. [pmid: 17448977].
589 Park JG, Vasen HF, Park YJ, et al. Suspected HNPCC and Amsterdam criteria II: evaluation of mutation detection rate, an international collaborative study. Int J Colorectal Dis. 2002;17(2):109-14. Excluded: Model does not categorize risk or validate, OVID-Medline. [pmid: 12014418].
590 Park,N. Effects of breast cancer risk, psychological distress, and dispositional optimism on immune responses in healthy women Excluded: Not an eligible publication type, OVID-Cinahl.
591 Parmigiani G, Chen S, Iversen ES Jr, et al. Validity of models for predicting BRCA1 and BRCA2 mutations. Summary for patients in Ann Intern Med. Oct 2. 2007;147(7):I38. PMID: 17909202. Excluded: Model does not categorize risk or validate, OVID-Medline.
592 Pasini B, Casalis Cavalchini GC, Genovese T, et al. Evaluating breast cancer risk: available models to assess individual breast cancer risk and probability to be a BRCA mutation carrier. J Exp Clin Cancer Res. 2002;21(Suppl. 3):23-9. Excluded: Not an eligible intervention or outcome, OVID-Medline.
593 Patenaude AF, Schneider KA, Kieffer SA, et al. Acceptance of invitations for p53 and BRCA1 predisposition testing: Factors infleuencing potential utilization of cancer genetic testing cancer genetic testing. Psychooncology. 1996;5(3):241-50. Excluded: Not an eligible population, OVID-Embase.
594 Percesepe A, Anti M, Roncucci L, et al. The effect of family size on estimates of the frequency of hereditary non-polyposis colorectal cancer. Br J Cancer. 1995;72(5):1320-3. Excluded: Not an eligible intervention or outcome, OVID-Medline. [pmid: 7577490].
595 Perkins JJ, Sanson-Fisher RW, Clarke SJ, et al. An exploration of screening practices for prostate cancer and the associated community expenditure. Br J Urol. 1998;82(4):524-9. Excluded: Not an eligible study design, OVID-Medline. [pmid: 9806181].
596 Perry N, Broeders M, de Wolf C, et al. European guidelines for quality assurance in breast cancer screening and diagnosis. Fourth edition—summary document. Ann Oncol. 2008;19(4):614-22. Excluded: Model does not categorize risk or validate, OVID-Medline. [pmid: 18024988].
597 Peshkin BN, Schwartz MD, Isaacs C, et al. Utilization of breast cancer screening in a clinically based sample of women after BRCA1/2 testing. Cancer Epidemiol Biomarkers Prev. 2002;11(10:Pt 1):t-8. Excluded: Not an eligible population, OVID-Medline.
598 Pestalozzi BC, Luporsi-Gely E, Jost LM, et al. ESMO Minimum Clinical Recommendations for diagnosis, adjuvant treatment and follow-up of primary breast cancer. Ann Oncol. 2005;16:Suppl-9. Excluded: Family history not systematically collected, OVID-Medline.
599 Peters NHGM, Borel IR, Zuithoff NPA, et al. Meta-analysis of MR imaging in the diagnosis of breast lesions. Radiology. 2008;246(1):116-24. Excluded: Not an eligible population, OVID-Embase. [pmid: 18024435].
600 Peterson SK, Watts BG, Koehly LM, et al. How families communicate about HNPCC genetic testing: findings from a qualitative study. Am J Med Genet 2003;Part(1):78–86. Excluded: Family history not systematically collected, OVID-Medline.
601 Petro-Nustas WI. Factors associated with mammography utilization among Jordanian women. J Transcult Nurs. 2001;12(4):284-91. Excluded: Family history not systematically collected, OVID-Cinahl. [pmid: 11989219].
602 Phillips KA, Jenkins MA, Lindeman GJ, et al. Risk-reducing surgery, screening and chemoprevention practices of BRCA1 and BRCA2 mutation carriers: a prospective cohort study. Clin Genet. 2006;70(3):198-206. Excluded: Not an eligible population, OVID-Medline. [pmid: 16922722].
603 Phillips,M.A. Reliability of a statistical instrument for predicting BRCA1/BRCA2 genetic mutation carrier status. Excluded: Not an eligible publication type, OVID-Cinahl.
604 Pieterse K, van Dooren S, Seynaeve C, et al. Passive coping and psychological distress in women adhering to regular breast cancer surveillance. Psychooncology. 2007;16(9):851-8. Excluded: Not an eligible study design, OVID-PsycInfo. [pmid: 17219399].
605 Pinol V, Castells A, Andreu M, et al. Accuracy of revised Bethesda guidelines, microsatellite instability, and immunohistochemistry for the identification of patients with hereditary nonpolyposis colorectal cancer. JAMA. 2005;293(16):1986-94. Excluded: Model does not categorize risk or validate, OVID-Medline. [pmid: 15855432].
606 Pittler MH, Ernst E. Clinical effectiveness of garlic (Allium sativum). Mol Nutr Food Res. 2007;51(11):1382-5. Excluded: Not an eligible study design, OVID-Medline. [pmid: 17918163].
607 Podoloff DA, Advani RH, Allred C, et al. NCCN Task Force report: Positron Emission Tomography (PET)/Computed Tomography (CT) scanning in cancer. J Natl Compr Cancer Netw. 2007;5(SUPPL. 1):S. Excluded: Not an eligible intervention or outcome, OVID-Embase.
608 Polednak AP. Knowledge of colorectal cancer and use of screening tests among higher-risk persons. J Cancer Educ. 1990;5(2):115-24. Excluded: Not an eligible population, OVID-Embase. [pmid: 2206933].
609 Polednak AP, Lane DS, Burg MA. Risk perception, family history, and use of breast cancer screening tests. Cancer Detect Prev. 1991;15(4):257-63. Excluded: Family history not systematically collected, OVID-Medline. [pmid: 1794132].
610 Potter CE, Beldock JG. Object Class Networks (OCNs) for interface-independent calculation with Gail and Claus models. Ann N Y Acad Sci. 1995;768:308-11. Excluded: Model does not categorize risk or validate, OVID-Medline. [pmid: 8526375].
611 Price MA, Butow PN, Lo SK, et al. Predictors of cancer worry in unaffected women from high risk breast cancer families: risk perception is not the primary issue. J Genet Couns. 2007;16(5):635-44. Excluded: Not an eligible study design, OVID-Medline. [pmid: 17828585].
612 Purkayastha S, Tekkis PP, Athanasiou T, et al. Magnetic resonance colonography versus colonoscopy as a diagnostic investigation for colorectal cancer: a meta-analysis.[see comment]. Clin Radiol. 2005;60(9):980-9. Excluded: Not an eligible population, OVID-Medline. [pmid: 16124980].
613 Pylvanainen K, Kairaluoma M, Mecklin JP. Compliance and Satisfaction with Long-Term Surveillance in Finnish HNPCC Families. Fam Cancer. 2006;5(2):175-8. Excluded: Not an eligible population, OVID-Medline. [pmid: 16736288].
614 Qaseem A, Snow V, Sherif K, et al. Screening mammography for women 40 to 49 years of age: a clinical practice guideline from the American College of Physicians.[summary for patients in Ann Intern Med. 2007 Apr 3;146(7):I20; PMID: 17404347]. Ann Intern Med. 2007;146(7):511-5. Excluded: Model does not categorize risk or validate, OVID-Medline. [pmid: 17404353].
615 Qin LQ, Xu JY, Wang PY, et al. Soyfood intake in the prevention of breast cancer risk in women: a meta-analysis of observational epidemiological studies. J Nutr Sci Vitaminol. 2006;52(6):428-36. Excluded: Not an eligible population, OVID-Medline. [pmid: 17330506].
616 Qin LQ, Xu JY, Wang PY, et al. Milk consumption is a risk factor for prostate cancer in Western countries: evidence from cohort studies. Asia Pac J Clin Nutr. 2007;16(3):467-76. Excluded: Not an eligible intervention or outcome, OVID-Medline.
617 Qureshi N, Wilson B, Santaguida P, et al. Collection and use of cancer family history in primary care. Evid Rep Technol Assess No.159, AHRQ Publication No. 08-E001 (prepared by the McMaster University Evidence-based Practice Center under Contract No. 290-02-0020). Rockville, MD: Agency for Health Care Research and Quality; 2007 Oct. Available at: http://www.ahrq.gov/clinic/tp/famhisttp.htm Excluded: Not an eligible intervention or outcome, OVID-Medline.
618 Rabeneck L, Rumble RB, Axler J, et al. Cancer Care Ontario Colonoscopy Standards: Standards and evidentiary base. Can J Gastroenterol. 2007;21(Suppl. D):5D-24D. Excluded: Not an eligible intervention or outcome, OVID-Embase.
619 Rabin C, Pinto B. Cancer-related beliefs and health behavior change among breast cancer survivors and their first-degree relatives. Psychooncology. 2006;15(8):701-12. Excluded: Family history not systematically collected, OVID-Medline. [pmid: 16302292].
620 Radtke HB, Sebold CD, Allison C, et al. Neurofibromatosis type 1 in genetic counseling practice: Recommendations of the national society of genetic counselors. J Genet Couns. 2007;16(4):387-407. Excluded: Not an eligible intervention or outcome, OVID-Embase. [pmid: 17636453].
621 Rahman SM, Dignan MB, Shelton BJ. Factors influencing adherence to guidelines for screening mammography among women aged 40 years and older. Ethn Dis. 2003;13(4):477-84. Excluded: Family history not systematically collected, OVID-Medline. [pmid: 14632267].
622 Rahman SMM, Dignan MB, Shelton BJ. A theory-based model for predicting adherence to guidelines for screening mammography among women age 40 and older. Int J Canc Prev. 2005;2(3):169-79. Excluded: Family history not systematically collected, OVID-Embase. [pmid: 19122776].
623 Rai T, Clements A, Bukach C, et al. What influences men's decision to have a prostate-specific antigen test? A qualitative study. Fam Pract. 2007;24(4):365-71. Excluded: Family history not systematically collected, OVID-Embase. [pmid: 17644829].
624 Rakowski W, Breen N, Meissner H, et al. Prevalence and correlates of repeat mammography among women aged 55–79 in the Year 2000 National Health Interview Survey. Prev Med. 2004;39(1):1-10. Excluded: Family history not systematically collected, OVID-Medline. [pmid: 15207980].
625 Ramji F, Cotterchio M, Manno M, et al. Association between subject factors and colorectal cancer screening participation in Ontario, Canada. Cancer Detect Prev. 2005;29(3):221-6. Excluded: Family history not systematically collected, OVID-Medline. [pmid: 15896925].
626 Ramsoekh D, van Leerdam ME, Tops CM, et al. The use of genetic testing in hereditary colorectal cancer syndromes: genetic testing in HNPCC, (A)FAP and MAP. Clin Genet. 2007;72(6):562-7. Excluded: Not an eligible population, OVID-Medline. [pmid: 17922849].
627 Ray JA, Loescher LJ, Brewer M. Risk-reduction surgery decisions in high-risk women seen for genetic counseling. J Genet Couns. 2005;14(6):473-84. Excluded: Not an eligible study design, OVID-Medline. [pmid: 16388328].
628 Rees G, Fry A, Cull A, et al. Illness perceptions and distress in women at increased risk of breast cancer. Psychol Health. 2004;19(6):749-65. Excluded: Not an eligible study design, OVID-Cinahl.
629 Rees G, Gaff C, Young MA, et al. Health beliefs and behaviors of women who have received genetic counseling for breast cancer. J Genet Couns. 2007;16(4):457-68. Excluded: Not an eligible population, OVID-Medline. [pmid: 17619128].
630 Reichelt JG, Dahl AA, Heimdal K, et al. Uptake of genetic testing and pre-test levels of mental distress in Norwegian families with known BRCA1 mutations. Dis Markers. 1999;15(13):139-43. Excluded: Not an eligible study design, OVID-Medline. [pmid: 10595268].
631 Rex DK. ACG Board of Trustees. American College of Gastroenterology action plan for colorectal cancer prevention. Am J Gastroenterol. 2004;99(4):574-7. Excluded: Model does not categorize risk or validate, OVID-Medline. [pmid: 15089883].
632 Rex DK, Kahi CJ, Levin B, et al. Guidelines for Colonoscopy Surveillance after Cancer Resection: A Consensus Update by the American Cancer Society and US Multi-Society Task Force on Colorectal Cancer. CA Cancer J Clin. 2006;56(3):160-7. Excluded: Model does not categorize risk or validate, OVID-Cinahl. [pmid: 16737948].
633 Reyes CM, Allen BA, Terdiman JP, et al. Comparison of selection strategies for genetic testing of patients with hereditary nonpolyposis colorectal carcinoma: effectiveness and cost-effectiveness. Cancer. 2002;95(9):1848-56. Excluded: Family history not systematically collected, OVID-Medline. [pmid: 12404277].
634 Richardson JL, Danley K, Mondrus GT, et al. Adherence to screening examinations for colorectal cancer after diagnosis in a first-degree relative. Prev Med. 1995;24(2):166-70. Excluded: Family history not systematically collected, OVID-Medline. [pmid: 7597019].
635 Rieck GC, Lim K, Rogers MT, et al. Screening for familial ovarian cancer—management and outcome of women with moderate to high risk of developing ovarian cancer. Int J Gynecol Cancer. 2006;16(Suppl. 1):86-91. Excluded: Not an eligible population, OVID-Medline. [pmid: 16515573].
636 Rimer BK, Schildkraut JM, Lerman C, et al. Participation in a women's breast cancer risk counseling trial. Who participates? Who declines? High Risk Breast Cancer Consortium. Cancer. 1996;77(11):2348-55. Excluded: Family history not systematically collected, OVID-Medline. [pmid: 8635106].
637 Rini C, Jandorf L, Valdimarsdottir H, et al. Distress among inflammatory bowel disease patients at high risk for colorectal cancer: a preliminary investigation of the effects of family history of cancer, disease duration, and perceived social support. sychooncology. 2008;17(4):354-62. Excluded: Family history not systematically collected, OVID-Medline.
638 Ritvo P, Robinson G, Irvine J, et al. A longitudinal study of psychological adjustment to familial genetic risk assessment for ovarian cancer. Gynecol Oncol. 1999;74(3):331-7. Excluded: Not an eligible population, OVID-Medline. [pmid: 10479489].
639 Ritvo P, Irvine J, Robinson G, et al. Psychological adjustment to familial-genetic risk assessment for ovarian cancer: predictors of nonadherence to surveillance recommendations. Gynecol Oncol. 2002;84(1):72-80. Excluded: Not an eligible study design, OVID-Medline. [pmid: 11748980].
640 Rockhill B, Byrne C, Rosner B, et al. Breast cancer risk prediction with a log-incidence model: evaluation of accuracy. J Clin Epidemiol. 2003;56(9):856-61. Excluded: Not an eligible study design, OVID-Medline. [pmid: 14505770].
641 Roddam AW, Duffy MJ, Hamdy FC, et al. Use of prostate-specific antigen (PSA) isoforms for the detection of prostate cancer in men with a PSA level of 2–10 ng/ml: systematic review and meta-analysis. Eur Urol 398;48(3):386–99. Excluded: Not an eligible population, OVID-Medline.
642 Rodriguez-Moranta F, Castells A, Andreu M, et al. Clinical performance of original and revised Bethesda guidelines for the identification of MSH2/MLH1 gene carriers in patients with newly diagnosed colorectal cancer: proposal of a new and simpler set of recommendations. Am J Gastroenterol. 2006;101(5):1104-11. Excluded: Model does not categorize risk or validate, OVID-Medline. [pmid: 16696788].
643 Rodriguez C, Plasencia A, Schroeder DG. Predictive factors of enrollment and adherence in a breast cancer screening program in Barcelona (Spain). Soc Sci Med. 1995;40(8):1155-60. Excluded: Family history not systematically collected, OVID-Medline. [pmid: 7597469].
644 Roetzheim R, Fox SA, Leake B, et al. The influence of risk factors on breast carcinoma screening of Medicare-insured older women. National Cancer Institute Breast Cancer Screening Consortium. Cancer. 1996;78(12):2526-34. Excluded: Family history not systematically collected, VID-Medline. [pmid: 8952561].
645 Roetzheim RG, Fox SA, Leake B. The effect of risk on changes in breast cancer screening rates in Los Angeles, 1988-1990. Cancer. 1994;74(2):625-31. Excluded: Family history not systematically collected, OVID-Medline. [pmid: 8033041].
646 Rojas, MP, Telaro, et al. Follow-up strategies for women treated for early breast cancer. Cochrane Database of Syst Rev 2008;(1): Excluded: Not an eligible intervention or outcome, OVID-Cochrane.
647 Rojas MP, Telaro E, Russo A, et al. Follow-up strategies for women treated for early breast cancer. Cochrane Database Syst Rev 2005;(1):CD001768 Excluded: Not an eligible intervention or outcome, OVID-Medline.
648 Ronco AL. Use of artificial neural networks in modeling associations of discriminant factors: Towards an intelligent selective breast cancer screening. Artif Intell Med. 1999;16(3):299-309. Excluded: Model does not categorize risk or validate, OVID-Embase. [pmid: 10397306].
649 Ropka ME, Wenzel J, Phillips EK, et al. Uptake rates for breast cancer genetic testing: a systematic review. Cancer Epidemiol Biomarkers Prev. 2006;15(5):840-55. Excluded: Not an eligible intervention or outcome, OVID-Medline. [pmid: 16702359].
650 Rosen B, Kwon J, Fung Kee FM, et al. Systematic review of management options for women with a hereditary predisposition to ovarian cancer. Gynecol Oncol. 2004;93(2):280-6. Excluded: Not an eligible intervention or outcome, OVID-Medline. [pmid: 15099934].
651 Rosman AS, Korsten MA. Meta-analysis comparing CT colonography, air contrast barium enema, and colonoscopy. Am J Med. 2007;120(3):203-10. Excluded: Not an eligible population, OVID-Medline. [pmid: 17349438].
652 Rosolowich V. Breast Disease Committee of the Society of Obstetricians and Gynaecologists of Canada. Breast self-examination. J Obstet Gynaecol Can. 2006;28(8):728-30. Excluded: Model does not categorize risk or validate, OVID-Medline. [pmid: 17022914].
653 Rothemund Y, Paepke S, Flor H. Perception of risk, anxiety, and health behaviors in women at high risk for breast cancer. Int J Behav Med. 2001;8(3):230-9. Excluded: Not an eligible study design, OVID-Embase.
654 Rouleau I, Chiquette J, Plante M, et al. Changes in health-related behaviours following BRCA 1/2 genetic testing: the case of hormone replacement therapy. J Obstet Gynaecol Can. 2004;26(12):1059-66. Excluded: Not an eligible population, OVID-Medline. [pmid: 15607041].
655 Roumier X, Azzouzi R, Valeri A, et al. Adherence to an annual PSA screening program over 3 years for brothers and sons of men with prostate cancer. Eur Urol. 45(3):280-5. Excluded: Not an eligible study design, OVID-Medline. [pmid: 15036671].
656 Rowse J, Brown K, Jandorf L, et al. Breast cancer specific distress prior to genetic counseling in women of African descent at increased risk of hereditary breast and ovarian cancer. J Genet Couns. 2007;16(1):11. Excluded: Family history not systematically collected, OVID-Cinahl.
657 Royak-Schaler R, Klabunde CN, Greene WF, et al. Communicating breast cancer risk: patient perceptions of provider discussions. Medscape Womens Health 7(2):2-Apr Excluded: Not an eligible study design, OVID-Medline.
658 Royak-Schaler R, DeVellis BM, Sorenson JR, et al. Breast cancer in African-American families. Risk perception, cancer worry, and screening practices of first-degree relatives. Ann N Y Acad Sci. 1995;768:281-5. Excluded: Not an eligible study design, OVID-Medline. [pmid: 8526367].
659 Ruthotto F, Papendorf F, Wegener G, et al. Participation in screening colonoscopy in first-degree relatives from patients with colorectal cancer. Ann Oncol. 2007;18(9):1518-22. Excluded: Not an eligible study design, OVID-Medline. [pmid: 17761708].
660 Ryan EL. Risk perception, risk attribution, and risk modification beliefs among women with a family history of breast cancer Dissertation Abstract, 1998 Excluded: Not an eligible publication type, OVID-PsycInfo.
661 Sabatino SA, Burns RB, Davis RB, et al. Breast carcinoma screening and risk perception among women at increased risk for breast carcinoma: results from a national survey. Cancer. 2004;100(11):2338-46. Excluded: Family history not systematically collected, OVID-Medline. [pmid: 15160336].
662 Saini SD, Kim HM, Schoenfeld P. Incidence of advanced adenomas at surveillance colonoscopy in patients with a personal history of colon adenomas: a meta-analysis and systematic review. Gastrointest Endosc. 2006;64(4):614-26. Excluded: Not an eligible population, OVID-Medline. [pmid: 16996358].
663 Salmon PG, Swank AM. Exercise-based disease management guidelines for individuals with cancer: Potential applications in a high-risk mid-southern state. Journal of Exercise Physiology Online. 2002;5(4):1-10. Excluded: Not an eligible study design, OVID-Embase.
664 Salsman JM, Pavlik E, Boerner LM, et al. Clinical, demographic, and psychological characteristics of new, asymptomatic participants in a transvaginal ultrasound screening program for ovarian cancer. Prev Med. 2004;39(2):315-22. Excluded: Family history not systematically collected, OVID-Medline. [pmid: 15226040].
665 Samad AKA, Taylor RS, Marshall T, et al. A meta-analysis of the association of physical activity with reduced risk of colorectal cancer. Colorectal Dis. 2005;7(3):204-13. Excluded: Not an eligible intervention or outcome, OVID-Embase. [pmid: 15859955].
666 Sanjoaquin MA, Allen N, Couto E, et al. Folate intake and colorectal cancer risk: A meta-analytical approach. Int J Cancer. 2005;113(5):825-8. Excluded: Not an eligible intervention or outcome, OVID-Embase. [pmid: 15499620].
667 Saraiya M, Coughlin SS, Burke W, et al. The role of family history in personal prevention practices among US women physicians. Community Genetics. 2001;4(2):102-8. Excluded: Family history not systematically collected, OVID-Embase.
668 Saslow D, Boetes C, Burke W, et al. American Cancer Society guidelines for breast screening with MRI as an adjunct to mammography.[erratum appears in CA Cancer J Clin. 2007 May-Jun;57(3):185]. CA Cancer J Clin. 2007;57(2):75-89. Excluded: Model does not categorize risk or validate, OVID-Medline. [pmid: 17392385].
669 Scardino P. Update: NCCN prostate cancer Clinical Practice Guidelines. J Natl Compr Cancer Netw. 2005;3(Suppl.1):S29-S33. Excluded: Not an eligible intervention or outcome, OVID-Medline.
670 Scherr D, Swindle PW, Scardino PT. National Comprehensive Cancer Network guidelines for the management of prostate cancer. Urology. 2003;61(Suppl.2):14-24. Excluded: Not an eligible intervention or outcome, OVID-Embase. [pmid: 12667883].
671 Schildkraut JM, Lerman C, Lustbader E, et al. Adherence to mammography among subgroups of women at high risk for breast cancer. J Womens Health. 1995;4(6):645-54. Excluded: Family history not systematically collected, OVID-Embase.
672 Schmidt S, Becher H, Chang-Claude J. Breast cancer risk assessment: use of complete pedigree information and the effect of misspecified ages at diagnosis of affected relatives. Hum Genet. 1998;102(3):348-56. Excluded: Model does not categorize risk or validate, OVID-Medline. [pmid: 9544851].
673 Schnur JB, Valdimarsdottir HB, Montgomery GH, et al. Social constraints and distress among women at familial risk for breast cancer. Ann Behav Med. 2004;28(2):142-8. Excluded: Not an eligible study design, OVID-Medline. [pmid: 15454362].
674 Schnur JB, DiLorenzo TA, Montgomery GH, et al. Perceived risk and worry about prostate cancer: a proposed conceptual model. Behav Med. 2006;32(3):89-96. Excluded: Not an eligible study design, OVID-Medline. [pmid: 17120384].
675 Schnur JB. Social constraints, avoidance, and psychological distress in women with and without family histories of breast cancer. Dissertation abstract. 2003 Excluded: Not an eligible publication type, OVID-PsycInfo.
676 Schreer I. Early detection and diagnosis of breast cancer. Breast Care. 2006;1(4):227-8. Excluded: Model does not categorize risk or validate, OVID-Cinahl.
677 Schwartz M, Lerman C, Daly M, et al. Utilization of ovarian cancer screening by women at increased risk. Cancer Epidemiol Biomarkers Prev. 1995;4(3):269-73. Excluded: Family history not systematically collected, OVID-Medline. [pmid: 7606202].
678 Schwartz MD, Lerman C, Miller SM, et al. Coping disposition, perceived risk, and psychological distress among women at increased risk for ovarian cancer. Health Psychol. 1995;14(3):232-5. Excluded: Family history not systematically collected, OVID-Medline. [pmid: 7641664].
679 Schwartz MD, Taylor KL, Willard KS, et al. Distress, personality, and mammography utilization among women with a family history of breast cancer. Health Psychol. 1999;18(4):327-32. Excluded: Family history not systematically collected, OVID-Medline. [pmid: 10431933].
680 Schwartz MD, Taylor KL, Willard KS. Prospective association between distress and mammography utilization among women with a family history of breast cancer. J Behav Med. 2003;26(2):105-17. Excluded: Not an eligible study design, OVID-Medline. [pmid: 12776381].
681 Schwartz MD, Kaufman E, Peshkin BN, et al. Bilateral prophylactic oophorectomy and ovarian cancer screening following BRCA1/BRCA2 mutation testing. J Clin Oncol. 2003;21(21):4034-41. Excluded: Not an eligible population, OVID-Medline. [pmid: 14581427].
682 Seely D, Mills EJ, Wu P, et al. The effects of green tea consumption on incidence of breast cancer and recurrence of breast cancer: A systematic review and meta-analysis. Integr Cancer Ther. 2005;4(2):144-55. Excluded: Not an eligible intervention or outcome, OVID-Embase. [pmid: 15911927].
683 Shah M, Zhu K, Palmer RC, et al. Family history of cancer and utilization of prostate, colorectal and skin cancer screening tests in U.S. men. Prev Med. 2007;44(5):459-64. Excluded: Family history not systematically collected, OVID-Medline. [pmid: 17320159].
684 Shah M, Zhu K, Palmer RC, et al. Breast, colorectal, and skin cancer screening practices and family history of cancer in U.S. women. J Womens Health (Larchmt). 2007;16(4):526-34. Excluded: Family history not systematically collected, OVID-Medline. [pmid: 17521256].
685 Shaukat A, Scouras N, Schunemann HJ. Role of supplemental calcium in the recurrence of colorectal adenomas: a metaanalysis of randomized controlled trials. Am J Gastroenterol. 2005;100(2):390-4. Excluded: Not an eligible intervention or outcome, OVID-Medline. [pmid: 15667497].
686 Sheinfeld GS, Albert SM. The meaning of risk to first degree relatives of women with breast cancer. Women Health. 2003;37(3):97-117. Excluded: Family history not systematically collected, OVID-Medline. [pmid: 12839310].
687 Shen Y, Yang Y, Inoue LY, et al. Role of detection method in predicting breast cancer survival: analysis of randomized screening trials.[see comment]. J Natl Cancer Inst. 2005;97(16):1195-203. Excluded: Family history not systematically collected, OVID-Medline. [pmid: 16106024].
688 Shergill AK, Terdiman JP. Refining Colorectal Cancer Screening Recommendations Based on Gender. Gastroenterology. 2007;132(7):2605-6. Excluded: Model does not categorize risk or validate, OVID-Embase. [pmid: 17570233].
689 Siddiqui AA, Patel A, Huerta S. Determinants of compliance with colonoscopy in patients with adenomatous colon polyps in a veteran population. Aliment Pharmacol Ther. 2006;24(1112):1623-30. Excluded: Family history not systematically collected, OVID-Medline. [pmid: 17206950].
690 Simard J, Dumont M, Moisan AM, et al. Evaluation of BRCA1 and BRCA2 mutation prevalence, risk prediction models and a multistep testing approach in French-Canadian families with high risk of breast and ovarian cancer.[erratum appears in J Med Genet. 2007 Jul;44(7):471]. J Med Genet. 2007;44(2):107-21. Excluded: Model does not categorize risk or validate, OVID-Medline. [pmid: 16905680].
691 Sinicrope PS, Vernon SW, Diamond PM, et al. Development and preliminary validation of the cancer family impact scale for colorectal cancer. Genet Test. 2008;12(1):161-9. Excluded: Family history not systematically collected, OVID-Embase. [pmid: 18373413].
692 Sivell S, Iredale R, Gray J, et al. Cancer genetic risk assessment for individuals at risk of familial breast cancer. [Review][93 refs]. Cochrane Database Syst Rev 2007;(2):CD003721 Excluded: Not an eligible intervention or outcome, OVID-Medline.
693 Slattery ML, Kinney AY, Levin TR. Factors associated with colorectal cancer screening in a population-based study: the impact of gender, health care source, and time. Prev Med. 2004;38(3):276-83. Excluded: Family history not systematically collected, OVID-Medline. [pmid: 14766109].
694 Smith RA, Saslow D, Sawyer KA, et al. American Cancer Society guidelines for breast cancer screening: update. CA Cancer J Clin. 2003;53(3):141-69. Excluded: Model does not categorize risk or validate, OVID-Medline. [pmid: 12809408].
695 Smith RA, Standiford CJ, Saraiya M. Updates in colon, cervical, breast, and prostate cancer screening. Patient Care Nurse Pract 2005;7. Excluded: Model does not categorize risk or validate, OVID-Cinahl.
696 Smith RA, Cokkinides V, Eyre HJ. American Cancer Society guidelines for the early detection of cancer. CA Cancer J Clin. 2005;55(1):31-44. Excluded: Model does not categorize risk or validate, OVID-Embase. [pmid: 15661685].
697 Smith RA, Cokkinides V, Eyre HJ. American Cancer Society guidelines for the early detection of cancer. CA Cancer J Clin. 2006;56(1):11-25. Excluded: Model does not categorize risk or validate, OVID-Embase. [pmid: 16449183].
698 Smith TJ, Khatcheressian J. Review: chemotherapy and hormonal therapy reduce recurrence and mortality at 15 years in early breast cancer. Evid Based Med. 2005;10(6):169. Excluded: Not an eligible study design, OVID-Cinahl.
699 Society of Gastroenterology Nurses and Associates I. SGNA Guideline: Performance of flexible sigmoidoscopy by registered nurses for the purpose of colorectal cancer screening. Gastroenterol Nurs. 2003;26(6):261-3. Excluded: Not an eligible intervention or outcome, OVID-Medline. [pmid: 14676614].
700 Sohl SJ, Moyer A. Tailored interventions to promote mammography screening: a meta-analytic review. Prev Med. 2007;45(4):252-61. Excluded: Not an eligible intervention or outcome, OVID-Medline. [pmid: 17643481].
701 Song JM, Kim CB, Chung HC, et al. Prostate-specific antigen, digital rectal examination and transrectal ultrasonography: a meta-analysis for this diagnostic triad of prostate cancer in symptomatic korean men. Yonsei Med J. 2005;46(3):414-24. Excluded: Not an eligible population, OVID-Medline. [pmid: 15988815].
702 Sooriakumaran P, Langley SEM, Laing RW, et al. COX-2 inhibition: A possible role in the management of prostate cancer?. J Chemother. 2007;19(1):21-32. Excluded: Not an eligible intervention or outcome, OVID-Embase. [pmid: 17309847].
703 Sorscher S, Levonian P. BCRA 1 testing guidelines for high-risk patients. J Clin Oncol. 1997;15(4):1711. Excluded: Not an eligible study design, OVID-Medline. [pmid: 9213589].
704 Sosna J, Morrin MM, Kruskal JB, et al. CT colonography of colorectal polyps: a metaanalysis. AJR Am J Roentgenol 2003;(6):1593–8. Excluded: Not an eligible population, OVID-Medline.
705 Sotiriou C, Desmedt C. Gene expression profiling in breast cancer. Ann Oncol. 2006;17(SUPPL. 10):259-62. Excluded: Not an eligible study design, OVID-Embase. [pmid: 16282245].
706 Soyer MT, Ciceklioglu M, Ceber E. Breast cancer awareness and practice of breast self examination among primary health care nurses: influencing factors and effects of an in-service education. J Clin Nurs. 2007;16(4):707-15. Excluded: Family history not systematically collected, OVID-Cinahl. [pmid: 17402952].
707 Spencer BA, Babey SH, Etzioni DA, et al. A population-based survey of prostate-specific antigen testing among California men at higher risk for prostate carcinoma. Cancer. 2006;106(4):765-74. Excluded: Family history not systematically collected, OVID-Medline. [pmid: 16419068].
708 Stamler LL. Review: limited evidence on regular breast examination does not support its effectiveness for reducing breast cancer deaths. Evid Based Nurs. 2004;7(1):15. Excluded: Not an eligible study design, OVID-Cinahl. [pmid: 14994688].
709 Standard TF. American Society of Colon and Rectal Surgeons, Collaborative Group of the Americas on Inherited Colorectal Cancer. Practice parameters for the identification and testing of patients at risk for dominantly inherited colorectal cancer. Dis Colon Rectum. 2001;44(10):1403. Excluded: Model does not categorize risk or validate, OVID-Medline. [pmid: 11598465].
710 Stefanek ME, Wilcox P. First degree relatives of breast cancer patients: screening practices and provision of risk information. Cancer Detect Prev. 1991;15(5):379-84. Excluded: Not an eligible study design, OVID-Medline. [pmid: 1751948].
711 Stefanek ME, Helzlsouer KJ, Wilcox PM, et al. Predictors of and satisfaction with bilateral prophylactic mastectomy. Prev Med. 1995;24(4):412-9. Excluded: Not an eligible study design, OVID-Medline. [pmid: 7479633].
712 Stephens JH, Moore JW. Can targeted intervention in CRC patients' relatives influence screening behaviour? A pilot study. Colorectal Dis. 2008;10(2):179-86. Excluded: Family history not systematically collected, OVID-Medline. [pmid: 17459064].
713 Stoffel EM, Garber JE, Grover S, et al. Cancer surveillance is often inadequate in people at high risk for colorectal cancer. J Med Genet. 2003;40(5):e54. Excluded: Not an eligible population, OVID-Medline. [pmid: 12746408].
714 Stormorken AT, Muller W, Lemkemeyer B, et al. Prediction of the outcome of genetic testing in HNPCC kindreds using the revised Amsterdam criteria and immunohistochemistry. Familial Cancer. 2001;1(34):169-73. Excluded: Model does not categorize risk or validate, OVID-Medline. [pmid: 14574174].
715 Straus WL, Mansley EC, Gold KF, et al. Colorectal cancer screening attitudes and practices in the general population: a risk-adjusted survey. J Public Health Manag Pract. 2005;11(3):244-51. Excluded: Family history not systematically collected, OVID-Cinahl. [pmid: 15829838].
716 Strzelczyk JJ, Dignan MB. Disparities in adherence to recommended followup on screening mammography: interaction of sociodemographic factors. Ethn Dis. 2002;12(1):77-86. Excluded: Family history not systematically collected, OVID-Medline. [pmid: 11913611].
717 Su X, Ma GX, Seals B, et al. Breast cancer early detection among Chinese women in the Philadelphia area. J Womens Health (Larchmt). 2006;15(5):507-19. Excluded: Family history not systematically collected, OVID-Medline. [pmid: 16796478].
718 Sun CL, Yuan JM, Koh WP, et al. Green tea, black tea and breast cancer risk: A meta-analysis of epidemiological studies. Carcinogenesis. 2006;27(7):1310-5. Excluded: Not an eligible population, OVID-Embase. [pmid: 16311246].
719 Sweetman J, Watson M, Norman A, et al. Feasibility of familial PSA screening: psychosocial issues and screening adherence. Br J Cancer. 2006;94(4):507-12. Excluded: Family history not systematically collected, OVID-Medline. [pmid: 16434991].
720 Syngal S, Fox EA, Eng C, et al. Sensitivity and specificity of clinical criteria for hereditary non-polyposis colorectal cancer associated mutations in MSH2 and MLH1. J Med Genet. 2000;37(9):641-5. Excluded: Model does not categorize risk or validate, OVID-Medline. [pmid: 10978352].
721 Takakuwa KM, Ernst AA, Weiss SJ, et al. Breast cancer knowledge and preventive behaviors: An urban emergency department-based survey. Acad Emerg Med. 2000;7(12):1393-8. Excluded: Family history not systematically collected, OVID-Medline. [pmid: 11099430].
722 Taplin SH, Thompson RS, Schnitzer F, et al. Revisions in the risk-based Breast Cancer Screening Program at Group Health Cooperative. Cancer. 1990;66(4):812-8. PM:2386908 Excluded: Not an eligible study design. [pmid: 2386908].
723 Tatemichi S, Miedema B, Leighton S. Breast cancer screening. First Nations communities in New Brunswick. Can Fam Physician. 2002;48:1084-9. Excluded: Family history not systematically collected, OVID-Medline. [pmid: 12113195].
724 Tavani A, Vecchia CL. Coffee, decaffeinated coffee, tea and cancer of the colon and rectum: A review of epidemiological studies, 1990-2003. Cancer Causes Control. 2004;15(8):743-57. Excluded: Not an eligible intervention or outcome, OVID-Embase. [pmid: 15456988].
725 Taylor P, Potts HWW. Computer aids and human second reading as interventions in screening mammography: Two systematic reviews to compare effects on cancer detection and recall rate. Eur J Cancer. 2008;44(6):798-807. Excluded: Not an eligible intervention or outcome, OVID-Embase. [pmid: 18353630].
726 Taylor R, Ivanov O, Page A, et al. Predictors of non-attendance from BreastScreen NSW in women who report current mammography screening. Aust N Z J Public Health. 2003;27(6):581-7. Excluded: Family history not systematically collected, OVID-Embase. [pmid: 14723404].
727 Taylor R, Taguchi K. Tamoxifen for breast cancer chemoprevention: low uptake by high-risk women after evaluation of a breast lump. Ann Fam Med. 2005;3(3):242-7. Excluded: Not an eligible study design, OVID-Medline. [pmid: 15928228].
728 Taylor SA, Laghi A, Lefere P, et al. European society of gastrointestinal and abdominal radiology (ESGAR): Consensus statement on CT colonography. Eur Radiol. 2007;17(2):575-9. Excluded: Not an eligible intervention or outcome, OVID-Embase. [pmid: 16967260].
729 Tchou J, Hou N, Rademaker A, et al. Acceptance of tamoxifen chemoprevention by physicians and women at risk. Cancer. 2004;100(9):1800-6. Excluded: Not an eligible study design, OVID-Medline. [pmid: 15112259].
730 Teillac P. The global state of prostate cancer: New diagnostic tools, minimal requirements for diagnosis and staging, and guidelines in the second millennium. BJU Int. 2004;94(Suppl 3):3-4. Excluded: Model does not categorize risk or validate, OVID-Embase.
731 Thiel LM. Health beliefs and breast cancer screening behaviors of women religious in America. Doctoral dissertation, research. Excluded: Not an eligible publication type, OVID-Cinahl.
732 Thirlaway K, Fallowfield L, Nunnerley H, et al. Anxiety in women ‘at risk’ of developing breast cancer. Br J Cancer. 1996;73(11):1422-4. Excluded: Family history not systematically collected, OVID-Medline. [pmid: 8645590].
733 Thompson IM, Ankerst DP, Chi C, et al. Assessing prostate cancer risk: Results from the Prostate Cancer Prevention Trial. J Natl Cancer Inst. 2006;98(8):529-34. Excluded: Model does not categorize risk or validate, OVID-Embase. [pmid: 16622122].
734 Thomssen C. AGO recommendations for the diagnosis and therapy of breast cancer. Breast Care. 2007;2(4):244-50. Excluded: Not an eligible intervention or outcome, OVID-Cinahl.
735 Thorogood M, Simera I, Dowler E, et al. A systematic review of population and community dietary interventions to prevent cancer. Nutr Res Rev. 2007;20(1):74-88. Excluded: Not an eligible intervention or outcome, OVID-Embase. [pmid: 19079861].
736 Thrasher JF, Cummings KM, Michalek AM, et al. Colorectal cancer screening among individuals with and without a family history. J Public Health Manag Pract. 2002;8(2):1-9. Excluded: Family history not systematically collected, OVID-Medline.
737 Tice JA, Cummings SR, Ziv E, et al. Mammographic breast density and the Gail model for breast cancer risk prediction in a screening population. Breast Cancer Res Treat. 2005;94(2):115-22. Excluded: Model does not categorize risk or validate, OVID-Medline. [pmid: 16261410].
738 Tice JA, Miike R, Adduci K, et al. Nipple aspirate fluid cytology and the Gail model for breast cancer risk assessment in a screening population. Cancer Epidemiol Biomarkers Prev. 2005;14(2):324-8. Excluded: Model does not categorize risk or validate, OVID-Medline. [pmid: 15734953].
739 Tice JA, Cummings SR, Smith-Bindman R, et al. Using clinical factors and mammographic breast density to estimate breast cancer risk: development and validation of a new predictive model. Ann Intern Med. 2008;148(5):337-47. PM:18316752 Excluded: Not an eligible study design. [pmid: 18316752].
740 Tiller K, Meiser B, Butow P, et al. Psychological impact of prophylactic oophorectomy in women at increased risk of developing ovarian cancer: a prospective study. Gynecol Oncol. 2002;86(2):212-9. Excluded: Not an eligible study design, OVID-Medline. [pmid: 12144830].
741 Tinley ST, Houfek J, Watson P, et al. Screening adherence in BRCA1/2 families is associated with primary physicians' behavior. Am J Med Genet 2004;Part(1):5–11. Excluded: Not an eligible population, OVID-Medline.
742 Touvier M, Kesse E, Volatier JL, et al. Dietary and cancer-related behaviors of vitamin/mineral dietary supplement users in a large cohort of French women. Eur J Nutr. 2006;45(4):205-14. Excluded: Family history not systematically collected, OVID-Medline. [pmid: 16382374].
743 Trafalis DTP, Athanassiou AE. A guideline for the management of women at substantially increased risk of breast cancer development. J B U ON. 2005;10(4):443-58. Excluded: Model does not categorize risk or validate, OVID-Embase.
744 Trask PC, Paterson AG, Wang C, et al. Cancer-specific worry interference in women attending a breast and ovarian cancer risk evaluation program: impact on emotional distress and health functioning. Psychooncology. 2001;10(5):349-60. Excluded: Family history not systematically collected, OVID-Medline. [pmid: 11536413].
745 Trepanier A, Ahrens M, McKinnon W, et al. Genetic cancer risk assessment and counseling: recommendations of the national society of genetic counselors. J Genet Couns. 2004;13(2):83-114. Excluded: Model does not categorize risk or validate, OVID-Medline. [pmid: 15604628].
746 Trock BJ, Hilakivi-Clarke L, Clarke R. Meta-analysis of soy intake and breast cancer risk.[see comment]. J Natl Cancer Inst. 2006;98(7):459-71. Excluded: Not an eligible population, OVID-Medline. [pmid: 16595782].
747 Tsouskas LI, Liaros A, Tzitzikas J, et al. The use of an expert system of composite risk factors in breast cancer screening. Stud Health Technol Inform. 1997;43:t-63. Excluded: Not an eligible intervention or outcome, OVID-Medline.
748 Tsouskas LI, Noula M, Dimopoulos P. Practicing an expert system for definition of high-risk group in breast cancer screening. ICUS Nurs Web J 2005;(22):5p Excluded: Model does not categorize risk or validate, OVID-Cinahl.
749 Turner-Cobb JM, Bloor LE, Whittemore AS, et al. Disengagement and social support moderate distress among women with a family history of breast cancer. Breast J. 2006;12(1):7-15. Excluded: Not an eligible study design, OVID-Medline. [pmid: 16409581].
750 Tyler CV Jr, Snyder CW. Cancer risk assessment: examining the family physician's role. J Am Board Fam Med. 2006;19(5):468-77. Excluded: Family history not systematically collected, OVID-Medline. [pmid: 16951296].
751 Tyrer J, Duffy SW, Cuzick J. A breast cancer prediction model incorporating familial and personal risk factors.[erratum appears in Stat Med. 2005 Jan 15;24(1):156]. Stat Med. 2004;23(7):1111-30. Excluded: Model does not categorize risk or validate, OVID-Medline. [pmid: 15057881].
752 U.S.Preventive Services Task Force. Screening for prostate cancer: recommendations and rationale. Am Fam Physician. 2003;67(4):787-92. Excluded: Model does not categorize risk or validate, OVID-Medline. [pmid: 12613733].
753 U.S.Preventive Services Task Force. Routine Vitamin Supplementation to Prevent Cancer and Cardiovascular Disease: Recommendations and Rationale. Ann Intern Med. 2003;139(1):51-5. Excluded: Model does not categorize risk or validate, OVID-Embase. [pmid: 12834319].
754 U.S.Preventive Services Task Force. Clinical guidelines. Genetic risk assessment and BRCA mutation testing for breast and ovarian cancer susceptibility: recommendation statement [corrected] [published erratum appears in Ann Intern Med 2005;143(7):547]. Ann Intern Med. 2005;143(5):355-61. Excluded: Model does not categorize risk or validate, OVID-Cinahl. [pmid: 16144894].
755 U.S.Preventive Services Task Force. Summaries for patients. Genetic risk assessment and BRCA mutation testing for breast and ovarian cancer susceptibility: U.S. Preventive Services Task Force recommendations.[see comment]. Ann Intern Med. 2005;143(5):I47. Excluded: Not an eligible study design, OVID-Medline. [pmid: 16144889].
756 U.S.Preventive Services Task Force. Genetic risk assessment and BRCA mutation testing for breast and ovarian cancer susceptibility: recommendation statement.[erratum appears in Ann Intern Med. 2005 Oct 4;143(7):547]. Ann Intern Med. 2005;143(5):355-61. Excluded: Model does not categorize risk or validate, OVID-Medline. [pmid: 16144894].
757 U.S.Preventive Services Task Force. Screening for ovarian cancer: recommendation statement. U.S. Preventive Services Task Force. Am Fam Physician. 2005;71(4):759-62. Excluded: Model does not categorize risk or validate, OVID-Medline. [pmid: 15756773].
758 U.S.Preventive Services Task Force. Routine aspirin or nonsteroidal anti-inflammatory drugs for the primary prevention of colorectal cancer: recommendation statement. Am Fam Physician. 2007;76(1):109-13. Excluded: Model does not categorize risk or validate, OVID-Cinahl. [pmid: 17668849].
759 Uyei A, Peterson SK, Erlichman J, et al. Association between clinical characteristics and risk-reduction interventions in women who underwent BRCA1 and BRCA2 testing: a single-institution study. Cancer. 2006;107(12):2745-51. Excluded: Not an eligible population, OVID-Medline. [pmid: 17109443].
760 Uzzo RG, Brown JG, Horwitz EM, et al. Prevalence and patterns of self-initiated nutritional supplementation in men at high risk of prostate cancer. BJU Int. 2004;93(7):955-60. Excluded: Not an eligible study design, OVID-Medline. [pmid: 15142142].
761 Vadaparampil ST, Jacobsen PB, Kash K, et al. Factors predicting prostate specific antigen testing among first-degree relatives of prostate cancer patients. Cancer Epidemiol Biomarkers Prev. 2004;13(5):753-8. Excluded: Not an eligible study design, OVID-Medline. [pmid: 15159306].
762 Vahteristo P, Eerola H, Tamminen A, et al. A probability model for predicting BRCA1 and BRCA2 mutations in breast and breast-ovarian cancer families. Br J Cancer. 2001;84(5):704-8. Excluded: Model does not categorize risk or validate, OVID-Medline. [pmid: 11237395].
763 Valdimarsdottir HB, Bovbjerg DH, Kash KM, et al. Psychological distress in women with a familial risk of breast cancer. Psychooncology. 1995;4(2):133-41. Excluded: Family history not systematically collected, OVID-Embase.
764 Valdimarsdottir HB, Bovbjerg DH, Brown K, et al. Cancer-specific distress is related to women's decisions to undergo BRCA1 testing. Cancer Research Therapy and Control. 1999;8(12):61-8. Excluded: Not an eligible publication type, OVID-Embase.
765 Valdimarsdottir HB, Zakowski SG, Gerin W, et al. Heightened psychobiological reactivity to laboratory stressors in healthy women at familial risk for breast cancer. J Behav Med. 2002;25(1):51-65. Excluded: Not an eligible intervention or outcome, OVID-Medline. [pmid: 11845558].
766 van Asperen CJ, Jonker MA, Jacobi CE, et al. Risk estimation for healthy women from breast cancer families: new insights and new strategies. Cancer Epidemiol Biomarkers Prev. 2004;13(1):87-93. Excluded: Model does not categorize risk or validate, OVID-Medline. [pmid: 14744738].
767 Van Cutsem EJ, Oliveira J, Kataja VV, et al. ESMO Minimum Clinical Recommendations for diagnosis, treatment and follow-up of advanced colorectal cancer. Ann Oncol. 2005;16:Suppl-9. Excluded: Model does not categorize risk or validate, OVID-Medline.
768 Van Cutsem EJD, Kataja VV. ESMO minimum clinical recommendations for diagnosis, adjuvant treatment and follow-up of colon cancer. Ann Oncol. 2005;16(Suppl. 1):i16-i17. Excluded: Model does not categorize risk or validate, OVID-Embase. [pmid: 15888737].
769 van der Rhee HJ, de Vries E, Coebergh JWW. Does sunlight prevent cancer? A systematic review. Eur J Cancer. 2006;42(14):2222-32. Excluded: Not an eligible population, OVID-Embase. [pmid: 16904314].
770 Van Der KT, Lopes C, Santonja C, et al. Guidelines for processing and reporting of prostatic needle biopsies. J Clin Pathol. 2003;56(5):336-40. Excluded: Not an eligible intervention or outcome, OVID-Embase. [pmid: 12719451].
771 van Dooren S, Rijnsburger AJ, Seynaeve C, et al. Psychological distress and breast self-examination frequency in women at increased risk for hereditary or familial breast cancer. Community Genet. 2003;6(4):235-41. Excluded: Not an eligible study design, OVID-Medline. [pmid: 15331869].
772 van Dooren S, Rijnsburger AJ, Seynaeve C, et al. Psychological distress in women at increased risk for breast cancer: the role of risk perception. Eur J Cancer. 2004;40(14):2056-63. Excluded: Not an eligible population, OVID-Medline. [pmid: 15341979].
773 van Dooren S, Seynaeve C, Rijnsburger AJ, et al. The impact of having relatives affected with breast cancer on psychological distress in women at increased risk for hereditary breast cancer. Breast Cancer Res Treat. 2005;89(1):75-80. Excluded: Family history not systematically collected, OVID-Medline. [pmid: 15666200].
774 van Dooren S, Seynaeve C, Rijnsburger AJ, et al. Exploring the course of psychological distress around two successive control visits in women at hereditary risk of breast cancer. Eur J Cancer. 2005;41(10):1416-25. Excluded: Family history not systematically collected, OVID-Medline. [pmid: 15913982].
775 van Oostrom I, Meijers-Heijboer H, Duivenvoorden HJ, et al. Comparison of individuals opting for BRCA1/2 or HNPCC genetic susceptibility testing with regard to coping, illness perceptions, illness experiences, family system characteristics and hereditary cancer distress. Patient Educ Couns. 2007;65(1):58-68. Excluded: Not an eligible population, OVID-Medline. [pmid: 16872788].
776 Varghese SS, Wilson DB, Penberthy LT, et al. North American perspectives. Examining the evidence for breast self examination recommendations. Clin Governance Int J. 2006;11(3):225-33. Excluded: Not an eligible study design, OVID-Cinahl.
777 Vasen HF, Moslein G, Alonso A, et al. Guidelines for the clinical management of familial adenomatous polyposis (FAP). Gut. 2008;57(5):704-13. Excluded: Model does not categorize risk or validate, OVID-Medline. [pmid: 18194984].
778 Vasey PA, Herrstedt J, Jelic S, et al. ESMO Minimum Clinical Recommendations for diagnosis, treatment and follow-up of epithelial ovarian carcinoma. Ann Oncol. 2005;16(Suppl 1):i13-5. Excluded: Model does not categorize risk or validate, OVID-Medline. [pmid: 15888736].
779 Velayos FS, Terdiman JP, Walsh JM. Effect of 5-aminosalicylate use on colorectal cancer and dysplasia risk: a systematic review and metaanalysis of observational studies. Am J Gastroenterol. 2005;100(6):1345-53. Excluded: Not an eligible population, OVID-Medline. [pmid: 15929768].
780 Velayos FS, Allen BA, Conrad PG, et al. Low rate of microsatellite instability in young patients with adenomas: reassessing the Bethesda guidelines. Am J Gastroenterol. 2005;100(5):1143-9. Excluded: Model does not categorize risk or validate, OVID-Medline. [pmid: 15842591].
781 Veschi S, Aceto G, Scioletti AP, et al. High prevalence of BRCA1 deletions in BRCAPRO-positive patients with high carrier probability. Ann Oncol. 2007;18:Suppl-92. Excluded: Model does not categorize risk or validate, OVID-Medline.
782 Vicini FA, Vargas C, Abner A, et al. Limitations in the use of serum prostate specific antigen levels to monitor patients after treatment for prostate cancer. J Urol. 2005;173(5):1456-62. Excluded: Not an eligible intervention or outcome, OVID-Medline. [pmid: 15821460].
783 Vogel KJ, Atchley DP, Erlichman J, et al. BRCA1 and BRCA2 genetic testing in Hispanic patients: mutation prevalence and evaluation of the BRCAPRO risk assessment model. J Clin Oncol. 2007;25(29):4635-41. Excluded: Model does not categorize risk or validate, OVID-Medline. [pmid: 17925560].
784 Vogel VG, Graves DS, Vernon SW, et al. Mammographic screening of women with increased risk of breast cancer. Cancer. 1990;66(7):1613-20. Excluded: Family history not systematically collected, OVID-Medline. [pmid: 2208012].
785 Vogel VG. Can statin therapy reduce the risk of breast cancer?. J Clin Oncol. 2005;23(34):8553-5. Excluded: Not an eligible study design, OVID-Embase. [pmid: 16260689].
786 Vogel VG. Recent results from clinical trials using SERMs to reduce the risk of breast cancer. Ann N Y Acad Sci. 2006;1089:127-42. Excluded: Not an eligible study design, OVID-Medline. [pmid: 17261762].
787 Vogel VG. Chemoprevention in breast cancer. Cancer and Chemotherapy Reviews. 2007;2(1):33-40. Excluded: Not an eligible study design, OVID-Embase.
788 Von Roon AC, Karamountzos L, Purkayastha S, et al. Diagnostic precision of fecal calprotectin for inflammatory bowel disease and colorectal malignancy. Am J Gastroenterol. 2007;102(4):803-13. Excluded: Not an eligible study design, OVID-Embase. [pmid: 17324124].
789 Wade WM. Women receiving genetic counseling for breast cancer risk: Cancer worry, psychological distress, and risk recall accuracy. Dissertation Abstracts International: Section B: the Sciences and Engineering. 2001;61(7-b):2865. Excluded: Not an eligible publication type, OVID-Cochrane.
790 Wagner A, van Kessel I, Kriege MG, et al. Long term follow-up of HNPCC gene mutation carriers: compliance with screening and satisfaction with counseling and screening procedures. Fam Cancer. 2005;4(4):295-300. Excluded: Family history not systematically collected, OVID-Medline. [pmid: 16341806].
791 Wahlberg SS, Schmeits J, Thomas G, et al. Evaluation of microsatellite instability and immunohistochemistry for the prediction of germ-line MSH2 and MLH1 mutations in hereditary nonpolyposis colon cancer families. Cancer Res. 2002;62(12):3485-92. Excluded: Model does not categorize risk or validate, OVID-Medline. [pmid: 12067992].
792 Wainberg S, Husted J. Utilization of screening and preventive surgery among unaffected carriers of a BRCA1 or BRCA2 gene mutation. [Review] [27 refs]. Cancer Epidemiol Biomarkers Prev. 2004;13(12):1989-95. Excluded: Not an eligible intervention or outcome, OVID-Medline. [pmid: 15598752].
793 Walleser S, Griffiths A, Lord SJ, et al. What is the value of computered tomography colonography in patients screening positive for fecal occult blood? A systematic review and economic evaluation. [Review] [42 refs]. Clin Gastroenterol Hepatol. 1368;5(12):1439-46. Excluded: Not an eligible population, OVID-Medline.
794 Wallis M, Tarvidon A, Helbich T, et al. Guidelines from the European Society of Breast Imaging for diagnostic interventional breast procedures. Eur Radiol. 2007;17(2):581-8. Excluded: Not an eligible intervention or outcome, OVID-Embase. [pmid: 17013595].
795 Walsh JME, Posner SF, Perez-Stable EJ. Colon cancer screening in the ambulatory setting. Prev Med. 2002;35(3):209-18. Excluded: Family history not systematically collected, OVID-Embase. [pmid: 12202062].
796 Wampler NS, Saba L, Rahman SM, et al. Factors associated with adherence to recommendations for screening mammography among American Indian women in Colorado. Ethn Dis. 2006;16(4):808-14. Excluded: Family history not systematically collected, OVID-Medline. [pmid: 17061731].
797 Wane D, Lengacher CA. Integrative review of lycopene and breast cancer. Oncol Nurs Forum. 2006;33(1):127-37. Excluded: Not an eligible population, OVID-Cinahl. [pmid: 16470241].
798 Wang PH, Chao HT. A reconsideration of tamoxifen use for breast cancer. Taiwan J Obstet Gynecol. 2007;46(2):93-5. Excluded: Not an eligible study design, OVID-Embase. [pmid: 17638615].
799 Wang Y, Sun G, Pan JG, et al. Performance of tPSA and f/tPSA for prostate cancer in Chinese. A systematic review and meta-analysis. Prostate Cancer Prostatic Dis. 2006;9(4):374-8. Excluded: Not an eligible population, OVID-Medline. [pmid: 16926855].
800 Wang YP, Pan T, Yang JL, et al. Nonsteroidal anti-inflammatory drugs for prevention of colorectal neoplasms: A systematic review. Chinese Journal of Evidence-Based Medicine. 2005;5(6):438-43. Excluded: Not an eligible intervention or outcome, OVID-Embase.
801 Wardle J. Women at risk of ovarian cancer. J Natl Cancer Inst. 1995;Monographs(17):81-5. Excluded: Not an eligible publication type, OVID-Medline.
802 Warner E. Intensive radiologic surveillance: A focus on the psychological issues. Ann Oncol. 2004;15(SUPPL. 1):i43-i47. Excluded: Family history not systematically collected, OVID-Embase. [pmid: 15280187].
803 Warner E, Messersmith H, Causer P, et al. Systematic review: using magnetic resonance imaging to screen women at high risk for breast cancer. [Review] [35 refs]. Ann Intern Med. 2008;148(9):671-9. Excluded: Not an eligible population, OVID-Medline. [pmid: 18458280].
804 Wasvary HJ. Pathology features in Bethesda guidelines predict colorectal cancer microsatellite instability: A population-based study. Dis Colon Rectum. 2007;50(10):1732-3. Excluded: Model does not categorize risk or validate, OVID-Embase.
805 Watine JC, Bunting PS. Mass colorectal cancer screening: Methodological quality of practice guidelines is not related to their content validity. Clin Biochem. 2008;41(78):459-66. Excluded: Not an eligible intervention or outcome, OVID-Embase. [pmid: 18226597].
806 Watson M, Kash KM, Homewood J, Ebbs S, Murday V, Eeles R. Does genetic counseling have any impact on management of breast cancer risk?. Genetic Testing. 2005;9(2):167-174. Excluded: Not an eligible population, OVID-Embase. [pmid: 15943558].
807 Weik JL, Lum SS, Esquivel PA, et al. The Gail model predicts breast cancer in women with suspicious radiographic lesions. Am J Surg. 2005;190(4):526-9. Excluded: Model does not categorize risk or validate, OVID-Medline. [pmid: 16164914].
808 Weinberg AD, Cooper HP, Lane M, et al. Screening behaviors and long-term compliance with mammography guidelines in a breast cancer screening program. Am J Prev Med. 1997;13(1):29-35. Excluded: Family history not systematically collected, OVID-Medline. [pmid: 9037339].
809 Weinberg DS. In the clinic.Colorectal cancer screening. Ann Intern Med. 2008;148(3):ITC2-1-16. Excluded: Model does not categorize risk or validate, OVID-Cinahl. [pmid: 18252680].
810 Weinrich SP. Prostate cancer screening in high-risk men: African American Hereditary Prostate Cancer Study Network. Cancer. 2006;106(4):796-803. Excluded: Family history not systematically collected, OVID-Medline. [pmid: 16411222].
811 Weischer M, Bojesen SE, Ellervik C, et al. CHEK2*1100delC genotyping for clinical assessment of breast cancer risk: meta-analyses of 26,000 patient cases and 27,000 controls.[see comment]. [Review] [51 refs]. J Clin Oncol. 2008;26(4):542-8. Excluded: Not an eligible population, OVID-Medline. [pmid: 18172190].
812 Weitzel JN, Lagos VI, Cullinane CA, et al. Limited family structure and BRCA gene mutation status in single cases of breast cancer.[see comment]. JAMA. 2007;297(23):2587-95. Excluded: Model does not categorize risk or validate, OVID-Medline. [pmid: 17579227].
813 Weller DP, Owen N, Hiller JE, et al. Colorectal cancer and its prevention: prevalence of beliefs, attitudes, intentions and behaviour. Aust J Public Health. 1995;19(1):19-23. Excluded: Family history not systematically collected, OVID-Cinahl. [pmid: 7734587].
814 Wellisch DK, Lindberg NM. A psychological profile of depressed and nondepressed women at high risk for breast cancer. Psychosomatics. 2001;42(4):330-6. Excluded: Family history not systematically collected, OVID-Medline. [pmid: 11496022].
815 West DS, Greene PG, Kratt PP, et al. The impact of a family history of breast cancer on screening practices and attitudes in low-income, rural, African American women. J Womens Health (Larchmt). 2003;12(8):779-87. Excluded: Family history not systematically collected, OVID-Medline. [pmid: 14588128].
816 Wiernikowski J, Mohide EA. Review: adequately randomised trials showed that mammography screening did not significantly reduce breast cancer, cancer, or all cause mortality but increased breast surgeries. Evid Based Nurs. 2007;10(3):80. Excluded: Not an eligible study design, OVID-Cinahl. [pmid: 17596385].
817 Williams GL, Clarke P, Vellacott KD. Anxieties should not be forgotten when screening relatives of colorectal cancer patients by colonoscopy. Colorectal Dis. 2006;8(9):781-4. Excluded: Family history not systematically collected, OVID-Medline. [pmid: 17032325].
818 Winawer S, Fletcher R, Rex D, et al. Colorectal cancer screening and surveillance: clinical guidelines and rationale-Update based on new evidence. Gastroenterology. 2003;124(2):544-60. Excluded: Model does not categorize risk or validate, OVID-Medline. [pmid: 12557158].
819 Winawer SJ, Zauber AG, Fletcher RH, et al. Guidelines for colonoscopy surveillance after polypectomy: a consensus update by the US Multi-Society Task Force on Colorectal Cancer and the American Cancer Society. CA Cancer J Clin 184;56(3):143–59.
820 Winawer SJ. New post-polypectomy surveillance guidelines. Practical Gastroenterology. 2007;31(8):30-42. Excluded: Model does not categorize risk or validate, OVID-Embase.
821 Wolf B, Gruber S, Henglmueller S, et al. Efficiency of the revised Bethesda guidelines (2003) for the detection of mutations in mismatch repair genes in Austrian HNPCC patients. Int J Cancer. 2006;118(6):1465-70. Excluded: Model does not categorize risk or validate, OVID-Medline. [pmid: 16206289].
822 Wu TY, Guthrie BJ, Bancroft JM. An integrative review on breast cancer screening practice and correlates among Chinese, Korean, Filipino, and Asian Indian American women.[erratum appears in Health Care Women Int. 2005 Oct;26(9):877. Health Care for Women Int. 2005;26(3):225-46. Excluded: Not an eligible intervention or outcome, OVID-Medline.
823 Wullenweber HP, Sutter C, Autschbach F, et al. Evaluation of Bethesda guidelines in relation to microsatellite instability. Dis Colon Rectum. 2001;44(9):1281-9. Excluded: Model does not categorize risk or validate, OVID-Medline. [pmid: 11584201].
824 Yan L, Spitznagel EL. Meta-analysis of soy food and risk of prostate cancer in men. Int J Cancer. 2005;117(4):667-9. Excluded: Not an eligible intervention or outcome, OVID-Embase. [pmid: 15945102].
825 Yang K, Allen B, Conrad P, et al. Awareness of gynecologic surveillance in women from hereditary non-polyposis colorectal cancer families. Fam Cancer. 2006;5(4):405-9. Excluded: Not an eligible study design, OVID-Medline. [pmid: 16937235].
826 Yasui Y, Newcomb PA, Trentham-Dietz A, et al. Familial relative risk estimates for use in epidemiologic analyses. Am J Epidemiol. 2006;164(7):697-705. Excluded: Model does not categorize risk or validate, OVID-Medline. [pmid: 16923773].
827 Yin LY, Wai KL, Chuan TN, et al. Factors influencing women undertaking screening mammography in primary care in Singapore. Singapore Nurs J. 2007;34(3):74-80. Excluded: Family history not systematically collected, OVID-Cinahl.
828 Yokoe T, Takei H, Horiguchi J, et al. Family history in participants of breast cancer screening. Oncol Rep. 1997;4(5):973-6. Excluded: Family history not systematically collected, OVID-Embase.
829 Yossepowitch O, Eggener SE, Bianco FJ, Jr., et al. Radical prostatectomy for clinically localized, high risk prostate cancer: critical analysis of risk assessment methods. J Urol 499;178(2):493–9. Excluded: Family history not systematically collected, OVID-Medline.
830 Zakowski SG, Valdimarsdottir HB, Bovbjerg DH, et al. Predictors of intrusive thoughts and avoidance in women with family histories of breast cancer. Ann Behav Med. 1997;19(4):362-9. Excluded: Family history not systematically collected, OVID-PsycInfo. [pmid: 9706363].
831 Zakowski SG, Valdimarsdottir HB, Bovbjerg DH. Emotional expressivity and intrusive cognitions in women with family histories of breast cancer: Application of a cognitive processing model. Br J Health Psychol. 2001;6(2):151-65. Excluded: Family history not systematically collected, OVID-PsycInfo. [pmid: 14596731].
832 Zaloudik J, Coufal O, Kocakova I, et al. Chemoprevention of colorectal carcinoma in high-risk patients. Acta Univ Palacki Olomuc Fac Med. 2000;143:109. Excluded: Family history not systematically collected, OVID-Medline.
833 Zapka J, Fisher G, Lemon S, et al. Relationship and distress in relatives of breast cancer patients. Families, Systems and Health. 2006;24(2):198-212. Excluded: Family history not systematically collected, OVID-Embase.
834 Zapka JG, Stoddard A, Maul L, et al. Interval adherence to mammography screening guidelines. Med Care. 1991;29(8):697-707. Excluded: Family history not systematically collected, OVID-Medline. [pmid: 1875738].
835 Zapka JG, Hosmer D, Costanza ME, et al. Changes in mammography use: economic, need, and service factors. Am J Public Health. 1992;82(10):1345-51. Excluded: Family history not systematically collected, OVID-Medline. [pmid: 1415857].
836 Zhou B, Yang L, Wang L, et al. The association of tea consumption with ovarian cancer risk: A metaanalysis. Am J Obstet Gynecol. 2007;197(6):594-6. Excluded: Not an eligible population, OVID-Medline. [pmid: 17905170].
837 Zhou B, Sun Q, Cong R, et al. Hormone replacement therapy and ovarian cancer risk: A meta-analysis. Gynecol Oncol. 2008;108:641-51. Excluded: Not an eligible population, OVID-Embase. [pmid: 18221779].
838 Zwick YC. Outlining a pan-European colon cancer screening programme. Z Gastroenterol. 2008;46(Suppl.1):S52-S53. Excluded: Not an eligible publication type, OVID-Embase.