# Appendix C - Studies Retained But Not Extracted

Table 1 Eligible Studies Extracted and Those Retained But Not Extracted

Retained But Not Extracted | Superseded by (extracted)
Huang 2006 ^1^ Huang 2006 ^2^ | Bardia 2008 ^3^
Moayyedi 2006 ^4^ | Hewitson 2007 ^5^
Walsh 2003 ^6^ | Hewitson 2007 ^5^
Bonovas 2007 ^7^ Bonovas 2005 ^8^ | Browning 2007 ^9^
Hoffmeister 2006 ^10^ | Dubé 2007 ^11^
Asano 2004 ^12^ | Dubé 2007 ^11^
Coulter 2006 ^13^ | Alkhenizan 2007 ^14^
Dale 2006 ^15^ | Browning 2007 ^9^
Heresbach 2006 ^16^ | Hewitson 2007 ^5^
Hackshaw 2003 ^17^ | Kosters 2003 ^18^
| Gotzsche 2006 ^19^
| Kerr 2007 ^20^
| Bristol SLR Team 2006 ^21^
| Ilic 2006 ^22^
Eligible, but did not report usable data
Dutch Review Team, Bakker 2006 ^23^
Italian Review Team, Agnoli 2005 ^24^
Eligible, but no eligible intervention studies identified
Mahmud 2004 ^25^
Rostom 2007 ^26^
Weingarten 2008 ^27^
Brett 2005 ^28^
Watson 2005 ^29^

## Appendix C - Eligible Studies Extracted and Those Retained But Not Extracted

1 Huang HY, Caballero B, Chang S et al. Multivitamin/mineral supplements and prevention of chronic disease. Evid Rep Technol Assess No.139, AHRQ Publication No.06-E012. (Prepared by The Johns Hopkins University Evidence-based Practice Center under Contract No.290-02-0018). Rockville, MD: Agency for Healthcare Research and Quality; 2006 May. [underlined: PM:17764205]
2 Huang HY, Caballero B, Chang S, et al. The efficacy and safety of multivitamin and mineral supplement use to prevent cancer and chronic disease in adults: a systematic review for a National Institutes of Health state-of-the-science conference. [Review] [44 refs]. Ann Intern Med. 2006;145(5):372-85. [pmid: 16880453].
3 Bardia A, Tleyjeh IM, Cerhan JR, et al. Efficacy of antioxidant supplementation in reducing primary cancer incidence and mortality: systematic review and meta-analysis. [Review] [73 refs]. Mayo Clin Proc. 2008;83(1):23-34. [pmid: 18173999].
4 Moayyedi P, Achkar E. Does fecal occult blood testing really reduce mortality? A reanalysis of systematic review data. [Review] [25 refs]. Am J Gastroenterol. 2006;101(2):380-4. [pmid: 16454847].
5 Hewitson P, Glasziou P, Irwig L, et al. Screening for colorectal cancer using the faecal occult blood test, Hemoccult. “update of Cochrane Database Syst Rev. 2000;(2):CD001216; PMID: 10796760”. [Review][46 refs]. Cochrane Database Syst Rev 2007;(1):CD001216
6 Walsh JM, Terdiman JP. Colorectal cancer screening: scientific review. [Review] [105 refs]. JAMA. 2003;289(10):1288-96. [pmid: 12633191].
7 Bonovas S, Filioussi K, Flordellis CS, et al. Statins and the risk of colorectal cancer: a meta-analysis of 18 studies involving more than 1.5 million patients. J Clin Oncol. 2007;25(23):3462-8. [pmid: 17687150].
8 Bonovas S, Filioussi K, Tsavaris N, et al. Use of statins and breast cancer: A meta-analysis of seven randomized clinical trials and nine observational studies. J Clin Oncol. 2005;23(34):8606-12. [pmid: 16260694].
9 Browning DR, Martin RM. Statins and risk of cancer: A systematic review and metaanalysis. Int J Cancer. 2007;120(4):833-43. [pmid: 17131313].
10 Hoffmeister M, Chang-Claude J, Brenner H. Do older adults using NSAIDs have a reduced risk of colorectal cancer?. Drugs Aging. 2006;23(6):513-23. [pmid: 16872234].
11 Dube C, Rostom A, Lewin G, et al. The use of aspirin for primary prevention of colorectal cancer: a systematic review prepared for the U.S. Preventive Services Task Force. Ann Intern Med. 2007;146(5):365-75. [pmid: 17339622].
12 Asano TK, McLeod RS. Nonsteroidal anti-inflammatory drugs and aspirin for the prevention of colorectal adenomas and cancer: a systematic review. [Review] [45 refs]. Dis Colon Rectum. 2004;47(5):665-73. [pmid: 15054679].
13 Coulter ID, Hardy ML, Morton SC, et al. Antioxidants Vitamin C and Vitamin E for the Prevention and Treatment of Cancer. J Gen Intern Med. 2006;21(7):735-44. [pmid: 16808775].
14 Alkhenizan A, Hafez K. The role of vitamin E in the prevention of cancer: a meta-analysis of randomized controlled trials. Ann Saudi Med. 2007;27(6):409-14. [pmid: 18059122].
15 Dale KM, Coleman CI, Henyan NN, et al. Statins and cancer risk: a meta-analysis. JAMA. 2006;295(1):74-80. [pmid: 16391219].
16 Heresbach D, Manfredi S, D'halluin PN, et al. Review in depth and meta-analysis of controlled trials on colorectal cancer screening by faecal occult blood test. [Review] [61 refs]. Eur J Gastroenterol Hepatol. 2006;18(4):427-33. [pmid: 16538116].
17 Hackshaw AK, Paul EA. Breast self-examination and death from breast cancer: a meta-analysis. Br J Cancer. 2003;88(7):1047-53. [pmid: 12671703].
18 Kosters JP, Gotzsche PC. Regular self-examination or clinical examination for early detection of breast cancer [Review][24 refs]. Cochrane Database Syst Rev 2003;(2):CD003373
19 Gotzsche PC, Nielsen M. Screening for breast cancer with mammography. Cochrane Database Syst Rev 2006;(4):CD001877
20 Kerr J, Day P, Broadstock M, et al. Systematic review of the effectiveness of population screening for colorectal cancer. [Review] [28 refs]. N Z Medl Jl. 2007;120(1258):U2629.
21 Bristol SLR Team 2006. Systematic Literature Review Report. The associations between food, nutrition, physical activity and the risk of prostate cancer and underlying mechanisms. World Cancer Research Fund/American Institute for Cancer Research, Food, Nutrition, Physical Activity, and the Prevention of Cancer: a Global Perspective. Washington, DC: 2006 Jun 30.
22 Ilic D, O'Connor D, Green S, et al. Screening for prostate cancer. Cochrane Database Syst Rev 2006; Issue 3, Art.No.: CD004720.DOI:10.1002/14651858.CD004720.pub2:
23 Dutch Review Team 2006. Systematic Literature Review Report. The associations between food, nutrition and physical activity and the risk of colorectal cancer and underlying mechanisms. World Cancer Research Fund/American Institute for Cancer Research, Food, Nutrition, Physical Activity, and the Prevention of Cancer: a Global Perspective. Washington, DC: 2007.
24 Italian Review Team 2005. Systematic Literature Review Report. The Associations between Food, Nutrition and Physical Activity and the Risk of Breast Cancer and Underlying Mechanisms. World Cancer Research Fund/American Institute for Cancer Research, Food, Nutrition, Physical Activity, and the Prevention of Cancer: a Global Perspective. Washington, DC: 2007.
25 Mahmud S, Franco E, Aprikian A. Prostate cancer and use of nonsteroidal anti-inflammatory drugs: systematic review and meta-analysis. [Review] [43 refs]. Br J Cancer. 2004;90(1):93-9. [pmid: 14710213].
26 Rostom A, Dube C, Lewin G, et al. Nonsteroidal anti-inflammatory drugs and cyclooxygenase-2 inhibitors for primary prevention of colorectal cancer: a systematic review prepared for the U.S. Preventive Services Task Force. Ann Intern Med. 2007;146(5):376-89. [pmid: 17339623].
27 Weingarten MA, Zalmanovici A, Yaphe J. Dietary calcium supplementation for preventing colorectal cancer and adenomatous polyps. “update of Cochrane Database Syst Rev. 2005;(3):CD003548; PMID: 16034903”. [Review][38 refs]. Cochrane Database Syst Rev 2008;(1):CD003548
28 Brett J, Bankhead C, Henderson B, et al. The psychological impact of mammographic screening. A systematic review. [Review] [74 refs]. Psychooncology. 2005;14(11):917-38. [pmid: 15786514].
29 Watson EK, Henderson BJ, Brett J, et al. The psychological impact of mammographic screening on women with a family history of breast cancer—a systematic review. [Review] [26 refs]. Psychooncology. 2005;14(11):939-48. [pmid: 15744777].