# Appendix B - Forms and Guides

To view the Forms and Guides, please select the link below. This link will take you to a PDF of the Forms and Guides.

Forms and Guides