# Appendix A - Search Strategies Detailed

## Question 1

### Ovid-MEDLINE

1 claus.tw.
2 gail.tw.
3 BRCAPRO.tw.
4 BOADICEA.tw.
5 UK cancer family study group.tw.
6 UKCFSG.tw.
7 Myriad.ti,ab.
8 tyrer Cuzick.ti,ab.
9 ((Amsterdam or Bethesda or Manchester or Gilpin or Evans or Frank or Finnish or Yale or Spanish) adj5 (criteria or guideline? or scor$ or model? or protocol? or algorithm?)).ti,ab.
10 FHAT.ti,ab.
11 (Australia adj5 breast cancer cent$).tw.
12 couch.ti,ab.
13 ((mendel or LAMBDA) adj5 (criteria or guideline? or scor$ or model? or protocol? or algorithm?)).ti,ab.
14 (Dutch guideline adj7 breast).ti,ab.
15 (nice guideline? and breast cancer).ti,ab.
16 or/1–15
17 models, statistical/
18 models, theoretical/ or models, genetic/
19 17 or 18
20 genes, brca1/ or genes, brca2/
21 BRCA$.tw.
22 20 or 21
23 19 and 22
24 16 or 23
25 exp breast neoplasms/ or exp colorectal neoplasms/ or exp ovarian neoplasms/ or exp prostatic neoplasms/
26 ((breast or ovar$ or prostate or colon or colorectal) adj3 (cancer$ or neoplasm$ or carcinom$ or tumo?r$)).ti,ab.
27 *Neoplasms/
28 or/25–27
29 validation.ti.
30 accuracy.ti.
31 validation studies/
32 evaluation studies/
33 exp “Sensitivity and Specificity”/
34 “reproducibility of results”/
35 odds ratio/
36 multivariate analysis/
37 exp Probability/
38 predictive value?.ti,ab.
39 or/29–38
40 24 and 28 and 39
41 animals/ not (humans/ and animals/)
42 40 not 41
43 limit 42 to english language
44 limit 43 to yr=“1990 - 2008”
45 Breast Neoplasms/
46 exp Colorectal Neoplasms/
47 exp Prostatic Neoplasms/
48 exp Ovarian Neoplasms/
49 ((breast or ovar$ or prostate or colon or colorectal) adj3 (cancer$ or neoplasm$ or carcinom$)).ti,ab.
50 or/45–49
51 exp Mass Screening/
52 (surveillance or screening).ti.
53 Primary Prevention/
54 Preventive Medicine/
55 prophylactic.ti.
56 prevention.ti.
57 (genetic adj2 (counsel?ing or test$)).ti.
58 Risk Assessment/
59 (risk adj (assessment? or stratification)).ti.
60 Preventive Health Services/
61 or/51–60
62 exp Pedigree/
63 limit 62 to humans
64 exp Medical History Taking/
65 ((family or familial) adj3 (histor$ or history-taking or risk$)).ti,ab.
66 anamnesis.ti.
67 (human adj2 pedigree).ti,ab.
68 (genetic adj2 (risk adj3 (assessment or evaluation))).ti,ab.
69 genogram$.ti,ab.
70 ((famil$ or heredi$ or inherit$) adj3 (cancer$ or carcinom$ or neoplasm$)).ti,ab.
71 (genetic adj2 (screening or test$)).ti,ab.
72 Family Health/
73 or/63–72
74 exp Neoplasms/
75 (neoplasm? or carcinoma? or cancer?).ti.
76 74 or 75
77 guideline.pt.
78 practice guideline.pt.
79 guideline?.ti.
80 or/77–79
81 73 and 76 and 80
82 50 and 61 and 80
83 81 or 82
84 (note or comment or editorial).pt.
85 83 not 84
86 limit 85 to english language
87 limit 86 to yr=“2003 - 2008”
88 44 or 87

### Ovid-EMBASE

1 claus.tw.
2 gail.tw.
3 BRCAPRO.tw.
4 BOADICEA.tw.
5 UK cancer family study group.tw.
6 UKCFSG.tw.
7 Myriad.ti,ab.
8 tyrer Cuzick.ti,ab.
9 ((Amsterdam or Bethesda or Manchester or Gilpin or Evans or Frank or Finnish or Yale or Spanish) adj5 (criteria or guideline? or scor$ or model? or protocol? or algorithm?)).ti,ab.
10 FHAT.ti,ab.
11 (Australia adj5 breast cancer cent$).tw.
12 couch.ti,ab.
13 ((mendel or LAMBDA) adj5 (criteria or guideline? or scor$ or model? or protocol? or algorithm?)).ti,ab.
14 (Dutch guideline adj7 breast).ti,ab.
15 (nice guideline? and breast cancer).ti,ab.
16 or/1–15
17 MATHEMATICAL MODEL/ or STATISTICAL MODEL/ or CANCER MODEL/ or GENETIC MODEL/
18 GENETIC ALGORITHM/ or ALGORITHM/
19 or/17–18
20 Brca1 Protein/ or Brca2 Protein/
21 oncogene/
22 brca2 gene/
23 BRCA$.tw.
24 or/20–23
25 19 and 24
26 exp breast neoplasms/ or exp colorectal neoplasms/ or exp ovarian neoplasms/ or exp prostatic neoplasms/
27 ((breast or ovar$ or prostate or colon or colorectal) adj3 (cancer$ or neoplasm$ or carcinom$ or tumo?r$)).ti,ab.
28 *Neoplasms/
29 or/26–28
30 16 or 25
31 29 and 30
32 validation.ti.
33 accuracy.ti.
34 agreement.ti.
35 VALIDATION STUDY/ or INSTRUMENT VALIDATION/ or VALIDATION PROCESS/
36 diagnostic accuracy/
37 exp statistical parameters/
38 prediction/
39 “SENSITIVITY AND SPECIFICITY”/
40 predictive value?.ti,ab.
41 or/32–40
42 31 and 41
43 limit 42 to human
44 limit 43 to english language
45 limit 44 to yr=“1990 - 2008”
46 exp Neoplasms/
47 (neoplasm? or carcinoma? or cancer?).ti.
48 46 or 47
49 exp Breast Cancer/
50 exp Colon Cancer/
51 exp Ovary Cancer/
52 exp Prostate Cancer/
53 ((breast or ovar$ or prostate or colon or colorectal) adj3 (cancer$ or neoplasm$ or carcinom$ or tumo?r$)).ti,ab.
54 or/49–53
55 exp anamnesis/
56 ((family or familial) adj3 (histor$ or history-taking or risk$)).ti,ab.
57 anamnesis.ti.
58 (human adj2 pedigree).ti,ab.
59 (genetic adj2 (risk adj3 (assessment or evaluation))).ti,ab.
60 ((famil$ or heredi$ or inherit$) adj3 (cancer$ or carcinom$ or neoplasm$ or tumo?r$)).ti,ab.
61 (genetic adj2 (screening or test$)).ti,ab.
62 genogram$.ti,ab.
63 or/55–62
64 prevention/ or primary prevention/ or prophylaxis/ or breast care/ or cancer prevention/ or chemoprophylaxis/ or periodic medical examination/ or personal monitoring/ or secondary prevention/
65 screening/ or screening test/ or mass screening/ or cancer screening/ or genetic screening/
66 risk/ or genetic risk/ or risk assessment/ or risk factor/ or risk management/ or risk reduction/
67 preventive medicine/
68 preventive health service/
69 prevention.ti.
70 prophylactic.ti.
71 or/64–70
72 (note or comment or editorial).pt.
73 practice guideline/
74 guideline?.ti.
75 73 or 74
76 48 and 63 and 75
77 54 and 71 and 75
78 76 or 77
79 78 not 72
80 limit 79 to human
81 limit 80 to english language
82 limit 81 to yr=“2003 - 2008”
83 45 or 82

### Ovid-CINAHL

1 claus.tw.
2 gail.tw.
3 BRCAPRO.tw.
4 BOADICEA.tw.
5 UK cancer family study group.tw.
6 UKCFSG.tw.
7 Myriad.ti,ab.
8 tyrer Cuzick.ti,ab.
9 ((Amsterdam or Bethesda or Manchester or Gilpin or Evans or Frank or Finnish or Yale or Spanish) adj5 (criteria or guideline? or scor$ or model? or protocol? or algorithm?)).ti,ab.
10 FHAT.ti,ab.
11 (Australia adj5 breast cancer cent$).tw.
12 couch.ti,ab.
13 ((mendel or LAMBDA) adj5 (criteria or guideline? or scor$ or model? or protocol? or algorithm?)).ti,ab.
14 (Dutch guideline adj7 breast).ti,ab.
15 (nice guideline? and breast cancer).ti,ab.
16 or/1–15
17 practice guidelines.pt.
18 Practice Guidelines/
19 guidelines.ti,ab.
20 or/17–19
21 exp Medical History Taking/
22 exp Family Health/
23 exp Pedigree/
24 ((family or familial) adj3 (histor$ or history-taking or risk$)).ti,ab.
25 anamnesis.ti,ab.
26 (human adj2 pedigree).ti,ab.
27 (genetic adj2 (risk adj3 (assessment or evaluation))).ti,ab.
28 ((famil$ or heredi$ or inherit$) adj3 (cancer$ or carcinom$ or neoplasm$ or tumo?r$)).ti,ab.
29 or/21–28
30 exp Breast Neoplasms/
31 exp Colorectal Neoplasms/
32 exp Ovarian Neoplasms/
33 exp Prostatic Neoplasms/
34 ((breast or ovar$ or prostate or colon or colorectal) adj3 (cancer$ or neoplasm$ or carcinom$ or tumo?r$)).ti,ab.
35 or/30–34
36 cancer screening/ or genetic screening/
37 (surveillance or screening).ti.
38 Preventive Health Care/
39 Chemoprevention/
40 Risk Assessment/
41 prophylactic.ti.
42 prevention.ti.
43 (gentic adj2 (counsel?ing or test$ or screen$)).ti.
44 Genetic Counseling/
45 (risk adj (assessment? or stratification)).ti.
46 or/36–45
47 exp Neoplasms/
48 (neoplasm? or carcinoma? or cancer?).ti.
49 or/47–48
50 20 and 29 and 49
51 20 and 35 and 46
52 50 or 51
53 limit 52 to (book chapter or case study or commentary or editorial)
54 52 not 53
55 limit 54 to english
56 limit 55 to yr=“2000 - 2008”
57 limit 55 to yr=“2003 - 2008”
58 models, theoretical/ or models, statistical/
59 Genes, BRCA/
60 BRCA$.tw.
61 59 or 60
62 58 and 61
63 16 or 62
64 exp breast neoplasms/ or exp colorectal neoplasms/ or exp ovarian neoplasms/ or exp prostatic neoplasms/
65 ((breast or ovar$ or prostate or colon or colorectal) adj3 (cancer$ or neoplasm$ or carcinom$ or tumo?r$)).ti,ab.
66 64 or 65
67 63 and 66
68 limit 67 to english
69 (book chapter or case study or commentary or editorial).pt.
70 68 not 69
71 limit 70 to yr=“1990 - 2008”
72 57 or 71

### Ovid-CCRT

1 claus.tw.
2 gail.tw.
3 BRCAPRO.tw.
4 BOADICEA.tw.
5 UK cancer family study group.tw.
6 UKCFSG.tw.
7 Myriad.ti,ab.
8 tyrer Cuzick.ti,ab.
9 ((Amsterdam or Bethesda or Manchester or Gilpin or Evans or Frank or Finnish or Yale or Spanish) adj5 (criteria or guideline? or scor$ or model? or protocol? or algorithm?)).ti,ab.
10 FHAT.ti,ab.
11 (Australia adj5 breast cancer cent$).tw.
12 couch.ti,ab.
13 ((mendel or LAMBDA) adj5 (criteria or guideline? or scor$ or model? or protocol? or algorithm?)).ti,ab.
14 (Dutch guideline adj7 breast).ti,ab.
15 (nice guideline? and breast cancer).ti,ab.
16 or/1–15
17 models, statistical/
18 models, theoretical/ or models, genetic/
19 17 or 18
20 genes, brca1/ or genes, brca2/
21 BRCA$.tw.
22 20 or 21
23 19 and 22
24 16 or 23
25 exp breast neoplasms/ or exp colorectal neoplasms/ or exp ovarian neoplasms/ or exp prostatic neoplasms/
26 ((breast or ovar$ or prostate or colon or colorectal) adj3 (cancer$ or neoplasm$ or carcinom$ or tumo?r$)).ti,ab.
27 *Neoplasms/
28 or/25–27
29 validation.ti.
30 accuracy.ti.
31 validation studies/
32 evaluation studies/
33 exp “Sensitivity and Specificity”/
34 “reproducibility of results”/
35 odds ratio/
36 multivariate analysis/
37 exp Probability/
38 predictive value?.ti,ab.
39 or/29–38
40 24 and 28 and 39
41 limit 40 to yr=“1990 - 2008”
42 Breast Neoplasms/
43 exp Colorectal Neoplasms/
44 exp Prostatic Neoplasms/
45 exp Ovarian Neoplasms/
46 ((breast or ovar$ or prostate or colon or colorectal) adj3 (cancer$ or neoplasm$ or carcinom$)).ti,ab.
47 or/42–46
48 exp Mass Screening/
49 (surveillance or screening).ti.
50 Primary Prevention/
51 Preventive Medicine/
52 prophylactic.ti.
53 prevention.ti.
54 (genetic adj2 (counsel?ing or test$)).ti.
55 Risk Assessment/
56 (risk adj (assessment? or stratification)).ti.
57 Preventive Health Services/
58 or/48–57
59 exp Pedigree/
60 limit 59 to humans
61 exp Medical History Taking/
62 ((family or familial) adj3 (histor$ or history-taking or risk$)).ti,ab.
63 anamnesis.ti.
64 (human adj2 pedigree).ti,ab.
65 (genetic adj2 (risk adj3 (assessment or evaluation))).ti,ab.
66 genogram$.ti,ab.
67 ((famil$ or heredi$ or inherit$) adj3 (cancer$ or carcinom$ or neoplasm$)).ti,ab.
68 (genetic adj2 (screening or test$)).ti,ab.
69 Family Health/
70 or/60–69
71 exp Neoplasms/
72 (neoplasm? or carcinoma? or cancer?).ti.
73 71 or 72
74 guideline.pt.
75 practice guideline.pt.
76 guideline?.ti.
77 or/74–76
78 70 and 73 and 77
79 47 and 58 and 77
80 78 or 79
81 (note or comment or editorial).pt.
82 80 not 81
83 limit 82 to yr=“2003 - 2008”
84 41 or 83

## Question 2

### Ovid-MEDLINE

1 exp Diet Therapy/ or exp Nutrition Physiology/ or exp Nutritional Sciences/
2 (diet or diets or dietetic or dietary or eating or intake or nutrient$ or nutrition or vegetarian$ or vegan$ or “seventh day adventist” or macrobiotic or breastfeed$ or breast feed$ or breastfed or breast fed or breastmilk or breast milk).ti,ab.
3 exp “food and beverages”/
4 (food$ or cereal$ or grain$ or granary or wholegrain or wholewheat or roots or plantain$ or tuber or tubers or vegetable$ or fruit$ or pulses or beans or lentils or chickpeas or legume$ or soy or soya or nut or nuts or peanut$ or groundnut$ or seeds or meat or beef or pork or lamb or poultry or chicken or turkey or duck or fish or fat or fats or fatty or egg or eggs or bread or oils or shellfish or seafood or sugar or syrup or dairy or milk or herbs or spices or chilli or chillis or pepper$ or condiments).ti,ab.
5 (fluid intake or water or drinks or drinking or tea or coffee or caffeine or juice or beer or spirits or liquor or wine or alcohol or alcoholic or beverage$ or ethanol or yerba mate or ilex paraguariensis).ti,ab.
6 fertilizers/ or exp pesticides/ or Veterinary Drugs/
7 (pesticide$ or herbicide$ or DDT or fertiliser$ or fertilizer$ or organic or contaminants or contaminate$ or veterinary drug$ or polychlorinated dibenzofuran$ or PCDF$ or polychlorinated dibenzodioxin$ or PCDD$ or polychlorinated biphenyl$ or PCB$ or cadmium or arsenic or chlorinated hydrocarbon$ or microbial contamination$).ti,ab.
8 exp Food Preservation/
9 (mycotoxin$ or aflatoxin$ or pickled or bottled or bottling or canned or canning or vacuum pack$ or refrigerate$ or refrigeration or cured or smoked or preserved or preservatives or nitrosamine or hydrogenation or fortified or additive$ or colouring$ or coloring$ or flavouring$ or flavoring$ or nitrates or nitrites or solvent or solvents or ferment$ or processed or antioxidant$ or genetic modif$ or genetically modif$ or vinyl chloride or packaging or labelling or phthalates).ti,ab.
10 Cookery/
11 (cooking or cooked or grill or grilled or fried or fry or roast or bake or baked or stewing or stewed or casserol$ or broil or broiled or boiled or microwave or microwaved or re-heating or reheating or heating or re-heated or heated or poach or poached or steamed or barbecue$ or chargrill$ or heterocyclic amines or polycyclic aromatic hydrocarbons).ti,ab.
12 exp Dietary Carbohydrates/ or exp Dietary Proteins/ or exp Sweetening Agents/
13 (salt or salting or salted or fiber or fibre or polysaccharide$ or starch or starchy or carbohydrate$ or lipid$ or linoleic acid$ or sterols or stanols or sugar$ or sweetener$ or saccharin$ or aspartame or acesulfame or cyclamates or maltose or mannitol or sorbitol or sucrose or xylitol or cholesterol or protein or proteins or hydrogenated dietary oils or hydrogenated lard or hydrogenated oils).ti,ab.
14 exp Vitamins/
15 (supplements or supplement or vitamin$ or retinol or carotenoid$ or tocopherol or folate$ or folic acid or methionine or riboflavin or thiamine or niacin or pyridoxine or cobalamin or mineral$ or sodium or iron or calcium or selenium or iodine or magnesium or potassium or zinc or copper or phosphorus or manganese or chromium or phytochemical or allium or isothiocyanate$ or glucosinolate$ or indoles or polyphenol$ or phytoestrogen$ or genistein or saponin$ or coumarin$).ti,ab.
16 Physical Fitness/ or exp Exertion/ or exp Physical Endurance/ or Walking/
17 (recreational activit$ or household activit$ or occupational activit$ or physical activit$ or physical inactivit$ or exercise or exercising or energy intake or energy expenditure or energy balance or energy density).ti,ab.
18 exp Growth/ or exp Anthropometry/ or exp Body Composition/ or exp Body Constitution/
19 (weight loss or weight gain or anthropometry or birth weight or birthweight or birth-weight or child development or height or body composition or body mass or BMI or obesity or obese or overweight or over-weight or over weight or skinfold measurement$ or skinfold thickness or DEXA or bio-impedence or waist circumference or hip circumference or waist hip ratio$).ti,ab.
20 or/1–19
21 animals/ not (humans/ and animals/)
22 20 not 21
23 meta-analysis.pt,ti,ab,sh.
24 (meta anal$ or metaanal$).ti,ab,sh.
25 ((methodol$ or systematic$ or quantitativ$) adj3 (review$ or overview$ or survey$)).ti,ab,sh.
26 (medline or embase or index medicus).ti,ab.
27 ((pool$ or combined or combining) adj (data or trials or studies or results)).ti,ab.
28 25 or 26 or 27
29 review.pt,sh.
30 28 and 29
31 23 or 24
32 30 or 31
33 exp Neoplasms/pc “Prevention & Control”
34 ((cancer or carcinoma$ or neoplasm$) adj3 (prevent$ or reduc$)).tw.
35 Breast Neoplasms/
36 exp Colorectal Neoplasms/
37 exp Ovarian Neoplasms/
38 exp Prostatic Neoplasms/
39 ((breast or ovar$ or prostate or colon or colorectal) adj3 (cancer$ or neoplasm$ or carcinom$ or tumo?r$)).ti,ab.
40 or/33–39
41 22 and 32 and 40
42 limit 41 to english language
43 limit 42 to ed=20060101-20080425

### Ovid-Medline

1 Mass Screening/
2 Smoking Cessation/
3 Alcohol Drinking/
4 Chemoprevention/
5 chemoprevention.ti.
6 (surveillance or screening).ti.
7 Primary Prevention/
8 Preventive Medicine/
9 Preventive Health Services/
10 (prophylactic or preventive or risk reduc$).ti.
11 risk reduction behavior/
12 “Referral and Consultation”/
13 medical consultation.ti.
14 (health adj3 consultation).ti.
15 or/1–14
16 Breast Neoplasms/
17 exp Colorectal Neoplasms/
18 exp Prostatic Neoplasms/
19 exp Ovarian Neoplasms/
20 ((breast or ovar$ or prostate or colon or colorectal) adj3 (cancer$ or neoplasm$ or carcinom$)).ti,ab.
21 or/16–20
22 self exam$.ti.
23 Breast Self-Examination/
24 exp Mammography/
25 mammog$.ti.
26 Ovariectomy/
27 risk reduction mastectomy.ti.
28 ((prophylactic or preventive or risk reduc$) adj3 (mastectomy or oophorectomy or ovariectomy)).tw.
29 ((magnetic resonance imaging or mri) adj3 breast).ti.
30 breast exam$.ti.
31 (ovarian adj3 screening).ti.
32 exp Contraceptives, Oral/
33 tamoxifen/ or raloxifene/ or toremifene/
34 (tamoxifen or raloxifene or toremifene or fareston).ti.
35 or/22–34
36 Breast Neoplasms/
37 (breast adj3 (cancer$ or neoplasm$ or carcinom$)).ti.
38 exp Ovarian Neoplasms/
39 (ovar$ adj3 (cancer$ or neoplasm$ or carcinom$)).ti.
40 or/36–39
41 35 and 40
42 Fenretinide/
43 Finasteride/
44 (Fenretinide or Finasteride or proscar).ti.
45 Digital Rectal Examination/
46 Toremifene/
47 fareston.ti.
48 (avodart or dutasteride).ti.
49 Prostate-Specific Antigen/
50 (psa adj3 test$).ti.
51 prostate specific antigen.ti.
52 or/42–51
53 exp Prostatic Neoplasms/
54 (prostat$ adj3 (cancer$ or neoplasm$ or carcinom$)).ti.
55 or/53–54
56 52 and 55
57 Digital Rectal Examination/
58 f?ecal occult blood test$.ti.
59 (FOBT or fob test$).ti.
60 colonoscopy/ or sigmoidoscopy/
61 (sigmoidoscopy or colonoscopy).ti.
62 Hormone Replacement Therapy/
63 hrt.ti.
64 exp Anti-Inflammatory Agents, Non-Steroidal/
65 NSAID?.ti.
66 (nonsteroidal adj3 inflammatory).ti.
67 exp Hydroxymethylglutaryl-CoA Reductase Inhibitors/
68 HMG-CoA reductase inhibitors.ti.
69 statins.ti.
70 or/57–69
71 exp Colorectal Neoplasms/
72 ((colon or colorectal) adj3 (cancer$ or neoplasm$ or carcinom$)).ti,ab.
73 or/71–72
74 70 and 73
75 genetic services/ or genetic counseling/ or genetic screening/
76 21 and 75
77 15 and 21
78 41 or 56 or 74 or 76 or 77
79 meta-analysis.pt,ti,ab,sh.
80 (meta anal$ or metaanal$).ti,ab,sh.
81 ((methodol$ or systematic$ or quantitativ$) adj3 (review$ or overview$ or survey$)).ti.
82 ((methodol$ or systematic$ or quantitativ$) adj3 (review$ or overview$ or survey$)).ab.
83 (medline or embase or index medicus).ti,ab.
84 ((pool$ or combined or combining) adj (data or trials or studies or results)).ti,ab.
85 or/82–84
86 review.pt,sh.
87 85 and 86
88 79 or 80 or 81 or 87
89 78 and 88
90 limit 89 to english language
91 limit 90 to yr=“2000 - 2008”
92 limit 90 to yr=“2003 - 2008”

### Ovid-EMBASE

1 exp nutrition/
2 (diet or diets or dietetic or dietary or eating or intake or nutrient$ or nutrition or vegetarian$ or vegan$ or “seventh day adventist” or macrobiotic or breastfeed$ or breast feed$ or breastfed or breast fed or breastmilk or breast milk).ti,ab.
3 (food$ or cereal$ or grain$ or granary or wholegrain or wholewheat or roots or plantain$ or tuber or tubers or vegetable$ or fruit$ or pulses or beans or lentils or chickpeas or legume$ or soy or soya or nut or nuts or peanut$ or groundnut$ or seeds or meat or beef or pork or lamb or poultry or chicken or turkey or duck or fish or fat or fats or fatty or egg or eggs or bread or oils or shellfish or seafood or sugar or syrup or dairy or milk or herbs or spices or chilli or chillis or pepper$ or condiments).ti,ab.
4 (fluid intake or water or drinks or drinking or tea or coffee or caffeine or juice or beer or spirits or liquor or wine or alcohol or alcoholic or beverage$ or ethanol or yerba mate or ilex paraguariensis).ti,ab.
5 exp Fertilizer/
6 exp Pesticide/
7 Veterinary Drug/
8 (pesticide$ or herbicide$ or DDT or fertiliser$ or fertilizer$ or organic or contaminants or contaminate$ or veterinary drug$ or polychlorinated dibenzofuran$ or PCDF$ or polychlorinated dibenzodioxin$ or PCDD$ or polychlorinated biphenyl$ or PCB$ or cadmium or arsenic or chlorinated hydrocarbon$ or microbial contamination$).ti,ab.
9 exp food preservation/
10 (mycotoxin$ or aflatoxin$ or pickled or bottled or bottling or canned or canning or vacuum pack$ or refrigerate$ or refrigeration or cured or smoked or preserved or preservatives or nitrosamine or hydrogenation or fortified or additive$ or colouring$ or coloring$ or flavouring$ or flavoring$ or nitrates or nitrites or solvent or solvents or ferment$ or processed or antioxidant$ or genetic modif$ or genetically modif$ or vinyl chloride or packaging or labelling or phthalates).ti,ab.
11 cooking/
12 (cooking or cooked or grill or grilled or fried or fry or roast or bake or baked or stewing or stewed or casserol$ or broil or broiled or boiled or microwave or microwaved or re-heating or reheating or heating or re-heated or heated or poach or poached or steamed or barbecue$ or chargrill$ or heterocyclic amines or polycyclic aromatic hydrocarbons).ti,ab.
13 *Carbohydrate/
14 exp “peptides and proteins”/ or protein/
15 (salt or salting or salted or fiber or fibre or polysaccharide$ or starch or starchy or carbohydrate$ or lipid$ or linoleic acid$ or sterols or stanols or sugar$ or sweetener$ or saccharin$ or aspartame or acesulfame or cyclamates or maltose or mannitol or sorbitol or sucrose or xylitol or cholesterol or protein or proteins or hydrogenated dietary oils or hydrogenated lard or hydrogenated oils).ti,ab.
16 exp Vitamin/
17 (supplements or supplement or vitamin$ or retinol or carotenoid$ or tocopherol or folate$ or folic acid or methionine or riboflavin or thiamine or niacin or pyridoxine or cobalamin or mineral$ or sodium or iron or calcium or selenium or iodine or magnesium or potassium or zinc or copper or phosphorus or manganese or chromium or phytochemical or allium or isothiocyanate$ or glucosinolate$ or indoles or polyphenol$ or phytoestrogen$ or genistein or saponin$ or coumarin$).ti,ab.
18 exp “physical activity, capacity and performance”/
19 (recreational activit$ or household activit$ or occupational activit$ or physical activit$ or physical inactivit$ or exercise or exercising or energy intake or energy expenditure or energy balance or energy density).ti,ab.
20 growth/ or exp body growth/
21 anthropometry/
22 exp body composition/
23 body constitution/
24 (weight loss or weight gain or anthropometry or birth weight or birthweight or birth-weight or child development or height or body composition or body mass or BMI or obesity or obese or overweight or over-weight or over weight or skinfold measurement$ or skinfold thickness or DEXA or bio-impedence or waist circumference or hip circumference or waist hip ratio$).ti,ab.
25 or/1–24
26 meta-analysis.ti,ab,sh.
27 (meta anal$ or metaanal$).ti,ab,sh.
28 ((methodol$ or systematic$ or quantitativ$) adj3 (review$ or overview$ or survey$)).ti,ab,sh.
29 (medline or embase or index medicus).ti,ab.
30 ((pool$ or combined or combining) adj (data or trials or studies or results)).ti,ab.
31 28 or 29 or 30
32 review.pt,sh.
33 31 and 32
34 26 or 27 or 33
35 exp Breast Cancer/
36 exp Colon Cancer/
37 exp Ovary Cancer/
38 exp Prostate Cancer/
39 ((breast or ovar$ or prostate or colon or colorectal) adj3 (cancer$ or neoplasm$ or carcinom$ or tumo?r$)).ti,ab.
40 exp Neoplasm/pc “Prevention”
41 cancer prevention/
42 ((cancer or carcinoma$ or neoplasm$ or tumo?r$) adj3 (prevent$ or reduc$)).tw.
43 or/35–42
44 25 and 34 and 43
45 limit 44 to english language
46 animal/ not (human/ and animal/)
47 45 not 46
48 limit 47 to em=200601-200817

### Ovid-EMBASE

1 cancer screening/
2 genetic services/ or genetic counseling/ or genetic screening/
3 prophylaxis/ or breast care/ or cancer prevention/ or chemoprophylaxis/ or periodic medical examination/ or personal monitoring/ or secondary prevention/ or smoking cessation/
4 alcohol abstinence/ or behavioral risk factor surveillance system/ or drinking behavior/ or risk reduction/
5 (chemoprevention or chemoprophylaxis).ti.
6 (surveillance or screening).ti.
7 disease surveillance/
8 PREVENTIVE HEALTH SERVICE/ or PREVENTIVE MEDICINE/
9 (prophylactic or preventive or risk reduc$).ti.
10 patient referral/
11 medical consultation.ti.
12 (health adj3 consultation).ti.
13 or/1–12
14 exp Breast Cancer/
15 exp Colon Cancer/
16 exp Ovary Cancer/
17 exp Prostate Cancer/
18 ((breast or ovar$ or prostate or colon or colorectal) adj3 (cancer$ or neoplasm$ or carcinom$ or tumo?r$)).ti,ab.
19 or/14–18
20 exp breast examination/
21 self exam$.ti.
22 Ovariectomy/
23 exp mastectomy/
24 mammog$.ti.
25 ((prophylactic or preventive or risk reduc$) adj3 (mastectomy or oophorectomy or ovariectomy)).tw.
26 ((magnetic resonance imaging or mri) adj3 breast).ti.
27 breast exam$.ti.
28 (ovarian adj3 screening).ti.
29 exp Oral Contraceptive Agent/
30 raloxifene/ or tamoxifen/ or toremifene/
31 (tamoxifen or raloxifene or toremifene or fareston).ti.
32 or/20–31
33 exp Breast Cancer/
34 (breast adj3 (cancer$ or neoplasm$ or carcinom$)).ti.
35 exp Ovary Cancer/
36 (ovar$ adj3 (cancer$ or neoplasm$ or carcinom$)).ti.
37 or/33–36
38 32 and 37
39 Fenretinide/
40 Finasteride/
41 (Fenretinide or Finasteride or proscar).ti.
42 digital rectal examination/
43 Toremifene/
44 fareston.ti.
45 (avodart or dutasteride).ti.
46 Prostate Specific Antigen/
47 (psa adj3 test$).ti.
48 prostate specific antigen.ti.
49 or/39–48
50 exp Prostate Cancer/
51 (prostat$ adj3 (cancer$ or neoplasm$ or carcinom$)).ti.
52 or/50–51
53 49 and 52
54 digital rectal examination/
55 f?ecal occult blood test$.ti.
56 (FOBT or fob test$).ti.
57 colonoscopy/ or sigmoidoscopy/
58 hormone replacement therapy.ti.
59 hrt.ti.
60 exp Hormone Substitution/
61 exp Nonsteroid Antiinflammatory Agent/
62 NSAID?.ti.
63 (nonsteroidal adj3 inflammatory).ti.
64 exp Hydroxymethylglutaryl Coenzyme a Reductase Inhibitor/
65 HMG-CoA reductase inhibitors.ti.
66 statins.ti.
67 or/54–66
68 exp Colon Cancer/
69 ((colon or colorectal) adj3 (cancer$ or neoplasm$ or carcinom$)).ti,ab.
70 or/68–69
71 67 and 70
72 13 and 19
73 38 or 53 or 71 or 72
74 meta analysis/
75 meta-analysis.ti,ab.
76 (meta anal$ or metaanal$).ti,ab.
77 ((methodol$ or systematic$ or quantitativ$) adj3 (review$ or overview$ or survey$)).ti.
78 ((methodol$ or systematic$ or quantitativ$) adj3 (review$ or overview$ or survey$)).ab.
79 (medline or embase or index medicus).ti,ab.
80 ((pool$ or combined or combining) adj (data or trials or studies or results)).ti,ab.
81 or/78–80
82 review.pt,sh.
83 81 and 82
84 or/74–77
85 83 or 84
86 73 and 85
87 limit 86 to english language
88 limit 87 to yr=“2000 - 2008”
89 limit 87 to yr=“2003 - 2008”

### Ovid-CINAHL

1 Diet Therapy/
2 exp Nutrition/
3 (diet or diets or dietetic or dietary or eating or intake or nutrient$ or nutrition or vegetarian$ or vegan$ or “seventh day adventist” or macrobiotic or breastfeed$ or breast feed$ or breastfed or breast fed or breastmilk or breast milk).ti,ab.
4 exp “food and beverages”/ or food/
5 (food$ or cereal$ or grain$ or granary or wholegrain or wholewheat or roots or plantain$ or tuber or tubers or vegetable$ or fruit$ or pulses or beans or lentils or chickpeas or legume$ or soy or soya or nut or nuts or peanut$ or groundnut$ or seeds or meat or beef or pork or lamb or poultry or chicken or turkey or duck or fish or fat or fats or fatty or egg or eggs or bread or oils or shellfish or seafood or sugar or syrup or dairy or milk or herbs or spices or chilli or chillis or pepper$ or condiments).ti,ab.
6 (fluid intake or water or drinks or drinking or tea or coffee or caffeine or juice or beer or spirits or liquor or wine or alcohol or alcoholic or beverage$ or ethanol or yerba mate or ilex paraguariensis).ti,ab.
7 exp Pesticides/
8 Veterinary Medicine/
9 (pesticide$ or herbicide$ or DDT or fertiliser$ or fertilizer$ or organic or contaminants or contaminate$ or veterinary drug$ or polychlorinated dibenzofuran$ or PCDF$ or polychlorinated dibenzodioxin$ or PCDD$ or polychlorinated biphenyl$ or PCB$ or cadmium or arsenic or chlorinated hydrocarbon$ or microbial contamination$).ti,ab.
10 exp Food Preservation/
11 (mycotoxin$ or aflatoxin$ or pickled or bottled or bottling or canned or canning or vacuum pack$ or refrigerate$ or refrigeration or cured or smoked or preserved or preservatives or nitrosamine or hydrogenation or fortified or additive$ or colouring$ or coloring$ or flavouring$ or flavoring$ or nitrates or nitrites or solvent or solvents or ferment$ or processed or antioxidant$ or genetic modif$ or genetically modif$ or vinyl chloride or packaging or labelling or phthalates).ti,ab.
12 Cooking/
13 (cooking or cooked or grill or grilled or fried or fry or roast or bake or baked or stewing or stewed or casserol$ or broil or broiled or boiled or microwave or microwaved or re-heating or reheating or heating or re-heated or heated or poach or poached or steamed or barbecue$ or chargrill$ or heterocyclic amines or polycyclic aromatic hydrocarbons).ti,ab.
14 exp Dietary Carbohydrates/
15 exp Dietary Proteins/
16 exp Sweetening Agents/
17 (salt or salting or salted or fiber or fibre or polysaccharide$ or starch or starchy or carbohydrate$ or lipid$ or linoleic acid$ or sterols or stanols or sugar$ or sweetener$ or saccharin$ or aspartame or acesulfame or cyclamates or maltose or mannitol or sorbitol or sucrose or xylitol or cholesterol or protein or proteins or hydrogenated dietary oils or hydrogenated lard or hydrogenated oils).ti,ab.
18 exp Vitamins/
19 (supplements or supplement or vitamin$ or retinol or carotenoid$ or tocopherol or folate$ or folic acid or methionine or riboflavin or thiamine or niacin or pyridoxine or cobalamin or mineral$ or sodium or iron or calcium or selenium or iodine or magnesium or potassium or zinc or copper or phosphorus or manganese or chromium or phytochemical or allium or isothiocyanate$ or glucosinolate$ or indoles or polyphenol$ or phytoestrogen$ or genistein or saponin$ or coumarin$).ti,ab.
20 Physical Fitness/
21 exp Exertion/
22 Walking/
23 (recreational activit$ or household activit$ or occupational activit$ or physical activit$ or physical inactivit$ or exercise or exercising or energy intake or energy expenditure or energy balance or energy density).ti,ab.
24 exp Growth/
25 exp “Body Weights and Measures”/
26 exp Body Composition/
27 exp Body Constitution/
28 (weight loss or weight gain or anthropometry or birth weight or birthweight or birth-weight or child development or height or body composition or body mass or BMI or obesity or obese or overweight or over-weight or over weight or skinfold measurement$ or skinfold thickness or DEXA or bio-impedence or waist circumference or hip circumference or waist hip ratio$).ti,ab.
29 or/1–28
30 meta-analysis.ti,ab,sh.
31 (meta anal$ or metaanal$).ti,ab,sh.
32 systematic review.pt.
33 systematic review.ti.
34 ((methodol$ or systematic$ or quantitativ$) adj3 (review$ or overview$ or survey$)).ti,ab,sh.
35 (medline or embase or index medicus).ti,ab.
36 ((pool$ or combined or combining) adj (data or trials or studies or results)).ti,ab.
37 34 or 35 or 36
38 review.pt,sh.
39 37 and 38
40 30 or 31 or 32 or 33
41 39 or 40
42 exp Breast Neoplasms/
43 exp Colorectal Neoplasms/
44 exp Ovarian Neoplasms/
45 exp Prostatic Neoplasms/
46 ((breast or ovar$ or prostate or colon or colorectal) adj3 (cancer$ or neoplasm$ or carcinom$ or tumo?r$)).ti,ab.
47 or/42–46
48 29 and 41 and 47
49 limit 48 to ew=2006$
50 limit 48 to ew=2007$
51 limit 48 to ew=2008$
52 49 or 50 or 51
53 limit 52 to english

### Ovid-CINAHL

1 cancer screening/ or genetic screening/
2 Genetic Counseling/
3 Chemoprevention/
4 “Referral and Consultation”/
5 Smoking Cessation/
6 Alcohol Drinking/
7 (chemoprevention or chemoprophylaxis).ti.
8 Disease Surveillance/
9 (surveillance or screening).ti.
10 Preventive Health Care/
11 (prophylactic or preventive or risk reduc$).ti.
12 medical consultation.ti.
13 (health adj3 consultation).ti.
14 Risk Management/
15 or/1–14
16 Breast Care/
17 breast examination/ or breast self-examination/
18 self exam$.ti.
19 Oophorectomy/
20 Mastectomy/
21 Mammography/
22 mammog$.ti.
23 ((prophylactic or preventive or risk reduc$) adj3 (mastectomy or oophorectomy or ovariectomy)).tw.
24 ((magnetic resonance imaging or mri) adj3 breast).ti.
25 breast exam$.ti.
26 (ovarian adj3 screening).ti.
27 exp Contraceptives, Oral/
28 raloxifene/ or tamoxifen/
29 (tamoxifen or raloxifene or toremifene or fareston).ti.
30 or/16–29
31 exp Breast Neoplasms/
32 exp Ovarian Neoplasms/
33 (breast adj3 (cancer$ or neoplasm$ or carcinom$)).ti.
34 (ovar$ adj3 (cancer$ or neoplasm$ or carcinom$)).ti.
35 or/31–34
36 30 and 35
37 Finasteride/
38 (Fenretinide or Finasteride or proscar).ti.
39 Digital Rectal Examination/
40 Toremifene.ti.
41 fareston.ti.
42 (avodart or dutasteride).ti.
43 Prostate-Specific Antigen/
44 (psa adj3 test$).ti.
45 prostate specific antigen.ti.
46 or/37–45
47 exp Prostatic Neoplasms/
48 (prostat$ adj3 (cancer$ or neoplasm$ or carcinom$)).ti.
49 or/47–48
50 46 and 49
51 Digital Rectal Examination/
52 f?ecal occult blood test$.ti.
53 (FOBT or fob test$).ti.
54 colonoscopy/ or sigmoidoscopy/
55 Hormone Replacement Therapy/
56 hormone replacement therapy.ti.
57 hrt.ti.
58 exp Antiinflammatory Agents, Non-Steroidal/
59 NSAID?.ti.
60 (nonsteroidal adj3 inflammatory).ti.
61 exp Statins/
62 HMG-CoA reductase inhibitors.ti.
63 statins.ti.
64 or/51–63
65 exp Colorectal Neoplasms/
66 ((colon or colorectal) adj3 (cancer$ or neoplasm$ or carcinom$)).ti.
67 or/65–66
68 64 and 67
69 exp Breast Neoplasms/
70 exp Colorectal Neoplasms/
71 exp Prostatic Neoplasms/
72 exp Ovarian Neoplasms/
73 ((breast or ovar$ or prostate or colon or colorectal) adj3 (cancer$ or neoplasm$ or carcinom$ or tumo?r$)).ti.
74 or/69–73
75 15 and 74
76 36 or 50 or 68 or 75
77 Meta Analysis/
78 (meta anal$ or metaanal$).ti,ab.
79 meta-analysis.ti,ab.
80 ((methodol$ or systematic$ or quantitativ$) adj3 (review$ or overview$ or survey$)).ti.
81 ((methodol$ or systematic$ or quantitativ$) adj3 (review$ or overview$ or survey$)).ab.
82 (medline or embase or index medicus).ti,ab.
83 ((pool$ or combined or combining) adj (data or trials or studies or results)).ti,ab.
84 or/81–83
85 review.pt,sh.
86 84 and 85
87 “Systematic Review”/
88 systematic review.pt.
89 78 or 79 or 80 or 86 or 87 or 88
90 76 and 89
91 limit 90 to english
92 limit 91 to yr=“2000 - 2008”
93 limit 91 to yr=“2003 - 2008”

### Ovid-CDSR

1 (diet or diets or dietetic or dietary or eating or intake or nutrient$ or nutrition or vegetarian$ or vegan$ or “seventh day adventist” or macrobiotic or breastfeed$ or breast feed$ or breastfed or breast fed or breastmilk or breast milk).ti,ab.
2 (food$ or cereal$ or grain$ or granary or wholegrain or wholewheat or roots or plantain$ or tuber or tubers or vegetable$ or fruit$ or pulses or beans or lentils or chickpeas or legume$ or soy or soya or nut or nuts or peanut$ or groundnut$ or seeds or meat or beef or pork or lamb or poultry or chicken or turkey or duck or fish or fat or fats or fatty or egg or eggs or bread or oils or shellfish or seafood or sugar or syrup or dairy or milk or herbs or spices or chilli or chillis or pepper$ or condiments).ti,ab.
3 (fluid intake or water or drinks or drinking or tea or coffee or caffeine or juice or beer or spirits or liquor or wine or alcohol or alcoholic or beverage$ or ethanol or yerba mate or ilex paraguariensis).ti,ab.
4 (pesticide$ or herbicide$ or DDT or fertiliser$ or fertilizer$ or organic or contaminants or contaminate$ or veterinary drug$ or polychlorinated dibenzofuran$ or PCDF$ or polychlorinated dibenzodioxin$ or PCDD$ or polychlorinated biphenyl$ or PCB$ or cadmium or arsenic or chlorinated hydrocarbon$ or microbial contamination$).ti,ab.
5 (mycotoxin$ or aflatoxin$ or pickled or bottled or bottling or canned or canning or vacuum pack$ or refrigerate$ or refrigeration or cured or smoked or preserved or preservatives or nitrosamine or hydrogenation or fortified or additive$ or colouring$ or coloring$ or flavouring$ or flavoring$ or nitrates or nitrites or solvent or solvents or ferment$ or processed or antioxidant$ or genetic modif$ or genetically modif$ or vinyl chloride or packaging or labelling or phthalates).ti,ab.
6 (cooking or cooked or grill or grilled or fried or fry or roast or bake or baked or stewing or stewed or casserol$ or broil or broiled or boiled or microwave or microwaved or re-heating or reheating or heating or re-heated or heated or poach or poached or steamed or barbecue$ or chargrill$ or heterocyclic amines or polycyclic aromatic hydrocarbons).ti,ab.
7 (salt or salting or salted or fiber or fibre or polysaccharide$ or starch or starchy or carbohydrate$ or lipid$ or linoleic acid$ or sterols or stanols or sugar$ or sweetener$ or saccharin$ or aspartame or acesulfame or cyclamates or maltose or mannitol or sorbitol or sucrose or xylitol or cholesterol or protein or proteins or hydrogenated dietary oils or hydrogenated lard or hydrogenated oils).ti,ab.
8 (supplements or supplement or vitamin$ or retinol or carotenoid$ or tocopherol or folate$ or folic acid or methionine or riboflavin or thiamine or niacin or pyridoxine or cobalamin or mineral$ or sodium or iron or calcium or selenium or iodine or magnesium or potassium or zinc or copper or phosphorus or manganese or chromium or phytochemical or allium or isothiocyanate$ or glucosinolate$ or indoles or polyphenol$ or phytoestrogen$ or genistein or saponin$ or coumarin$).ti,ab.
9 (recreational activit$ or household activit$ or occupational activit$ or physical activit$ or physical inactivit$ or exercise or exercising or energy intake or energy expenditure or energy balance or energy density).ti,ab.
10 (weight loss or weight gain or anthropometry or birth weight or birthweight or birth-weight or child development or height or body composition or body mass or BMI or obesity or obese or overweight or over-weight or over weight or skinfold measurement$ or skinfold thickness or DEXA or bio-impedence or waist circumference or hip circumference or waist hip ratio$).ti,ab.
11 ((breast or ovar$ or prostate or colon or colorectal) adj3 (cancer$ or neoplasm$ or carcinom$ or tumo?r$)).ti,ab.
12 or/1–10
13 11 and 12

### Ovid-CDSR

1 chemoprevention.ti.
2 (surveillance or screening).ti.
3 (prophylactic or preventive or risk reduc$).ti.
4 medical consultation.ti.
5 (health adj3 consultation).ti.
6 ((breast or ovar$ or prostate or colon or colorectal) adj3 (cancer$ or neoplasm$ or carcinom$)).ti,ab.
7 self exam$.ti.
8 mammog$.ti.
9 risk reduction mastectomy.ti.
10 ((prophylactic or preventive or risk reduc$) adj3 (mastectomy or oophorectomy or ovariectomy)).tw.
11 ((magnetic resonance imaging or mri) adj3 breast).ti.
12 breast exam$.ti.
13 (ovarian adj3 screening).ti.
14 (tamoxifen or raloxifene or toremifene or fareston).ti.
15 (breast adj3 (cancer$ or neoplasm$ or carcinom$)).ti.
16 (ovar$ adj3 (cancer$ or neoplasm$ or carcinom$)).ti.
17 (Fenretinide or Finasteride or proscar).ti.
18 fareston.ti.
19 (avodart or dutasteride).ti.
20 (psa adj3 test$).ti.
21 prostate specific antigen.ti.
22 (prostat$ adj3 (cancer$ or neoplasm$ or carcinom$)).ti.
23 f?ecal occult blood test$.ti.
24 (FOBT or fob test$).ti.
25 hrt.ti.
26 NSAID?.ti.
27 (nonsteroidal adj3 inflammatory).ti.
28 HMG-CoA reductase inhibitors.ti.
29 statins.ti.
30 ((colon or colorectal) adj3 (cancer$ or neoplasm$ or carcinom$)).ti,ab.
31 or/1–5
32 or/7–14
33 or/15–16
34 or/17–21
35 or/23–29
36 6 and 31
37 33 and 32
38 22 and 34
39 35 and 30
40 or/36–39

## Question 3

### Ovid-Medline

1 family history.ab.
2 Genetic Predisposition to Disease/
3 BRCA$.ti.
4 (relative? or genetic or heredit$ or famil$ or inherit$ or high$ risk or “at risk” or increased risk).ti.
5 exp Genetic Services/
6 genes, brca1/ or genes, brca2/
7 or/1–6
8 exp breast neoplasms/ or exp colorectal neoplasms/ or exp ovarian neoplasms/ or exp prostatic neoplasms/
9 ((breast or ovar$ or prostate or colon or colorectal) adj3 (cancer$ or neoplasm$ or carcinom$ or tumo?r$)).ti,ab.
10 *Neoplasms/
11 or/8–10
12 ((relative? or genetic or heredit$ or famil$ or inherit$ or high$ risk or “at risk” or increased risk) adj8 (factors or behavio?r$ or intention or increase or change or impact)).ti.
13 ((relative? or genetic or heredit$ or famil$ or inherit$ or high$ risk or “at risk” or increased risk) adj8 (mammography or test$ or screen$ or exercise or physical activity or diet or food or smoking or alcohol or utili?ation or “use”)).ti.
14 ((factors or behavio?r$ or intention or increase or change or impact or risk) adj8 (mammography or test$ or screen$ or exercise or physical activity or diet or food or smoking or alcohol or utili?ation or “use”)).ti.
15 (uptake or motivation or compliance or adherence or seeking or practices or patterns).ti.
16 ((relative? or genetic or heredit$ or famil$ or inherit$ or high$ risk or “at risk” or increased risk) adj8 (change? or impact? or modification? or influence or risk)).ti.
17 ((after or following or “because of” or “due to” or “result of”) adj9 (genetic test$ or genetic counsel?ing or genetic screening)).ti.
18 ((after or following or “because of” or “due to” or “result of”) adj9 (mutation test$ or mutation screen$)).ti.
19 exp Health Behavior/
20 risk reduction behavior/
21 or/12–20
22 7 and 11 and 21
23 animals/ not (humans/ and animals/)
24 22 not 23
25 limit 24 to english language
26 (note or comment or editorial).pt.
27 25 not 26
28 limit 27 to yr=“1990 - 2008”

### Ovid-EMBASE

1 exp health behavior/
2 behavior change/
3 ((relative? or genetic or heredit$ or famil$ or inherit$ or high$ risk or “at risk” or increased risk) adj8 (factors or behavio?r$ or intention or increase or change or impact)).ti.
4 ((relative? or genetic or heredit$ or famil$ or inherit$ or high$ risk or “at risk” or increased risk) adj8 (mammography or test$ or screen$ or exercise or physical activity or diet or food or smoking or alcohol or utili?ation or “use”)).ti.
5 ((factors or behavio?r$ or intention or increase or change or impact or risk) adj8 (mammography or test$ or screen$ or exercise or physical activity or diet or food or smoking or alcohol or utili?ation or “use”)).ti.
6 (uptake or motivation or compliance or adherence or seeking or practices or patterns).ti.
7 ((relative? or genetic or heredit$ or famil$ or inherit$ or high$ risk or “at risk” or increased risk) adj8 (change? or impact? or modification? or influence or risk)).ti.
8 ((after or following or “because of” or “due to” or “result of”) adj9 (genetic test$ or genetic counsel?ing or genetic screening)).ti.
9 ((after or following or “because of” or “due to” or “result of”) adj9 (mutation test$ or mutation screen$)).ti.
10 or/1–9
11 Familial Cancer/
12 exp Breast Cancer/
13 exp Colon Cancer/
14 exp Ovary Cancer/
15 exp Prostate Cancer/
16 ((breast or ovar$ or prostate or colon or colorectal) adj3 (cancer$ or neoplasm$ or carcinom$ or tumo?r$)).ti,ab.
17 *Cancer/
18 or/11–17
19 genetic predisposition/ or genetic susceptibility/
20 family history/
21 (relative? or genetic or heredit$ or famil$ or inherit$ or high$ risk or “at risk” or increased risk).ti.
22 exp genetic service/
23 brca1 protein/ or brca2 protein/
24 family history.ab.
25 Familial Cancer/
26 BRCA$.ti.
27 or/19–26
28 10 and 18 and 27
29 limit 28 to human
30 limit 29 to english language
31 (note or editorial).pt.
32 30 not 31
33 limit 32 to yr=“1990 - 2008”

### Ovid-CCRT

1 family history.ab.
2 Genetic Predisposition to Disease/
3 BRCA$.ti.
4 (relative? or genetic or heredit$ or famil$ or inherit$ or high$ risk or “at risk” or increased risk).ti.
5 exp Genetic Services/
6 genes, brca1/ or genes, brca2/
7 or/1–6
8 exp breast neoplasms/ or exp colorectal neoplasms/ or exp ovarian neoplasms/ or exp prostatic neoplasms/
9 ((breast or ovar$ or prostate or colon or colorectal) adj3 (cancer$ or neoplasm$ or carcinom$ or tumo?r$)).ti,ab.
10 *Neoplasms/
11 or/8–10
12 ((relative? or genetic or heredit$ or famil$ or inherit$ or high$ risk or “at risk” or increased risk) adj8 (factors or behavio?r$ or intention or increase or change or impact)).ti.
13 ((relative? or genetic or heredit$ or famil$ or inherit$ or high$ risk or “at risk” or increased risk) adj8 (mammography or test$ or screen$ or exercise or physical activity or diet or food or smoking or alcohol or utili?ation or “use”)).ti.
14 ((factors or behavio?r$ or intention or increase or change or impact or risk) adj8 (mammography or test$ or screen$ or exercise or physical activity or diet or food or smoking or alcohol or utili?ation or “use”)).ti.
15 (uptake or motivation or compliance or adherence or seeking or practices or patterns).ti.
16 ((relative? or genetic or heredit$ or famil$ or inherit$ or high$ risk or “at risk” or increased risk) adj8 (change? or impact? or modification? or influence or risk)).ti.
17 ((after or following or “because of” or “due to” or “result of”) adj9 (genetic test$ or genetic counsel?ing or genetic screening)).ti.
18 ((after or following or “because of” or “due to” or “result of”) adj9 (mutation test$ or mutation screen$)).ti.
19 exp Health Behavior/
20 risk reduction behavior/
21 or/12–20
22 7 and 11 and 21
23 limit 22 to yr=“1990 - 2008”

### Ovid-CINAHL

1 health behavior/ or patient compliance/ or medication compliance/ or treatment refusal/ or help seeking behavior/
2 Behavioral Changes/
3 ((relative? or genetic or heredit$ or famil$ or inherit$ or high$ risk or “at risk” or increased risk) adj8 (factors or behavio?r$ or intention or increase or change or impact)).ti.
4 ((relative? or genetic or heredit$ or famil$ or inherit$ or high$ risk or “at risk” or increased risk) adj8 (mammography or test$ or screen$ or exercise or physical activity or diet or food or smoking or alcohol or utili?ation or “use”)).ti.
5 ((factors or behavio?r$ or intention or increase or change or impact or risk) adj8 (mammography or test$ or screen$ or exercise or physical activity or diet or food or smoking or alcohol or utili?ation or “use”)).ti.
6 (uptake or motivation or compliance or adherence or seeking or practices or patterns).ti.
7 ((relative? or genetic or heredit$ or famil$ or inherit$ or high$ risk or “at risk” or increased risk) adj8 (change? or impact? or modification? or influence or risk)).ti.
8 ((after or following or “because of” or “due to” or “result of”) adj9 (genetic test$ or genetic counsel?ing or genetic screening)).ti.
9 ((after or following or “because of” or “due to” or “result of”) adj9 (mutation test$ or mutation screen$)).ti.
10 attitude to change/ or attitude to risk/
11 or/1–10
12 exp Breast Neoplasms/
13 exp Colorectal Neoplasms/
14 exp Ovarian Neoplasms/
15 exp Prostatic Neoplasms/
16 ((breast or ovar$ or prostate or colon or colorectal) adj3 (cancer$ or neoplasm$ or carcinom$ or tumo?r$)).ti,ab.
17 *Neoplasms/pc “Prevention and Control”
18 or/12–17
19 Genetic Screening/ or Genetic Counseling/
20 Family History/
21 (relative? or genetic or heredit$ or famil$ or inherit$ or high$ risk or “at risk” or increased risk).ti.
22 Genes, BRCA/
23 family history.ab.
24 BRCA$.ti.
25 or/19–24
26 11 and 18 and 25
27 limit 26 to english
28 limit 27 to yr=“1990 - 2008”

### Ovid-PsycINFO

1 health behavior/
2 lifestyle changes/ or behavior change/ or health promotion/ or readiness to change/
3 preventive medicine/ or health promotion/
4 ((relative? or genetic or heredit$ or famil$ or inherit$ or high$ risk or “at risk” or increased risk) adj8 (factors or behavio?r$ or intention or increase or change or impact)).ti.
5 ((relative? or genetic or heredit$ or famil$ or inherit$ or high$ risk or “at risk” or increased risk) adj8 (mammography or test$ or screen$ or exercise or physical activity or diet or food or smoking or alcohol or utili?ation or “use”)).ti.
6 ((factors or behavio?r$ or intention or increase or change or impact or risk) adj8 (mammography or test$ or screen$ or exercise or physical activity or diet or food or smoking or alcohol or utili?ation or “use”)).ti.
7 (uptake or motivation or compliance or adherence or seeking or practices or patterns).ti.
8 ((relative? or genetic or heredit$ or famil$ or inherit$ or high$ risk or “at risk” or increased risk) adj8 (change? or impact? or modification? or influence or risk)).ti.
9 ((after or following or “because of” or “due to” or “result of”) adj9 (genetic test$ or genetic counsel?ing or genetic screening)).ti.
10 ((after or following or “because of” or “due to” or “result of”) adj9 (mutation test$ or mutation screen$)).ti.
11 risk management/
12 or/1–11
13 at risk populations/ or predisposition/ or “susceptibility (disorders)”/
14 family history.ab.
15 genetics/ or mutations/
16 (relative? or genetic or heredit$ or famil$ or inherit$ or high$ risk or “at risk” or increased risk).ti.
17 genetic testing/ or genetic counseling/
18 BRCA$.ti.
19 or/13–18
20 breast neoplasms/
21 ((breast or ovar$ or prostate or colon or colorectal) adj3 (cancer$ or neoplasm$ or carcinom$ or tumo?r$)).ti,ab.
22 *neoplasms/
23 or/20–22
24 12 and 19 and 23
25 limit 24 to human
26 limit 25 to english language
27 limit 26 to yr=“1990 - 2008”

## Question 4

### Ovid-MEDLINE

1 family history.ab.
2 Genetic Predisposition to Disease/
3 BRCA$.ti.
4 (relative? or genetic or heredit$ or famil$ or inherit$ or high$ risk or “at risk” or increased risk).ti.
5 exp Genetic Services/
6 genes, brca1/ or genes, brca2/
7 or/1–6
8 exp breast neoplasms/ or exp colorectal neoplasms/ or exp ovarian neoplasms/ or exp prostatic neoplasms/
9 ((breast or ovar$ or prostate or colon or colorectal) adj3 (cancer$ or neoplasm$ or carcinom$ or tumo?r$)).ti,ab.
10 *Neoplasms/
11 or/8–10
12 anxiety/ or fear/
13 depression/ or stress, psychological/
14 ((worry or anxiety or depression or distress or coping or fear) and cancer).ti.
15 ((psychological or psychosocial) and cancer).ti.
16 (perception and cancer).ti.
17 (impact and cancer).ti.
18 family relations/
19 ((insurance or employment) and cancer).ti.
20 insurance/ or exp insurance, health/
21 insurance.ti.
22 (prejudice or discrimination).ti.
23 (harm? or fatalism).tw.
24 or/12–23
25 employment/ or workplace/
26 prejudice/
27 24 or 26
28 7 and 11 and 27
29 animals/ not (humans/ and animals/)
30 28 not 29
31 (note or comment or editorial).pt.
32 30 not 31
33 limit 32 to english language
34 limit 33 to yr=“1990 - 2008”

### Ovid-EMBASE

1 emotional stress/ or family stress/ or interpersonal stress/
2 fear/ or anxiety/
3 exp Depression/
4 ((worry or anxiety or depression or distress or coping or fear) and cancer).ti.
5 ((psychological or psychosocial) and cancer).ti.
6 (perception and cancer).ti.
7 (impact and cancer).ti.
8 family relation/
9 family stress/
10 CANCER FAMILY/
11 ((insurance or employment) and cancer).ti.
12 exp health insurance/
13 insurance/ or exp insurance, health/
14 (prejudice or discrimination).ti.
15 (harm? or fatalism).tw.
16 employment discrimination/
17 or/2–16
18 Familial Cancer/
19 exp Breast Cancer/
20 exp Colon Cancer/
21 exp Ovary Cancer/
22 exp Prostate Cancer/
23 ((breast or ovar$ or prostate or colon or colorectal) adj3 (cancer$ or neoplasm$ or carcinom$ or tumo?r$)).ti,ab.
24 *Cancer/
25 or/18–24
26 genetic predisposition/ or genetic susceptibility/
27 family history/
28 (relative? or genetic or heredit$ or famil$ or inherit$ or high$ risk or “at risk” or increased risk).ti.
29 exp genetic service/
30 brca1 protein/ or brca2 protein/
31 family history.ab.
32 Familial Cancer/
33 BRCA$.ti.
34 or/26–33
35 17 and 25 and 34
36 limit 35 to human
37 (note or comment or editorial).pt.
38 36 not 37
39 limit 38 to english language
40 limit 39 to yr=“1990 - 2008”

### OVID-CCRT

1 family history.ab.
2 Genetic Predisposition to Disease/
3 BRCA$.ti.
4 (relative? or genetic or heredit$ or famil$ or inherit$ or high$ risk or “at risk” or increased risk).ti.
5 exp Genetic Services/
6 genes, brca1/ or genes, brca2/
7 or/1–6
8 exp breast neoplasms/ or exp colorectal neoplasms/ or exp ovarian neoplasms/ or exp prostatic neoplasms/
9 ((breast or ovar$ or prostate or colon or colorectal) adj3 (cancer$ or neoplasm$ or carcinom$ or tumo?r$)).ti,ab.
10 *Neoplasms/
11 or/8–10
12 anxiety/ or fear/
13 depression/ or stress, psychological/
14 ((worry or anxiety or depression or distress or coping or fear) and cancer).ti.
15 ((psychological or psychosocial) and cancer).ti.
16 (perception and cancer).ti.
17 (impact and cancer).ti.
18 family relations/
19 ((insurance or employment) and cancer).ti.
20 insurance/ or exp insurance, health/
21 insurance.ti.
22 (prejudice or discrimination).ti.
23 (harm? or fatalism).tw.
24 or/12–23
25 employment/ or workplace/
26 prejudice/
27 24 or 26
28 7 and 11 and 27
29 limit 28 to yr=“1990 - 2008”

### Ovid-CINAHL

1 exp Breast Neoplasms/
2 exp Colorectal Neoplasms/
3 exp Ovarian Neoplasms/
4 exp Prostatic Neoplasms/
5 ((breast or ovar$ or prostate or colon or colorectal) adj3 (cancer$ or neoplasm$ or carcinom$ or tumo?r$)).ti,ab.
6 *Neoplasms/pc “Prevention and Control”
7 or/1–6
8 Genetic Screening/ or Genetic Counseling/
9 Family History/
10 (relative? or genetic or heredit$ or famil$ or inherit$ or high$ risk or “at risk” or increased risk).ti.
11 Genes, BRCA/
12 family history.ab.
13 BRCA$.ti.
14 or/8–13
15 exp Coping/
16 exp “Psychosocial Aspects of Illness”/
17 stress/ or stress, psychological/
18 anxiety/ or depression/
19 Fear/
20 ((worry or anxiety or depression or distress or coping or fear) and cancer).ti.
21 ((psychological or psychosocial) and cancer).ti.
22 (perception and cancer).ti.
23 (impact and cancer).ti.
24 family functioning/ or family coping/ or family relations/
25 ((insurance or employment) and cancer).ti.
26 insurance coverage/ or insurance, health/
27 Discrimination, Employment/
28 (prejudice or discrimination).ti.
29 (harm? or fatalism).tw.
30 or/15–29
31 7 and 14 and 30
32 limit 31 to english
33 limit 32 to yr=“1990 - 2008”

### Ovid-PsycINFO

1 coping behavior/ or hopelessness/
2 anxiety/
3 psychological stress/
4 emotional states/ or “depression (emotion)”/
5 fear/
6 ((worry or anxiety or depression or distress or coping or fear) and cancer).ti.
7 ((psychological or psychosocial) and cancer).ti.
8 (perception and cancer).ti.
9 (impact and cancer).ti.
10 distress/
11 family relations/ or interpersonal relationships/
12 emotional adjustment/ or coping behavior/
13 emotional adjustment/
14 or/1–13
15 at risk populations/ or predisposition/ or “susceptibility (disorders)”/
16 family history.ab.
17 genetics/ or mutations/
18 (relative? or genetic or heredit$ or famil$ or inherit$ or high$ risk or “at risk” or increased risk).ti.
19 genetic testing/ or genetic counseling/
20 BRCA$.ti.
21 or/15–20
22 breast neoplasms/
23 ((breast or ovar$ or prostate or colon or colorectal) adj3 (cancer$ or neoplasm$ or carcinom$ or tumo?r$)).ti,ab.
24 *neoplasms/
25 or/22–24
26 14 and 21 and 25
27 limit 26 to human
28 limit 27 to english language
29 limit 28 to yr=“1990 - 2008”