# Appendixes

Appendix A - Search Strategies Detailed

Appendix B - Forms and Guides

Appendix C - Studies Retained But Not Extracted

Appendix D - Excluded Studies

Appendix E - Partners, Technical Expert Panel, and Peer Reviewers