# References

1 Korthals-de Bos IB, Hoving JL, van Tulder MW, et al. Cost effectiveness of physiotherapy, manual therapy, and general practitioner care for neck pain: economic evaluation alongside a randomised controlled trial. BMJ (Clinical research ed). 2003;326(7395):911.
2 Cote P, van der Velde G, Cassidy JD, et al. The burden and determinants of neck pain in workers: results of the Bone and Joint Decade 2000-2010 Task Force on Neck Pain and Its Associated Disorders. Spine. 2008;33(4 Suppl):S60-S74. [pmid: 18204402].
3 Hogg-Johnson S, van der Velde G, L J, et al. The burden and determinants of neck pain in the general population: results of the Bone and Joint Decade 2000-2010 Task Force on Neck Pain and Its Associated Disorders. Spine. 2008;33(4 Suppl):S39-S51. [pmid: 18204398].
4 Dagenais S, Caro J, Haldeman S. A systematic review of low back pain cost of illness studies in the United States and internationally. Spine J. 2008;8(1):8-20. [pmid: 18164449].
5 Eisenberg DM, Davis RB, Ettner SL, et al. Trends in alternative medicine use in the United States, 1990-1997: Results of a follow-up national survey. JAMA. 1998;280(18):1569-75. [pmid: 9820257].
6 Barnes PM, Powell-Griner E, McFann K, et al. Complementary and alternative medicine use among adults: United States, 2002. Adv Data. 2004;(343):1-19.
7 Fouladbakhsh J, Stommel M. Using the Behavioral Model for Complementary and Alternative Medicine: The CAM Healthcare Model. Journal of Complementary and Integrative Medicine. 2007;4(1, Art.11):1-19.
8 Andersen RM. Revisiting the behavioral model and access to medical care: does it matter?. J Health Soc Behav. 1995;36(1):1-10. [pmid: 7738325].
9 Carey TS, Evans A, Hadler N, et al. Care-seeking among individuals with chronic low back pain. Spine. 1995;20(3):312-7. [pmid: 7732467].
10 Bruce B, Lorig K, Laurent D, et al. The impact of a moderated e-mail discussion group on use of complementary and alternative therapies in subjects with recurrent back pain. Patient Educ Couns. 2005;58(3):305-11. [pmid: 16122642].
11 Long DM, BenDebba M, Torgerson WJ, et al. Persistent back pain and sciatica in the United States: patient characteristics. J Spinal Disord. 1996;9(1):40-58. [pmid: 8727456].
12 Wolsko PM, Eisenberg DM, Davis RB, et al. Patterns and perceptions of care for treatment of back and neck pain: results of a national survey. Spine. 2003;28(3):292-7. [pmid: 12567035].
13 Fleming S, Rabago DP, Mundt MP, et al. CAM therapies among primary care patients using opioid therapy for chronic pain. BMC Complement Altern Med. 2007;7:15. [pmid: 17506893]. [pmcid: 1885447].
14 Hurwitz EL, Chiang LM. A comparative analysis of chiropractic and general practitioner patients in North America: findings from the joint Canada/United States Survey of Health, 2002-03. BMC Health Serv Res. 2006;6:49. [pmid: 16600038]. [pmcid: 1458338].
15 Sherman KJ, Cherkin DC, Deyo RA, et al. The diagnosis and treatment of chronic back pain by acupuncturists, chiropractors, and massage therapists. Clin J Pain. 2006;22(3):227-34. [pmid: 16514321].
16 Lind BK, Lafferty WE, Tyree PT, et al. The role of alternative medical providers for the outpatient treatment of insured patients with back pain. Spine. 2005;30(12):1454-9. [pmid: 15959379].
17 Cote P, Baldwin ML, Johnson WG. Early patterns of care for occupational back pain. Spine. 2005;30(5):581-7. [pmid: 15738794].
18 Sherman KJ, Cherkin DC, Connelly MT, et al. Complementary and alternative medical therapies for chronic low back pain: What treatments are patients willing to try?. BMC Complement Altern Med. 2004;4:9. [pmid: 15260884]. [pmcid: 503394].
19 Feuerstein M, Marcus SC, Huang GD. National trends in nonoperative care for nonspecific back pain. Spine J. 2004;4(1):56-63. [pmid: 14749194].
20 Stano M, Haas M, Goldberg B, et al. Chiropractic and medical care costs of low back care: results from a practice-based observational study. Am J Manag Care. 2002;8(9):802-9. [pmid: 12234021].
21 Coulter ID, Hurwitz EL, Adams AH, et al. Patients using chiropractors in North America: who are they, and why are they in chiropractic care?. Spine. 2002;27(3):291-6. [pmid: 11805694].
22 Nyiendo J, Haas M, Goldberg B, et al. A descriptive study of medical and chiropractic patients with chronic low back pain and sciatica: management by physicians (practice activities) and patients (self-management). J Manipulative Physiol Ther. 2001;24(9):543-51. [pmid: 11753326].
23 Nyiendo J, Haas M, Goldberg B, et al. Patient characteristics and physicians' practice activities for patients with chronic low back pain: a practice-based study of primary care and chiropractic physicians. J Manipulative Physiol Ther. 2001;24(2):92-100. [pmid: 11208221].
24 Nyiendo J, Haas M, Goodwin P. Patient characteristics, practice activities, and one-month outcomes for chronic, recurrent low-back pain treated by chiropractors and family medicine physicians: a practice-based feasibility study. J Manipulative Physiol Ther. 2000;23(4):239-45. [pmid: 10820296].
25 Hawk C, Long CR, Boulanger KT, et al. Chiropractic care for patients aged 55 years and older: report from a practice-based research program. J Am Geriatr Soc. 2000;48(5):534-45. [pmid: 10811547].
26 Hawk C, Long CR. Factors affecting use of chiropractic services in seven midwestern states of the United States. J Rural Health. 1999;15(2):233-9. [pmid: 10511760].
27 Carey TS, Garrett JM, Jackman A, et al. Recurrence and care seeking after acute back pain: results of a long-term follow-up study. North Carolina Back Pain Project. Med Care. 1999;37(2):157-64. [pmid: 10024120].
28 Hurwitz EL, Coulter ID, Adams AH, et al. Use of chiropractic services from 1985 through 1991 in the United States and Canada. Am J Public Health. 1998;88(5):771-6. [pmid: 9585743]. [pmcid: 1508935].
29 Hurwitz EL, Morgenstern H. The effects of comorbidity and other factors on medical versus chiropractic care for back problems. Spine. 1997;22(19):2254-63. [pmid: 9346146].
30 Mielenz TJ, Carey TS, Dyrek DA, et al. Physical therapy utilization by patients with acute low back pain. Phys Ther. 1997;77(10):1040-51. [pmid: 9327819].
31 Carey TS, Evans AT, Hadler NM, et al. Acute severe low back pain. A population-based study of prevalence and care-seeking. Spine. 1996;21(3):339-44. [pmid: 8742211].
32 Stano M, Smith M. Chiropractic and medical costs of low back care. Med Care. 1996;34(3):191-204. [pmid: 8628040].
33 Shekelle PG, Hurwitz EL, Coulter I, et al. The appropriateness of chiropractic spinal manipulation for low back pain: a pilot study. J Manipulative Physiol Ther. 1995;18(5):265-70. [pmid: 7673792].
34 Shekelle PG, Markovich M, Louie R. Comparing the costs between provider types of episodes of back pain care. Spine. 1995;20(2):221-6. [pmid: 7716629].
35 Jette AM, Smith K, Haley SM, et al. Physical therapy episodes of care for patients with low back pain. Phys Ther. 1994;74(2):101-10. [pmid: 8290616].
36 Jarvis KB, Phillips RB, Morris EK. Cost per case comparison of back injury claims of chiropractic versus medical management for conditions with identical diagnostic codes. J Occup Med. 1991;33(8):847-52. [pmid: 1834819].
37 Nyiendo J. Disabling low back Oregon workers' compensation claims. Part III: Diagnostic and treatment procedures and associated costs. J Manipulative Physiol Ther. 1991;14(5):287-97. [pmid: 1833494].
38 Shekelle PG, Brook RH. A community-based study of the use of chiropractic services. Am J Public Health. 1991;81(4):439-42. [pmid: 2003620]. [pmcid: 1405032].
39 Wasiak R, McNeely E. Utilization and costs of chiropractic care for work-related low back injuries: Do payment policies make a difference?. Spine J. 2006;6(2):146-53. [pmid: 16517385].
40 Metz RD, Nelson CF, LaBrot T, et al. Chiropractic care: Is it substitution care or add-on care in corporate medical plans?. J Occup Environ Med. 2004;46(8):847-55. [pmid: 15300137].
41 Gilkey DP, Keefe TJ, Hautaluoma JE, et al. Low back pain in residential construction carpenters: Hispanic and non-Hispanic chiropractic patient differences. Topics in Clinical Chiropractic. 2002;9(4):26-32.
42 Coulter ID, Shekelle PG. Chiropractic in North America: a descriptive analysis. J Manipulative Physiol Ther. 2005;28(2):83-9. [pmid: 15800506].
43 Shekelle PG, Markovich M, Louie R. Factors associated with choosing a chiropractor for episodes of back pain care. Med Care. 1995;33(8):842-50. [pmid: 7637405].
44 Cherkin DC, Deyo RA, Sherman KJ, et al. Characteristics of visits to licensed acupuncturists, chiropractors, massage therapists, and naturopathic physicians. J Am Board Fam Pract. 2002;15(6):463-72. [pmid: 12463292].
45 Burke A, Upchurch DM, Dye C, et al. Acupuncture use in the United States: findings from the National Health Interview Survey. J Altern Complement Med. 2006;12(7):639-48. [pmid: 16970534].
46 National Guideline Clearinghouse (NGC). Guideline Summary. Acupuncture and electroacupuncture: evidence based treatment guidelines. In: National Guideline Clearinghouse (NGC). [http://www.guideline.gov/summary/summary.aspx?doc_id=9343&nbr=5010&ss=6&xl=999] Rockville (MD): [cited 2008]. Available at: http://www.guideline.gov
47 Wang SM, DeZinno P, Fermo L, et al. Complementary and alternative medicine for low-back pain in pregnancy: a cross-sectional survey. J Altern Complement Med. 2005;11(3):459-64. [pmid: 15992230].
48 Sawni A, Thomas R. Pediatricians' attitudes, experience and referral patterns regarding Complementary/Alternative Medicine: a national survey. BMC Complement Altern Med. 2007;7:18. [pmid: 17547752]. [pmcid: 1894987].
49 Pincus T, Foster NE, Vogel S, et al. Attitudes to back pain amongst musculoskeletal practitioners: a comparison of professional groups and practice settings using the ABS-mp. Manual Ther. 2007;12(2):167-75.
50 Pincus T, Vogel S, Breen A, et al. Persistent back pain—why do physical therapy clinicians continue treatment? A mixed methods study of chiropractors, osteopaths and physiotherapists. Eur J Pain. 2006;10(1):67-76. [pmid: 16291300].
51 Chenot JF, Becker A, Leonhardt C, et al. Determinants for receiving acupuncture for LBP and associated treatments: a prospective cohort study. BMC Health Serv Res. 2006;6:149. [pmid: 17112374]. [pmcid: 1657011].
52 Long L, Huntley A, Ernst E. Which complementary and alternative therapies benefit which conditions? A survey of the opinions of 223 professional organizations. Complement Ther Med. 2001;9(3):178-85. [pmid: 11926432].
53 Carey TS, Garrett J, Jackman A, et al. The outcomes and costs of care for acute low back pain among patients seen by primary care practitioners, chiropractors, and orthopedic surgeons. The North Carolina Back Pain Project. N Engl J Med. 1995;333(14):913-7. [pmid: 7666878].
54 Sundararajan V, Konrad TR, Garrett J, et al. Patterns and determinants of multiple provider use in patients with acute low back pain. J Gen Intern Med. 1998;13(8):528-33. [pmid: 9734789]. [pmcid: 1497001].
55 Cherkin DC, Deyo RA, Battie M, et al. A comparison of physical therapy, chiropractic manipulation, and provision of an educational booklet for the treatment of patients with low back pain. N Engl J Med. 1998;339(15):1021-9. [pmid: 9761803].
56 Eisenberg DM, Post DE, Davis RB, et al. Addition of choice of complementary therapies to usual care for acute low back pain: a randomized controlled trial. Spine. 2007;32(2):151-8. [pmid: 17224808].
57 Haas M, Sharma R, Stano M. Cost-effectiveness of medical and chiropractic care for acute and chronic low back pain. J Manipulative Physiol Ther. 2005;28(8):555-63. [pmid: 16226622].
58 Kominski GF, Heslin KC, Morgenstern H, et al. Economic evaluation of four treatments for low-back pain: results from a randomized controlled trial. Med Care. 2005;43(5):428-35. [pmid: 15838406].
59 Smith M, Stano M. Costs and recurrences of chiropractic and medical episodes of low-back care. J Manipulative Physiol Ther. 1997;20(1):5-12. [pmid: 9004117].
60 Williams DA, Feuerstein M, Durbin D, et al. Health care and indemnity costs across the natural history of disability in occupational low back pain. Spine. 1998;23(21):2329-36. [pmid: 9820914].
61 Legorreta AP, Metz RD, Nelson CF, et al. Comparative analysis of individuals with and without chiropractic coverage: patient characteristics, utilization, and costs. Arch Intern Med. 2004;164(18):1985-92. [pmid: 15477432].
62 Ernst E. Prevalence of use of complementary/alternative medicine: A systematic review. Bull World Health Organ. 2000;78(2):252-7. [pmid: 10743298].
63 Martin BI, Deyo RA, Mirza SK, et al. Expenditures and health status among adults with back and neck problems. JAMA. 2008;299(6):656-64. [pmid: 18270354].
64 Strine TW, Hootman JM. US national prevalence and correlates of low back and neck pain among adults. Arthritis Rheum. 2007;57(4):656-65. [pmid: 17471542].
65 Ricci JA, Stewart WF, Chee E, et al. Back pain exacerbations and lost productive time costs in United States workers. Spine. 2006;31(26):3052-60. [pmid: 17173003].
66 Stewart WF, Ricci JA, Chee E, et al. Lost productive time and cost due to common pain conditions in the US workforce. JAMA. 2003;290(18):2443-54. [pmid: 14612481].
67 Jones MA, Stratton G, Reilly T, et al. A school-based survey of recurrent non-specific low-back pain prevalence and consequences in children. Health Educ Res. 2004;19(3):284-9. [pmid: 15140848].
68 Loney PL, Stratford PW. The prevalence of low back pain in adults: a methodological review of the literature. Phys Ther. 1999;79(4):384-96. [pmid: 10201544].
69 United States Bureau of Census. Statistical Abstract of the United States 1996. [http://www.census.gov/prod/2/gen/96statab/96statab.html]. Washington (DC): [cited 2008]. Available at: http://www.census.gov
70 Hansson EK, Hansson TH. The costs for persons sick-listed more than one month because of low back or neck problems. A two-year prospective study of Swedish patients. Eur Spine J. 2005;14(4):337-45. [pmid: 15150703].
71 Astin JA. Why patients use alternative medicine: results of a national study. JAMA. 1998;279(19):1548-53. [pmid: 9605899].
72 White House Commission. White House Commission on Complementary and Alternative Medicine Policy. NIH Publication 03-5411. 2002.
73 National Center for Complementary and Alternative Medicine (NCCAM). CAMBasics. [http://nccam.nih.gov/health/whatiscam/]. Bethesda (MD): [cited 2008]. Available at: http://nccam.nih.gov/health
74 Wootton JC, Sparber A. Surveys of Complementary and Alternative Medicine Usage: A review of general population trends and specific patient Populations. Semin Integr Med. 2003;1(1):10-24.
75 World Health Organization (WHO). WHO Traditional Medicine Strategy. [http://whqlibdoc.who.int/hq/2002/WHO_EDM_TRM_2002.1.pdf]. Geneva (Switzerland): [cited 2008]. Available at: http://www.who.int/medicines/publications/traditionalpolicy/en/index.html
76 Conboy L, Patel S, Kaptchuk TJ, et al. Sociodemographic Determinants of the Utilization of Specific Types of Complementary and Alternative Medicine: An Analysis Based on a Nationally Representative Survey Sample. J Altern Complement Med. 2005;11(6):977-94. [pmid: 16398589].
77 Wootton JC, Sparber A. Surveys of complementary and alternative medicine: Part I. General trends and demographic groups. J Altern Complement Med. 2001;7(2):195-208. [pmid: 11327525].
78 McMahan S, Lutz R. Alternative therapy use among the young-old (Ages 65 to 74): An evaluation of the MIDUS database. J Appl Gerontol. 2004;23(2):91-103.
79 Schuster TL, Dobson M, Jauregui M, et al. Wellness lifestyles I: A theoretical framework linking wellness, health lifestyles, and complementary and alternative medicine. J Altern Complement Med. 2004;10(2):349-56. [pmid: 15165416].
80 Bhandari A, Wagner T. Self-reported utilization of health care services: improving measurement and accuracy. Med Care Res Rev. 2006;63(2):217-35. [pmid: 16595412].
81 MacLennan AH, Myers SP, Taylor AW. The continuing use of complementary and alternative medicine in South Australia: costs and beliefs in 2004. Med J Aust. 2006;184(1):27-31. [pmid: 16398628].
82 Phillips KA, Morrison KR, Andersen R, et al. Understanding the context of healthcare utilization: assessing environmental and provider-related variables in the behavioral model of utilization. Health Serv Res. 1998;33(3 Pt 1):571-96. [pmid: 9685123]. [pmcid: 1070277].
83 Mootz RD, Cherkin DC, Odegard CE, et al. Characteristics of chiropractic practitioners, patients, and encounters in Massachusetts and Arizona. J Manipulative Physiol Ther. 2005;28(9):645-53. [pmid: 16326233].
84 Kelley K, Clark B, Brown V, et al. Good practice in the conduct and reporting of survey research. Int J Qual Health Care. 2003;15(3):261-6. [pmid: 12803354].
85 Schneeweiss S, Avorn J. A review of uses of health care utilization databases for epidemiologic research on therapeutics. J Clin Epidemiol. 2005;58(4):323-37. [pmid: 15862718].
86 Raina P, Torrance-Rynard V, Wong M, et al. Agreement between self-reported and routinely collected health-care utilization data among seniors. Health Serv Res. 2002;37(3):751-74. [pmid: 12132604]. [pmcid: 1434660].
87 Schneider, D, Appleton, L, and McLemore, T. Reason for Visit Classification for Ambulatory Care. National Center for Health Statistics.(PHS) 79-1352.PB88-226196.PC A04 MF A01, February 1979. Hyattsville (MD): [cited 2008]. Available at: http://www.cdc.gov/nchs/products/pubs/pubd/series/ser.htm
88 Committee on the Use of Complementary and Alternative Medicine by the American Public. Prevalence, Cost and Patterns of CAM Use. In: Complementary and Alternative Medicine in the United States. 2005. National Academies Press. Washington (DC): [cited 2008]. Available at: http://www.nap.edu/catalog.php?record_id=11182
89 The Agree Collaboration. Appraisal of Guidelines for Research & Evaluation (AGREE) Instrument. 2001. London (UK): [cited 2008]. Available at: www.agreecollaboration.org/pdf/agreeinstrumentfinal.pdf
90 Ofman JJ, Sullivan SD, Neumann PJ, et al. Examining the value and quality of health economic analyses: implications of utilizing the QHES. J Manag Care Pharm. 2003;9(1):53-61. [pmid: 14613362].
91 McEachrane-Gross FP, Liebschutz JM, Berlowitz D. Use of selected complementary and alternative medicine (CAM) treatments in veterans with cancer or chronic pain: a cross-sectional survey. BMC Complement Altern Med. 2006;6:34. [pmid: 17026768]. [pmcid: 1617117].
92 Widerstrom-Noga EG, Turk DC. Types and effectiveness of treatments used by people with chronic pain associated with spinal cord injuries: influence of pain and psychosocial characteristics. Spinal Cord. 2003;41(11):600-9. [pmid: 14569261].
93 Warms CA, Turner JA, Marshall HM, et al. Treatments for chronic pain associated with spinal cord injuries: many are tried, few are helpful. Clin J Pain. 2002;18(3):154-63. [pmid: 12048417].
94 Nayak S, Matheis RJ, Agostinelli S, et al. The use of complementary and alternative therapies for chronic pain following spinal cord injury: a pilot survey. J Spinal Cord Med. 2001;24(1):54-62. [pmid: 11587436].
95 Gulla J, Singer AJ. Use of alternative therapies among emergency department patients. Ann Emerg Med. 2000;35(3):226-8. [pmid: 10692188].
96 Wainapel SF, Thomas AD, Kahan BS. Use of alternative therapies by rehabilitation outpatients. Arch Phys Med Rehabil. 1998;79(8):1003-5. [pmid: 9710177].
97 Tindle HA, Wolsko P, Davis RB, et al. Factors associated with the use of mind body therapies among United States adults with musculoskeletal pain. Complement Ther Med. 2005;13(3):155-64. [pmid: 16150369].
98 Astin JA, Pelletier KR, Marie A, et al. Complementary and alternative medicine use among elderly persons: One-year analysis of a Blue Shield Medicare supplement. J Gerontol A Biol Sci Med Sci. 2000;55(1):M4-M9. [pmid: 10719766].
99 Bausell RB, Lee WL, Berman BM. Demographic and health-related correlates of visits to complementary and alternative medical providers. Med Care. 2001;39(2):190-6. [pmid: 11176556].
100 Bullock ML, Pheley AM, Kiresuk TJ, et al. Characteristics and Complaints of Patients Seeking Therapy at a Hospital-Based Alternative Medicine Clinic. J Altern Complement Med. 1997;3(1):31-7. [pmid: 9395692].
101 Foster DF, Phillips RS, Hamel MB, et al. Alternative medicine use in older Americans. J Am Geriatr Soc. 2000;48(12):1560-5. [pmid: 11129743].
102 Eisenberg DM, Kessler RC, Foster C, et al. Unconventional medicine in the United States. Prevalence, costs, and patterns of use. N Engl J Med. 1993;328(4):246-52. [pmid: 8418405].
103 Wolsko PM, Eisenberg DM, Davis RB, et al. Insurance coverage, medical conditions, and visits to alternative medicine providers: Results of a national survey. Arch Intern Med. 2002;162(3):281-7. [pmid: 11822920].
104 Kronenberg F, Cushman LF, Wade CM, et al. Race/ethnicity and women's use of complementary, and alternative medicine in the United States: Results of a national survey. Am J Public Health. 2006;96(7):1236-42. [pmid: 16735632]. [pmcid: 1483863].
105 Cherkin DC, Deyo RA, Sherman KJ, et al. Characteristics of licensed acupuncturists, chiropractors, massage therapists, and naturopathic physicians. J Am Board Fam Pract. 2002;15(5):378-90. [pmid: 12350060].
106 Swift MB, Cole DC, Beaton DE, et al. Health care utilization and workplace interventions for neck and upper limb problems among newspaper workers. J Occup Environ Med. 2001;43(3):265-75. [pmid: 11285875].
107 Pringle M, Tyreman S. Study of 500 patients attending an osteopathic practice. Br J Gen Pract. 1993;43(366):15-8. [pmid: 8457357]. [pmcid: 1372201].
108 Freeman BJC, Ainscow DAP. Use of alternative therapy by orthopaedic outpatients. J Orthop Rheumatol. 1996;9(1):57-9.
109 Read DT, Wilson FJ, Gemmell HA. Activator as a therapeutic instrument: Survey of usage and opinions amongst members of the British Chiropractic Association. Clin Chiro. 2006;9(2):70-5.
110 Cooney M, Kelliher S, Barrett A. An investigation into the prevalence of use of alternative therapy among physiotherapy outpatients. Physiotherapy Ireland. 2000;21(1):3-8.
111 Kerr DP, Walsh DM, Baxter GD. A study of the use of acupuncture in physiotherapy. Complement Ther Med. 2001;9(1):21-7. [pmid: 11264966].
112 Norrbrink BC, Lundeberg T. Non-pharmacological pain-relieving therapies in individuals with spinal cord injury: a patient perspective. Complement Ther Med. 2004;12(4):189-97. [pmid: 15649832].
113 Bassols A, Bosch F, Banos JE. How does the general population treat their pain? A survey in Catalonia, Spain. J Pain Symptom Manage. 2002;23(4):318-28. [pmid: 11997201].
114 Ong CK, Petersen S, Bodeker GC, et al. Health status of people using complementary and alternative medical practitioner services in 4 English counties. Am J Public Health. 2002;92(10):1653-6. [pmid: 12356616]. [pmcid: 1447302].
115 Muhajarine N, Neudorf C, Martin K. Concurrent consultations with physicians and providers of alternative care: results from a population-based study. Can J Public Health. 2000;91(6):449-53. [pmid: 11200737].
116 Ramsay C, Walker M, Alexander J. Alternative Medicine in Canada: Use and Public Opinions. Public Policy Sources, 21. http://oldfraser.lexi.net/publications/pps/21/: Fraser Institute; 1999.
117 Esmail N. Use and Complementary and Alternative Medicine in Canada: Trends in Use and Public Attitudes, 1997-2006. Public Policy Sources, Number 87. Fraser Institute; 2007.
118 Foltz V, St Pierre Y, Rozenberg S, et al. Use of complementary and alternative therapies by patients with self-reported chronic back pain: a nationwide survey in Canada. Joint, Bone, Spine. 2005;72(6):571-7. [pmid: 16256395].
119 Walker BF, Muller R, Grant WD. Low back pain in Australian adults. health provider utilization and care seeking. J Manipulative Physiol Ther. 2004;27(5):327-35. [pmid: 15195040].
120 Hopman WM, Towheed TE, Gao Y, et al. Prevalence of and factors associated with glucosamine use in Canada. Osteoarthr Cartilage. 2006;14(12):1288-93.
121 Groenendijk JJ, Swinkels IC, de Bakker D, et al. Physical therapy management of low back pain has changed. Health Policy. 2007;80(3):492-9. [pmid: 16787681].
122 Burton AK, McClune TD, Clarke RD, et al. Long-term follow-up of patients with low back pain attending for manipulative care: outcomes and predictors. Manual Ther. 2004;9(1):30-5.
123 Hartvigsen J, Bolding-Jensen O, Hviid H, et al. Danish chiropractic patients then and now - a comparison between 1962 and 1999. J Manipulative Physiol Ther. 2003;26(2):65-9. [pmid: 12584504].
124 Kilvaer A, Rasmussen G, Soot T, et al. A comparison between referred and nonreferred patients in chiropractic practices in Norway. J Manipulative Physiol Ther. 1997;20(7):448-53. [pmid: 9310899].
125 Davies HT, Crombie IK, Macrae WA, et al. Audit in pain clinics: changing the management of low-back and nerve-damage pain. Anaesthesia. 1996;51(7):641-6. [pmid: 8758155].
126 Giles LG, Muller R, Winter GJ. Patient satisfaction, characteristics, radiology, and complications associated with attending a specialized government-funded multidisciplinary spinal pain unit. J Manipulative Physiol Ther. 2003;26(5):293-9. [pmid: 12819625].
127 Sibbritt D, Adams J, Young AF. The characteristics of middle aged Australian women who consult acupuncturists. Acupunct Med. 2007;25(12):22-8. [pmid: 17641564].
128 Caswell AM, West J. An investigation into the factors affecting patient selection of chronic low back management methods, with particular reference to non-utilization of the complimentary therapies, in the United Kingdom. J Back Musculoskel Rehabil. 2002;16(4):121-33.
129 Scheurmier N, Breen AC. A pilot study of the purchase of manipulation services for acute low back pain in the United Kingdom. J Manipulative Physiol Ther. 1998;21(1):14-8. [pmid: 9467096].
130 Vos C, Verhagen A, Passchier J, et al. Management of acute neck pain in general practice: a prospective study. Br J Gen Pract. 2007;57(534):23-8. [pmid: 17244420]. [pmcid: 2032696].
131 Cote P, Cassidy JD, Carroll L. The treatment of neck and low back pain: who seeks care? who goes where?. Med Care. 2001;39(9):956-67. [pmid: 11502953].
132 Armstrong MP, McDonough S, Baxter GD. Clinical guidelines versus clinical practice in the management of low back pain. Int J Clin Pract. 2003;57(1):9-13. [pmid: 12587934].
133 Jacobs P, Schopflocher D, Klarenbach S, et al. A health production function for persons with back problems: results from the Canadian Community Health Survey of 2000. Spine. 2004;29(20):2304-8. [pmid: 15480146].
134 Hartvigsen J, Sorensen LP, Graesborg K, et al. Chiropractic patients in Denmark: a short description of basic characteristics. J Manipulative Physiol Ther. 2002;25(3):162-7. [pmid: 11986577].
135 Cote P, Hogg-Johnson S, Cassidy JD, et al. Initial patterns of clinical care and recovery from whiplash injuries: a population-based cohort study. Arch Intern Med. 2005;165(19):2257-63. [pmid: 16246992].
136 Ong CK, Doll H, Bodeker G, et al. Use of osteopathic or chiropractic services among people with back pain: a UK population survey. Health Soc Care Comm. 2004;12(3):265-73.
137 Boon HS, Cherkin DC, Erro J, et al. Practice patterns of naturopathic physicians: Results from a random survey of licensed practitioners in two US States. BMC Complement Altern Med. 2004;4:14. [pmid: 15496231]. [pmcid: 529271].
138 Saper RB, Eisenberg DM, Davis RB, et al. Prevalence and patterns of adult yoga use in the United States: Results of a national survey. Altern Ther Health Med. 2004;10(2):44-9. [pmid: 15055093].
139 McCaffrey AM, Eisenberg DM, Legedza AT, et al. Prayer for health concerns: results of a national survey on prevalence and patterns of use. Arch Intern Med. 2004;164(8):858-62. [pmid: 15111371].
140 Wolsko PM, Eisenberg DM, Davis RB, et al. Use of mind-body medical therapies. J Gen Intern Med. 2004;19(1):43-50. [pmid: 14748859]. [pmcid: 1494676].
141 National Guideline Clearinghouse (NCG). Guideline Summary: Clinical Practice Guidelines for Electrical Stimulation. In: National Guideline Clearinghouse (NGC). [http://www.guideline.gov/summary/summary.aspx?doc_id=9918]. Rockville (MD): [cited 2008]. Available at: http://www.guideline.gov.
142 National Guideline Clearinghouse (NGC). Guideline Summary: Clinical practice guidelines for acupuncture. In: National Guideline Clearinghouse (NGC). [http://www.guideline.gov/summary/summary.aspx?doc_id=9921]. Rockville (MD): [cited 2008]. Available at: http://www.guideline.gov
143 National Guideline Clearinghouse (NGC). Guideline Summary: Clinical practice guidelines for biofeedback. In: National Guideline Clearinghouse (NGC). [http://www.guideline.gov/summary/summary.aspx?doc_id=9912]. Rockville (MD): [cited 2008]. Available at: http://www.guideline.gov
144 National Guideline Clearinghouse (NGC). Guideline Summary: Interventional techniques: evidence-based practice guidelines in the management of chronic spinal pain. In: National Guideline Clearinghouse (NGC). [http://www.guideline.gov/summary/summary.aspx?ss=15&doc_id=10531&nbr=5510]. Rockville (MD): [cited 2008]. Available at: http://www.guideline.gov
145 National Guideline Clearinghouse (NGC). Guideline Summary: Acute low back pain. In: National Guideline Clearinghouse (NGC). [http://www.guideline.gov/summary/summary.aspx?ss=15&doc_id=4112&nbr=3157]. Rockville (MD): [cited 2008]. Available at: http://www.guideline.gov
146 National Guideline Clearinghouse (NGC). Guideline Summary: Primary care interventions to prevent low back pain in adults: recommendation statement. In: National guideline Clearinghouse (NGC). [http://www.guideline.gov/summary/summary.aspx?doc_id=4772]. Rockville (MD); [cited 2008]. Available at: http://www.guideline.gov
147 National Guideline Clearinghouse (NGC). Guideline Summary: Chronic neck pain. In: National Guideline Clearinghouse (NGC). [http://www.guideline.gov/summary/summary.aspx?doc_id=8297]. Rockville (MD): [cited 2008]. Available at: http://www.guideline.gov
148 Koes BW, van Tulder MW, Ostelo R, et al. Clinical guidelines for the management of low back pain in primary care: an international comparison. Spine. 2001;26(22):2504-13. [pmid: 11707719].
149 Council on Chiropractic Guidelines and Practice Parameters (CCGPP) Research Commission. Literature Synthesis: Chiropractic management of low back pain and low back related leg complaints (Final Version). In: Council on Chiropractic Guidelines and Practice Parameters (CCGPP). [http://www.ccgpp.org/lowbackliterature.pdf]. Lexington (SC): [cited 2008]. Available at: www.ccgpp.org/view.htm
150 National Guideline Clearinghouse (NGC). Guideline Summary: Vertebral subluxation in chiropractic practice. In: National Guideline Clearinghouse (NGC). [http://www.guideline.gov/summary/summary.aspx?doc_id=4746]. Rockville (MD): [cited 2008]. Available at: http://www.guideline.gov
151 National Guideline Clearinghouse (NGC). Guideline Summary: Low back - lumbar & thoracic (acute & chronic). In: National Guideline Clearinghouse (NGC). [http://www.guideline.gov/summary/summary.aspx?ss=15&doc_id=11024&nbr=5804]. Rockville (MD): [cited 2008]. Available at: http://www.guideline.gov
152 National Guideline Clearinghouse (NGC). Guideline Summary: Neck and upper back (acute & chronic). In: National Guideline Clearinghouse (NGC). [http://www.guideline.gov/summary/summary.aspx?ss=15&doc_id=11025&nbr=5805]. Rockville (MD): [cited 2008]. Available at: http://www.guideline.gov
153 California Health Benefits Review Program (CHBRP). Analysis of Assembly Bill 54: Health Care Coverage: Acupuncture. Report to California State Legislature 2007-2008. Oakland, CA: 2007. CHBRP 07-07, June 22, 2007.
154 National Guideline Clearinghouse (NGC). Guideline Summary: Neck and Upper Back Complaints. In: National Guideline Clearinghouse (NGC). [http://www.guideline.gov/summary/summary.aspx?doc_id=8542]. Rockville (MD): [cited 2008]. Available at: http://www.guideline.gov
155 Elk Grove Village. Low back complaints. National Guideline Clearinghouse. 2004. http://www.guideline.gov/summary/summary.aspx?doc_id=8546&nbr=4755&ss=6&xl=999
156 National Guideline Clearinghouse (NGC). Guideline Summary. Diagnosis and treatment of low back pain: A joint clinical practice guideline from the American College of Physicians and the American Pain Society. In: National Guideline Clearinghouse (NGC). [http://www.guideline.gov/summary/summary.aspx?doc_id=11515&nbr=005968]. Rockville (MD); [cited 2008]. Available at: http://www.guideline.gov
157 National Guideline Clearinghouse (NGC). Guideline Summary: Adult low back pain. In: National Guideline Clearinghouse (NGC). [http://www.guideline.gov/summary/summary.aspx?doc_id=9863]. Rockville (MD): [cited 2008]. Available at: http://www.guideline.gov
158 National Guideline Clearinghouse (NGC). Guideline Summary: Manual medicine guidelines for musculoskeletal injuries. In: National Guideline Clearinghouse (NGC). [http://www.guideline.gov/summary/summary.aspx?ss=15&doc_id=10798&nbr=5626]. Rockville (MD): [cited 2008]. Available at: http://www.guideline.gov
159 Hall CM, Brody LT. Therapeutic Exercise: Moving Toward Function. 2nd ed. Baltimore, MD: Lippincott Williams & Wilkins; 2005.