# Executive Summary

## Introduction

The high prevalence rates for neck, thoracic, and low back pain, indicate the importance of this health problem as a public health concern. Back related pain has a high morbidity and cost burden in the United States (U.S.) and other industrialized countries.^1^–^4^ Treatment for this pain can be multidimensional and include conventional care, complementary and alternative medicines (CAM), or both. CAM is comprised of a group of therapies that are considered to be outside the scope of treatment of most conventional practitioners or therapies. The large constellation of treatment modalities that constitute CAM are used widely throughout the U.S. and internationally, both by individuals who are healthy and those who have specific health concerns such as back pain.^5,^ ^6^ Use of CAM therapies can include visits to specific practitioners, as well as self-treatment (for example, when using herbal products, or relaxation techniques).

## Scope and Purposes of This Systematic Review

What CAM therapies are being used for treatment of persons with back pain in the United States? (overarching question)

1) What is the relative utilization for the different CAM therapies?
  i Does the utilization differ by where the back pain is anatomically located (i.e., neck, mid-back, low back)?
  ii Which therapies are used as complementary to conventional care and which are used as alternative?
  iii When more than one therapy is used for back pain, how are these combined?
2) What is the utilization that is recommended by different types of healthcare providers?
  i How do these recommendations compare to the actual utilization reported in studies from question one?
  ii How do the recommended and actual utilization reported differ by CAM practitioner type?
3) What are usual costs for these therapies per treatment and for the prescribed course of treatments?
  i How much of this cost is covered by insurance or included in health plans?

## Methods

### Analytic Framework

When considering the use of health services, the traditional understanding of utilization is a visit to a CAM provider or service. However, CAM includes the use of products and practices that may not be directed by a CAM provider. As such we adopted the model by Foubadbakhsh and Stommel^7^ as our analytic framework. This model, adapted specifically for CAM from Andersen's behavioral model of healthcare utilization,^8^ goes beyond provider directed service provision and incorporates CAM resources such as nutritional supplements and self-directed CAM practices such as meditation.

### Searching and Eligibility Criteria

Standard systematic review methodology was employed. Traditional bibliographic databases, CAM specific databases and grey literature sources were searched from 1990 to November 2007. The traditional medical and allied health databases searched included; Medline^®^; CINAHL^®^; PsychINFO; EMBASE^®^, and Cochrane Central Register of Controlled Trials^®^. Alternative therapy bibliographic databases included: AMED; Index to Chiropractic Literature (ILC); National Library of Health: Complementary and Alternative Medicine Specialist Library; Acubriefs; Bandoliers CAM database; Mantis; Micromedex; Agricola; and HOM-INFORM.

Eligible studies were limited to those published in English and from 1990 forward. National U.S. population based surveys that probed CAM utilization were searched from 1970 to November 2007. Although our focus was on U.S. utilization of CAM, studies undertaken in Canada, the United Kingdom, Europe, Australia, and New Zealand were also eligible and compared to American patterns of use.

Studies were included if they presented information on the utilization of CAM therapies, CAM practitioners, or costs associated with CAM service use in adults with back pain in the neck, thorax, or lumbar regions. Self-administered home remedies were also included. The use of medical injections, prescription drugs, and back surgery were excluded as were mechanical traction, a variety of exercise techniques, patient education, cognitive behavioral therapy, deep brain therapy and orthoses. There were no restrictions for primary study designs. Clinical practice guidelines (CPG) were eligible if they focused on back pain and CAM use within the U.S.. Similarly, studies evaluating costs for CAM use in the United States for back pain were included.

## Results

From an initial 8,323 unique citations, 6,667 were excluded during title and abstract screening. The full text publications of 239 citations were retrieved and 95 of these were excluded as they did not address utilization or costs associated with the use of CAM; 103 publications were eligible for data extraction. We identified 19 CPG and 8 were excluded as there were no recommendations for optimal utilization. There were 22 publications on providers views about CAM and of these 16 were excluded as they did not focus on use. There were 18 studies evaluating the use of CAM therapies and cost outcomes relating to the use of CAM for back pain.

## Question 1: What is the Relative Utilization for the Different CAM Therapies?

From 103 citations, 85 were unique to utilization and nine overlapped (total 94) with the cost papers; of these, 29 publications had limited information on utilization as the data were not stratified for persons with back pain. Of the remaining 65 publications, 43 were from the U.S. and 22 from other eligible countries. For the purposes of this executive summary we have limited our presentation to U.S utilization patterns and trends.

### Relative Use of CAM Therapies in Persons With Back Pain

We identified those publications that presented the relative use of CAM therapies in order to rank them from the most to least frequently utilized by persons with back pain. We did not select studies where subjects were recruited from the practices of CAM providers, as this would not reflect relative utilization but would reflect practice patterns with respect to combining differing CAM therapies. Four U.S. studies^9^–^12^ reported utilization data for a minimum of four different CAM therapies or practitioners. All but one^9^ measured lifetime use of CAM and all subjects had chronic or recurrent back pain. Chiropractor or “chiropractic” was the CAM therapy that was most frequently used by patients with chronic low back or combined neck and back pain in three publications.^10^–^12^ In one publication^9^ massage was the most frequently used CAM therapy; massage also ranked as the second mostly frequently used therapy in the other publications. Acupuncture was the third most frequently used therapy. When reported, other frequently used modalities were prayer and spirituality and glucosamine.

Given the limited number of studies that evaluated relative CAM utilization, we explored patterns for those individual therapies shown to be frequently used by persons with back pain.

### Chiropractic/Spinal Manipulation

Thirty-six publications^9^–^44^ on chiropractic/spinal manipulation, were undertaken in the U.S. The majority (n = 24) reported on low back pain (LBP) and the fewest on neck (n = 3) and thoracic spine (n = 1). Our review suggests that chiropractic care/spinal manipulation is commonly sought by patients with back pain. In the 10 cross-sectional studies^9,^ ^12^–^14,^ ^18,^ ^19,^ ^26,^ ^29,^ ^31,^ ^35^ based predominately on random or systematic samples, rates of utilization varied from 16^14^ to 45 percent.^18^ Eligible U.S. trials on LBP populations found that rates of attending for chiropractic/spinal manipulative therapy range from 10 to 47 percent.^9,^ ^11,^ ^18,^ ^19,^ ^28,^ ^30,^ ^32,^ ^35,^ ^41^ The number of visits for chiropractic care or other providers of spinal manipulative therapy varied from a mean of 4.3 to 15.7.^9,^ ^19,^ ^22^–^24,^ ^28,^ ^33^ Between 79 and 94 percent of treatment by chiropractors included spinal manipulative therapy.^9,^ ^11,^ ^22,^ ^23,^ ^28,^ ^33,^ ^37^ Three studies provided some evidence for a gradient of use based on anatomical regions; thoracic pain was treated least often,^40^ followed by the neck, with the low back being the most commonly treated.^25,^ ^40,^ ^44^

Chiropractors were the providers of spinal manipulative therapy in most publications (n = 34), and physiotherapists in two publications.^30,^ ^35^ Details on the type of spinal manipulation was provided in three only publications.^15,^ ^24,^ ^33^ The available information suggests that roughly equal proportions of LBP patients use chiropractic as complementary to conventional care and as an alternate. Current literature provides little insight into the manner in which chiropractic/spinal manipulation is combined with other therapies for back pain. Despite the common use of chiropractic/spinal manipulation by patients with back pain the current literature provides limited data on utilization.

### Massage

Twelve U.S. publications^9,^ ^11,^ ^12,^ ^15,^ ^16,^ ^18,^ ^20,^ ^22,^ ^23,^ ^30,^ ^33,^ ^44^ evaluated the use of massage in persons with back pain. The majority of populations were from specialized clinical practices or from the practices of licensed CAM providers. Two publications^16,^ ^20^ using data from large health claims databases showed low rates of massage utilization for LBP, varying from 4 to 5 percent of the total sample. One study recruiting from a population based sample^12^ reported a massage utilization rate of 14.1 (95 percent CI, 10.8–17.4) for patients with combined neck and back pain. Publications that evaluated use of massage in smaller samples, showed rates of use varying from 17 to 52 percent. The timeframe of reported use was one year, with the exception of two studies evaluating lifetime use.^11,^ ^18^ The majority of studies reported on LBP (n = 9) and mostly for chronic pain; one study^44^ reported on utilization of massage for neck pain. Only one publication^15^ provided any detail as to the type of massage administered, the provider, and use with other CAM therapies, or with conventional care.

### Acupuncture

Eight publications^10^–^12,^ ^15,^ ^16,^ ^18,^ ^44,^ ^45^ evaluated the use of acupuncture in persons with back pain and all but one used self-report methods.^16^ Two of these studies^12,^ ^45^ were based on randomly selected general population samples and, as expected, these showed markedly lower rates of utilization for both neck and unspecified back (1 to 4 percent) and combined neck and back pain (1 percent). Similar rates of utilization were observed (1 percent) in a study evaluating a large administrative database.^16^ All other studies based primarily on subjects from clinical practices or with back pain showed higher rates of utilization (7 to 36 percent). Rates of use also varied by the timeframe for recall (12 months to lifetime prevalence), interval of analysis for administrative databases, and recruitment of subjects from clinical practices.

The majority of publications evaluated LBP or unspecified pain, with utilization for neck or combined neck and back problems being less commonly assessed. No clear pattern emerges for utilization rates as a function of the anatomical back region. One publication^44^ reported no difference in the relative frequency of CAM use for neck and back but another^45^ showed lower rates of use for persons with neck (14 percent) relative to back pain (34 percent). In part this may be due to the limited number of studies, but it may also be related to the lower prevalence of neck pain relative to LBP. Only one publication,^15^ provided any detail as to the specific type of acupuncture, the provider, the overlap with other CAM therapies, or with conventional care.

## Question 2: What is the Utilization Recommended by Different Types of Healthcare Providers?

From 11 eligible CPG only one^46^ made specific utilization recommendations for acute, subacute, chronic and recurrent back patient groups. The recommended frequency from this CPG^46^ for electro-acupuncture was for 2 to 3 times weekly for a duration of 4 weeks (acute and subacute) and 6 to 8 weeks (chronic and recurrent/flare-up). The recommendations were not specific to neck or back problems, and therefore applied to both of these locations. Although very similar in its recommendations, this guideline distinguishes between utilization with respect to an initial and a continuing course of treatment. The CPG recommends re-evaluation after 12 weeks of treatment irrespective of the acuity of the condition.

Six studies^47^–^52^ presented information on provider views on utilization, but none specified details with regards to the frequency or duration of treatment. These publications suggest that the frequency of utilization may be influenced by provider organization policies, insurance coverage, access or availability of CAM services, attitudes of the practitioner, and a public versus private practice setting.^52^

## Question 3: What are the Usual Costs for These Therapies per Treatment and for the Prescribed Course of Treatments?

Our review identified 18 publications that were associated with costs or economic evaluations related to the use of CAM for back pain in the US. The majority of publications (n = 13) focused on costs associated with CAM services for LBP;^16,^ ^20,^ ^32,^ ^37,^ ^39,^ ^53^–^60^ the remaining studies evaluated unspecified^34,^ ^36^ and combined neck and back pain.^61^ Fifteen of the publications were not true economic analyses, but rather cost identification studies. A single study^57^ undertook a complete cost-effectiveness analysis (CEA) from the perspective of the payer.

The majority of publications (n = 13) evaluated chiropractors as the CAM provider.^20,^ ^32,^ ^34,^ ^36,^ ^37,^ ^39,^ ^53^–^55,^ ^57^–^59,^ ^61^ The conventional providers to which they were compared included medical doctors (M.D.s) (n = 11)^16,^ ^20,^ ^32,^ ^34,^ ^36,^ ^37,^ ^53,^ ^54,^ ^56,^ ^59,^ ^60^ or orthopedic surgeons or internists.^53,^ ^54^ The source of payment for the CAM therapies in these studies included private health insurance (n = 5),^16,^ ^32,^ ^34,^ ^59,^ ^61^ workers' compensation insurance (n = 4),^36,^ ^37,^ ^39,^ ^60^ and mixed sources including out of pocket (n = 4).^20,^ ^53,^ ^54,^ ^57^ The three randomized controlled trials^55,^ ^56,^ ^58^ had the study or the participants insurance pay for treatments.

All studies included costs of visits to practitioners, but varied with respect to: a) inclusion of imaging or diagnostic tests, b) visits to specialists, c) back surgery costs, and d) the use of medications. For studies with workers' compensation insurance as the payer, some included costs for lost days^36,^ ^60^ while the others excluded these.^37,^ ^39^ There was no clear trend of relative increase or decrease in costs associated with CAM versus conventional services; interpretation across studies is problematic given the differences in items included within the total costs, and the timeframe for which these were estimated. The only study providing a CEA suggested that chiropractic care was cost-effective for chronic pain patients, but variable for acute pain.

Three publications^20,^ ^53,^ ^57^ were based on samples entirely covered by insurance from private health organizations or workers' compensation. These studies suggest that a greater portion of patients seeking chiropractic care had no insurance coverage than those seeking care from an M.D.

## Discussion

In this systematic review we addressed a series of broad questions related to the utilization of CAM therapies in persons with back pain. Unlike previous reviews,^62^ we found that the majority of studies did differentiate the various types of CAM with respect to use. However, approximately one-third of the literature on patterns of use did not report outcomes stratified for those with back pain.

Our systematic review identifies the need for more research to evaluate the relative utilization and trends over time of CAM use specific to persons with back pain. Differentiating patterns of relative use for acute versus chronic/recurrent back pain and the degree to which different CAM therapies are sought would assist in understanding patterns of use within these populations.

In general, our findings on utilization of CAM in persons with back pain, highlight the need for high quality prospective observational studies to establish utilization data by location of complaint, the specific type of CAM therapy linked to specific providers, the degree to which the care is used as complementary or alternative to conventional care, and the degree to which different CAM therapies are combined for an episode of care. The widely varying rates of use are related to number of factors including: the type of sample recruited (i.e., large national sample or smaller practice based sample), the timeframe for recall (i.e., four weeks versus lifetime use), the anatomical region, and the method used to measure utilization. The majority of studies reported on contact utilization (ever using the service or provider) rather than volume utilization (the frequency and duration of visits). The majority of studies also reported on use for the low back and did not evaluate the effects of the duration of the back pain (acute versus chronic) in regards to the reported use of CAM.

Our evaluation of U.S. CPG showed very limited information on the recommended use of CAM therapies with only a single guideline providing utilization recommendations. A significant gap with regards to recommended utilization for persons with back pain of differing duration and anatomical region has been identified. In part, this lack of recommendations on CAM utilization for back pain may reflect the lack of high quality evidence from randomized trials focusing on the optimal dosage for treatment benefit.

The majority of studies reporting cost outcomes for the use of CAM therapies were cost identification analyses and not true economic analyses; the single study that undertook a formal CEA showed benefit of chiropractic for chronic LBP alone. More research is required to link costs of CAM therapies to outcomes of benefit and harm.

As more “conventional practitioners” choose to use CAM therapies in their “conventional” practices, the distinction between alternative and traditional is becoming blurred. Future studies should endeavor to specify operational definitions for alternative and conventional therapies and providers.

## Conclusions

Although we evaluated a large number of studies (74 that stratified data) on utilization and costs in persons with back pain using CAM therapies, there were significant limitations in understanding the patterns of use across studies. In part the variation and inconsistencies across studies may be attributable to lack of consensus on reporting in utilization and other health services studies; future research to establish these criteria will contribute to evaluation of use.

Our systematic review demonstrates that CAM therapies are frequently used by persons with back pain. Our findings would support the following conclusions and recommendations for future research in this area:

Population

1) Many studies provided minimal information about the characteristics of the sample. In particular, most reports on utilization of CAM therapies do not specify an operational definition for back pain with respect to the anatomical location, or the duration of pain. We recommend that future studies adequately detail the study subjects under investigation and explicitly detail the location of the back pain and its duration (acute or chronic).
2) Low back was the most frequently evaluated anatomical region. Fewer studies evaluated the use of CAM for neck and thorax. Although, we recognize that the prevalence of back problems is lower in these regions, our review did not find sufficient evidence to support the differential use of CAM therapies as a function of location. We recommend that future utilization studies of CAM use for back pain address any potential differential use of therapies as a function of anatomical location. We also recommend capture of use of CAM therapies for multiple back regions being treated within or across episodes of care, since some CAM therapies treat regions distant from the low back as part of their theoretical model of back pain care.

Intervention

3) CAM therapies were frequently identified as broad categories, with little specification of the type of modality used. Similarly, the providers of the therapies were very poorly detailed or were not linked to the therapies received. We recommend that future studies adequately detail the specific type of CAM therapy, and link this to the providers of the therapy.
4) There were few studies that evaluated the use of CAM therapies relative to each other for back pain. The available studies would suggest that chiropractic/manipulation is the most frequently used modality followed by massage and acupuncture. We recommend that future studies evaluating relative use of CAM include a comprehensive list of CAM therapies and provide details in this regard. We recommend that this use be linked to all providers of the therapy. We also recommend that use with other CAM therapies is differentiated with respect to current and past episodes of back pain.

Comparator

5) Concurrent use of different CAM or conventional therapies was not well reported. A significant gap in the literature has been identified. We recommend that future studies detail the level of concurrent use of other CAM or conventional therapies with respect to current or past episodes of care, location of back pain, and the provider of the therapy.
6) Our review would suggest that there was inconsistency with regards to the types of therapies and providers considered conventional or alternative. We recommend that future studies explicitly detail the nature of the therapies linked to specific providers rather than relying on labels of conventional or alternative therapies or providers.

Outcomes

7) Utilization of CAM services is generally presented as a dichotomous outcome (use or non-use); less information is available with regards to frequency, duration and type of service provision for an episode of care. We would recommend that future research probe frequency and duration of use (preferably in more than one time interval), associated with both the CAM therapy and the provider of the therapy. We also recommend that the “episode of care” being evaluated be explicitly defined.
8) The primary source of information on utilization of CAM therapies for back pain comes from self-report within questionnaires and from retrospective administrative healthcare analyses. We recommend that explicit details of the survey or interview questions are provided including the operational definitions of the CAM therapies and the categories of providers. Similarly, we recommend that explicit definitions for the type of back pain, the provider types, and the therapy received are provided for studies using administrative databases.
9) The studies reporting cost outcomes are primarily cost identification in nature rather than true economic analyses. The perspective was primarily that of the payer and as such, only direct costs were evaluated. We recommend that future evaluation of costs include details about indirect costs, consider the costs from a societal perspective, and use formal economic analyses that consider the benefits and harms associated with intensity of use.

Other

10) A single CPG reported on frequency of use as a function of LBP duration. The majority of U.S. CPG guidelines on CAM therapies did not report utilization or recommend parameters for optimal use. A significant gap in the literature has been identified. We recommend that future guideline development attempt to address this gap for CAM therapies as a function of back region and duration; guideline developers should indicate when these recommendations are based on evidence and when they reflect best practice.
11) Few studies were found that reported provider views on recommendations for the optimal utilization of CAM therapies for back pain. Providers' philosophies of care and healthcare setting constraints may affect patterns of use. We recommend that future studies explore issues in provider and possibly patient views about the frequency and duration of utilization. We recommend that these views be explored in the context of specific subgroups of back patients based on location and duration, different providers of the same CAM therapy, and conventional providers' views of their own interventions and those of CAM providers.