# Acknowledgments

We thank the representatives of our partner organization, National Center for Complementary and Alternative Medicine (NCCAM).

Our thanks go to librarian Maureen Rice for her thorough management of the search terms and methodology. We would like to thank the following people who helped with screening, and the data abstraction for this review: Connie Freeborn, Rob Stevens, Lynda Booker, Solina Yoo, Kathryn Walker, and Mary Gauld. We would also like to thank Mary Gauld, Lynda Booker, and Kathryn Walker for their coordination activities.

Our editorial staff, Cecile Royer, Roxanne Cheeseman, and Maureen Rice have provided invaluable input into this document.