# Discussion

## Summary of the Evidence

In this systematic review we evaluated a series of broad questions related to the utilization of CAM therapies in persons with back pain. Unlike previous reviews,^62^ we found that the majority of studies did differentiate the various types of CAM with respect to use. However, we found that approximately one-third of the literature on patterns of use did not report outcomes stratified for those with back pain. Although, several of the U.S. and non-U.S. studies were based on well conducted national sample cross-sectional surveys, CAM utilization for persons with back pain was not well detailed, despite having been identified as a high user group.

## Utilization of CAM Therapies

A limited number of publications (n = 8) for both the U.S. and non-U.S. countries evaluated the relative utilization of CAM therapies for persons with back pain. Our criteria for selection of studies included the evaluation of a minimum of four different CAM modalities. In both U.S. and non-U.S. studies, chiropractic/spinal manipulation, followed by massage, and then acupuncture were reported as the most frequently used CAM therapies by persons with back pain. In many of the studies most subjects reported using more than one CAM therapy which would seem consistent with reporting lifetime use. These studies focused primarily on chronic low back or unspecified back pain, with none evaluating acute back pain. The timeframe for use and the manner in which the CAM therapies were probed are important factors accounting for the range of utilization rates observed. Future research should evaluate the degree of overlap in the use of different CAM therapies to better evaluate relative utilization. This may be particularly important for persons with chronic back pain that is characterized by recurrent episodes of disabling symptoms. Differentiating patterns of relative use for acute versus chronic/recurrent back pain populations is important in future evaluation of relative use of these CAM therapies.

The number of studies evaluating trends over time in the use of CAM therapies in back pain patients is limited, particularly for U.S. studies (n = 2). These studies would suggest that both CAM use in general and CAM practitioner visits for back pain have not shifted dramatically over time. More research is required to establish the nature of trends in use as a function of the anatomical back region, the duration of the back pain, and the specificity of both the CAM therapy and the practitioner.

Because so few studies evaluated relative CAM utilization, we explored patterns of use for individual CAM therapies and stratified these by U.S. versus non-U.S. studies. We focused on the four most frequently used provider-based therapies including: spinal manipulation/chiropractic, massage, acupuncture, and naturopathic medicine. In general, the patterns of utilization and the flaws within the literature were similar for U.S. and non-U.S. publications, with minor variations in the provider types for the later.

Our review indicates that chiropractic care/spinal manipulation is the most commonly reported and sought CAM therapy by persons with back pain in the U.S. and other western countries. It is also the most commonly evaluated modality within the U.S. Mean number of patient visits tended to be double the median number of visits suggesting that a subpopulation of patients pursuing chiropractic care and/or spinal manipulation are frequent or long term users of these services. The majority of studies focused on low back pain (LBP) relative to other back regions, predominately in persons with chronic pain. The available information suggests that roughly equal proportions of LBP patients use chiropractic as complementary to conventional care and as alternative to conventional care. Current literature provides little insight into the manner in which chiropractic care/spinal manipulation is combined with other therapies for LBP.

Despite the common use of chiropractic care/spinal manipulation by patients with back pain the current literature provides limited data on utilization. This relative dearth of information challenges the design of meaningful pragmatic trials by researchers, confuses expectations of clinicians considering referral to such services, and impedes the ability of policymakers and healthcare payers to establish if provision of chiropractic care/spinal manipulation is in keeping with clinical guidelines. High quality prospective observational studies on chiropractic care/spinal manipulation are needed to establish utilization data by location of complaint, the specific type of spinal manipulative therapy applied, if chiropractic care is used as complementary or alternative to conventional care, and how spinal manipulative therapy is combined with other therapies in the management of axial pain.

This systematic review also shows that persons with back pain frequently use massage and acupuncture for treating their back pain in both the U.S. and in other eligible countries. The rates of use were widely varying and were related to a number of factors, including: the type of sample recruited (i.e., large national sample or smaller practice based sample), the timeframe for recall, the anatomical region, and the method used to measure utilization. Few studies evaluated rates of use as a function of the anatomical location of the back pain. The attributes of the CAM provider and the specifics of the therapy administered, such as treatment location, duration and frequency, were poorly detailed. Given the variety of modalities within acupuncture and massage, it would be important to establish differences in patterns of use, if any, for the differing location and duration of back pain. Future research should also adequately link the specific provider types to the specific subcategories of CAM therapies and contrast these with patterns of use in differing back pain populations.

There were a few studies evaluating the use of naturopathic medicine and other related therapies in the management of back or neck pain. These suggest that naturopathic medicine and related therapies are utilized in a limited manner by persons with back pain. However, the use of dietary supplements is generally not well captured in utilization studies, since they may be self-administered, and the lack of studies in this review on this type of CAM may reflect a limitation in our search strategy. More research is required to gain an accurate estimate of the use of dietary supplements for back pain.

There were some challenges when evaluating methodological quality of the utilization studies given the differing designs and outcomes. The outcomes establishing patterns of use specific to persons with back pain were collected from patient or practitioner recall surveys/interview, health record review, or analysis of administrative health claim databases. Similarly, the majority of studies on utilization employed observational designs without a true control or concurrent group. Approximately one-quarter of the U.S. studies and half of the non-U.S. studies were cross-sectional in design. Many of these studies recruited random, population-based samples with acceptable response rates; standardized and pre-tested methods for data collection were likely used in these studies. One-third of studies were based on medical records or administrative database utilization data. The majority of the U.S. studies used standardized coding for classifying back pain (predominately ICD 9 codes), provider visits, and enrollee characteristics and treatments; given the pre-specified coding systems, linkages between elements within the database were likely limited in errors. The majority of non-U.S. studies were based on health record extraction for which the use of standardized forms was not specified.

Approximately half the U.S. studies were single group prospective design and one-quarter used retrospective database information. These study designs and methods of data collection, lend themselves to consistent biases, in particular, selection and recall bias. Many of the samples for these studies were recruited from practitioner settings and may reflect provider practice patterns rather than health system utilization. However, they do provide some information that may benefit research undertaken using large samples and comparative designs. From a quality perspective, observational study designs that lack comparator groups are problematic to assess, as there is currently no consensus on the criteria to judge validity. Future research in this area may benefit from potential consensus on the most important validity criteria for these designs, which will ultimately assist in comparison across different studies. The rest of the publications were cross-sectional in design along and a few were randomized trials; relatively fewer of these studies were undertaken within the U.S. than in other eligible countries. These comparative design studies were generally well conducted using large population samples.

However, irrespective of the design type, the majority of studies reviewed were based on patient or practitioner self-report that has inherent limitations that may not be addressed by the study design. For example, there is the trade-off between increased accuracy by asking patients to report “lifetime use” rather than more detailed utilization information which is highly prone to inaccuracy. Similarly, interpreting the differing operational definitions of the CAM therapies and providers, and the definition of back pain across studies, even when using comparative designs, is problematic. Overall, we judged the literature on utilization of CAM and back pain as fair in methodological quality; studies as a whole are susceptible to some biases, and do not meet all criteria for excellent validity. However, the flaws are not sufficient to completely negate all the results.

### Recommendations for Use of CAM

Our evaluation of U.S. clinical practice guidelines (CPG) showed extremely limited information on the recommended use of CAM services for persons with back pain. Only one CPG, for electro-acupuncture use, provided recommendations for the frequency of treatment that was stratified by pain duration, and recurrence. All other eligible CPG recommended the use of a particular therapy based on efficacy or effectiveness, but did not provide guidelines for frequency and duration of treatment intervals. A significant gap with regards to recommended utilization for persons with back pain of differing durations and anatomical regions has been identified. In part, the lack of utilization recommendations may reflect limitations in high quality evidence from randomized trials focusing on the optimal dosage for treatment benefit. This precludes some consensus amongst clinicians and methodologists with regards to the specifics of “dosage” as a function of therapy. Descriptions of both the frequency and the duration of each treatment session would provide the minimum level of dosage for utilization for a course of treatment. However, there are other factors to consider such as the intensity of treatment or the speed of application.^159^ Although, these finer aspects of dosage will likely vary with the CAM therapy, they may ultimately impact use and efficacy.

Reluctance on the part of provider organizations to prescribe recommended frequency and duration of treatment in the absence of credible efficacy evidence may be another consideration. A number of other factors that may also influence recommended use include: provider organization policies, moderating factors such as access to, or availability of the CAM service, attitudes or philosophies of the practitioner (reactivation treatment versus biomedical activity restriction approaches), and the practice setting, particularly national health service versus private practice.^52^ A mixed method approach including qualitative components^50^ may hold some promise for future investigation of provider attitudes and concerns about establishing and adhering to utilization guidelines.

### Costs Associated With CAM Therapies and Back Pain

We also evaluated studies that measured cost-related outcomes associated with CAM use for back pain patients in the United States. The majority of studies reporting cost outcomes were cost identification analyses and not true economic analyses; a single study undertook a formal cost effectiveness analysis (CEA). The studies with cost outcomes were primarily from a payer perspective and as such evaluated direct costs; indirect costs were not captured or reported. A variety of cost estimates were reported spanning from 1982 to 2003 U.S. dollars. Although most studies showed that costs vary with the provider type, the interpretation of these differences is problematic in the absence of links to benefits or harms. Also problematic is the often implicit assumption that the effects of the providers and their treatments are equivalent. The majority of studies evaluated chiropractors as the exclusive CAM provider and medical doctors (M.D.s) as the conventional practitioners; comparison of costs between these two providers is dominant in the studies evaluated. In general, these studies suggest that treatments by chiropractors and physical therapist were characterized by more visits relative to M.D.s; visits to M.D.'s, although less frequent were more costly, particularly for specialists.

## Challenges of Evaluating Utilization

### Variation in Measuring and Reporting Utilization

Our systematic review found that studies used definitions ranging from a maximum of lifetime use, to a minimum of one visit to a CAM practitioner to determine use. The proportion of patients with back pain within a practice of a CAM provider was also a commonly reported outcome for utilization. Although this would provide some insight into practice patterns for specific providers, it limits interpretation at the population or system level. Overall, there was limited information with regards to the frequency of visits for specified intervals, the duration of each visit, the details of the CAM therapies administered, and the provider attributes.

A variety of methods and outcomes has been used to measure utilization of health services in the CAM studies evaluated in this review. Primarily these include self-report in surveys, administration databases using health claims, and physician record. A review of literature on the accuracy of self-report of health care utilization,^80^ identified six key factors affecting the accuracy of self-report and the potential for response bias: 1) recall time-frame, with under reporting increasing with longer time intervals, 2) type of utilization data requested (for example emergency room, or clinic visit), 3) utilization frequency, 4) questionnaire design, 5) mode of data collection, and 6) the use of memory aids or probes. Additional factors that affect accuracy of self-reported healthcare utilization include stress, motivation, and interview dynamics. In this particular review,^80^ and indeed in many of the studies included in our review, utilization was defined as a visit to a clinical provider or clinical entity. This definition may present some limitations when reporting utilization of supplements or home remedies. Additionally, there is some indication that characteristics of the respondents may impact recall and response bias. For example, elderly respondents were found to over report contact with general practitioners, physiotherapists, and chiropractors and under report contact with other medical specialists; in addition, the elderly respondents were more accurate at reporting no use of a practitioner or service than use.^86^ Whether or not persons with back pain have an increased propensity to err in accuracy of self-reported utilization is not known.

The type of utilization that is being reported may also impact accuracy. Some errors in self-reported utilization of services may be related to aspects of reporting on contact utilization or volume utilization. Respondents reporting ever having seen a practitioner or used a service (contact utilization) may be more accurate than reporting details of the frequency and duration of visits (volume utilization).^86^ Studies evaluating self-report of utilization consistently show an association between increased visit frequency and under reporting.^80^

Errors when using data from administrative databases for health claims can include problems created by reliance on the database administrator to input claims data accurately and in a timely manner. Typically there may be problems with linking patient demographic information and patient use information, as well as incomplete data on some enrolled members. For studies in the U.S., it is likely that patients who are not covered or who have insufficient medical coverage will be less likely to seek services; as such there is the potential for selection biases despite large claimant samples.^85^ In addition, differences in codes to define back pain, episodes of care, the provider types, and method of cost estimates may present some limitations in comparison across studies. It is not clear to what degree these factors can be standardized for future research, but reporting of these key characteristics would be helpful.

### Distinguishing the CAM Practitioner From the CAM Intervention

Our systematic review consistently found that the use of the CAM therapy and the provider of the therapy were poorly detailed. Many of the eligible studies on CAM use were based on populations derived from CAM provider practices; as such one could assume that 100 percent of the sample used CAM but no clarity as to which of many potential therapies the patient received. There is also the problem of describing CAM therapies using broad categories that in reality encompass a variety of different therapies. For example, Traditional Chinese Medicine employs a variety of treatments some of which, such as use of herbals and needling, are considered CAM while others such as exercise therapy or the use of heat and cold are not.

The lack of specificity of the provider type is also problematic. Consider again Traditional Chinese Medicine, where based on most of the literature we would likely assume that the provider was an acupuncturist, but this is not necessarily the case. There is also the possibility that the same provider types located in different countries, display markedly different patterns of use. For example, osteopathic practices within the U.S. have broader philosophies of care relative to their counterparts within the United Kingdom who focus more on traditional spinal adjustments. The degree to which the provider type contributes to differences in patterns of use is generally not known in the literature specific to CAM use for back pain. As well, the degree to which regional, rather than national differences, are factors contributing to varying rates of use, could not be assessed within the current literature.

Provider attributes such as professional designation, years of experience, and area of specialty, were also detailed poorly, limiting evaluation of the level of influence these factors have on frequency and duration of CAM use. The lack of detail about the provider is further confounded when some CAM therapies can be administered by non-professionals or are self-administered. If the goal of utilization research is to evaluate provider-based use, then care should be taken in the phrasing of survey or interview questions querying CAM therapies that can be self-administered. Clearly, to understand the patterns of use the provider details are critical.

The lack of specificity about both the CAM therapy and the provider, present challenges in interpreting utilization patterns across studies. Future research should provide greater clarity about the type of provider and the CAM therapy. More importantly, future research endeavors should link the detailed CAM therapies utilization data to specific provider types.

### Distinguishing Complementary Versus Alternative

Lack of specificity regarding both the provider and the details of the CAM therapy administered are also important limitations with regards to evaluating the degree to which CAM services overlap with each other or with services or care from conventional providers. The degree of overlap was not reported in the majority of studies. This lack of specificity was also evident in descriptions of therapies provided by “conventional” providers which can include CAM therapies. Future research in this area should endeavor to document these aspects of overlap in order to better understand patterns of use.

As more “conventional practitioners” choose to use CAM therapies within their “conventional” practices, the distinction between alternative and traditional is becoming blurred. When evaluating studies, it was not clear what “CAM use only” or “conventional care only” implied with respect to alternative versus complementary treatments. There is also the problem of shifting classification of what is labeled CAM. As noted previously, the operational definition of “alternative” implies that the therapy is used in place of conventional medicine.^73^ Our review would suggest that chiropractic treatment is used frequently and in many instances is “conventional care” in the U.S. Similarly in studies undertaken in the United Kingdom, acupuncture provided by a physiotherapist was labeled as conventional therapy; acupuncture provided by a “conventional” provider is the primary modality used to manage chronic back pain in the U.K.^110^ Classification is further complicated by the designation of some treatments as “integrative” medicine, implying that care combines alternative and conventional care. It is likely that patterns of use of a particular therapy, irrespective of the label of alternative or conventional will be affected by the provider and their care philosophy. Future studies should endeavor to specify operational definitions for alternative and conventional therapies and providers. This will assist not only in understanding patterns of use within a study, but also interpretation of variations across utilization studies.

### Potential Limitations of the Systematic Review Process

The eligible studies within this systematic review were limited to primary studies in the English language; although this may not be an important factor for U.S. studies, it may be a source of bias for studies in the other eligible countries. Our focus was on summarizing literature from the U.S. Evaluating literature on CAM use in Canada, the United Kingdom, Europe, New Zealand, and Australia was a secondary focus.

We undertook a comprehensive search and used over 150 CAM related search terms; however we recognize that we used a relatively small number of terms specific to supplements and herbals. There are over 10,000 types of these products and searching for each specifically was not within the scope of this review.

Although we recognize that there is inconsistency in these terms, we did not exclude studies based on their definition of back pain, and its duration (i.e., chronic or acute). When operational definitions for neck or back pain were provided, considerable variability was observed across studies. The majority of studies in this review focused on querying subjects with regard to their back complaint(s) and use of CAM; most studies did not distinguish the potential for CAM therapies received to include management of other secondary health complaints which are a potential source of contamination. We did not restrict the source of the back pain allowing for both musculoskeletal and non-musculoskeletal causes. Nor did we restrict studies because of the potential for associated co-morbidities such as depression in chronic LBP patients.

Many of the studies depended on self-report of CAM and back pain, and as such, are dependent on the respondents' knowledge of both the CAM therapy and their understanding of back pain either of which may differ from that of the researchers. Additionally, we accepted any definition of the CAM therapies specified within each study and this would naturally introduce variability in our summaries of the use of these therapies. Some studies defined CAM as “any treatment or remedy, other than standard over the counter medications, which you are using or have used” and others provided great level of detail with regard to different CAM therapies. We did restrict some types of therapies that we were considered predominately conventional such the use of medications and spinal injections. No attempt was made to distinguish those CAM therapies that are safe or effective, but rather the focus was on reporting all use of CAM therapies.

Finally, we did not restrict studies by the manner in which the utilization was collected or reported. Variability in reporting and means of collecting utilization of CAM therapies was substantial. We evaluated both contact and volume utilization outcomes.

## Conclusions

Although we evaluated 74 studies on utilization and costs in persons with back pain using CAM therapies, there were significant limitations in understanding the patterns of use across studies. In part the variation and inconsistencies across studies may be attributable to lack of consensus on reporting in utilization and other health services studies. Consensus on reporting standards such as the CONSORT Statement for randomized control trial studies provide guidance as to the level of detail required in specifying the characteristics of the population, the intervention, and the outcomes. Activities in this regard will assist future evaluation of utilization studies in general.

Our systematic review demonstrates that CAM therapies are frequently used by persons with back pain. Understanding the patterns of CAM therapy utilization would assist in setting research priorities for evaluation of specific CAM therapies or providers. Our findings would support the following conclusions and recommendations for future research in this area:

### Population

1) Many studies provided minimal information about the characteristics of the sample. In particular, most reports on utilization of CAM therapies do not specify an operational definition for back pain with respect to the anatomical location, or the duration of pain. We recommend that future studies adequately detail the study subjects under investigation and explicitly detail the location of the back pain and whether it is acute or chronic.
2) Low back was the most frequently evaluated anatomical region. Fewer studies evaluated the use of CAM for neck and thorax. Although, we recognize that the prevalence of back problems is lower in these regions, our review did not find sufficient evidence to support the differential use of CAM therapies as a function of location. We recommend that future utilization studies of CAM use for back pain address any potential differential use of therapies as a function of anatomical location. We also recommend capture of use of CAM therapies for multiple back regions being treated within or across episodes of care, since some CAM therapies treat regions distant from the low back as part of their theoretical model of back pain care.

### Intervention

3) CAM therapies were frequently identified as broad categories, with little specification of the type of modality used. Similarly, the providers of the therapies were very poorly detailed or were not linked to the therapies received. We recommend that future studies adequately detail the specific type of CAM therapy, and link this to the providers of the therapy.
4) There were few studies that evaluated the use of CAM therapies relative to each other for back pain. The available studies would suggest that chiropractic/manipulation is the most frequently used modality followed by massage and acupuncture. We recommend that future studies evaluating relative use of CAM include a comprehensive list of CAM therapies and provide details in this regard. We recommend that this use be linked to all providers of the therapy. We also recommend that use with other CAM therapies is differentiated with respect to current and past episodes of back pain.

### Comparator

5) Concurrent use of different CAM or conventional therapies was not well reported. A significant gap in the literature has been identified. We recommend that future studies detail the level of concurrent use of other CAM or conventional therapies with respect to current or past episodes of care, location of back pain, and the provider of the therapy.
6) Our review would suggest that there was inconsistency with regards to the types of therapies and providers considered conventional or alternative. We recommend that future studies explicitly detail the nature of the therapies linked to specific providers rather than relying on labels of conventional or alternative therapies or providers.

### Outcomes

7) Utilization of CAM services is generally presented as a dichotomous outcome (use or non-use); less information is available with regards to frequency, duration and type of service provision for an episode of care. We would recommend that future research probe frequency and duration of use (preferably in more than one time interval), associated with both the CAM therapy and the provider of the therapy. We also recommend that the “episode of care” being evaluated be explicitly defined.
8) The primary source of information on utilization of CAM therapies for back pain comes from self-report within questionnaires and from retrospective administrative healthcare analyses. We recommend that explicit details of the survey or interview questions are provided including the operational definitions of the CAM therapies and the categories of providers. Similarly, we recommend that explicit definitions for the type of back pain, the provider types, and the therapy received are provided for studies using administrative databases.
9) The studies reporting cost outcomes are primarily cost identification in nature rather than true economic analyses. The perspective was primarily that of the payer and as such, only direct costs were evaluated. We recommend that future evaluation of costs include details about indirect costs, consider the costs from a societal perspective, and use formal economic analyses that consider the benefits and harms associated with intensity of use.

### Other

10) A single CPG reported on frequency of use as a function of low back pain duration. The majority of U.S. CPG guidelines on CAM therapies did not report utilization or recommend parameters for optimal use. A significant gap in the literature has been identified. We recommend that future guideline development attempt to address this gap for CAM therapies as a function of back region and duration; guideline developers should indicate when these recommendations are based on evidence and when they reflect best practice.
11) Few studies were found that reported provider views on recommendations for the optimal utilization of CAM therapies for back pain. Providers' philosophies of care and healthcare setting constraints may affect patterns of use. We recommend that future studies explore issues in provider and possibly patient views about the frequency and duration of utilization. We recommend that these views be explored in the context of specific subgroups of back patients based on location and duration, different providers of the same CAM therapy, and conventional providers' views of their own interventions and those of CAM providers.