# Results

From an initial inclusion of 8,347 unique citations, 8,108 were excluded as they were not on topic, not English language publications, or not undertaken within the countries of interest (see Figure 2). The remaining 239 were identified as potentially being about complementary and alternative medicine (CAM) and about utilization, costs, patient or provider views, recommendations about optimal frequency and duration of visits, or clinical practice guidelines (CPG).

Figure 2. Flow of publications from initial search to final eligibility

The full text publications for these 239 citations were retrieved and from these 95 were excluded as not addressing utilization, costs, or recommendations for use of CAM. Following full text screening, we further excluded non-U.S. publications for cost-related outcomes (n = 19), as comparability with American costs for CAM use would be limited. Our complete eligibility criteria were met by 103 publications for utilization, recommendations, and costs related to CAM use.

We partitioned CPG reports or publications related to recommended use of CAM (Figure 2). From these, eight CPG were excluded as not providing any specific recommendations on CAM use for back pain. Additionally we separated primary publications (n = 22) of provider or patient views about CAM utilization. Eighteen of these publications on provider or patient views were excluded as these did not provide information on “recommended” use of CAM therapies.

We grouped eligible publications according to their primary focus on utilization, recommendations for frequency of use, or costs associated with use of CAM; these publications were further divided into those undertaken within the U.S. and those from the other countries eligible for this systematic review. Figure 2 shows the overlap.

## Question 1. What is the Relative Utilization for the Different CAM Therapies?

A total of 94 publications provided some information on utilization specifying either the prevalence of visits to CAM practitioners or more detailed service use based on specific therapies. These include publications based both within the U.S. and within other eligible countries including: Canada, United Kingdom, Europe, Australia, and New Zealand. Approximately one-third of the publications presented utilization of CAM but did not stratify these results specifically for persons with back pain. The remaining publications were partitioned to address: 1) relative utilization of CAM therapies evaluated concurrently, 2) trends over time, and 3) individual CAM therapy utilization for the most prevalent provider-based CAM therapies. There was significant overlap of publications among the research questions addressed in this review. The majority of publications (52 of 65) reported some aspect of use related to chiropractors, or chiropractic, or manipulation, or mobilization. Despite the overlap we summarize findings and quality assessment for each section and for the utilization publications as a whole.

### Utilization of CAM, Data not Stratified by Back Pain or Therapy

Twenty-nine publications did not stratify CAM utilization data with respect to use by persons with back pain. Rather than exclude these publications, we chose to identify and detail some aspects of these studies; many of these publications are recognized as contributing significantly to our current understanding of CAM utilization. Our intention was to highlight that these studies were lacking in utilization results specific to persons with back pain, despite being the sources that originally identified back pain patients as a key population that utilize CAM services. Similarly, we wished to highlight that several of the non-stratified studies evaluated different subgroups of persons that experience significant back pain related to spinal cord injuries, cancer, or pregnancy. Nineteen publications^6,^ ^47,^ ^71,^ ^76,^ ^91^–^105^ were based on utilization data from the U.S. and 10 publications^106^–^115^ were from other eligible countries.

### Utilization not Stratified by Back Pain Within the United States

Several American studies are seminal works based on large national samples^6,^ ^71,^ ^76,^ ^98,^ ^99,^ ^102,^ ^105^ that surveyed CAM utilization and established that back and neck pain were important reasons for seeking CAM treatments. However, the utilization data presented did not link the specific type of CAM therapy to persons with back pain; rather the prevalence of back pain within the samples was reported. Four publications^101^–^104^ were based on the same study cohort, representing survey results from a national sample.

Three publications focused on persons with spinal cord injuries. Two of the publications^92,^ ^93^ on spinal cord injury patients showed that back and neck pain was frequently a major source of their chronic pain (varying from 46 to 75 percent), but did not present stratified CAM utilization information. One study^92^ reported utilization of CAM combined with medical injections to manage pain.

One study^91^ evaluated the use of CAM for cancer and other chronic pain in American Veterans. Other publications identified CAM use within patients presenting to the emergency department,^95^ a specialized CAM clinic within a university hospital,^100^ or concurrent use of CAM in patients attending outpatient physiotherapy departments.^96^ Another study^97^ indicated the use of mind body therapies among patients with musculoskeletal pain. One study^47^ assessed the use of CAM by pregnant women; although rates of back pain are very high within this population, the publication did not specify the trimester or whether or not the whole sample was experiencing back pain at the time of the study.

Summary of U.S. publications on utilization not stratified by back pain. Nineteen publications were based on utilization data from the U.S. Although, these establish that back pain was an important symptom for which patients sought services, they do not present results on utilization of CAM therapies stratified for persons with back pain. Several studies evaluated subgroups of patients with non-musculoskeletal related back pain and would suggest that CAM therapies are commonly used by these populations.

### Utilization not Stratified by Back Pain Within Other Countries

There were 10 publications from other eligible countries that did not present utilization data stratified for persons with back pain. One study^106^ evaluated neck and shoulder pain in newspaper workers, another the general population in Canada.^115^ Three publications^108,^ ^110,^ ^111^ evaluated physiotherapy outpatients and another^107^ patients at osteopathic clinics. One study^109^ evaluated the use of a chiropractic activator and another, general population with back pain in the United Kingdom.^114^ Another study evaluated persons with spinal cord injuries in Sweden.^112^ Finally, one study evaluated the general population in Spain.^113^

Summary of non-U.S. publications on utilization not stratified by back pain. Ten publications were based on utilization data outside the U.S. No clear pattern emerges from these studies; there are differences in populations, providers, and CAM therapies evaluated that contribute to this heterogeneity.

### Relative use of CAM Therapies

We identified publications that presented the relative frequency of CAM utilization in order to rank the most to least frequently used therapies by persons with back pain. We identified four U.S.^9^–^12^ and four non-U.S. publications^116^–^119^ that reported utilization data for a minimum of four different CAM therapies or practitioners. An additional study^30^ reporting more than four CAM therapies provided solely by a physical therapist, was not included in this grouping. Electrotherapies provided by conventional providers (such as physical therapists) were defined as non-CAM therapy; however, this publication provided utilization data for spinal manipulation and is detailed in the specific CAM therapy section below.

We did not select publications where subjects were recruited from the practices of CAM providers. The utilization patterns described within these studies would reflect practice patterns of concurrent CAM therapies and not that of relative utilization of CAM services. For example, utilization of differing CAM therapies reported from subjects currently receiving care by a chiropractor would reflect the manner in which this particular CAM practitioner combines various CAM modalities rather than the frequency with which persons with back pain would choose to use one CAM therapy over another. The manner in which CAM therapies are concurrently combined for treatment is described within the specific CAM therapy sections that follow.

Table 1 compares reports of the use of four or more different CAM therapies for back pain. Note that the proportion of use was not exclusive to a single category; most subjects reported using more than one CAM therapy for lifetime use. What was generally not specified within these publications was the order in which CAM therapies were selected for single or multiple episodes of care.

Table 1 Studies listing the use of 4 or greater different CAM therapies specific to back pain

Study | Type of Back Pain | Subjects with Back Pain/Total Study n | Total n Seeking Care or Reporting CAM Use | Chiropractic (%) | Manipulation (%) | Massage (%) | Acupuncture (%) | Naturopathy (%) | Homeopathy (%) | Herbals (%) / Food Supplements (%) | Prayer Spirituality (%) | Ultrasonography (%) | Electrothreapy (%) | Yoga (%) | Relaxation Techniques (%) | Other (%)
U.S. Studies
Bruce^10^ ⁁ Intervention Group | CLBP | 190/296 | 190 | 62e | | | 20e | | | G:45.8 | | | | I:29e | | M:15
Bruce^10^ ⁁ Control Group | CLBP | 236/284 | 231 | C:64e | | | 22e | | | G:25.5 | | | | C:24e | | M:18
Carey^9^ | CLBP | 269/4437 | 186 | 24.6 | 22.0 | 42.0 | | | | | 27.0* | 27.0* | 18*
Long^11^ | LBP | 2374/4171 | 2374 | 46.7 | 41.3 | 43.2 | 9.3 P:10.2 | | | V:8.2 | 41.6 | 41.6 | 31.8* | | 21.5 | HC:67.9
Wolsko^12^ | CLBP | 644/2055 | 644 | 19.8 P:18 | | 14.1 P:9 | 0.9 P:0.9 | 2.6 | P:2.0 | V:1.8 | | | | 1.5 P:0.3 | 11.7 P:1.7
Non U.S. Studies
Ramsay^116^+ | CBN | 667/2,000 | Varies | 75 | | 43 | 30 | 16 | | 20 | 29 | | | 19 | R:22 | EH:11
Esmail^117^+ | CBN | 667/2,000 | Varies | 61 | | 39 | 30 | 10 | | 14 | 18 | | | 14 | R:13 | EH:20
Foltz^118^ | UBP | 3259/12,946 | 3259 | 74.4 | | 55.5 | 20.6 | | H:17.8 | 6.2 | 0.3 | | | | 0.6 | SG:11.0
Walker^119^ | LBP | 1,228/1,913 | 547 | | 12.6 | 17.9 | 2.2 | | | | | 3.7* | 2.5*

⁁ = data for lifetime prevalence of use of CAM;

* = provider not specified;

+ = Percent estimates for use of CAM therapy based on frequency for each specific CAM (i.e., sample size varied for each CAM therapy)

Abbreviations: C = Control group; CBN = combined back and neck pain; CLBP = chronic low back pain; e = estimated from bar graph; EH = Energy healing; EL = electrotherapy; G = Glucosamine; HC = hot and cold; I = intervention group; LBP = Low back pain; M = Magnets; P = Provider; R = Reflexology; SG = Support group; UBP = unspecified back pain; V = vitamins

### Relative Utilization of CAM Therapies Within the United States

Of the four U.S. publications for which relative utilization could be evaluated, all but one^9^ measured lifetime use of CAM (Table 1). All subjects within these publications had chronic or recurrent back pain. The sample sizes for those seeking care varied from 186 to 2,374 subjects. A single study^9^ reported the use of CAM therapies for a subgroup of the chronic back patients (69 percent seeking care within the last 6 months); the other publications reported on CAM use for the entire study sample with back pain. One publication^12^ reported on combined neck and back pain and the remaining ones on LBP. A single publication^12^ was based on a randomly selected population sample and another on North Carolina residents.^9^ The remaining publications were based on patients with chronic pain.^10,^ ^11^ All publications evaluated utilization with respect to the proportion of patients who used any of several CAM therapies and all but one study^10^ reported on the percent accessing at least one CAM provider.

Table 1 shows the relative utilization rates across the four U.S. publications. Chiropractor/chiropractic was the CAM therapy that was most frequently used by patients with chronic LBP or combined neck and back pain.^10^–^12^ In one study^9^ massage was the most frequently used CAM therapy; massage was also highly utilized in the other publications ranking second most frequent (Table 1). Although the use of ultrasonography, electrotherapy, and heat and cold modalities was high (18 to 68 percent), the provider of these therapies was not specified and treatment may have been provided by non-CAM practitioners. Other frequently used modalities were prayer and spirituality (27 to 42 percent) and glucosamine (26 to 46 percent); but these were reported in only two of the four publications. Both prayer and glucosamine were likely to be self-administered. It is probable that the empty cells within Table 1 can be accounted for by differences in study protocols with regards to which, of many potential CAM therapies, were probed.

Three publications^9^–^11^ specified that there was overlap in use of the various CAM therapies, but type of therapy overlap was not detailed. One study^12^ indicated that more than one CAM practitioner may have provided the therapy in the estimates of utilization. Similarly, overlap with conventional providers was not stratified for specific CAM therapies; a single study specified overlap with chiropractors alone but not other CAM practitioners.^9^

Summary of relative utilization of CAM therapies in persons with back pain in the U.S. There are a limited number of publications (n = 4) based on population-based samples that show the relative use of CAM therapies in persons with back pain. Two of these publications recruited subjects from large general population-based samples, and two recruited samples with chronic LBP. In general, these publications show that chiropractic/spinal manipulation is the most frequently utilized provider based CAM therapy followed by massage and acupuncture. Prayer and herbals and food supplements were also frequently used (self-practiced) CAM therapies although they were only evaluated in half the publications. Differences in study protocols for probing the type of CAM therapies used likely account for missing utilization data from the range of CAM services available in Table 1. Rates of utilization may also vary because of differences in populations and in location of back pain. The methodological quality of these four studies is generally good with minimal biases and valid results.

### Relative Utilization of CAM Therapies Outside the United States

Three publications^116^–^118^ evaluating CAM use in Canadians and one^119^ in Australians provided information on at least four different therapies (Table1). These publications evaluated a combination of neck and back pain,^116,^ ^117^ unspecified back pain,^118^ or LBP.^119^

Two companion publications^116,^ ^117^ reported utilization with respect to the proportion of back pain patients using specific CAM therapies rather than the proportion relative to all persons with back pain. Three publications^116^–^118^ found chiropractic to be the most frequently used modality/practitioner, with massage in second place (Table 1). In another study^119^ massage was the most frequently used CAM therapy. Acupuncture was the third most frequently used modality in two studies.^116^–^118^ The use of prayer and spirituality was reported in three of the publications but varied significantly. The use of herbals and food supplements was reported in a single study.^116,^ ^117^ These resources were excluded from the operational definition of CAM within another study.^118^

Two related publications^116,^ ^117^ did not specify complementary or combined CAM therapy use. Two publications^118,^ ^119^ evaluated patients with back pain alone and presented the degree of overlap with other CAM therapies. One of these publications^118^ showed a degree of overlap with conventional providers that varied from 6 percent with any physician to 1 percent with specialists; similarly, overlap with other conventional providers varied from 2 percent with physiotherapists to 0.3 percent with psychologists.

Summary of relative utilization of CAM therapies in persons with back pain. There are four publications based on population-based samples that show the relative use of CAM therapies in persons with back pain outside the U.S. These publications reported predominately on combined or unspecified back pain of variable duration. All publications undertaken outside the U.S. were based on larger, randomly selected, population-based samples. Three of these publications show that chiropractic/spinal manipulation is the most frequently utilized provider-based CAM therapy followed by massage and acupuncture. Prayer and herbals and food supplements were also frequently utilized CAM therapies although the rates of use were highly variable. Differences in study protocols with regards to probing the type of CAM therapies used likely account for missing utilization data from the range of CAM services available in Table 1. Rates of utilization may also vary because of the differing populations, as duration and location of back pain were combined or not specified in these studies. In general, these cross-sectional studies are rated as high quality with few biases and valid results.

## Trends in CAM Utilization

We identified 10 publications within the U.S. ^5,^ ^19^ and other countries^112,^ ^117,^ ^120^–^125^ containing data on the trends across time in the utilization of CAM interventions for back and neck pain. These papers were published between 1996 and 2007 and examined trends between 1962 and 2006. They had various designs and included patients with neck and/or back pain. Specifics regarding these publications are located in summary Tables 2 and 3.

Table 2 Summary table of studies evaluating trends in utilization of CAM therapies over time for persons with low back pain

Author Year Country | Sample Size Time-Frame (Years and Dates) | Description of Type of Pain | CAM Therapy | Utilization Over Time | Other Therapy Use
Studies conducted in the United States
Feuerstein^19^ 2004 U.S. | 1987 n = 1053 1997 n = 1082 | Nonspecific backache: defined using a modified version of algorithm developed by Cherkin et al.^44^ | Chiropractic care | Mean # of outpatient visits: 1987 = 9.2 1997 = 7.8 (p = 0.1) Use of chiropractic care reduced over the decade (40.5% vs. 30.6%; p<0.01) | NA
Non-United States Studies
Burton^122^ 2004 U.K. | n = 151 Respondents at 4 year followup Data collected at an average of 4 years (range 3.5 to 5 years) since presentation | New occurrence of low back (lumbar) trouble unrelated to any serious pathology | Osteopathic manipulative therapy varied number of treatments over periods of time involved passive soft tissue stretching, articulation of lumbar spine, high-velocity thrust techniques | Mean number of sessions = 6.6 (over 1 year) utilization of therapy over the followup period of 1 to 4 years by 50.3% of patients, who sought further care was 17.1% physiotherapy and 56.5% osteopathy | NA
Davies^125^ 1996 U.K. | Observation period 1: n = 1,236 Observation period 2: n = 1,791 Observation period 1: July–Dec, 1992 Audit intervention period: May–July, 1993 Observation period 2: Oct 1993–Apr 1994 | Lumbar pain Obs 1: 62% LBP 57% nerve-damage pain 18% both Obs 2: 61% LBP 50% nerve-damage pain 11% both | Acupuncture | Baseline: 9.2% of patients from teaching hospitals with LBP used acupuncture 31.9% of patients from district general hospitals used acupuncture no followup on acupuncture utilization | Reported utilization rate changes for anti-depressant drugs, anticonvulsant drugs and TENS
Groenendijk^121^ 2007 Netherlands | n = 3,148 Study 1 n = 1,948 Study 2 n = 200 Study 1: 1989-1992 Study 2: 2002-2003 | LBP without radiation | Physical therapy | 100% utilized physical therapy Utilized physical therapy for LBP: Study 1:11.9% Study 2: 15.4% | PT interventions: (% of population in 1989-1992 and 2002-2003 respectively): Massage 55.9%, 38.5%; Physical therapy modalities 45.1%, 11.8%; Exercise therapy 40.9%, 76.3%; Passive mobilization 37.1%, 43.4%; Instruction and advice 22.7%, 29.1%
Hopman^120^ 2006 Canada | n = 7,652 Baseline assessments: 1996-1997 5-year followup: 2001-2002 | Self-reported back pain; “ever had BP” | Glucosamine | Ever had back pain and used glucosamine Men: 5.1% (95% CI, 4.2–6.0) Women: 9.5% (95% CI, 8.4–10.7) People who have had back pain are 1.38 (OR; 95% CI: 1.17, 1.64) times more likely to take glucosamine; across all conditions, glucosamine use increased from baseline to 5 year followup Men: 1.2% to 8.5%, Women: 1.8% to 12.8% | NA
Kilvaer^124^ 1997 Norway | n = 1,992 98 out of 140 chiropractors participated, returned 2,401 questionnaires | Back pain (unclear definition) | Chiropractor: Looked at chiropractic as a complementary or alternative intervention Alternative: Non-referred patients who did not consult a medical doctor before commencing chiro treatment Complementary: Referred patients from M.D.s | 59.4% of non-referred chiropractic patients had LBP 61.5% of referred patients had LBP Calculated from age and sex-stratified Table 2 (in Kilvaer): 387/653 non-referred women who saw chiropractor had LBP 448/699 non-referred men had LBP 182/317 referred women had LBP 173/268 referred men had LBP | NA
Norrbrink-Budh^112^ 2004 Sweden | n = 90 In 1999, 456 patients with SCI (76.5% of the total population of patients with SCI in the Spinalis database at that time) were assessed in a yearly health control | Nocioceptive, neuropathic mixed back pain | TENS acupuncture massage therapy heat/cold mental training physical training | Present and former use: 57 (63.3%) tried 1 or more options | NA

Abbreviations: BP = back pain; LBP = Low back pain; M.D. = Medical Doctor; NA = not applicable; NHS = National Health Service; SCI = spinal cord injury; TENS = Transcutaneous Electrical Nerve Stimulation; TI = Telephone Interview

Table 3 Summary table of studies evaluating trends in utilization of CAM therapies over time for persons with combined neck and back pain

Author Year Country | Sample Size Time-Frame (Years and Dates) | Description of Type of Pain | CAM Therapy | Utilization Over Time | Other Therapy Use
Studies conducted in the United States
Eisenberg^5^ 1998 U.S. | T1 (1990) n = 1, 539 T2 (1997) n = 2, 055 | Back pain (both 1990 and 1997), Neck pain (1997) | Relaxation techniques, herbal medicine, massage therapy, chiropractic care, megavitamins, self-help groups, imagery techniques, commercial diet, folk remedies, lifestyle diet, energy healing, homeopathy, hypnosis, biofeedback, acupuncture, and prayer/spiritual healing | For BACK problems: T1: 19.9% reported back problems 35.9% of those used alternative therapy for back pain (BP), 19.5% saw alternative practitioner COMPLEMENTARY: 36.1% saw M.D. and used alternative therapy for BP, 23% saw M.D. and alternative practitioner for BP T2: 24% reported back problems 47.6% used alternative therapy for back pain, 30.1% saw alternative practitioner COMPLEMENTARY: 58.8% saw M.D. and used alternative therapy for BP, 39.1% saw M.D. and alternative practitioner for BP For NECK problems: T2: 12.1% reported neck problems 57% used alternative therapy for BP, 37.5% saw alternative practitioner for BP, 66.6% saw M.D. and used alternative therapy for BP, 47.5% saw M.D. and alternative practitioner for BP Chiropractic therapy and massage were most commonly used therapies in 1997 | NA
Studies conducted outside the U.S.
Esmail^117^ 2007 Canada | 2006 followup of the 1997 study n = 2,000 | Self-reported back or neck problems | Chiropractic care, massage, relaxation techniques, prayer/spiritual practice, acupuncture, yoga, herbal therapies, special diet programs, energy healing, naturopathy, homeopathy, folk remedies, self-help group, aromatherapy, imagery techniques, lifestyle diet, spiritual or religious healing by others, hypnosis, osteopathy, high dose/mega vitamins, biofeedback, chelation | Past 12 months back or neck problems treated with the following: chiropractic care 61% massage 39% relaxation techniques 10% prayer/spiritual practice 5% acupuncture 30% yoga 14% energy healing 16% 28% reported having back or neck problems (second most common medical condition reported) 71% used alternative therapy 47% saw CAM provider 3 most commonly therapies: massage therapies, chiropractic care, and prayer | NA
Hartvigsen^123^ 2003 Denmark | T1 (1962) n = 1,118 T2 (1999) n = 1,897 | Primary complaint LBP LBP and sciatica Neck pain Neck and arm pain | Chiropractor | T1: LBP alone: 33% LBP and sciatica: 17% Neck pain: 6% Neck and arm pain: 6% T2: LBP alone: 40.7% LBP and sciatica: 8.8% Neck pain: 9.2% Neck and arm pain: 6.2% Thoracic spine: 7.0% Thoracic spine and chest/upper extremity: 2.4% | NA

Abbreviations: NR = not reported; T1 = Time 1; T2 = Time 2

### Trends in Utilization Within the United States

For those with LBP only, study^19^ showed that in 1987, 41 percent used chiropractic medicine and in 1997, 31 percent. Another study found that in 1990, 36 percent of individuals with unspecified back pain used a CAM therapy while 20 percent saw a CAM practitioner; in 1997, 48 percent used CAM for back pain while 30 percent saw a CAM practitioner.^5^ This same study found that in 1997, 57 percent of individuals with neck pain used a CAM therapy and 37 percent saw a CAM practitioner.^5^

Summary of trends in CAM utilization within the U.S. The limited literature on trends over time would suggest that utilization of chiropractic/spinal manipulation for LBP in the U.S. has decreased, while the use of CAM generally has increased, although data on specific CAM therapies was not reported. More research is required to highlight trends in the utilization of CAM therapies for back pain in the U.S.

### Trends in Utilization Outside the United States

One study of LBP patients in the United Kingdom found that osteopathy was used by 49 percent of patients over an 18 month period.^122^ Note that osteopathy practices outside of the U.S. may differ in the types of CAM therapies administered. Another study found that over a 4-year period acupuncture was used for LBP by 9 percent of patients from teaching hospitals and 32 percent of patients from general hospitals.^125^ One study from the Netherlands found that between 1989 and 1992, physical therapists (PT) administering massage and passive mobilizations were used by 12 percent of those suffering from LBP. This increased to 15 percent in 2002 to 2003.^121^ A Canadian study found that between 1996 and 2002 glucosamine was used by 5 percent of men and 10 percent of women with back pain.^120^ A study from Norway found that in 1992, 59 percent of non-referred and 62 percent of referred chiropractic patients had LBP.^124^

For those suffering from neck and back pain, in Canada, “in the past 12 months” the following utilization rates of CAM therapies were reported: chiropractic care 61 percent; massage 39 percent; acupuncture 30 percent; energy healing 16 percent; yoga 14 percent; relaxation techniques 10 percent; and prayer/spiritual practice 5 percent.^117^ In Denmark, between 1962 and 1999 patients visiting chiropractors increased by over 7 percent for the primary complaint of LBP alone, decreased by almost 9 percent for LBP with sciatica; increased by over 3 percent for neck pain, and remained essentially the same for neck and arm pain.^123^

Summary of trends in CAM utilization outside the U.S. The limited literature on trends in countries outside the U.S. would suggest that utilization rates differ between countries and between specific CAM interventions. More research is required to determine the extent of these differences. No data were reported on the usual costs for these therapies per treatment or for the prescribed course of treatments.

### Specific CAM Therapy Utilization: Acupuncture

Eighteen publications provided data on utilization of acupuncture by back pain patients. Of these, eight were specific to the U.S.;^10^–^12,^ ^15,^ ^16,^ ^18,^ ^44,^ ^45^ two of these publications were based on the same sample.^15,^ ^44^ Ten publications provided utilization outcomes from other eligible countries;^51,^ ^116^–^119,^ ^125^–^129^ one publication^117^ was a companion to a previous study^116^ as it incorporated the findings of the initial survey and utilization from a resampling of new subjects 6 years later. The variation in the samples recruited for these studies is noteworthy and includes subjects from large population-based surveys or administrative databases and subjects from small clinical practices, or populations limited only to patients with back pain. As expected, the estimates of utilization varied substantially based on the type of denominator used to estimate prevalence.

### Acupuncture Utilization Within the United States

There were eight U.S. publications that provided data on acupuncture utilization in persons with back pain. Three of these were of cross-sectional design using interviews.^12,^ ^18,^ ^45^ Three publications from two study cohorts used a single group prospective cohort study design based on interviews^15,^ ^44^ and self-administered questionnaires.^11^ One study was a retrospective design using data from a health claims database^16^ and another was a randomized controlled trial^10^ that used a self-administered questionnaire to evaluate use of CAM.

Two publications^12,^ ^45^ reported CAM utilization based on samples from the general population. Two publications recruited subjects from health claims databases in Washington state.^16,^ ^18^ Two publications^15,^ ^44^ randomly sampled licensed acupuncturists and patients in their practices from seven states, including Washington and Massachusetts. One study recruited subjects from large urban specialty clinics for orthopedic or neurosurgery consultation^11^ and another recruited a small sample of back pain subjects who had access to the internet.^10^

Utilization was primarily defined as a visit to an acupuncturist or having received or “ever tried” acupuncture based on self-report with or without information from health records. Three publications queried use “within the last 12 months”,^10,^ ^12,^ ^45^ three^11,^ ^18,^ ^45^ reported “lifetime” use, and two^15,^ ^44^ reviewed visits to practitioner over a 1-year interval.

Only one of the publications^15^ provided any detail as to the type of acupuncture administered. This same study was the sole publication to provide information about the mean duration of the visits (60 minutes) but it did not specify the frequency of visits over the course of treatment. The training or type of acupuncturist was specified as “licensed acupuncturist”^15,^ ^18,^ ^44^ in three publications; the remaining eligible publications provided no further details about the practitioner.

Acupuncture utilization based on anatomical region. Tables 4A to 7A show utilization of acupuncture in the U.S. specific to neck pain (n = 2), unspecified back pain (n = 4), LBP (n = 3) and combined back and neck pain (n = 1). Neck pain utilization was reported in two publications^44,^ ^45^ from general population samples and the use of acupuncture varied from 7 to 14 percent of persons with neck pain of unspecified severity and duration. Four publications^10,^ ^15,^ ^44,^ ^45^ reported utilization for unspecified back pain (Table 5A) and found widely varying rates for the use of acupuncture, from 2 percent (recurrent but not disabling back pain from small sample) to 34 percent (severity and location not specified).

Table 4A Utilization of acupuncture in persons with neck pain

Author Year Country | Study Design | Reporting Mode | Timing of CAM Visit | Sample Size | Population | Clinical Presentation | Episode of Care | Outcomes
Studies from the United States
Burke^45^ 2006 U.S. | CS | FI | “Lifetime” use and use in the past 12 months | 30,278 | General population | Any condition | Any use of acupuncture | 1,266/30,278 (4.1%) reported “lifetime use” of acupuncture 327/30,278 (1.1%) reported use of acupuncture in the “past 12 months” 37/270 (13.6%) used acupuncture for neck pain
Cherkin^44^ 2002 U.S. Companion to Sherman^15^ 2006 U.S. | SGPS | SAQ | Visits to practitioner in a 12 month period | 133 AT/488 eligible practitioners | Practitioners were asked to collect patient information | Any condition | Visit to a licensed acupuncturist | % of neck symptoms being the primary reason for visit by practitioner type and state Reported for Washington only: 92/1,263 (7.3%)

Abbreviations: AT = acupuncture therapist; CS = Cross-sectional; FI = Face to face interview; SAQ = Self-administered questionnaire; SGPS = Single group prospective study

Table 5A Utilization of acupuncture in persons with unspecified back pain

Author Year Country | Study Design | Reporting Mode | Timing of CAM Visit | Sample Size | Population | Clinical Presentation | Episode of Care | Outcomes
Studies from the United States
Bruce^10^ 2004 U.S. | RCT | SAQ | Past 12 months | Intervention: 190/296 (64.1%) Control: 231/284 (81.3%) | Participants with recurrent back pain but not receiving any disability insurance | CBP Mean duration back pain: 13.4 yrs (SD=10) | Baseline: “Ever tried CAM”. Could include ≥1 CAM therapy 1 year: “CAM in past 6 months” | Baseline: Intervention: 38/190 (20%) Control: 53/231 (23%) Outcomes: Intervention: 5/190 (2.6%) Control: 5/231 (2.2%)
Burke^45^ 2006 U.S. | CS | FI | “Lifetime” use and use within the past 12 months | 30,278 | General population | Any condition | Ever used or recent use of acupuncture | 1,266/30,278 (4.1%) reported “lifetime use” of acupuncture 327/30,278 (1.1%) reported use of acupuncture in the “past 12 months” 92/270 (34.0%) used acupuncture for back pain
Cherkin^44^ 2002 U.S. | SGPS | SAQ | Visits to practitioner in a 12-month period | 133 AT, 488 eligible practitioners | Practitioners were asked to collect patient information | Any condition | Visit to a practitioner | Back ‘symptoms’ Massachusetts: 147/1,298 (11.3%) Washington: 215/1,263 (17.0%)
Sherman^15^ 2006 U.S. Companion to Cherkin^44^ 2002 U.S. | SGPS | SAQ | Visits to practitioner in a 12-month period | 219 visits to licensed AT | Patients with CBP | Any condition | Visit to AT | 10% of visits to the AT were for any back pain 2/3 of visits were for CBP 1/3 of visits were for acute back pain Visit duration: Median 60 minutes
Studies from outside the United States
Foltz^118^ 2005 Canada | CS | TI | Past 12 months | Complete sample 66,253 Non-specific CBP 11,736 (17.7%) CAM users 3,259 (39%) | Subset from a large national general sample collected from 1996 to 1998 1 of 4 groups identified was “CBP or musculo-skeletal disease” | CBP was diagnosed by a health professional | ‘CAM users’ if:; 1) received or discussed CAM with a non-mainstream practitioner; 2) used a support group for health problem; 3) received care from D.C. | CBP respondents, 39% (95% CI: 38.1–39.9) had used CAM during the past 12 months 20.6% (95% CI: 19.4 to 22.8) of this sample used acupuncture
Giles^126^ 2003 Australia | SGPS | HRR SAQ | New cases followed for 12 months | 861/1,775 (48.5%) patients referred to spine pain clinic received treatment with CAM | Sample from a specialized clinic (multi-disciplinary spinal pain unit) Majority chronic pain (92.7%) | 100% with spinal pain; of the 941 patients who could recall when their symptom began 92.7% reported chronic pain (>3 months duration) | Treatment with acupuncture | 507/1,775 (28.6%) treated with needle acupuncture. Of those receiving treatment (507/861), 58.9% received needle acupuncture 7,831 visits patients receiving acupuncture
Sibbritt^127^ 2007 Australia | CS | SAQ | Past 12 months | 11,143/11,202 responded to question about acupuncture use. 466/11,143 (4.2%) women reported use of acupuncture | Middle-aged Australian women, aged 50 to 55 | Variety of conditions | Consultation with an AT | 284/466 (61%) consulted an AT for back pain

Abbreviations: AT = acupuncture therapist; CAM = Complementary and Alternative Medicine; CBP = chronic back pain; CLBP = Chronic low back pain; CS = Cross-sectional; D.C. = Doctor of Chiropractic; FI = Face to face interview; HRR = Health record review; LBP = Low back pain; M.D. = Medical Doctor; MT = massage therapist; NP = Naturopathic Physician; SAQ = Self-administered questionnaire; SD = Standard Deviation; SGPS = Single group prospective study; TI = Telephone interview; yrs = years

Table 5B Utilization of acupuncture in persons with unspecified back pain

Author Year Country | Use with Conventional Care | Concurrent use with Other CAM
Studies from the United States
Bruce^10^ 2004 U.S. | Not collected | Not reported but data presented indicated respondents had used 1 or more CAM therapy
Burke^45^ 2006 U.S. | Not reported | Not reported
Cherkin^44^ 2002 U.S. | NSBP | NSCAM
Sherman^15^ 2006 U.S. Companion to Cherkin^44^ 2002 U.S. | Not reported | Heat: 61 to 72% East Asian massage: 24 to 42% Herbs: 27to 29% Cupping: 14 to 26%
Studies conducted outside the United States
Foltz^118^ 2005 Canada | For CAM users: Percent reporting visit: To any physician: 6.2% (95% CI 6.0–6.4) To GP: 5.1% (95% CI 5.0–5.3) To specialists: 1.1% (95% CI 1.0–1.2) To PT: 2.4% (95% CI 2.2–2.4) To psychologists: 0.3% (95% CI 0.3–0.3) | Concurrent use evident but data not stratified by type of CAM therapy
Giles^126^ 2003 Australia | Not reported | Not specified
Sibbritt^127^ 2007 Australia | Not collected | Not collected

Abbreviations: CAM = Complementary and Alternative Therapy; NSBP = Data not stratified by back pain; NSCAM = Not stratified by CAM therapy; PT = Physical Therapist

Table 7A Utilization of acupuncture in persons with combined neck and back pain

Author Year Country | Study Design | Reporting Mode | Timing of CAM Visit | Sample Size | Population | Clinical Presentation | Episode of Care | Outcomes
Studies from the United States
Wolsko^12^ 2003 U.S. | CS | TI | Past 12 months | 644/2,055 respondents reported back pain (60% response rate) | Individuals who have had neck or back pain in the past 12 months | 46% had pain in more than 1 location 38% had LBP only 16% had neck or upper back pain only | Use of a CAM therapy or visit with CAM practitioner | Acupuncture: 0.9% Mean number of visits: 2.6 Estimated total visits: 1.6 million Relative frequency for CAM use did not differ by the location of the back pain
Studies outside the United States
Esmail^117^ 2007 Canada Companion to Ramsay^116^ 1999 Canada | CS | TI | Past 12 months | Second wave: 376/2,000 (18.8%) respondents First wave: 386/1,500 (25.7%) | General adult population | NSBP back or neck problems in the past 12 months | Use of a CAM therapy or visit with a practitioner who is not a medical doctor | Acupuncture use in persons with back pain 30% (1997) 30% (2006)

Abbreviations: AT = Acupuncture Therapist; CAM = Complementary and Alternative Medicine; CS = Cross-sectional; LBP = Low back pain; NSBP = Data not stratified by back pain; TI = Telephone interview

Similarly, the three publications^11,^ ^16,^ ^18^ evaluating the use of acupuncture for LBP patients (Table 6A) showed rates ranging from 3 to 11 percent of the total sample of subjects; two of these publications^11,^ ^18^ indicate the back pain was chronic in nature. One study^12^ (Table 7A) reported acupuncture use for patients with combined neck and back pain and showed a utilization rate of 0.9 percent (95 percent CI, 0–1.9), and an estimated total of 1.6 million visits (mean of 2.6 visits); this study also reported no difference in the relative frequency of CAM use by location of the back pain. However, a single study^45^ that segregated rates for persons with neck and back pain found that acupuncture was used more frequently for back pain than for neck pain (34 versus 14 percent).

Table 6A Utilization of acupuncture in persons with low back pain

Author Year Country | Study Design | Reporting Mode | Timing of CAM Visit | Sample Size | Population | Clinical Presentation | Episode of Care | Outcomes
Studies from the United States
Lind^16^ 2005 U.S. | Retro Rev | AD | Outpatient visits over course of 1 year | 109,080/601,044 enrollees had back pain; 104,358 (96%) were eligible for review | Enrollees (ages 18–64) in large health insurance plans; enrollees had NOT been hospitalized or undergone surgery for back pain | Back pain | At least one visit for back pain to a CAM provider | Acupuncture; - used by 2,701 persons (2.6% of back pain population); - had 15,500 visits (2.4% of total visits); - median number of visits was 4; - 962/104,358 (0.9%) LBP sought acupuncture only
Long^11^ 1996 U.S. | SGPS | SAQ | Past 12 months | 2,374/4,171 subjects had complete data and followup | Adult patients presenting to centers for orthopedic surgery or neurosurgery consultation | 100% of patients presented with persistent LBP (mean duration of current episode 2.52 years) | Treatments or visits to CAM practitioners | Acupuncture was previously used by 9.3% Specialists consulted for back pain before enrollment in the study: AT - 10.2%
Studies from the United States
Sherman^18^ 2004 U.S. | CS | TI | Lifetime use | Pilot sample obtained from health claims database; 249/787 patients responded to interview | Members of a non-profit managed health care system and a large multi-specialty group practice | 100% persistent non-specific LBP >3 months | Reported “Ever tried” | Acupuncture had been “ever tried” by 11% of back pain patients
Studies from outside the United States
Caswell^128^ 2002 U.K. | CS | SAQ | Lifetime use | 150 subjects had back pain divided into three groups:; 1) CBP using CAM; 2) CBP not using CAM; 3) no back pain | Subjects attending private physiotherapy or NHS pain clinics | CLBP | Visit to CAM practitioner | 10/50(20%) used acupuncture to treat back pain 36% conventional patients had used at least 1 CAM therapy in the management of their back pain (use with acupuncture not specified)
Chenot^51^ 2006 Germany | SGPS | FI | Past 12 months | 1,345/ 1,588 (84.6%) back pain patients 1,218/1,345 (90.6%) completed 12 month followup | Sample recruited within practices of general practitioners | Consecutive patients with LBP | Use of CAM therapy | 179/1,218 (13%) received acupuncture during 12 month followup Acupuncture sessions Range = 1 to 47 mean 12 (SD ± 8.8)
Davies^125^ 1996 U.K. | BA | HRR | Within 6 months, then following 7 months | Observation period 1: 761/ 1,236 (62%) LBP Observation period 2: 1,096/1,791 (61%) LBP | Patients from 10 specialized outpatient pain clinics Patients with either nerve damage or LBP were selected | Nerve damage, LBP | Receiving acupuncture | Observation period 1: 142/ 761 (18.7%) acupuncture treatment Observation period 2: Not specified
Scheurmier^129^ 1998 U.K. | SGPS Retro Rev | HRR | Past 4 months | 484/592 (84%) | Patients from GP practices in the U.K. | 100% with acute LBP (duration <6 weeks) | Visit to CAM provider | 49/259 (19%) received acupuncture referral
Walker^119^ 2004 Australia | CS | SAQ | Past 6 months | 1,913/2,748 (69.6%) responded; 1,228/1,913 (64.1%) indicated at least 1 episode of back pain | Individuals from the electoral roll in Australia | 100% reported LBP in the last 6 months | Visit to CAM practitioner | Acupuncture was sought by 35 patients (2.2%) with back pain and seeking care

Abbreviations: AD = administrative database; AT = Acupuncture Therapist; BA = before after; CAM = Complementary and Alternative Medicine; CI = Confidence interval; CBP = Chronic back pain; CS = Cross-sectional; D.C. = Doctor of Chiropractic; FI = Face to face interview; GP = general practitioner; HRR = Health record review; LBP = Low back pain; M.D. = Medical Doctor; MT = massage therapist; NHS = National Health Service; NP = Naturopathic Physician; Retro Rev = Retrospective Review; SAQ = Self-administered questionnaire; SD = standard deviation; SGPS = Single group prospective study; TI = Telephone interview

Table 6B Utilization of acupuncture in persons with low back pain

Author Year Country | Use with Conventional Care | Concurrent use with Other CAM
Studies from the United States
Lind^16^ 2005 U.S. | Concurrent use possible, but not specified | Concurrent use evident but data not stratified by type of CAM therapy. However, 89% of CAM users saw one type of CAM provider (but not stratified by therapy type)
Long^11^ 1996 U.S. | NSBP: Not reported for period prior to enrollment | NSCAM: Concurrent use evident but data not stratified by type of CAM therapy
Sherman^18^ 2004 U.S. | Not specified for acupuncture | Not collected
Studies conducted outside the United States
Caswell^128^ 2002 U.K. | 90% (9/10) acupuncture patients used at least 1 conventional therapy as a CLBP management method 62% CAM users sought conventional care | Not collected
Chenot^51^ 2006 Germany | Patients using acupuncture saw specialists (84%), physiotherapy (63%), took medications (16% to 75%), and injection therapy (75%) | Also received chiropractic (46%), and massage (37%) Electrotherapy and TENS also received but provider type not specified
Davies^125^ 1996 U.K. | Use of medications, TENS, and nerve blocks were frequently used but proportion overlap with acupuncture not specified | Not collected
Scheurmier^129^ 1998 U.K. | Not specified for acupuncture | Not specified for acupuncture
Walker^119^ 2004 Australia | Not stratified by therapy | NSCAM

Abbreviations: CLBP = Chronic low back pain; LBP = Low back pain; NSBP = Data not stratified by back pain; NSCAM = Not stratified by CAM therapy; TENS = Transcutaneous Electrical Nerve Stimulation

It is important to note whether the denominator used to estimate utilization was based on the entire sample enrolled or just a specific subset of patients with back pain. Two studies^12,^ ^45^ were based on general population samples and, not surprisingly, showed markedly lower rates of acupuncture utilization for both neck and unspecified back (1 to 4 percent) and combined neck and back pain (1 percent) than studies that recruited smaller samples of persons all of whom had back pain.

Acupuncture use as complementary care or combined with other CAM. The majority of publications did not collect or report sufficient information to determine concurrent use of conventional with CAM therapies for back pain. Two publications provided information on use with conventional care but were not specific to those respondents with back pain^44^ or specific to those receiving acupuncture^12^ (Table A2 and A4). Although not stratified for persons with back pain, up to 53 percent of acupuncture patients saw a medical or osteopathic physician, but only 10 percent of persons with back pain reported speaking to their doctor about using acupuncture.^44^ Another study^12^ suggested that CAM alone had been used by 29 percent of persons with back and neck pain; however, this was not specific to those receiving acupuncture.

Most studies did not report concurrent or combined use of different CAM therapies in a detailed manner. Overall, when conventional or combined therapy details were reported, the results were not stratified with respect to using acupuncture or specifically for those with back pain (Tables 4B to 7B). There was one exception^15^ and this publication indicated that acupuncture was used predominately with other CAM therapies such as east Asian massage, cupping, heat, and herbs.

Table 4B Utilization of acupuncture in persons with neck pain

Author Year Country | Use with Conventional Care | Concurrent use with Other CAM
Studies from the United States
Burke45 2006 U.S. | Not reported | Not reported
Cherkin44 2002 U.S. Companion to Sherman15 2006 U.S. | NSBP Acupuncture patients receiving care from M.D. or OD Massachusetts: 49.7% Washington: 56.2% | Not reported

Abbreviations: CAM = Complementary and Alternative Therapy; M.D. = Medical Doctor; NSBP = Data not stratified by back pain; NSCAM = Not stratified by CAM therapy; OD = Osteopathic Doctor

Table 7B Utilization of acupuncture in persons with combined neck and back pain

Author Year Country | Use with Conventional Care | Concurrent use with Other CAM
Studies from the United States
Wolsko^12^ 2003 U.S. | NSCAM 25% had used both complementary medicine and a conventional provider | Used any CAM: from those with back and neck pain, 29% had used CAM alone Concurrent use not specified
Studies conducted outside the United States
Esmail^117^ 2007 Canada Companion to Ramsay^116^ 1999 Canada | NSBP 2006: 30% saw a medical doctor in the 12 months 1997: 14% utilized both a medical doctor and alternative provider within the past 12 months. | Not specified for acupuncture

Abbreviations: CAM = Complementary and Alternative Therapy; NSBP = Data not stratified by back pain; NSCAM = Not stratified by CAM therapy

Quality assessment of U.S. acupuncture publications. Only one^10^ of the eight U.S. publications on the utilization of acupuncture for back pain used a study design with a true comparator group; as such the focus of our quality assessment is on the potential for selection and reporting biases. All but a single publication^16^ are based on self-reported utilization and therefore subject to recall bias; heterogeneity with respect to survey versus interview and the types of CAM services queried are also important sources of reporting bias.

Two^12,^ ^45^ of three cross-sectional publications were of high quality, reporting CAM utilization based on random sampling of the general population with adequate response rates (74 and 63 percent respectively). The third study^18^ recruited subjects from a health database and then subsequently interviewed them. This study had a low response rate (36 percent) and had the potential for selection bias as the eligible sample had to have back pain (44 percent were ineligible due to no longer having back pain). One study, based on a large health insurance claims database, would also be considered high quality as it used standardized coding for back pain classification, provider visits, and treatments.^16^

There is greater potential for selection bias in studies using samples obtained from provider clinics. Two publications^15,^ ^44^ randomly sampled licensed acupuncturists using a recruitment strategy based on the National Ambulatory Medical Care Survey. This methodology collects service visit characteristics close to the time of each patient encounter thereby minimizing longterm provider recall, errors from chart extraction, and retrospective administrative data analysis. The two remaining studies recruited chronic back pain subjects who had been referred for orthopedic or neurosurgery consultation or from urban specialty clinics^11^ and a small sample of back pain subjects who had access to the internet.^10^ As noted previously, the rates of use for patients already seeking treatment differ from those in the general population; additionally, those already seeking CAM therapy services may possess inherent differences in defining characteristics that are not easily determined in the absence of comparison groups.

Across all eight U.S. publications, the methodological quality is rated as fair, indicating that they are susceptible to some biases but these, being somewhat endemic to self-report, are not sufficient to negate the results.

Summary of utilization for back pain for U.S. acupuncture publications. Eight publications evaluated the use of acupuncture in persons with back pain and all but one used self-report methods.^16^ Two of these studies^12,^ ^45^ were based on randomly selected general population samples and, as expected, these showed markedly lower rates of utilization for both neck and unspecified back (1 to 4 percent) and combined neck and back pain (1 percent). Similar rates of utilization were observed (1 percent) in a study evaluating a large administrative database. All other studies based primarily on subjects from clinical practices or with back pain showed higher rates of utilization (7 to 36 percent). Rates of use also varied by the timeframe for recall (12 months to lifetime prevalence), the interval of analysis for administrative databases, and recruitment of subjects from clinical practices.

The majority of publications evaluated LBP or unspecified pain, with utilization for neck or combined neck and back problems being less commonly assessed. No clear pattern emerges for acupuncture utilization rates as a function of region of the back; in part this is due to the limited number of studies, but it may also be related to the lower prevalence of neck pain relative to LBP.

Only one of the publications^15^ provided any detail as to the specific type of acupuncture provided. A single publication^44^ presented information on concurrent conventional care with acupuncture. When reported, conventional care overlap was generally not stratified for acupuncture. Similarly, a single publication^15^ sufficiently detailed combining of other alternative therapies with acupuncture. Overall these studies were rated as having fair methodological quality, indicating that they are susceptible to some biases. These threats to validity are somewhat endemic to the use of self-report of utilization but are not sufficient to negate the results.

### Acupuncture Utilization Outside the U.S

Of the 10 publications on utilization outside of the U.S., three^116^–^118^ were based in Canada, three^125,^ ^128,^ ^129^ in the United Kingdom, three^119,^ ^126,^ ^127^ in Australia, and one^51^ in Germany.

Six of the 10 publications were of cross-sectional design with utilization outcomes derived equally from interviews^116^–^118^ or self-administered questionnaires (Tables 4A to 7A).^119,^ ^127,^ ^128^ Three publications used medical chart data and a cohort study design with non-concurrent (historical) control,^129^ a single group prospective study design,^126^ and a before after study design.^125^ Another study used a single group prospective cohort design^51^ based on all subjects enrolled in a randomized controlled trial (RCT) and using interview data.

Half the studies recruited participants from the general population, including a national sample within Canada,^116^–^118^ one within Australia,^119^ and one of Australian women.^127^ The remaining studies recruited subjects from specialized outpatient or pain clinics,^125,^ ^126,^ ^128^ and general medical practices.^51,^ ^129^

Utilization was primarily defined as a visit with an acupuncturist or having received or “ever tried” acupuncture. In addition to a visit to a CAM practitioner, one study^118^ included “discussed CAM with, a non-mainstream practitioner” and “looked for a support group when faced with a health problem” as utilization. Half the publications^51,^ ^116^–^118,^ ^127^ queried use within the last 12 months, and two publications^119,^ ^125^ reported use within 6 months or less. One study^128^ did not report a timeframe and another^126^ reviewed visits over a 6-year interval.

None of the publications provided details as to the type of acupuncture provided. Only two publications indicated that the provider was either a medical acupuncturist^129^ or was likely a conventional practitioner.^125^

Acupuncture utilization based on anatomical region. None of the non-U.S. publications provided utilization specific to the neck and the use of acupuncture. In the three publications that did not specify the location of the back pain (Table 5A), rates of acupuncture use varied from 3 percent^127^ to 29 percent of those with back pain.^126^ Table 6A shows the five publications that evaluated acupuncture use in persons with LBP, and rates varied from 2 percent^119^ to 19 percent.^129^ Two related publications^116,^ ^117^ (Table A4) that combined neck and back pain reported that 28 to 30 percent of back pain patients used acupuncture. No clear trend emerges for the utilization of acupuncture as a function of back region; neck pain specifically was not evaluated in these eligible studies and the other back regions showed a similar range of rates of use. In general, as one would expect, rates of use of acupuncture were lower in population-based samples than those publications with samples from specialty clinics which tended to be smaller in number. It is this factor, rather than the back region that accounts for the majority of observed variability; the timeframe interval and methods used to collect rates of use are also important factors in explaining variability.

Acupuncture use as complementary care or combined with other CAM therapies. Seven publications did report some information regarding use of conventional care with CAM. Three of these^116^–^118^ did not stratify the proportions specific to persons reporting back pain and one did not stratify by practitioner type^119^ (Table 4A and 7A). Three publications^51,^ ^125,^ ^128^ reported use of acupuncture with conventional care and found rates of overlap varying from 90 percent^128^ to 63 percent.^51^ Three publications indicated that patients used medications and injection therapies^128^ (16 to 75 percent), and mixed therapies (medications, nerve blocks, electrotherapy, and transcutaneous electrical nerve stimulation).^51,^ ^125^

The majority of publications did not provide detail regarding concurrent or additional use with other CAM therapies. Two publications^51,^ ^119^ indicated use of acupuncture with other CAM therapies including chiropractic (46 percent) and massage (37 percent).^51^

Quality assessment for non-U.S. acupuncture publications. Seven^51,^ ^116^–^119,^ ^126,^ ^127^ of 10 non-U.S. publications used self-reported utilization data and were subject to some degree of recall bias. The remaining three publications^125,^ ^126,^ ^129^ used medical health record information. Six of the 10 publications were of cross-sectional design with utilization outcomes derived equally from interviews or self-administered questionnaires; of these, five publications^116^–^119,^ ^127^ were derived from random population samples, with one^127^ being limited to older Australian women. However, the response rate was low (19 to 26 percent)^116,^ ^117^ or not reported^118,^ ^127^ in four of these publications. Three publications using non-comparative study designs recruited patients from general practices^129^ or specialized pain clinics.^125,^ ^126^ For these 10 non-U.S. studies the overall methodological quality is fair, suggesting some susceptibility to bias, but not sufficient to negate all the results.

Summary of utilization for back pain for non-U.S. acupuncture publications. Ten publications undertaken in Canada,^116^–^118^ the United Kingdom,^125,^ ^128,^ ^129^ Australia,^119,^ ^126,^ ^127^ and Germany^51^ evaluated the use of acupuncture in persons with back pain. Three of these^125,^ ^126,^ ^129^ retrieved utilization data from health records rather than using self-report methods; the quality of utilization data retrieved was limited by lack of standardized extraction methods. Six of the publications^51,^ ^116^–^119,^ ^127^ using interview or survey methods were cross-sectional studies. Five of these selected random population samples and found utilization rates varying from 2 percent^119^ to 30 percent.^116,^ ^117^ Differences in timeframes queried may account for this variation.

Of the 10 non-U.S. publications, five^51,^ ^116^–^118,^ ^127^ probed use within the last 12 months, and two^119,^ ^125^ reported use within 6 months or less. One publication^128^ did not report a timeframe and another^126^ reviewed visits over a 6-year interval.

The majority of publications evaluated LBP (n = 5) or unspecified pain (n = 3) and none evaluated or reported specifically on neck pain. No clear trend for utilization rates as a function of region of the back was observed in the non-U.S. studies. None of the publications provided details as to the type of acupuncture provided and only two publications specified the type of practitioner.^125,^ ^129^ Although seven publications did report some information regarding use of conventional care with acupuncture, four of these did not either stratify results by persons with back pain^116^–^118^ or specify the CAM practitioner;^119^ the remaining three publications^51,^ ^125,^ ^128^ showed overlap varying from 63 to 90 percent. The majority of publications did not provide sufficient detail regarding concurrent or additional use with other CAM therapies. Two publications^51,^ ^119^ indicated use of acupuncture with other CAM therapies including chiropractic (46 percent) and massage (37 percent).^51^ For these 10 non-U.S. studies the overall methodological quality is fair, suggesting some susceptibility to bias, but not sufficient to negate all the results

### Specific CAM Therapy Utilization: Massage

Nineteen publications provided information on the utilization of massage in persons with back pain. Of these, 12 were specific to the U.S.^9,^ ^11,^ ^12,^ ^15,^ ^16,^ ^18,^ ^20,^ ^22,^ ^23,^ ^30,^ ^33,^ ^44^ Seven of these publications are based on three patient study cohorts from Oregon State medical and chiropractic practices,^20,^ ^22,^ ^23^ the practices of licensed CAM practitioners in Connecticut and Washington,^15,^ ^44^ and North Carolina.^9,^ ^30^ Eight publications provided utilization outcomes from eligible non-U.S. countries;^51,^ ^116^–^119,^ ^121,^ ^130,^ ^131^ one publication^117^ was a companion to a previous study^116^ as it incorporated the findings of the initial survey and utilization from a resampling of new subjects 6 years later.

### Massage Utilization Within the U.S

Three of the 12 eligible U.S. publications used cross-sectional study designs based on interviews.^9,^ ^12,^ ^18^ Two studies were based on retrospective health claims database review^16^ or chart review.^33^ Another study^9^ was designed as a single group prospective study but presented only baseline data for the subgroup of chronic pain patients and as such the results are cross-sectional. The remaining seven publications established CAM utilization using a single group prospective design based on telephone interviews,^15,^ ^30,^ ^44^ self-administered questionnaires,^11^ and health record audit with administrative billing records.^20,^ ^22,^ ^23^

The majority of populations were from specialized clinical practices or from the practices of licensed CAM providers. Three publications reported CAM utilization based on subjects from either a national sample,^12^ or regional samples from North Carolina.^9,^ ^30^ Two publications recruited subjects from health claims databases in Washington state,^16,^ ^18^ and three from family medical and chiropractic practices in Oregon state.^20,^ ^22,^ ^23^ Similarly, two publications^15,^ ^44^ randomly sampled licensed massage therapists and patients within their practices from the states of Washington and Connecticut. One study^33^ recruited patient charts from chiropractic practices within California and another study recruited subjects from large urban specialty clinics for orthopedic or neurosurgery consultation.^11^

Utilization was primarily defined as a visit with a CAM practitioner, having received or “ever tried” massage, or use from a health claims database or health record from a CAM practitioner. Persons with back pain were asked about use of CAM within the last 12 months,^9,^ ^10,^ ^12,^ ^20,^ ^22,^ ^23^ lifetime use,^11,^ ^18^ or visits to practitioner over a 1-year interval.^15,^ ^16,^ ^33,^ ^44^

Two publications^16,^ ^20^ using data from large health claims databases showed low rates of massage utilization for LBP, varying from 4 to 5 percent of the total sample. One study^12^ reported massage use for patients with combined neck and back pain and showed a utilization rate of 14.1 (95 percent CI, 10.8–17.4), an estimated 32.8 million visits (mean of 5.4 visits). In contrast, publications that evaluated use of massage within smaller samples, showed rates of use varying from 16 to 52 percent.

Only one publication^15^ provided any detail as to the type of massage administered to back pain patients. This publication also reported the mean duration of the visits as 60 minutes. The training or type of massage therapist was specified as a “licensed massage therapist”,^15,^ ^18,^ ^44^ provided within a chiropractor practice and thus likely provide by a chiropractor,^20,^ ^22,^ ^23,^ ^33^ or provided within a physical therapy practice thus possibly from a physical therapist.^30^ The remaining four publications^9,^ ^11,^ ^12,^ ^16^ provided no details regarding the massage practitioner.

Massage utilization based on anatomical region. Tables 8A to 11B indicate the number of publications specific to regions of the back and these include: one study evaluating massage utilization for neck pain,^44^ two for unspecified back pain,^15,^ ^44^ nine for LBP,^9,^ ^11,^ ^16,^ ^18,^ ^20,^ ^22,^ ^23,^ ^30,^ ^33^ and one study^12^ that combined back and neck pain. A single study^44^ evaluating patients in licensed massage therapist practices found rates of use of massage for neck pain to vary between 13 and 20 percent for the states of Connecticut and Washington (combined 17 percent). This same study found slightly higher rates of massage use for unspecified back pain at 20 percent for both states.

Table 8A Utilization of massage in persons with neck pain

Author Year Country | Study Design | Reporting Mode | Timing of CAM Visit | Sample Size | Population | Clinical Presentation | Episode of Care | Outcomes
Studies from the United States
Cherkin^44^ 2002 U.S. Companion to Sherman^15^ 2006 U.S. | SGPS | SAQ | Past 12 months | MT: 126/488 (25.8%) eligible practitioners | Practitioners from several professions asked to collect patient information | Any condition | Visit to a licensed MT | % of neck symptoms being the primary reason for visit by practitioner type and state Connecticut: 125/965 (13.0%) Washington: 208/1,040 (20.0%)
Studies from outside the United States
Vos^130^ 2007 Netherlands | SGPS | SAQ | Utilization reported prior to entry into the study | 187/259 (72%) patients enrolled in the study | Patients recruited from general practice setting - all persons had neck pain | Acute neck pain | Visit to CAM practitioner at baseline | Patients at baseline use: 13/187 (7%)

Abbreviations: CAM = Complementary and Alternative Medicine; MT = massage therapist; SAQ = Self-administered questionnaire; SGPS = Single group prospective study

Table 8B Utilization of massage in persons with neck pain

Author Year Country | Use with Conventional Care | Concurrent use with Other CAM
Studies from the United States
Cherkin^44^ 2002 U.S. Companion to Sherman^15^ 2006 U.S. | NSBP | NSCAM
Studies conducted outside the United States
Vos^130^ 2007 Netherlands | Not applicable as all enrolled patients saw conventional practitioner | Concurrent use at baseline apparent but overlap not specified. During followup 12% (23 patients) used CAM; most often this was Reiki/energy, healing therapy and acupuncture

Abbreviations: CAM = Complementary and Alternative Medicine; NSBP = Data not stratified by back pain; NSCAM = Not stratified by CAM therapy

Table 9A Utilization of massage in persons with unspecified back pain

Author Year Country | Study Design | Reporting Mode | Timing of CAM Visit | Sample Size | Population | Clinical Presentation | Episode of Care | Outcomes
Studies from the United States
Cherkin^44^ 2002 U.S. Companion to Sherman^15^ 2006 U.S. | SGPS | SAQ | Past 12 months | MT: 126/488 (25.8%) eligible practitioners | Practitioners from several professions, were asked to collect patient information | Any condition | Visit to a licensed MT | % of back symptoms being the primary reason for visit by practitioner type and state: Connecticut: 197/965 (20.4%) Washington: 210/1,040 (20.2%)
Sherman^15^ 2006 U.S. *Companion to Cherkin^44^ 2002 U.S. | SGPS | SAQ | Past 12 months | 236 visits to licensed MT | Patients with CBP | 100% had CBP | Visit to provider | # visits for CBP: Connecticut: 121 Washington: 115 Deep tissue 82(4%), 84(2%) Swedish 85(5%), 76(5%) Trigger point 57(6%), 62(5%) 1/3 ABP and 2/3 for chronic pain CBP
Studies from outside the United States
Foltz^118^ 2005 Canada | CS | TI | Past 12 months | Complete sample 66,253 Non-specific CBP 11,736 (17.7%) CAM users 3,259 (39%) | Subset from a large national general sample collected from 1996 to 1998 Four groups were identified and one group was “CBP or musculoskeletal disease” | CBP was diagnosed by a health professional | ‘CAM users’ if:; 1) received or discussed CAM with a non-mainstream practitioner; 2) used a support group for health problem; 3) received care from D.C. | Chronic back pain respondents, 39% (95% CI 38.1–39.9) had used CAM during the past 12 months 55.5 % (95% CI 54.1–57.0) used massage 21% (2,425) had attended a D.C. in the past 12 months

Abbreviations: CAM = Complementary and Alternative Medicine; CI = Confidence interval; CBP = Chronic back pain; CS = Cross-sectional; D.C. = Doctor of Chiropractic; MT = massage therapist; SAQ = Self-administered questionnaire; SGPS = Single group prospective study; TI = Telephone interview

Table 9B Utilization of massage in persons with unspecified back pain

Author Year Country | Use with Conventional Care | Concurrent use with Other CAM
Studies from the United States
Cherkin^44^ 2002 U.S. *Companion to Sherman^15^ 2006 U.S. | NSBP | NSCAM
Sherman^15^ 2006 U.S. Companion to Cherkin^44^ 2002 U.S. | Not specified for massage | Movement re-education 23%/30% Energetic work 5%/4% Neuromuscular 3%/6% Reflexology 3%/4% Breathwork 4%/4%
Studies conducted outside the United States
Foltz^118^ 2005 Canada | CAM users reporting visit to: Physician: 6.2% (95% CI 6.0–6.4) GP: 5.1% (95% CI 5.0–5.3) Specialists: 1.1% (95% CI 1.0–1.2) PT: 2.4% (95% CI 2.2–2.4) Psychologists: 0.3% (95% CI 0.3–0.3) | Concurrent use evident but data not stratified by type of CAM therapy

Abbreviations: CAM = Complementary and Alternative Medicine; CI = Confidence interval; GP = General Practitioner; NSBP = Data not stratified by back pain; NSCAM = Not stratified by CAM therapy; PT = Physical Therapist

Table 10A Utilization of massage in persons with low back pain

Author Year Country | Study Design | Reporting Mode | Timing of CAM Visit | Sample Size | Population | Clinical Presentation | Episode of Care | Outcomes
Studies from the United States
Carey^9^ 1995 U.S. | CS | TI | Past 12 months | 269/4,437 (3.9%) interviewed had CLBP | North Carolina residents | 100% with CLBP (functionally limited for >3 months or >25 episodes of LBP in past 12 months) | Visit with a health provider; lifetime prevalence | For those seeking care for LBP massage: 78/187 (42%)
Lind^16^ 2005 U.S. | Retro Rev | AD | Outpatient visits over 1 year | Back pain: 109,080/601,044 (18.1%) Reviewed: 104,358 (17.4%) Use massage; 11,694 (11.2%) | Enrollees in health insurance plans that had NOT been hospitalized or had surgery for back pain | Back pain | Visit for back pain to a CAM provider | Massage: 4,317/104,358 (4.1%) LBP patients sought massage only
Long ^11^ 1996 U.S. | SGPS | SAQ | Past 12 months | 2,374/4,171 (56.9%) subjects had complete data and followup | Adult patients presenting for orthopedic surgery on neurosurgery consultation | 100% of patients with persistent LBP Mean duration LBP: 2.52 years | Treatments for back pain prior to enrollment into the study | Massage previously used by 43.2%
Mielenz^30^ 1997 U.S. | SGPS | TI | Past 12 months | 1,540 ALBP 199/1540 (12.9%) seeking treatment from PT | Patients recruited from healthcare providers | 100% with acute LBP (<10 week duration) | Visit with a health provider; lifetime prevalence | Sought physical therapy: 49% received massage
Nyiendo^22^ 2001 U.S. | SGPS | SAQ HRR | Past 12 months | 121/2,945 (4.1%) from medical practices 147/2,945 (4.9%) chiropractor practices | Persons with CLBP with sciatica | 100% with CLBP and sciatica (>6 weeks duration) | Visit to practitioner | Chiropractic patients: 52.4% received massage
Nyiendo^23^ 2001 U.S. Companion to Nyiendo^22^ 2001 U.S. | SGPS | SAQ HRR | Past 12 months | 2,945 patients enrolled; 309 from medical practices 526 from chiropractic practices | Persons with CBP with sciatica | 100% with chronic LBP and sciatica (>6 weeks duration) | Visit to practitioner | D.C. use of massage was similar to that reported for electrotherapy (42.7%) received electrotherapy at least 1 visit >5 treatments (10%)
Stano^20^ 2002 U.S. Companion to Nyiendo^22,23^ 2001 U.S. | SGPS | SAQ HRR | Past 12 months | 2,872 total 922 medical patients 1,950 chiropractic patients | Patients with ALBP and CLBP | Acute and chronic ambulatory LBP of mechanical origin | Frequency of therapy procedure codes used | Out of 28,061 visits: 1,449 (5.2%) received massage
Shekelle^33^ 1995 U.S. | Retro Rev | HRR | Past 12 months | 80 patient records were selected (10 from each of 8 chiropractic practices) | Patient record from random sample of chiropractic practices | 100% with LBP (56%<3 weeks duration; 25% >13 weeks duration) | First visit between specified interval | Massage 25%
Sherman^18^ 2004 U.S. | SGPS | SAQ HRR | Lifetime use | Health claims database; Participants: 249/787 (31.6%) 24/249 (9.6%) tried massage for back pain | Members of a non-profit managed health care system and a large multi-specialty group practice | Non-specific LBP that had persisted for more than 3 months | Any visit to MT | Massage had been “ever tried” by 24% of back pain patients
Studies from outside the United States
Chenot^51^ 2006 Germany | SGPS | FI | Past 12 months | 1,345/ 1,588 recruited back pain patients. 1,218 completed 12 month followup; from these 179 used acupuncture | Sample recruited within practices of general practitioners | Consecutive patients with LBP | Use of CAM therapy | 67/175 (37%) received massage in addition to acupuncture 350/1,145 (30%) received massage only
Groenendijk^121^ 2007 Netherlands | Retro Rev | AD | Study 1: 1989 to 1992 Study 2: 2002 to 2003 | Study 1: LBP: 1,948/16,000 (11.9%) Study 2: LBP: 1,200/7,561 (15.4%) | Sample from AD of patients treated by PT for back pain | LBP without radiation, greater than 18 years of age | Visits to physical therapist | Study 1: 55.9% massage (most frequently used modality) Study 2: 38.5% massage (third most frequently used modality)
Walker^119^ 2004 Australia | CS | SAQ | Past 6 months | Responders: 1,913/2,748 (69.6%) At least 1 episode of back pain: 1,228/1,913 (64.1%) | Individuals from the electoral roll in Australia | 100% reported LBP in the last 6 months | Visit to CAM practitioner | Massage: 286/1,595 (17.9%) of those with back pain seeking care MT use: 161/1,076 (15.0%)

Abbreviations: AD = administrative database; ALBP = acute low back pain; CAM = Complementary and Alternative Medicine; CBP = Chronic back pain; CLBP = Chronic low back pain; CS = Cross-sectional; D.C. = Doctor of Chiropractic; FI = Face to face interview; HRR = health record review; LBP = Low back pain; M.D. = Medical Doctor; MT = massage therapist; ND = Naturopathic Doctor; O.D. = Osteopathic Doctor; PT = Physical Therapist; Retro Rev = Retrospective Review; Q = Self-administered questionnaire; SAQ = self-administered questionnaire; SGPS = Single group prospective study; TI = Telephone interview

Table 10B Utilization of massage in persons with low back pain

Author Year Country | Use with Conventional Care | Concurrent use with Other CAM
Studies from the United States
Carey^9^ 1995 U.S. | Concurrent use evident but not stratified by therapy | Concurrent use evident but not stratified by therapy
Lind^16^ 2005 U.S. | Concurrent use possible, but not specified | Concurrent use evident but data not stratified by type of CAM therapy 89% of CAM users saw one type of CAM provider not stratified by therapy type
Long ^11^ 1996 U.S. | Not reported for period prior to enrollment | Concurrent use evident but data not stratified by type of CAM therapy
Mielenz^30^ 1997 U.S. | Concurrent use evident but not stratified by therapy | Massage may have been used with spinal manipulation; other modalities are not considered CAM if administered by a physical therapist
Nyiendo^22^ 2001 U.S. | Not applicable | Concurrent use evident but not stratified by therapy; likely received spinal manipulation.
Nyiendo^23^ 2001 U.S. *Companion to Nyiendo^22^ 2001 U.S. | Not applicable | Concurrent use evident but not stratified by therapy; likely received spinal manipulation
Stano^20^ 2002 U.S. *Companion to Nyiendo^22^,^23^ 2001 U.S. | Not applicable | Physical therapy modalities were frequently used, with massage and trigger-point therapy used most often
Shekelle^33^ 1995 U.S. | Not applicable | Not specified for massage but likely received chiropractic manipulation
Sherman^18^ 2004 U.S. | Not specified | Not collected
Studies conducted outside the United States
Chenot^51^ 2006 Germany | Not specified for massage | Not specified for massage
Groenendijk^121^ 2007 Netherlands | Not applicable | Not specified, but likely used passive mobilizations
Walker^119^ 2004 Australia | 59% attended multiple providers 3.3% from a GP and D.C. 1.5% from a GP, D.C., and MT | NSCAM

Abbreviations: CAM = Complementary and Alternative Medicine; D.C. = Doctor of Chiropractic; GP = general practitioner; MT = Massage therapist; NSBP = Data not stratified by back pain; NSCAM = Not stratified by CAM therapy

Table 11A Utilization of massage in persons with combined neck and back pain

Author Year Country | Study Design | Reporting Mode | Timing of CAM Visit | Sample Size | Population | Clinical Presentation | Episode of Care | Outcomes
Studies from the United States
Wolsko^12^ 2003 U.S. | CS | TI | Past 12 months | 644/ 2,055 (60%) reported back pain | Individuals who have had neck or back pain in the past 12 months | 46% had pain in more than 1 location 38% had LBP only 16% had neck or upper back pain only | Use of a CAM therapy or visit with CAM practitioner | Massage used 14.1% (95% CI; 10.8–17.4) LBP (38%) Neck pain only (16%) Pain in more than 1 location (46%) Mean number of visits: 5.4 Estimated total visits: 32.8 million
Studies from outside the United States
Cote^131^ 2001 Canada | CS | SAQ | Past 4 weeks | 1,131/2,184 (55%) participated 907/1,131 (80%) had back or neck pain | Saskatchewan Health Insurance and Registration File | 100% had back and/or neck pain in the past 6 months | Visit to health care provider | 215 who saw a provider for neck or LBP within the last 4 weeks 7% consult massage therapist
Esmail^117^ 2007 Canada Companion to Ramsay^116^ 1999 Canada | CS | TI | Past 12 months | First wave: n = 1,500 28% reported back or neck problems Second wave: n = 2,000 30% reported back or neck problems | General adult population in Canada | 30% reported back or neck problems in the past 12 months | Use of a CAM therapy or visit with a practitioner who is not a medical doctor | Massage use in persons with back pain 39% (2006) 42% (1997)

Abbreviations: CAM = Complementary and Alternative Medicine; SAQ = Self-administered questionnaire; SGPS = Single group prospective study; TI = Telephone interview

Table 11B Utilization of massage in persons with combined neck and back pain

Author Year Country | Use with Conventional Care | Concurrent use with Other CAM
Studies from the United States
Wolsko^12^ 2003 U.S. | 25% had used both complementary medicine and a conventional provider | Used any CAM: back and neck pain, 29% had used CAM alone. However, concurrent use not specified. Relative frequency for CAM use did not differ by the location of the back pain.
Studies conducted outside the United States
Cote^131^ 2001 Canada | M.D. & MT: 3.7% M.D., D.C., PT, MT : 2.8% | D.C. & MT: 5.1 % Care seeking did not differ between neck and back pain patients
Esmail^117^ 2007 Canada *companion to Ramsay^116^ 1999 Canada | 25% had used both complementary medicine and a conventional provider | Not specified for massage

Abbreviations: CAM = Complementary and Alternative Medicine; D.C. = Doctor of Chiropractic; M.D. = Medical Doctor; MT = Massage therapist; NSBP = Data not stratified by back pain; NSCAM = Not stratified by CAM therapy; PT = Physical Therapist

The majority of publications^9,^ ^11,^ ^16,^ ^18,^ ^20,^ ^22,^ ^23,^ ^30^ reported on massage use in persons with LBP and all of these publications evaluated chronic LBP, except two^20,^ ^30^ which had combined acute and chronic groups. Two publications^16,^ ^20^ using data from large health claims databases showed low rates of utilization, varying from 4 to 5 percent of the total sample. In contrast, publications that evaluated use of massage within smaller samples with chronic back pain, showed rates of use varying from 24 to 52 percent. One study^12^ reported massage use for patients with combined neck and back pain also reported no difference in the relative frequency of massage use by location of the back pain.

Massage use as complementary care or combined with other CAM therapies. The majority of publications did not collect or report sufficient information to determine use of complementary or other CAM therapies specific to patients receiving massage. There was one exception^15^ and this study indicated that massage was used predominately with movement re-education and less frequently with energetic work, and reflexology.

Two publications reported use with other CAM therapies but were not specific to those respondents with back pain^44^ or specific to those receiving massage.^12^ Although not stratified by back pain, up to 29 percent of subjects receiving massage saw a medical or osteopathic physician.^44^ Another study^12^ suggested that CAM alone had been used by 25 percent of persons with back and neck pain; however, this was not specific to those receiving massage.

Quality assessment for U.S. massage publications. Three of the 12 eligible U.S. publications used cross-sectional study designs based on interviews.^9,^ ^12,^ ^18^ One publication^12^ was based on a randomly sampled population cohort with adequate response rate while another^18^ obtained a low response rate (36 percent) creating the potential for selection bias. Another study recruited subjects from North Carolina, and reported baseline data for subjects with chronic back pain^9^ or acute back pain.^30^ Four publications used retrospective administrative database information and employed methods to standardize coding for back pain classification, provider visits, and treatments; one was based on a large health plan database^16^ and the others from chiropractic practices across a state.^20,^ ^22,^ ^23^ There is greater potential for selection bias in studies stemming from samples obtained from provider clinics. Two related publications^15,^ ^44^ randomly sampled licensed massage therapists and patients within their practices but was essentially a single group prospective design. The remaining studies employed single group prospective designs from specialized settings.^11,^ ^33^ There is significant overlap with the studies included for acupuncture. These studies evaluating the use of massage within the U.S. are prone to some biases but these do not negate the validity of the results; the overall quality is rated as fair for these studies.

Summary of use for back pain in U.S. massage publications. Twelve U.S. publications evaluated the use of massage in persons with back pain. The majority of populations were from specialized clinical practices of back pain patients or CAM providers. Two publications^16,^ ^20^ using data from large health claims databases showed low rates of utilization, varying from 4 to 5 percent of the total sample. One study with a population based sample^12^ reported massage use for patients with combined neck and back pain as 14.1 percent (95 percent CI, 10.8–17.4). Publications that evaluated use of massage in smaller samples, showed rates of use varying from 17 to 52 percent. The timeframe of reported use was 1 year, with the exception of two studies evaluating lifetime use.^11,^ ^18^ Only one of the publications,^15^ provided any detail as to the type of massage administered to back pain patients.

From 11 publications, the majority reported on low back problems (n = 9) and mostly for chronic pain; only one study^44^ reported on utilization of massage in neck pain. A single publication^12^ reported no difference in the relative frequency of massage use by location of the back pain.

Most publications did not collect or report sufficient information to determine use of complementary or other CAM therapies by patients receiving massage. There was one exception^15^ and this study indicated that massage was used predominately with movement re-education and less frequently with energetic work, and reflexology. Although several studies indicated that massage was used in combination with other CAM therapies, none indicated which other therapies were combined with massage.

### Massage Utilization Outside the United States

From the eight publications undertaken outside of the U.S., four were from Canada,^116^–^118,^ ^131^ two from the Netherlands,^121,^ ^130^ one from Germany,^51^ and one from Australia.^119^ All the publications undertaken within Canada were cross-sectional design from randomly selected samples, predominately at a national level; all but one study^131^ was undertaken by telephone interview. The Australian study^119^ was also a population-based cross-sectional study using self-administered questionnaire. The two Dutch publications were both based on a single group prospective questionnaire completed by subjects selected from general medical practices^130^ and from a retrospective analysis of an administrative database for physical therapy.^121^ Similarly, the study from Germany^51^ interviewed a single group prospective cohort from general practices.

Utilization of massage therapy was primarily defined as a visit with a CAM practitioner, or use as indicated in a health claims database. All subjects were asked about use of CAM within the last 12 months with the exception of three publications, which evaluated use within the last 6 months,^119^ past 4 weeks,^131^ or lifetime use.^130^

Five publications^116^–^119,^ ^131^ were cross-sectional in design recruiting randomly selected national or provincial samples. In these studies utilization rates varied from 7 percent^131^ within the past 4 weeks to 42 percent lifetime use.^116^ Generally, studies of single group prospective design showed higher rates of utilization from 56 percent from an administrative database^121^ to 30 percent.^51^ The exception to this was a single study that evaluated massage use in persons with neck pain reporting a 7 percent rate of use at baseline.^130^

None of the publications provided detail as to the specific type of massage received by persons with back pain. The providers of massage were physical therapists in one publication,^121^ massage therapist in another,^119^ and were not specified in the remaining publications.

Massage utilization based on anatomical region. A single non-U.S. study^130^ found that utilization specific to the neck and the use of massage was 7 percent. A single study^118^ evaluating unspecified back pain reported a rate of 55.5 percent (95 percent CI< 54.1–57.0) for massage use. Similarly, the three publications^51,^ ^119,^ ^121^ evaluating LBP reported high rates of use that varied from 15 to 56 percent. Three publications^116,^ ^117,^ ^131^ evaluated rates of massage use reported for neck and back pain combined; in one study^131^ 7 percent of respondents saw massage therapist. In the other two publications 39 to 42 percent received massage.^116,^ ^117^

Massage use as complementary care or combined with other CAM therapies. Of the five publications providing some information regarding conventional care with CAM, three^116^–^118^ had not stratified the proportions specific to persons reporting back pain and one did not stratify by practitioner type.^119^ A single study^131^ indicated that 4 percent of combined neck and back patients saw a medical doctor and a massage therapist; similarly, 3 percent saw a medical doctor, a chiropractor, a physiotherapist and a massage therapist.^131^

The majority of publications did not provide detail regarding concurrent or additional use of other CAM therapies with massage, specific to persons with back pain and stratified by therapy. In one study^51^ 37 percent of patients receiving massage, also received acupuncture concurrently. Similarly, one study^131^ reported concurrent use of massage and chiropractic in 5 percent of the sample. Another study^130^ of persons with neck pain indicated that up to 12 percent of patients used other CAM therapies, including Reiki, energy healing, and acupuncture.

Quality assessment for non-U.S. massage publications. Five publications^116^–^119,^ ^131^ were cross-sectional in design recruiting randomly selected national or provincial samples; although derived from large samples, the response rates were relatively low varying from 19 to 69 percent. The survey methodology employed within these studies was of high quality, using pre-tested questionnaires. Three studies employed single group prospective design with subjects recruited from general medical practices^51,^ ^130^ or from an administrative database for physical therapy;^121^ one of these^130^ recruited a small sample relative to the other studies. The overall quality of these studies would be rated as fair.

Summary of use for back pain for non-U.S. massage publications. Of the eight publications undertaken outside of the U.S., four were from Canada,^116^–^118,^ ^131^ two from the Netherlands,^121,^ ^130^ one from Germany,^51^ and one from Australia.^119^ Five publications^116^–^119,^ ^131^ were cross-sectional in design recruiting randomly selected national or provincial samples. Within these studies utilization rates varied from 7 percent^131^ for seeing a massage therapist within the past 4 weeks to 42 percent for lifetime use.^116^ Generally, studies of single group prospective design showed higher rates from 56 percent from an administrative database^121^ to 30 percent.^51^ The exception to this was a single study that evaluated massage use in persons with neck pain which reported a 7 percent rate of use at baseline.^130^

All but one publication^130^ queried the use of massage within 12 months or less (as recent as 4 weeks). None of the publications provided detail as to the specific type of massage received by persons with back pain, or the type of provider.

The sole study evaluating neck pain^130^ reported a rate of 7 percent utilization. Rates of use for LBP or combined neck and back pain were generally higher, varying from 15 (6-month use) to 42 percent (lifetime use). Based on this single study for neck pain, it is difficult to establish whether or not the rate of massage use varies based on anatomical location.

While five publications provided some information regarding conventional care with CAM, four of these did not present results stratified by back pain or practitioner. A single study^131^ indicated that 4 percent of combined neck and back patients receiving massage also saw an M.D. concurrently; similarly, 3 percent saw an M.D., a chiropractor, and a physiotherapist in addition to a massage therapist.^131^ Only three studies reported on concurrent use of massage with other CAM therapies such as acupuncture^51^ (37 percent), chiropractic^131^ (5 percent), or mixed therapies^130^ (12 percent receiving either Reiki, energy healing, and acupuncture).

### Specific CAM Therapy Utilization: Chiropractic/Spinal Manipulation

We retrieved the full text of 52 articles that potentially provided information on utilization of chiropractic/spinal manipulative therapy for back pain. One publication^83^ is not summarized below, as this study included comparison data from three other publications already included. Of the 51 remaining publications, 31 were undertaken solely within the U.S., 15 in other eligible countries, and five included both U.S. and Canadian data. Although, one of the publications^25^ with U.S. and Canadian data did not stratify results by country, we classified this as U.S. as the majority of data was not Canadian.

Chiropractic/Spinal manipulation utilization within the U.S. Thirty-six publications on chiropractic and spinal manipulation, were undertaken in the U.S. The study design varied and included 15 single group prospective cohort study publications,^11,^ ^15,^ ^17,^ ^20,^ ^22^–^25,^ ^27,^ ^30,^ ^34,^ ^38,^ ^41,^ ^43,^ ^44^ 10 retrospective reviews of patient records or claims data,^16,^ ^21,^ ^28,^ ^32,^ ^33,^ ^36,^ ^37,^ ^39,^ ^40,^ ^42^ and 10 cross-sectional publications.^9,^ ^12^–^14,^ ^18,^ ^19,^ ^26,^ ^29,^ ^31,^ ^35^ One study was a randomized controlled trial.^10^

The majority (n = 24) focused on LBP.^9,^ ^11,^ ^16^–^24,^ ^27,^ ^28,^ ^30^–^33,^ ^35,^ ^37^–^42^ Three publications presented information on neck pain,^25,^ ^40,^ ^44^ one the thoracic spine,^40^ six on combined spinal sites^12^–^14,^ ^26,^ ^36,^ ^39^ and seven unspecified back region.^10,^ ^15,^ ^25,^ ^29,^ ^34,^ ^38,^ ^44^ Sixteen of 24 publications on LBP and the one study of neck pain provided details on the duration of patients' complaints. Twelve of the publications reported on chronic complaints,^9,^ ^11,^ ^18,^ ^21,^ ^22,^ ^24,^ ^27,^ ^28,^ ^31,^ ^37,^ ^41,^ ^42^ three on acute pain,^19,^ ^20,^ ^30^ and two on a range of duration.^20,^ ^33^

Chiropractors were the providers of spinal manipulative therapy in 34 of the publications,^9^–^29,^ ^31^–^34,^ ^36^–^44^ and physiotherapists in the remaining two.^30,^ ^35^

Details on the type of spinal manipulation was provided in three publications;^15,^ ^24,^ ^33^ one clarified that 75 percent of manual therapy provided was “manual, high-velocity, low-amplitude manipulation”,^24^ and one defined the manual therapy provided as “specific, short-lever dynamic thrusts (or spinal adjustments) or non-specific, long-lever manipulation”.^33^ The study by Sherman et al.,^15^ noted that the predominant manipulation provided was of the diversified type.

Eligible U.S. trials on LBP populations found that rates of attending for chiropractic/spinal manipulative therapy ranged from 10 to 47 percent.^9,^ ^11,^ ^18,^ ^19,^ ^28,^ ^30,^ ^32,^ ^35,^ ^41^ Between 79 and 94 percent of treatments provided by chiropractors included spinal manipulative therapy.^9,^ ^11,^ ^22,^ ^23,^ ^28,^ ^33,^ ^37^ In two studies in which physiotherapists were the treatment providers, 21 to 34 percent of patients with LBP were treated with spinal manipulative therapy either in isolation or with other modalities.^30,^ ^35^ The number of visits for chiropractic care or other providers of spinal manipulative therapy ranged from a mean of 4.3 to 15.7^9,^ ^19,^ ^22^–^24,^ ^28,^ ^33^ with the exception of one study of disability claimants who attended for an average of 41 visits,^37^ and a median of 4 to 7^16,^ ^28^ (Tables 12A to 16B). In one study in which the mean and median number of visits was provided, the mean was approximately double the median.^28^ In one study in which two similar cohorts of adults with LBP were surveyed 10 years apart, the rates of chiropractic utilization declined by 10 percent between 1987 (40 percent) and 1997 (31 percent).^19^

Table 12A Utilization of chiropractic/manipulation in persons with neck pain

Author Year Country | Study Design | Reporting Mode | Timing of CAM Visit | Sample Size | Population | Clinical Presentation | Episode of Care | Outcomes
Studies from the United States
Cherkin^44^ 2002 U.S. Companion to Sherman^15^ 2006 U.S. | SGPS | SAQ | Visits to practitioner in a 12-month period | 130 chiropractors/488 eligible practitioners | Practitioners from several professions | Any condition | Visit to practitioner | Massachusetts: 304/1,349 (22.5%) Arizona: 294/1,201 (24.5%)
Hawk^25^ 2000 U.S. | SGPS | SAQ | 17 week followup period | 8,312 patients all ages ≥55: 805 (9.7%) | Undergoing chiropractic care | Acute, subacute, and chronic | Visit to a D.C. | All patients Neck Pain: 1,388/8,312 (16.7%) ≥55: 68/805 (8.5%)
Metz^40^ 2004 U.S. | Retro Rev | AD | claims data from 1997 to 2001 | patients with coverage 81,833 without coverage 121,049 | Members of a health plan for regional managed care network | With and without coverage for chiropractic Neck pain with discopathy or radiculopathy | All services using ICD-9 codes with a maximum gap of 45 days between claims were called 1 episode of care | Rates of episodes of care (per 1,000 member years) Neck pain: with coverage 44.8% without coverage 30.7%
Studies from outside the United States
Cote^135^ Canada 2005 | Retro Rev | AD SAQ | Claims data and practitioner use 1995 | 2,486 | Patients claiming for disability benefits following an MVA | 100% acute whiplash (<30 days since accident) | Visit to D.C. | 227/2,486 (9.1%) D.C. care alone; 4.6% attended for 1–6 visits 4.5% attended for >6 visits
Hartvigsen^134^ 2002 Denmark | CS | SAQ | Ever have treatment | 176 Chiropractic clinics 1,897 patients within these practices | Chiropractic clinics | Neck or LBP | Any visit to a D.C. | Percent of patients seeing D.C. Neck: 9.2% Thorax: 7:0 % Low back: 40.7%
Hawk^25^ 2000 Canada | SGPS | SAQ | 17 week followup period | 8,312 patients all ages ≥55: 805 (9.7%) | Undergoing chiropractic care | Any condition | Visit to a D.C. | All patients: 1,388/8,312 (16.7%) ≥55: 68/805 (8.5%)
Kilaver^124^ 1997 Norway | CS | SAQ | Any visit to a D.C. | Patients within D.C. practices: 2,154 Patients 631 (29.3%) referred by M.D. 1,523 (70.7%) non-referred | Adult chiropractic patients | Various conditions | Ever seen a D.C. | Based on D.C. diagnosis cervicalgia and cervicobrachialgia 111/1,523 (7.3%) Non-referred patients 52/631 (8.3%) referred patients

Abbreviations: AD = administrative database; CAM = Complementary and Alternative Medicine; D.C. = Doctor of Chiropractic; ICD = International Classification of Diseases; LBP = Low back pain; M.D. = Medical Doctor; MT = massage therapist; MVA = Motor Vehicle Accident; SAQ = Self-administered questionnaire; SGPS=Single group prospective study

Table 12B Utilization of chiropractic/manipulation in persons with neck pain

Author Year Country | Use with Conventional Care | Concurrent use with Other CAM
Studies from the United States
Cherkin^44^ 2002 U.S. Companion to Sherman^15^ 2006 U.S. | NSBP | NSCAM
Hawk^25^ 2000 U.S. | NSBP | NSCAM
Metz^40^ 2004 U.S. | NSBP | NSCAM
Studies conducted outside the United States
Cote^135^ 2005 Canada | 11.8% pursued D.C. and GP care concurrently | NSCAM
Hartvigsen^134^ 2002 Denmark | NSBP | NSCAM
Kilaver^124^ 1997 Norway | Not applicable | NSCAM

Abbreviations: CAM = Complementary and Alternative Therapy; D.C. = Doctor of Chiropractic; GP = General Practitioner; NSBP = Data not stratified by back pain; NSCAM = Not stratified by CAM therapy

Table 13A Utilization of chiropractic/manipulation in persons with unspecified back pain

Author Year Country | Study Design | Reporting Mode | Timing of CAM Visit | Sample Size | Population | Clinical Presentation | Episode of Care | Outcomes
Studies from the United States
Bruce^10^ 2005 U.S. | RCT | SAQ | Past 12 months | Intervention: 190/296 (64.1%) Control: 231/ 284 (81.3%) | Recurrent back pain, not receiving any disability insurance | Recurrent back pain Mean duration of back pain 13.4 yrs (SD=10) | Baseline: “Ever tried D.C.” Could include ≥1 CAM therapy 1 year: “D.C. in past 6 months” | Baseline Intervention: 120/190 (63%) Control: 150/231 (65%) Outcomes Intervention: 8/190 (3.8%) Control: 10/231 (4.2%)
Cherkin^44^ 2002 U.S. | SGPS | SAQ | Visits to practitioner in a 12 month period | 130 chiropractors 488 eligible practitioners | Practitioners from several professions, were asked to collect patient information | Any condition | Visit to practitioner | % primary reason of chiropractic visit Massachusetts: 596/1,349 (44.2%) Arizona: 492/1,201 (41.0%)
Hawk^25^ 2000 U.S. | SGPS | SAQ | 17 week followup period | 8,312 patients all ages 805 aged 55+ | Undergoing chiropractic care | Any condition | Visit to a D.C. | All patients Back Pain: 3,142/8,312 (37.8%): ≥55: 265/805 (32.9%)
Hurwitz^29^ 1997 U.S. | CS | TI | Past 12 months | 4,790 | Survey data from randomly sampled adults with reported back pain | Majority of conditions were chronic traumatic (36.5%) or non-traumatic (27.5%) | Visit to practitioner | 3.5% (168) attended a D.C. during the 2-week reference period 43.6% of these had more than 1 visit
Shekelle^34^ 1995 U.S. Shekelle^43^ 1995 U.S. | SGPS | AD | Tracked use over a 3 to 5 year period | Data on 1,020 episodes of back pain care made by 686 different persons | From the RAND Health Insurance Experiment | 100% had back pain, defined as “pain, swelling, injury of back region” | “A visit or series of visits that belong together” | D.C.s were primary providers for 40% of all episodes of back pain D.C.s were the first provider for 38% of all episodes of back pain D.C.s provided a mean number of 10.4 visits per episode D.C.'s had a retention rate of 92% for 2^nd^ visits
Shekelle^38^ U.S. 1991 | SGPS | AD | Tracked use over a 3 to 5 year period | 5,279 | Enrolled in Health Insurance Experiment; from these 395 (7.5 %) made at least one visit to a D.C. | Pain, swelling, injury for the back region | Visit to practitioner | Per 100 person-years from 19,021 person years: 17.4 (42.1%) specified that problems with the back region was the main reason for the D.C. visit Back problems plus adjustment accounted for 50% of visits overall (varying from 41 to 69% depending on the site)
Sherman^15^ U.S. 2006 | SGPS | SAQ | Visits to practitioner in a 12-month period | 130 randomly selected D.C.s provided data on 523 consecutive patient visits | Patients with chronic BP in two states | 100% had chronic BP | visit to D.C. | Per 100 person-years from 19,021 person years: 17.4 (42.1%) specified that problems with the back region was the main reason for the D.C. visit Back problems plus adjustment accounted for 50% of visits overall (varying from 41 to 69 % depending on the site)
Studies from outside the United States
Foltz^118^ 2005 Canada | CS | TI | Past 12 months | Complete sample 66,253 Non-specific chronic BP 11,736 (17.7%) CAM users 3,259 (39%) | Subset from a large national general sample collected from 1996 to 1998 groups identified as “chronic BP or musculo-skeletal disease” | Chronic BP was diagnosed by a health professional | ‘CAM users’:; 1) received or discussed CAM with a non-mainstream practitioner; 2) used a support group for health problem; 3) received care from D.C. | Of the chronic BP respondents, 39% had used CAM during the past 12 months 74.4% had attended a D.C. in the past 12 months
Giles^126^ 2003 Australia | SGPS | HRR SAQ | Visits between 1995 and 2001 | 1,775 | Patients attending a hospital based, multidisciplinary spinal pain unit | 100% with spinal pain; 941 patients could recall when their symptoms began 92.7% reported CBP (>3 months duration) | Visit to D.C. | 208/1,175 (11.7%) were managed with chiropractic manipulation
Ong^136^ 2005 U.K. | CS | SAQ | 3 months | 1,377 | Randomly selected adults in 4 counties of England | 100% had back pain, including sciatica, lumbago and disc problems | Visit to practitioner | In the past 3 months 11.4% of respondents had sought osteopathy or D.C. care, and 2% had sought osteopathy or D.C. care and PT care

Abbreviations: AD = administrative database; BP = back pain; CAM = complementary and alternative medicine; CLBP = Chronic low back pain; CS = Cross-sectional; D.C. = Doctor of Chiropractic; FI = Face to face interview; HRR = Health record review; LBP = Low back pain; M.D. = Medical Doctor; MT = massage therapist; NP = Naturopathic Physician; RCT = randomized controlled trial; SD = standard deviation; SAQ = Self-administered questionnaire; SGPS = Single group prospective study; TI = Telephone interview

Table 13B Utilization of chiropractic/manipulation in persons with unspecified back pain

Author Year Country | Use with Conventional Care | Concurrent use with Other CAM
Studies from the United States
Bruce^10^ 2005 U.S. | Not collected | Not reported but data presented indicated respondents had used 1 or more CAM therapy
Cherkin^44^ 2002 U.S. | NSBP | NSCAM
Hawk^25^ 2000 U.S. | NSBP | NSCAM
Hurwitz^29^ 1997 U.S. | Not reported | Not reported
Shekelle^34^ 1995 U.S. Shekelle^43^ 1995 U.S. | Not reported | Not reported
Shekelle^38^ 1991 U.S. | Not reported | Not reported
Sherman^15^ U.S. 2006 | Not reported | Physiotherapeutics (hot, cold, electrical stimulation, ultrasound) Arizona 5% Massachusetts 4%
Studies conducted outside the United States
Foltz^118^ 2005 Canada | CAM users reporting visit to: Any physician: 6.2% (95% CI 6.0–6.4) GP: 5.1% (95% CI 5.0–5.3) Specialists: 1.1% (95% CI 1.0–1.2) PT: 2.4% (95% CI 2.2–2.4) Psychologists: 0.3% (95% CI 0.3–0.3) | Concurrent use evident but data not stratified by type of CAM therapy
Giles^126^ 2003 Australia | Not reported | Not specified
Ong^136^ 2005 U.K. | Not reported | 11.4% of respondents had sought osteopathy or D.C. care, and 2% had sought osteopathy or D.C. care and PT care

Abbreviations: CAM = Complementary and Alternative Therapy; D.C. = Doctor of Chiropractic; GP = General Practitioner; NSBP = Data not stratified by back pain; NSCAM = Not stratified by CAM therapy; PT = Physical Therapist

Table 14A Utilization of chiropractic/manipulation in persons with low back pain

Author Year Country | Study Design | Reporting Mode | Timing of CAM Visit | Sample Size | Population | Clinical Presentation | Episode of Care | Outcomes
Studies from the United States
Carey^9^ 1995 U.S. | CS | TI | Past 12 months | 269/4,437 (3.9%) CLBP 186/289 analyzed for care seeking | General population | 100% with CLBP (functionally limited for >3 months or >25 episodes of back pain) | Visit with health provider, lifetime prevalence | 24.6% attended a D.C. mean visits 15.7 22% received SMT
Carey^31^ 1996 U.S. | CS | TI | Past 12 months | 485 acute LBP 180 saw D.C. or M.D. | Adults | At least one occurrence of acute severe LBP in 1991 | Visit to practitioner | 13.6% (66) attended a D.C. during their most recent episode of pain
Carey ^27^ 1999 U.S. | SGPS | TI | Followed for 22 months after initial episode of LBP | 6 months: n = 921 22 months: n = 754 (81.9%) | Patients presenting with acute LBP | Recurrent episodes from 6 to 22 months | Visit to practitioner | Chiropractic care: 6 months: 354/921 (38.4%) 22 months: 294/754 (38.9%)
Cote^17^ 2005 U.S. and Canada | SGPS | SAQ | 6 months | 1,017/1,104 (92%) received health care | Workers with incident episodes of LBP | All subjects made a workers' compensation claim for LBP, with or without leg pain or sciatica | Visit to practitioner | During the first 4 to 16 weeks after an episode of occupational LBP 4.1% attended a D.C. only
Feuerstein^19^ 2004 U.S. | CS | TI and diaries | Not reported | Treated for back pain 1987: 1,053 1997: 1,082 | Adults | All responders had non-specific LBP; 1987: 51.23% acute 1997: 53.22% acute | Visit to practitioner | 1987: 40.48% of respondents sought D.C. care for mean 9.2 visits 1997: 30.63% of respondents sought D.C. care for mean 7.8 visits
Gilkey^41^ 2002 U.S. | SGPS | SAQ | Recall 2 weeks, 1 year and lifetime | 335 | Hispanic (His):241 non-Hispanic (nHis):94 reported continuous LBP His = 15% nHis = 32% | Reported continuous LBP His = 15% nHis = 32% | Visit to practitioner | 9.9% attended a D.C. 3% His went to D.C. 28% nHis went to D.C.
Hurwitz^28^ 1998 U.S. and Canada Companion to Coulter^21^ 2002 U.S. and Coulter^42^ 2005 U.S. | Retro Rev | HRR | Records from 1985 to 1991 | 1,397 charts | 1,397 charts from U.S. D.C.'s offices | 65.9% sought care for LBP (21.2% >6 months duration) 42.8% sought care for face and neck pain 20.0% sought care for mid-back pain | A period of time with no more than 30 days between visits | 920 patients with LBP: 84.0% received SMT Median duration of chiropractic treatment for LBP U.S. sites 29 days; mean 61.7 days Median visits 7; mean 15.6 visits
Jette^35^ 1994 U.S. | CS | TI and SAQ | Out patient visits over 1 year | 2,328 | Patients discharged from outpatient PT services (private practice and hospital) | Primary reason for seeking care was either sprain/pain of the lumbar back or degenerative disk disease | Visit to practitioner | 33.5% received manual therapy either in isolation or combined with other treatment
Lind^16^ 2005 U.S. | Retro Rev | AD | Out patient visits over 1 year | 104,358/601,044 (17.4%) had back pain and were eligible for study | Individuals enrolled in health insurance plans and allowed outpatient visits | Back pain | Visit to practitioner | 46% LBP attended a D.C. 33% attended only a D.C. Median of D.C. visits: 4
Long^11^ 1996 U.S. | SGPS | SAQ | Past 12 months | 2,374/4,171 (56.9%) had complete data and followup | Adult patients presenting for orthopedic surgery or neurosurgery consultation | 100% of patients presented with persistent LBP (mean duration of current episode was 2.52 years) | Treatments or visits to CAM practitioner | Prior to their surgical consultation 46.7% patients had consulted a chiropractor, and 41.3% patients had undergone chiropractic manipulation
Metz^40^ 2004 U.S. | Retro Rev | AD | Claims data from 1997 to 2001 | With coverage 124,727 without coverage 220,949 | Members of a health plan for large regional managed care network | With and without coverage for chiropractic-LBP with discopathy or radiculopathy | Rates of episodes of care (per 1,000 member years) | LBP: 64.4% with coverage 57.8% without coverage
Mielenz^30^ 1997 U.S. | SGPS | TI | Past 12 months | 1,540 had acute LBP | Patients recruited from healthcare providers | 100% with acute LBP (<10 week duration) | Visit with a healthcare provider, lifetime prevalence | 21% received SMT or an adjustment
Nyiendo^37^ 1991 U.S. | SEPS | AD | Disabling back claims filed June to Dec 1985 | 94 | A random sample of adults who filed an insurance claim and attended a D.C. in Oregon | 100% with LBP; 49% soft tissue injuries; none had persistent nerve root compromise | Patient visit to the treating physician or hospital or any auxiliary personnel | Over the duration of their claim patients attended a D.C.: 41 visits (SD = 47) average treatment period 53 weeks (SD = 49) 93.6% received manipulation as part of their treatment
Nyiendo^24^ 2000 U.S. | SGPS | SAQ TI | Past 12 months | 38 | Patients recruited from clinics M.D.: 45 D.C.: 93 | 100% with chronic LBP (>6 weeks duration) | Patient visit to the treating physician or hospital or any auxiliary personnel | Over the duration of their claim, patients attended a D.C.: 41 visits (SD = 47) Mean treatment period was 53 weeks (SD = 49) 93.6% received manipulation as part of their treatment
Nyiendo^22^ 2001 U.S. | SGPS | SAQ HRR | Past 12 months | 268 | M.D. clinics: n = 121 D.C. clinics: n = 147 | 100% with chronic LBP and sciatica (>6 weeks duration) | Visit to practitioner | Of those who received adjustments, 61% received full spine adjustment and 39% received an adjustment only to the lumbopelvic region Mean no. of visits to D.C. was 4.3 (SD=3.0)
Nyiendo^23^ 2001 U.S. | SGPS | SAQ HRR | Past 12 months | 835 | M.D. clinics: n = 309 D.C. clinics: n = 526 | 100% with chronic LBP (>6 weeks duration) | Visit to practitioner | Mean # visits to D.C.: 8.72 (SD=9.27) 91.8% attending a D.C. received spinal manipulation
Shekelle^33^ 1995 U.S. | Retro Rev | HRR | Past 12 months | 80 patients records were selected (10 from each of 8 chiropractic practices) | Patient record from random sample of chiropractic practices | 100% with LBP (56% <3 weeks duration; 25% >13 weeks duration) | First visit between specified interval | 79% SMT 77% non-thrust 25% massage 12% U/S 8% electro-acupuncture
Sherman^18^ 2004 U.S. | CS | TI | Past 12 months | 249 | Individuals registered with health care organizations | 100% with chronic LBP (>3 months duration) | Reported ‘ever tried’ | 45% surveyed had previously tried chiropractic for LBP
Stano^32^ 1996 U.S. | Retro Rev | AD | Claims data from 1988 to 1990 | 6,183 | Patients with insurance claims | Each patient had a claim with a low back ICD-9-CM code | ICD9 code | 45% surveyed had previously tried chiropractic for LBP
Stano^20^ 2002 U.S. Companion to Nyiendo^22,23^ 2001 U.S. | SGPS | HRR SAQ | Past 12 months | 2,872 total 922 medical patients 1,950 chiropractic patients | Patients with ALBP and CLBP | Acute and chronic ambulatory LBP of mechanical origin | Frequency of therapy procedure codes used | 8,712 regional manipulations 577 supplementary manipulations 406 manipulations of the spine
Wasiak^39^ 2006 U.S. | Retro Rev | AD | Claims data from 1999 to 2002 | 13,734 | Workman's Compensation claimants | 100% with a compensable low back injury (of which 81% claimed low back strain) | At least one visit to a D.C. in a 4-year period | 64.8% had all compensable D.C. services in 1 year Median annual visits to a D.C. 5 to 15
Studies from outside the United States
Armstrong^132^ 2003 U.K. | Retro Rev | HRR | Patient records from 1995-1996 | 200 | Patients in the U.K. | 100% with LBP lasting more than 24 hours, with or without referral of symptoms into the lower extremities | Visit to a physiotherapist | 3% of patients received manipulation
Burton^122^ 2004 U.K. | SGPS | FI SAQ | 12 months | 151 | Patients attended for manipulative care at a single U.K. clinic | 100% presented with LBP | Visit to osteopath | 76 respondents sought further care, of these 56.5% consulted an osteopath again
Caswell^128^ 2002 U.K. | CS | SAQ | NR | 50 | U.K. patients not using CAM | 100% with chronic LBP (at least 6 months duration) | Visit to CAM practitioner | 40% using CT attended an osteopath 40% using CT attended a chiropractor
Hartvigsen^134^ 2002 Denmark | CS | SAQ | Ever have treatment | 176 chiropractic clinics and 1,897 patients | D.C. clinics | Neck or back pain | Any visit to a chiropractor | Patients seeing D.C. Neck: 9.2% Thorax: 7:0 % Low back: 40.7%
Hurwitz^28^ 1998 Canada and U.S. Companion to Coulter^21^ 2002 U.S. Coulter^42^ 2005 U.S. | Retro Rev | HRR | Episodes of care from 1985 to 1991 | 519 | Charts from Canadian D.C.'s offices | 75.1% LBP (20.3% >6 months duration) 29.7% face and neck pain 13.1% mid-back pain | Period of time with no more than 30 days between visits | Of 390 patients with LBP: 80.8% received SMT Median duration of chiropractic treatment: Canadian sites 29 days mean 57.3 days Median visits: Canadian sites 6; mean 10.5 visits
Jacobs^133^ 2004 Canada | CS | FI | Past 12 months | 4,158 | Adults | 100% with CLBP (duration of ≥6 months) | Any visit to practitioner in past 12 months | 32.1% of respondents attended a D.C.
Kilaver^124^ 1997 Norway | CS | SAQ | Any visit to a D.C. | Within D.C. practices: 2,154 patients; 631 (29.3%) referred by M.D.; 1,523 (70.7%) non-referred | Adult chiropractic patients | LBP | Ever seen a D.C. | LBP: 59.4% referred 61.5% non-referred 58% from 0 to 3 months duration Sciatica: 11.3% referred sciatica 12.7% non-referred sciatica 44% from 0 to 3 months duration
Scheurmier^129^ 1998 U.K. | SGPS and Retro Rev | HRR | Past 4 months | 484 | Patients from GP practices | 100% with acute LBP (duration <6 weeks) | Visit to practitioner | Referred to D.C.: 2% before project 28% during project Mean project visits 5.7 Referred to OT: 0% before project 25% during project Mean project visits 4.2 Referred to PT: 72% before project 21% during project Mean project visits 5.0
Walker^119^ 2004 Australia | CS | SAQ | Past 6 months | 1,913/2,748 (69.6%) 1,228/1,913 (64.1%) ≥1 episode back pain | Individuals from the electoral roll | 100% reported LBP in the last 6 months | Visit to CAM practitioner | 547/1,228 (44.5%) sought care for LBP Of those who sought care, 78/547 (6.4%) exclusively from a D.C.

Abbreviations: AD = administrative database; ACBP = acute low back pain; CAM = Complementary and Alternative Medicine; CLBP = Chronic low back pain; CS = Cross-sectional; CT = complementary therapy D.C. = Doctor of Chiropractic; FI = Face to face interview; HRR = Health record review; LBP = Low back pain; M.D. = Medical Doctor; MT = massage therapist; NP = Naturopathic Physician; OP = occupational therapy; PT = physical therapist; SAQ = Self-administered questionnaire; SGPS = Single group prospective study; SMT = spinal manipulative therapy; TI = Telephone interview; U/S = ultrasound

Table 14B Utilization of chiropractic/manipulation in persons with low back pain

Author Year Country | Use with Conventional Care | Concurrent use with Other CAM
Studies from the United States
Carey^9^ 1995 U.S. | NSCAM | NSCAM
Carey^31^ 1996 U.S. | NSCAM | NSCAM
Carey ^27^ 1999 U.S. | Patients with initial consult with D.C. more than twice the Number of patients seeking M.D. care D.C. vs M.D. OR = 2.5 (95% CI, 1.5–4.3) | NSCAM
Cote^17^ 2005a U.S. and Canada | 9.7% attended a M.D., D.C., & PT 5.3% attended a M.D. & D.C. 1.2% attended a D.C. & PT | Not reported
Feuerstein^19^ 2004 U.S. | Not stratified by treatment | NSCAM
Gilkey^41^ 2002 U.S. | Not stratified by therapy | No other CAM use reported
Hurwitz^28^ 1998 U.S. and Canada Companion to Coulter^21^ 2002 U.S. and Coulter^42^ 2005 U.S. | Not applicable only D.C. in study | NSCAM
Jette^35^ 1994 U.S. | 8.0% received manual therapy and exercises | 11.9% received manual therapy, exercises and modalities
Lind^16^ 2005 U.S. | Not stratified by therapy 12% of CAM users also saw conventional provider | NSCAM
Long^11^ 1996 U.S. | Not stratified by therapy | NSCAM
Metz^40^ 2004 U.S. | NSBP | NSCAM
Mielenz^30^ 1997 U.S. | Not applicable | NSCAM
Nyiendo^37^ 1991 U.S. | Did not look at concurrent use of chiropractic and medical care | NSCAM
Nyiendo^24^ 2000 U.S. | Did not look at concurrent use of chiropractic and medical care | NSCAM
Nyiendo^22^ 2001 U.S. | Not applicable | NSCAM
Nyiendo^23^ 2001 U.S. | Not applicable | NSCAM
Shekelle^33^ 1995 U.S. | Not applicable | NSCAM
Sherman^18^ 2004 U.S. | Hypothetical question posed in this report | NSCAM
Stano^32^ 1996 U.S. | Examination of medical claims vs chiropractic claims | NSCAM
Stano^20^ 2002 U.S. | Not applicable | PT modalities were frequently used with massage and trigger point therapy used most often
Wasiak^39^ 2006 U.S. | Not applicable | NSCAM
Studies conducted outside the United States
Armstrong^132^ 2003 U.K. | Not applicable | NSCAM
Burton^122^ 2004 U.K. | Not stratified by practitioner | NSCAM
Caswell^128^ 2002 U.K. | 62% CAM users sought conventional care to manage their pain 36% using conventional treatment plus D.C., OT or AT | NSCAM
Hartvigsen^134^ 2002 Denmark | NSBP | NSCAM
Hurwitz^28^ 1998 Canada and U.S. Companion to Coulter^21^ 2002 U.S. and Coulter^42^ 2005 U.S. | Not applicable only D.C. in study | NSCAM
Jacobs^133^ 2004 Canada | NSBP | NSCAM
Kilaver^124^ 1997 Norway | Not applicable | NSCAM
Scheurmier^129^ 1998 U.K. | NSBP | NSCAM
Walker^119^ 2004 Australia | 59% attended multiple providers 3.3% from a GP and D.C. 1.5% from a GP, D.C., MT | NSCAM

Abbreviations: AT = Acupuncture Therapy; CAM = Complementary and Alternative Therapy; D.C. = Doctor of Chiropractic; M.D. = Medical Doctor; MT = Massage therapist; NSBP = Data not stratified by back pain; NSCAM = Not stratified by CAM therapy; OR = Odds Ratio; OT = Occupational Therapy; PT = Physical Therapist

Table 15A Utilization of chiropractic/manipulation in persons with combined neck and back pain

Author Year Country | Study Design | Reporting Mode | Timing of CAM Visit | Sample Size | Population | Clinical Presentation | Episode of Care | Outcomes
Studies from the United States
Fleming^13^ 2007 U.S. | CS | FI | Past 12 months | 908 | Patients receiving opioids for chronic pain | 38.4% had chronic LBP (>3 months) 6.8% presented with chronic neck/upper back pain (>3 months) | Visit to practitioner | Of those who attended a D.C. for any complaint the average number of annual visits was 14.1
Hawk^26^ 1999 U.S. | CS | TI | Past 12 months | 1,511 | Respondents to a 1994 population-based survey | Neck and back pain that required that respondent missed work | Visit to practitioner | 44/103 (42.7%) attended a D.C.
Hurwitz^14^ 2006 U.S. and Canada | CS | TI | Past 12 months | 595/5,183 (11.4%) | Respondents to a population health survey (Joint Canada/U.S. Survey of Health 2002-2003) | Neck or back problems responsible for difficulties with performing activities of daily living | Number of visits or contacts with various types of health professionals in the past 12 months | Results for U.S. only: 16.3% of respondents who saw a D.C. were for back or neck problems 9.1% of total sample
Jarvis^36^ 1991 U.S. | Retro Rev | HRR | 12-month period | 3,062 from 7,551 files (40.6%) | Back injury claims | Various conditions | Visit to D.C. practitioner | D.C.s provided patients with an average of 12.9 treatments over an average of 54.5 days Top 3 diagnoses were: sprain/strain lumbosacral spine (21.4%), sprain/strain cervical (15%) sprain/strain lumber (15%)
Wolsko^12^ 2003 U.S. | CS | TI | Past 12 months | 644/2,055 (60%) | Individuals who have had neck or back pain in the past 12 months | 46% had pain in more than 1 location 38% had LBP only 16% had neck or upper back pain only | Use of CAM therapy or visit to CAM practitioner | 19.8% attended a D.C. in the Mean number of visits 8.5
Studies from outside the United States
Cote^131^ Canada 2001 | CS | SAQ | Past 4 weeks | 2,184 in the sample 1,131(55%) participated 907/1,131 (80%) had back or neck pain | Health insurance and registration file | 100% had back and/or neck pain in the past 6 months | Visit to healthcare provider | 215/907 (24.7%) visited a healthcare provider in the past 4 weeks 28.8% saw a D.C. alone
Esmail^117^ 2007 Canada Companion to Ramsay^116^ 1999 Canada | CS | TI | Past 12 months | Second wave (Esmail): 2,000 respondents response rate 18.8%. 30% reported having back or neck problems | General adult population in Canada | 30% reported back or neck problems in the past 12 months | Use of a CAM therapy or visit with a practitioner who is not a medical doctor | 41% of respondents with back or neck pain had attended a CAM provider in the past 12 months, most commonly a D.C. 68% of all visits to D.C.s were for back and/or neck pain
Hurwitz^14^ 2006 Canada and U.S. | CS | TI | Past 12 months | 448/3505 (12.8%) | Population health survey (Joint Canada/U.S. Survey of Health 2002-2003) who received any chiropractic care | Neck or back problems responsible for difficulties with performing ADL | Number of visits or contacts with various types of health professionals in the past 12 months | Results for Canada only: 20.1% of respondents who saw a D.C. were for back or neck problems 10.4% of total sample
Ramsay^116^ 1999 Canada | CS | TI | Past 12 months | 1,500 | Survey of randomly selected Canadian adults | 30% reported back or neck problems in the past 12 months | Use of CAM therapy or visit with a practitioner who is not an M.D. | 11% with back or neck problems in the past 12 months attended an alternative provider, most commonly a chiropractor

Abbreviations: AD = administrative database; ADL = Activities of Daily Living; CLBP = Chronic low back pain; CS = Cross-sectional; D.C. = Doctor of Chiropractic; HRR = Health Records Review; SAQ = Self-administered questionnaire; SGPS = Single group prospective study; TI = Telephone interview

Table 15B Utilization of chiropractic/manipulation in persons with combined neck and back pain

Author Year Country | Use with Conventional Care | Concurrent use with Other CAM
Studies from the United States
Fleming^13^ 2007 U.S. | NSBP | NSCAM
Hawk^26^ 1999 U.S. | NSBP | NSCAM
Hurwitz^14^ 2006 U.S. and Canada | 85.3% received both D.C. and GP care | Not specified
Jarvis^36^ 1991 U.S. | Not reported | Not reported
Wolsko^12^ 2003 U.S. | NSCAM 25% had used both complementary medicine and a conventional provider | Used any CAM: from those with back and neck pain, 29% had used CAM alone, concurrent use not specified
Studies conducted outside the United States
Cote^131^ Canada 2001 | 7.9% saw a GP and a D.C. 2.8% saw a GP, D.C., and PT 2.8% saw a GP, D.C., MT, and PT | 5.1% saw a D.C. and a MT
Esmail^117^ 2007 Canada Companion to Ramsay^116^ 1999 Canada | 25% had used both complementary medicine and a conventional provider | NSCAM
Hurwitz^14^ 2006 Canada and U.S. | 87.7% received both D.C. and GP care | Not specified
Ramsay^116^ 1999 Canada | 25% had used both complementary medicine and a conventional provider | NSCAM

Abbreviations: CAM = Complementary and Alternative Therapy; D.C. = Doctor of Chiropractic; GP = General Practitioner; MT = massage therapist; NSBP = Data not stratified by back pain; NSCAM = Not stratified by CAM therapy; PT = Physical Therapist

Table 16A Utilization of chiropractic/manipulation in persons with thoracic back pain

Author Year Country | Study Design | Reporting Mode | Timing of CAM Visit | Sample Size | Population | Clinical Presentation | Episode of Care | Outcomes
Studies from the United States
Metz^40^ 2004 U.S. | Retro Rev | AD | Claims data from 1997 to 2001 | People with coverage 37,429 Without coverage 42,372 | Members of a health plan for large regional managed care network | With and without coverage for chiropractic care of thoracic spine pain | ICD-9 codes used to identify neuro-muscular pain episodes. All services using any of these codes, with a maximum gap of 45 days between claims were aggregated into 1 episode of care | Rates of episodes of care (per 1,000 member years) Thoracic pain: 19.8% with coverage 10.0% without coverage
Studies from outside the United States
Hartvigsen^134^ 2002 Denmark | CS | SAQ | Ever have treatment | 176 chiropractic clinics and 1,897 patients within these practices | Chiropractic clinics | Neck or back pain | Any visit to a D.C. | Percent of patients seeing D.C. Thorax: 7:0 %

Abbreviations: AD = administrative database; CLBP = Chronic low back pain; CS = Cross-sectional; D.C. = Doctor of Chiropractic; LBP = low back pain; SAQ = Self-administered questionnaire; SGPS = Single group prospective study; TI = Telephone interview

Table 16B Utilization of chiropractic/manipulation in persons with thoracic back pain

Author Year Country | Use with Conventional Care | Concurrent use with Other CAM
Studies from the United States
Metz^40^ 2004 U.S. | NSBP | NSCAM
Studies conducted outside the United States
Hartvigsen^134^ 2002 Denmark | NSBP | NSCAM

Abbreviations: NSBP = Data not stratified by back pain; NSCAM = Not stratified by CAM therapy

Chiropractic/spinal manipulation utilization based on anatomical region. A single study^40^ provided rates per 1,000 members episodes of care for all three spinal regions and showed a gradient with the thoracic spine being the region for which there was lowest use (10 to 20 percent), the neck, the second most common region (31 to 45 percent), and the low back, the most frequent region receiving chiropractic care (58 to 64 percent). A second study^44^ reported rates of use for two spinal regions and showed lower rates for the neck (23 to 25 percent) relative to unspecified back (41 to 44 percent). A third study^25^ showed a similar gradient for neck pain (17 percent for all subjects and 9 percent for those aged over 55 years) and unspecified back pain (38 percent for all subjects and 33 percent for those aged over 55 years).

Chiropractic/spinal manipulation use as complementary care or combined with other CAM therapies. Only two of the 36 eligible U.S. trials provided detailed information on patterns of care seeking; the majority of publications did not present complementary use stratified by persons with back pain. Use of chiropractic care as an alternative to conventional care ranged from 4 to 33 percent and use of chiropractic as complementary therapy ranged from 13 to 16 percent.^16,^ ^17^ One study^16^ explored the care seeking patterns of 104,358 Washington State residents who made a claim for LBP and found that 45 percent sought conventional care only (M.D. or PT), 33 percent sought chiropractic care only, 13 percent sought other CAM providers only (aside from chiropractors), and 12 percent pursued both conventional and CAM providers. Another study^34,^ ^43^ found that one-third of patients with unspecified back pain chose to attend a chiropractor, that chiropractors were the primary provider (defined as the provider who delivered the majority of care) for 40 percent of episodes of back pain, and that 92 percent of chiropractors' patients chose their services again for future episodes of back pain (Table 13A).

Although many authors described treatments provided to patients with back pain, only one study^35^ provided details on how spinal manipulative therapy is combined with other modalities (Table 14A). Of 2,328 American patients discharged from physiotherapy outpatient services 34 percent received spinal manipulative therapy either in isolation or with other therapy, 10 percent received spinal manipulative therapy with exercises and physiotherapy modalities, and 8 percent received spinal manipulative therapy and exercises.

Quality assessment for U.S. chiropractic/spinal manipulation publications. From 36 publications, 10 cross-sectional studies are based predominately on random samples,^9,^ ^12,^ ^14,^ ^26,^ ^31^ systematic samples,^13,^ ^18,^ ^29^ national probability samples,^19^ or not reported.^35^ Response rates varied from 36 to 95 percent; the methods of the surveys and interviews were generally of high quality.

There are 15 single-group prospective cohort study publications;^11,^ ^15,^ ^17,^ ^20,^ ^22^–^25,^ ^27,^ ^30,^ ^34,^ ^38,^ ^41,^ ^43,^ ^44^ two of these^15,^ ^44^ employed a random sampling of chiropractors. The majority of these papers recruited samples from chiropractic or other professional clinical practices, and as such represent selective groups of patients. From 10 retrospective publications, four were based on patient health records,^21,^ ^28,^ ^33,^ ^42^ two were from large administrative health databases,^16,^ ^40^ and four from workers' compensation databases;^32,^ ^36,^ ^37,^ ^39^ the latter using standardized coding for back injury diagnosis and utilization. Overall, the quality of these studies would be evaluated as fair, noting that biases are present but not sufficient to negate the validity of results.

Summary of utilization in U.S. chiropractic/spinal manipulation publications. Thirty-six publications^9^–^44^ on chiropractic and spinal manipulation, were undertaken in the U.S. The majority (n = 24) reported on LBP and the fewest on neck (n = 3) and thoracic spine (n = 1). Our review suggests that chiropractic care/spinal manipulation is commonly sought by patients with back pain. From 10 cross-sectional studies^9,^ ^12^–^14,^ ^18,^ ^19,^ ^26,^ ^29,^ ^31,^ ^35^ based predominately on random or systematic samples, rates of utilization varied from 16 percent^14^ to 45 percent.^18^ Eligible U.S. trials on LBP populations found that rates of attending for chiropractic/spinal manipulative therapy range from 10 to 47 percent.^9,^ ^11,^ ^18,^ ^19,^ ^28,^ ^30,^ ^32,^ ^35,^ ^41^ The number of visits for chiropractic care or other providers of spinal manipulative therapy ranged from a mean of 4.3 to 15.7^9,^ ^19,^ ^22^–^24,^ ^28,^ ^33^ Between 79 percent and 94 percent of treatment by chiropractors included spinal manipulative therapy.^9,^ ^11,^ ^22,^ ^23,^ ^28,^ ^33,^ ^37^ Two studies provided some evidence for a gradient of use based on anatomical regions; LBP was treated most often,^25,^ ^40,^ ^44^ followed by neck, and then thoracic pain.^40^

Chiropractors were the providers of spinal manipulative therapy in most publications (n = 34), and physiotherapists in two publications.^30,^ ^35^ Details on the type of spinal manipulation provided was provided in three only publications.^15,^ ^24,^ ^33^

The available information suggests that roughly equal proportions of LBP patients use chiropractic as complementary to conventional care and as an alternate. Current literature provides little insight into the manner in which chiropractic/spinal manipulation is combined with other therapies for back pain. Despite the common use of chiropractic/spinal manipulation by patients with back pain the current literature provides limited data on utilization.

Chiropractic/spinal manipulation utilization in non-U.S. publications. Nineteen publications^14,^ ^21,^ ^28,^ ^42,^ ^116^–^119,^ ^122,^ ^124,^ ^126,^ ^128,^ ^129,^ ^131^–^136^ on the utilization of chiropractic and spinal manipulation, were undertaken within other eligible countries. The majority of these publications (n = 11) focused on LBP.^21,^ ^28,^ ^42,^ ^119,^ ^122,^ ^124,^ ^128,^ ^129,^ ^132^–^134^ Three publications presented information on neck pain,^124,^ ^134,^ ^135^ one on the thoracic spine,^134^ three on combined spinal sites,^116,^ ^117,^ ^131^ and three on unspecified back regions.^118,^ ^126,^ ^136^

Study designs varied and included two single-group prospective cohort study publications,^122,^ ^126^ five retrospective reviews of patient records or claims data,^21,^ ^28,^ ^42,^ ^132,^ ^135^ one study that used both patient records and single-group prospective cohort data,^129^ and 11 cross-sectional publications.^14,^ ^116^–^119,^ ^124,^ ^128,^ ^131,^ ^133,^ ^134,^ ^136^ Four publications did not provide information on duration of pain.^14,^ ^118,^ ^122,^ ^136^ Ten studies evaluated chronic pain (greater than 3 months) in the back,^126^ combined back and neck,^116,^ ^117,^ ^131^ and the low back.^21,^ ^28,^ ^42,^ ^119,^ ^128,^ ^133^ Three studies evaluated acute pain in acute whiplash (less than 30 days),^135^ in the LB for pain greater than 24 hours,^132^ and less than 6 weeks.^129^ Two studies evaluated mixed duration populations.^124,^ ^134^

Chiropractors were the providers of spinal manipulative therapy in 14 of the publications,^14,^ ^21,^ ^28,^ ^42,^ ^116^–^119,^ ^124,^ ^126,^ ^131,^ ^133^–^135^ physiotherapists in one study,^132^ osteopathic doctors in one study,^122^ chiropractors and osteopaths in two publications,^128,^ ^136^ and osteopathic doctors, chiropractors and physiotherapists in one study.^129^ Details on the type of spinal manipulation was provided in one study;^122^ this study noted provision of osteopathic manipulation defined as “passive articulation of the lumbar spine and high-velocity thrust techniques”.^122^

The study that reported on neck pain (specifically, acute whiplash) found that 18 percent of respondents sought chiropractic care.^135^ Eligible trials on LBP populations found that rates of attending for chiropractic/spinal manipulative therapy ranged from 11 to 40 percent.^119,^ ^128,^ ^133^ One publication reported that 81 percent of treatment by chiropractors included spinal manipulative therapy.^28^ In the single study in which physiotherapists were the treatment providers, 3 percent of patients with LBP were treated with spinal manipulative therapy.^132^ A single study reported the average number of visits for chiropractic care was 10.5 and the median was six.^28^ A national survey found that overall use of chiropractic services among Canadians increased from 36 percent in 1997 to 40 percent in 2006.^116,^ ^117^

Chiropractic/spinal manipulation use based on anatomical region. A single study^134^ evaluated back pain in three regions and showed a gradient from the least utilization for the thorax (7 percent), to the neck (9 percent) and the low back (40 percent). One study^124^ showed lower rates of use for neck pain (24 to 25 percent) than for unspecified back pain (71 to 74 percent).

Chiropractic/spinal manipulation used as complementary care or combined with other CAM therapies. Of the 19 eligible non-U.S. publications, the five that provided information on patterns of care-seeking all showed that chiropractic care is used both as a complementary therapy and an alternative to conventional care, often in similar proportions.^119,^ ^128,^ ^131,^ ^135,^ ^136^ The proportion of patients with back pain that attended a chiropractor in isolation ranged from 6 to 29 percent, and use of chiropractic as a complementary therapy ranged from 2 to 36 percent.

Quality assessment for chiropratic/spinal manipulation. Of 19 publications, 11 were cross-sectional publications.^14,^ ^116^–^119,^ ^124,^ ^128,^ ^131,^ ^133,^ ^134,^ ^136^ Two studies did not report response rates^118,^ ^134^ while the remaining studies reported rates from 19 to 100 percent. All but two studies^124,^ ^134^ recruited random samples from the general population. In addition, these two studies did not report the method of questionnaire development. For the remaining eight publications, study design varied and included two single-group prospective cohort study publications,^122,^ ^126^ one study that used both patient records and single-group prospective cohort data,^129^ and five retrospective reviews of patient records or claims data.^21,^ ^28,^ ^42,^ ^132,^ ^135^ All of the retrospective database studies obtained data from practitioner sources, and one study^135^ also used insurance claim source from persons following a motor vehicle accident. These studies recruited from select back pain patient groups. Overall, the quality of these studies was rated as fair.

Summary of utilization in non-U.S. chiropractic/spinal publications. Nineteen publications^14,^ ^21,^ ^28,^ ^42,^ ^116^–^119,^ ^122,^ ^124,^ ^126,^ ^128,^ ^129,^ ^131^–^136^ on the utilization of chiropractic and spinal manipulation, were undertaken in other eligible countries. The majority of these publications (n = 11) focused on LBP.^21,^ ^28,^ ^42,^ ^119,^ ^122,^ ^124,^ ^128,^ ^129,^ ^132^–^134^

Chiropractors were the providers of spinal manipulative therapy in most publications (14 of 19), with other providers included physiotherapists or osteopathic doctors. Only one study provided details on the type of spinal manipulation used.^122^

One study reported use for acute whiplash neck pain at 18 percent.^135^ Eligible trials on LBP populations found that rates of attending for chiropractic/spinal manipulative therapy ranged from 11 to 40 percent.^119,^ ^128,^ ^133^ A single trial reported that 81 percent of treatment by chiropractors included spinal manipulative therapy.^28^ A national survey found that overall use of chiropractic services among Canadians increased from 36 percent in 1997 to 40 percent in 2006.^116,^ ^117^ Two studies showed some evidence of lower rates of use for neck/thoracic pain relative to the LBP.^124,^ ^134^ Only 5 publications provided information on use as complementary or combined care. The proportion of patients with back pain that attended a chiropractor in isolation ranged from 6 to 29 percent, and use of chiropractic as a complementary therapy ranged from 2 to 36 percent.

### Specific CAM Therapy Utilization: Naturopathic Medicine and Related Interventions

We identified eight publications examining the utilization of naturopathic medicine and other related CAM therapies. Five of these^10,^ ^12,^ ^16,^ ^44,^ ^137^ were undertaken in the U.S. and three^118^–^120^ in other eligible countries. These papers were published between 2002 and 2007 and included 184,907 participants aged 15 to over 90.

Naturopathic medicine utilization within the U.S. There were three publications from the U.S that clearly examined naturopathic medicine utilization. Of these, two were single group prospective study designs^44,^ ^137^ where data was collected through a self-administered questionnaire,^44^ or a telephone interview.^137^ One study was a retrospective review16 of an administrative database. Two publications sampled practitioners^44,^ ^137^ and one study extracted data from a health insurance plan database.^16^ All publications defined the utilization of CAM (of which naturopathic medicine was a subset) as ‘a visit to a practitioner’.

One study^44^ found that approximately 5 percent of patients with LBP saw a naturopathic doctor (ND) in Connecticut and Washington states in 1998 and 1999. A reanalysis of this study undertaken for back and neck pain,^137^ found that licensed NDs provided a wide variety of interventions for patients with these conditions. However, the frequency of use of the differing ND treatment modalities was not reported specifically for patients with back or neck pain. In the reanalysis, it was reported that 4 to 7 percent of visits to NDs were primarily due to symptoms diagnosed as back problems (Table 17A). Similarly, 2 to 3 percent of patients who visited NDs presented with neck problems as the primary complaint or symptom. A third study,^16^ unrelated to the previous two, indicated that 2 percent of patients visited an ND at least once in the previous year (2002) for back pain (mean visits = 2). Only 1 percent of people with back pain visited only an ND.^16^

Table 17A Utilization of naturopathic medicine in persons with unspecified back pain

Author Year Country | Study Design | Reporting Mode | Timing of CAM Visit | Sample Size | Population | Clinical Presentation | Episode of Care | Outcomes
Studies from the United States
Cherkin^44^ 2002 U.S. | SGPS | SAQ | Past 12 months | 99 NP 488 eligible practitioners | Practitioner collected patient information | Any condition | Visit to a NP | NP data: 1,817 patient visits Patients reporting ‘back symptoms’ as primary reason for visit to NP Connecticut: 28/631 (4.4%) Washington: 77/1,186 (6.5%)

Abbreviations: NP = Naturopathic Physician; SAQ = Self-administered questionnaire; SGPS = Single group prospective study

Table 17B Utilization of naturopathic medicine in persons with unspecified back pain

Author Year Country | Use with Conventional Care | Concurrent use with Other CAM
Studies from the United States
Cherkin^44^ 2002 U.S. | NSBP | NSCAM

Abbreviations: CAM = Complementary and Alternative Therapy; NSBP = Data not stratified by back pain; NSCAM = Not stratified by CAM therapy

Naturopathic medicine utilization outside of the U.S. One study with a cross-sectional design was conducted on the general Australian population in 2001^119^ and found that for those with LBP, approximately 3 percent had visited an ND in the past 6 months. No specifics regarding naturopathic treatments were reported in the study. It should be noted that the educational and licensing requirements for NDs in North America and Australia are drastically different, the former mimicking M.D. training in primary care very closely.

No data were reported on the usual costs for these therapies per treatment or for the prescribed course of treatments suggested. These data are insufficient to make any conclusions regarding the utilization of NDs for those with back pain. More research is needed.

### Dietary Supplements and Homeopathy Utilization Within the United States

This section focuses on those publications that assessed the utilization of CAM related to the use of dietary supplements and homeopathy for back pain. These interventions are often suggested and delivered by NDs but not all of these papers specifically mentioned that that was the case.

One study was cross-sectional^12^ and used a telephone interview and one study was an RCT^10^ that collected data with a self-administered questionnaire. Both publications sampled the general population in the U.S. and defined utilization of dietary supplements and homeopathy as ‘ever having tried’ (Tables 18A and 18B).

Table 18A Utilization of naturopathic medicine in persons with low back pain

Author Year Country | Study Design | Reporting Mode | Timing of CAM Visit | Sample Size | Population | Clinical Presentation | Episode of Care | Outcomes
Studies from the United States
Bruce^10^ 2004 U.S. | RCT | SAQ | Past 12 months | 190 intervention and 231 control subjects | General population with an email account and U.S. residency | Back pain in the past 12 months, no severe back pain symptoms that would be indicative of a very serious back condition or other comorbidity | Baseline: “ever used glucosamine supplement” 1 year: “glucosamine in past 6 months” | Baseline: 87/190 (45.8%) Control: 59/231 (25.5%) p<0.001 End of trial: Intervention: 24/190 (12.6%) Control: 18/231 (7.8%) p = 0.076
Lind^16^ 2005 U.S. | Retro Rev | AD | Out patient visits during 2002 | 104,358 individuals with back pain; 652,593 visits to practitioners | Enrollees aged 18 to 64 in large health insurance plans; enrollees had NOT been hospitalized or undergone surgery for back pain | Back pain | At least one visit for back pain to a CAM provider | 1.5% (n = 1,609) saw NP for at least one visit during 2002 0.6% used NP only Median number of visits to an NP was 2 (range = 1 to 4 visits)
Studies from outside the United States
Foltz^118^ 2005 Canada | CS | TI | Past 12 months | Complete sample 66,253 Non-specific CBP 11,736 (17.7%) CAM users 3,259 (39%) | Subset from national general sample collected 1996 - 1998 1 of 4 groups identified was “CBP or musculoskeletal disease” | Chronic BP was diagnosed by a health professional | ‘CAM users’; 1) received or discussed CAM with a non-mainstream practitioner; 2) used a support group for health problem; 3) received care from D.C. | 17.8% homeopathy 6.2% herbal medicine
Hopman^120^ 2006 Canada | CS | FI SAQ | 5 yr followup | 9,423 | General population randomly selected from 9 cities | Ever had back pain

Abbreviations: AD = administrative database; CAM = Complementary and Alternative Medicine; CI = Confidence interval; CLBP = Chronic low back pain; CS = Cross-sectional; D.C. = Doctor of Chiropractic; FI = Face to face interview; HRR = Health record review; LBP = Low back pain; M.D. = Medical Doctor; MT = massage therapist; NP = Naturopathic Physician; retro rev = Retro Rev; SAQ = Self-administered questionnaire; SGPS = Single group prospective study; TI = Telephone interview

Table 18B Utilization of naturopathic medicine in persons with low back pain

Author Year Country | Use with Conventional Care | Concurrent use with Other CAM
Studies from the United States
Bruce^10^ 2004 U.S. | Not applicable | Chiropractic: both groups 64% yoga (~25%), acupuncture (~20%), magnets (~16%)
Lind^16^ 2005 U.S. | Concurrent use possible but not specified by therapy 12% (n = 12,287) were “Mixers” meaning that they saw CAM and conventional providers | NSCAM
Studies conducted outside the United States
Foltz^118^ 2005 Canada | 6.2% CAM users with chronic back also saw a physician | NSCAM
Hopman^120^ 2006 Canada | Not applicable | NSCAM

Abbreviations: CAM = Complementary and Alternative Therapy; D.C. = Doctor of Chiropractic; GP = General Practitioner; NSBP = Data not stratified by back pain; NSCAM = Not stratified by CAM therapy; PT = Physical Therapist

The RCT^10^ compared an email discussion group behavioral intervention for LBP with usual care over a one year period. At baseline, 46 percent of the intervention group reported having ‘ever tried’ glucosamine compared to 26 percent in the control group. Thirteen percent of the intervention group and 8 percent of the control group reported trying glucosamine during the last 6 months of the study.

Wolsko^12^ in a national survey of back and neck pain from 1997 to 1998, found that those suffering from any back and or neck pain used the following CAM therapies over the preceding 12 months: 3 percent used homeopathy; 2 percent used vitamins, 1 percent used herbal medicines, and 1 percent used a special diet.

### Dietary Supplements and Homeopathy Utilization Outside the United States

Two Canadian publications sampling the general population, used cross-sectional designs to collect information on CAM use via telephone interview^118^ and face-to-face interview (Tables 19A and 19B).^120^ One study found that of the patients with chronic back pain (n = 3259), 39 percent had used a CAM therapy (massage, acupuncture, homeopathy, relaxation, reflexotherapy, or spiritual therapy) in the last year, 18 percent had used homeopathy and 6 percent had used herbal medicine.^118^ Another Canadian study^120^ looking at glucosamine use over a 5 year period (1997 to 2002) found that 5 percent of men and 10 percent of women had used glucosamine at some point for back pain. No data were reported on the usual costs for these therapies per treatment or the prescribed course of treatments suggested.

Table 19A Utilization of naturopathic medicine in persons with combined neck and back pain

Author Year Country | Study Design | Reporting Mode | Timing of CAM Visit | Sample Size | Population | Clinical Presentation | Episode of Care | Outcomes
Studies from the United States
Boon^137^ 2004 U.S. | SGPS | TI HRR | Consecutive patient visits in 1998 and 1999 | NP 99 patients 1,817 | Practice patterns of 99 NP | Various conditions | Visit to a NP | ‘Back symptoms’ primary reason for patient visits in: Connecticut 4.4% Washington 6.5% ‘Neck symptoms’ primary reason for visits in: Connecticut 2.3% Washington 3.3%
Wolsko^12^ 2003 U.S. | CS | TI | Past 12 months | 644/2,055 (31.3%) respondents reported back pain | Individuals who have had neck or back pain in the past 12 months | 46% had pain in more than 1 location 38% had LBP only 16% had neck or upper back pain only | Use of a CAM therapy or visit with CAM practitioner in the past 12 months | Homeopathy: 17/644 (2.6%) Vitamins: 12/644 (1.8%) Herbs: 8/644 (1.3%) Special diet: 8/644 (1.2%) Mean # of visits to CAM for in the past 12 months: Special diet therapy 2.7 Homeopathy 1.0
Studies from outside the United States
Walker^119^ 2004 Australia | CS | SAQ | Past 6 months | 1,913/2,748 (69.6%) response 1,228/1,913 (64.1%) ≥1 episode of back pain | Individuals from the electoral roll in Australia | LBP | Visit to a CAM practitioner | 2.6% of all visits for LBP over 6 months were to a NP No treatments specific to NP were listed

Abbreviations: CAM = Complementary and Alternative Medicine; CS = Cross-sectional; D.C. = Doctor of Chiropractic; FI = Face to face interview; HRR = Health record review; LBP = Low back pain; NP = Naturopathic Physician; SAQ = Self-administered questionnaire; SGPS = Single group prospective study; TI = Telephone interview

Table 19B Utilization of naturopathic medicine in persons with combined neck and back pain

Author Year Country | Use with Conventional Care | Concurrent use with Other CAM
Studies from the United States
Boon^137^ 2004 U.S. | Not reported | NSCAM
Wolsko^12^ 2003 U.S. | 25% had used both complementary medicine and a conventional provider for back or neck pain | NSCAM
Studies conducted outside the United States
Walker^119^ 2004 Australia | Not stratified by therapy | NSCAM

Abbreviations: CAM = Complementary and Alternative Therapy; D.C. = Doctor of Chiropractic; GP = General Practitioner; NSBP = Data not stratified by back pain; NSCAM = Not stratified by CAM therapy; PT = Physical Therapist

### Other CAM Therapies Based on Self-Care

Three publications focused on the use of single CAM therapies that are generally self-administered, including yoga,^138^ prayer,^139^ and mind body therapies.^140^ All three of these publications were subgroup analyses from a larger population-based survey undertaken in 1998.^5^ All evaluated both lifetime use and use within the last 12 months. Utilization reported in these studies was limited to the proportion of the sample who used these therapies and had neck or back pain.

Forty-two percent (standard deviation (SD) 4.5 percent) of those participating in yoga had back or neck pain; the concurrent or lifetime use of other CAM therapies for persons using yoga was not stratified by back pain. Prayer was used by 18 percent of persons with back or neck pain and 59 percent of these found it to be very helpful; 40 percent of these patients also saw a physician for their condition.^139^ Approximately 18 percent (standard error (SE) 2.6) of persons with back or neck pain also used mind body therapy within the last 12 months and 40 percent (SE 8.2) found this to be very helpful for their condition; mind body therapy can include relaxation techniques such as meditation, stress response, guided imagery, and biofeedback.^140^ The specific types of mind-body therapies used by persons with back or neck pain were not identified.

## Assessment of Quality of Utilization Publications

Given the degree of overlap of studies among the differing CAM therapies, we thought it useful to summarize quality for all the studies reporting utilization of any CAM therapy. As noted previously, single group cohort study designs are prone to a variety of biases and do not have specified criteria to assess methodological quality.

### Quality of Utilization Publications Undertaken Within the United States

A total of 46 publications on CAM utilization were from the U.S. Of these, 10 were based on retrospective patient records or claims data^16,^ ^21,^ ^28,^ ^32,^ ^33,^ ^36,^ ^37,^ ^39,^ ^40,^ ^42^ and 15 were cross-sectional publications.^5,^ ^9,^ ^12^–^14,^ ^18,^ ^19,^ ^26,^ ^29,^ ^31,^ ^35,^ ^45,^ ^138^–^140^ A single publication was based on an RCT.^10^ The remaining publications were single group cohort publications, for which quality was not assessed.

Of the publications based on retrospective health database or chart records, three were from large workers' compensation claims databases^36,^ ^37,^ ^39^ where the primary interest was in chiropractic visits. Three publications^16,^ ^32,^ ^40^ were from large health insurance claims or managed care network databases. All of these publications have standardized coding for classifying back pain (predominately ICD 9 codes), provider visits, and enrollee characteristics and treatments; given the pre-specified coding systems, linkages between elements within the database were likely limited in errors. Four publications used health record extraction from chiropractic charts;^21,^ ^28,^ ^33,^ ^42^ and standardized data collection forms were used.

All the U.S. cross-sectional publications used self-report methods of ascertaining utilization of CAM. Table 20 details these publications with respect to sampling strategy, response rate, mode of administration of the survey, questionnaire design (which we operationalized as pre-testing of questions) and the time frame for recall. Several publications were related to a single national survey,^5,^ ^12,^ ^138^–^140^ and two to residents of North Carolina.^9,^ ^31^ Response rates varied from 95 to 60 percent and all but one^5^ would be considered acceptable; an acceptable response rate is from 65 to 75 percent.^84^ Recall periods were 6 or 12 months, with the exception of two papers^29,^ ^35^ that collected current episode or the past 2 weeks. The majority of publications used telephone or in person interviews suggesting less potential for bias. Limited information about questionnaire design was provided.

Table 20 Quality characteristics of cross-sectional studies using self report utilization data from U.S

Study | Sample Selection | Mode of Administration | Pre-Testing of Survey | Recall Period | Response Rate (raw proportion)**
Burke^45^ 2006 | Random national sample | Face to face interview | Yes | Lifetime and past 12 months | 74.3%
Carey^9^ 1995 Carey^31^ 1996 | Random sample from North Carolina residents | Telephone interview | Yes | 1 year | n = 3,505/4,437 (79%)
Eisenburg^5^ 1998 McCaffrey^139^ 2004 Saper^138^ 2004 Wolsko^140^ 2004 Wolsko^12^ 2003 | Random national sample | Telephone interview | Not reported | Lifetime use Past 12 months | 60% overall weighted response rate among eligible respondents
Feuerstein^19^ 2004 | National probability sample | Telephone interview and respondent's completed diaries | No, data for this study was extracted from the 1987 National Medical Expenditure Survey (NMES) and the 1997 Medical Expenditure Panel Survey (MEPS) | Not reported | 80.1% for the NMES n = 34,459 74.1% for the MEPS n = 2,636
Fleming^13^ 2007 | Systematic sample | Face-to-face interview | No, but all questionnaires were previously validated | 1 year | n = 1,009/1,252 (80%)
Hawk^26^ 1999 | Random sample | Telephone interview | No, data for this study was extracted from the 1994 Heartland Poll | 1 year | n = 2,102 (66.4%)
Hurwitz^14^ 2006 | Random sample | Telephone interview | Joint Canada/US Survey of Health | 12 months | 66% in US
Hurwitz^29^ 1997 | Multistage sampling process | Telephone interview | No, data for this study was extracted from the 1989 National Health Interview Survey | 2 weeks | n = 116,929 (94.9%)
Jette^35^ 1994 | Not reported | Telephone interview and mailed survey | No, data for this study was extracted from a national survey of facilities that provided outpatient physical therapy services | Present | n = 2,329 (90%)
Sherman^18^ 2004 | Not reported | Telephone interview | Not reported | 6 months | Not reported n = 249

* the sample is described as randomly selected, but no details are provided

** if the denominator was not provided only the number of respondents (n) is reported

### Quality of Utilization Publications Undertaken in Other Countries

A total of 22 publications were undertaken within eligible countries outside the U.S. with an additional four overlapping with U.S. data.^14,^ ^21,^ ^28,^ ^42^ Of these, eight^21,^ ^28,^ ^42,^ ^121,^ ^125,^ ^129,^ ^132,^ ^135^ were based on retrospective patient record or claims data and 14 were cross-sectional publications.^14,^ ^116^–^120,^ ^123,^ ^124,^ ^127,^ ^128,^ ^131,^ ^133,^ ^134,^ ^136^ The remaining four publications were single group cohort publications, for which quality was not assessed.^51,^ ^122,^ ^126,^ ^130^

Among the publications from retrospective health database or chart records, one study^135^ used claims from a provincial insurance database for persons with whiplash. Others used, patient health records from physiotherapy practices,^121,^ ^132^ a pain clinic^125^ and chiropractic practices.^21,^ ^28,^ ^42,^ ^129^ It was not clear in all of these publications if standardized forms were used to collect utilization information.

The 14 cross-sectional publications all used self-report methods of ascertaining utilization of CAM. Table 21 shows these publications and their quality characteristics. Four of these publications^116^–^118,^ ^133^ were based in Canada and were undertaken at a national level using random sampling; similarly, two in Australia were nationally-based random sample surveys.^119,^ ^127^ Three publications recruited patients from practitioner clinics.^124,^ ^128,^ ^134^

Table 21 Quality characteristics of cross-sectional studies using self report utilization data from non-American Studies

Study | Sample Selection | Mode of Administration | Pre-Testing of Survey | Recall Period | Response Rate (raw proportion)**
Caswell^128^ 2002 | Recruited from private clinics* | Not reported | Not reported | Present | n = 100/100 (100%)
Cote^131^ 2001 | Random sample from Saskatchewan Health Insurance | Mailed survey | NR, but all questionnaires were previously validated | 6 months for complaints 4 weeks for care-seeking | n = 1,131/2,184 (55%)
Esmail^117^ 2007 Ramsay^116^ 1999 | Random sample | Telephone interview | Survey was previously administered from Ramsey 1999 | 1 year | 2005:18.8% (2,000 of 10,624) 1998: 25.7% (n = 1,500)
Foltz^118^ 2005 | Random sample | Telephone interview | No, data for this study was extracted from the 1996-1997 National Population Health Survey | 1 year | Not reported (n = 66,999)
Hartvigsen^123,134^ 1996 | 201 Chiropractic clinics in Denmark | Mailed questionnaire | No | Current episode of care | 88% of clinics
Hurwitz^14^ 2006 | Random sample | Telephone interview | NR, Joint Canada/US Survey of Health (JCUSH) | 12 months | 50% in Canada
Hopman^120^ 2006 | Randomly selected national sample | Face to face interview | Yes | Lifetime use of glucosamine use on a regular basis | 83% women and 77% men from original baseline sample
Jacobs^133^ 2004 | Not reported | Not reported but likely interview | No, data for this study was extracted from the 2000 Canadian Community Health Survey | 1 year | Not reported (n = 130,880)
Kilaver^134^ 2002 | Practices of Norwegian Chiropractors | Questionnaire | No | Current episode of care | NR
Ong^136^ 2005 | Random sample | Mailed survey | No, data for this study was extracted from the third Oxford Healthy Lifestyle Survey (1997) | 3 months | 64% (n = 8,889)
Sibbritt^127^ 2007 | Random sample; those reporting use of acupuncture selected | NR | Yes | Last 12 months | 83% of women aged 55 or older 4.2% of sample reported use of acupuncture
Walker^119^ 2004 | Age, gender, and state stratified random sample | Mailed survey | Yes | 6 months | 1,914/2,768 (69.1%)

* the sample is described as randomly selected, but no details are provided

** if the denominator was not provided only the number of respondents (n) is reported

Response rates varied from 19 to 100 percent when reported. Recall periods included lifetime use,^120^ 12 months,^116^–^118,^ ^127,^ ^133^ 3 to 6 months,^119,^ ^131,^ ^136^ 4 weeks,^131^ and current episode.^124,^ ^128,^ ^134^ Three publications^127,^ ^128,^ ^133^ did not report the mode of data collection for utilization data. The remaining publications all used mailed questionnaires or telephone interviews with the exception of one study that used face-to-face interviews.^120^ Limited information about questionnaire design was provided.

## Question 2. What is the Utilization Recommended by Different Types of Healthcare Providers?

To address this question we searched primarily for relevant U.S. based Clinical Practice Guidelines (CPG), and also publications that specified provider views on the recommended use of CAM therapies for patients with back pain.

### U.S. Clinical Practice Guidelines

We reviewed 19 U.S. CPG on neck or back pain. Of these, three were excluded as their target population was adults with spinal pain related to neurological conditions.^141^–^143^ Four were excluded as they did not provide any recommendations for the use of CAM therapies for back pain.^144^–^147^ A single publication^148^ compared CPG from 11 different countries; this study was excluded as the U.S. guideline was developed in 1994.

Eleven guidelines related to the management of back pain included the use of CAM and the characteristics of these CPGs are detailed in Appendix C Table 1. Of these guidelines, three were published by professional organizations (acupuncture^46^ and chiropractic organizations^149,^ ^150^), and three from payer organizations.^151^–^153^ Only one CPG^46^ made specific utilization recommendations for acute, subacute, chronic and recurrent flare-up patient conditions. The remaining 10 made general recommendations for using specific CAM therapies either by treatment type (n = 10), practitioner type (n = 2), or back region (n = 9) as follows:

By treatment type including. 1) Manipulation/Mobilization,^149^–^152,^ ^154^–^158^ 2) Heat or Cold,^154,^ ^155,^ ^157^ 3) Relaxation,^155,^ ^156^ 4) Acupuncture/electro-acupuncture,^46,^ ^153,^ ^156^ 5) Massage,^151,^ ^156^ 6) Manual Therapy,^152,^ ^158^ and 7) Yoga.^156^

By practitioner. 1) Chiropractor,^151,^ ^152^ 2) Massage Therapist,^151,^ ^152^ and 3) Manual Therapist.^152^

By spinal region. 1) Neck (none), 2) Neck/thorax,^152,^ ^154^ 3) Thorax,^151^ 4) Low back,^149,^ ^151,^ ^155^–^157^ 5) Mixed back regions,^46,^ ^150,^ ^158^ and 6) Back region not specified.^153^

For the single CPG^46^ with utilization recommendations, the recommended frequency for electro-acupuncture was for two to three times weekly for a duration of 4 weeks for acute and subacute back pain and 6 to 8 weeks for chronic back pain and recurrent/flare-up, Appendix C Table 1. Although, these recommendations were not specific to either neck or back problems, the CPG was developed to apply to all these conditions. Although very similar in its recommendations, this guideline distinguishes between utilization with respect to initial course of treatment and a continuing course of treatment. The CPG recommends re-evaluation after 12 weeks of treatment irrespective of the duration of the condition. Two independent raters scored this CPG using the AGREE scoring instrument.(see Appendix C Table 2) For this guideline, stakeholder involvement scored 6 out of 12, applicability 8 out of 12, and rigor and development 25 out of 32. Based on the AGREE^89^ score, this CPG would be acceptable with greater clarification and specifically a stronger link to the evidence for recommendations for utilization.

Summary of recommended use of CAM therapies. A single CPG, for electro-acupuncture, provided recommendations for the frequency of treatment that was stratified by duration, and recurrence. The guideline was developed from a provider organization and was acceptable based on the AGREE quality score.

### Provider Views About Recommended Use of CAM

Of the 22 publications that focused primarily on patient or provider views on CAM, 16 were excluded because they had no direct or indirect information on recommendations for CAM specific to back pain and in the context of optimal frequency and duration of utilization. Two publications^47,^ ^48^ were U.S. and four^49^–^52^ were from other eligible countries.

Of the two U.S. publications providing direct recommendations, one^48^ did not provide information stratified for back pain. The other publication^47^ recommended the type of CAM treatment for LBP in pregnancy and included heat/cold, yoga, and massage; no information on the utilization was provided. This recommendation was based on the views of American health care providers (physicians, nurses, midwives, prenatal educators).

Four non-U.S. publications provided some recommendations for the treatment of back pain; three of these were from the United Kingdom^49,^ ^50,^ ^52^ and one from Germany.^51^ Two of these publications^51,^ ^52^ made recommendations primarily with regard to the type of CAM appropriate for managing back pain. CAM practitioners in the United Kingdom recommended the Bowen technique, chiropractic, magnet therapy, massage, reflexology and yoga for LBP and the Bowen technique, chiropractic and massage for neck pain.^52^ The German publication^51^ cautioned that receiving acupuncture for acute, recurrent or chronic LBP seemed to be a function of availability and did not offset the use of other health care resources. In fact, there were both increased consultation rates and use of other health care services after adjusting for key patient characteristics.

Two related publications undertaken in the United Kingdom based on a cross-sectional questionnaire^49^ and a mixed methods design that included a qualitative component,^50^ captured attitudes toward LBP and included opinions about recommended utilization. These publications helped to explain the practice patterns observed in three provider groups (chiropractors, osteopaths, and physiotherapists). Based on provider survey views, these publications found that osteopaths and physiotherapists endorsed limiting the number of treatment sessions more than chiropractors did. Additionally, those working in private practice did not endorse limiting the number of treatment sessions as frequently as those working in a national health service setting. Those in private practice also endorsed a biomedical treatment oriented attitude advising their patient to be more vigilant and restrict activity versus a reactivation treatment orientation (items that concern return to work, daily activity and increasing mobility). These two publications would suggest that there may be moderating factors that influence the recommended use of CAM. These include availability of the CAM service, attitude of the practitioner (reactivation versus biomedical orientation) and a national health service versus private practice setting.

Summary of provider views on utilization. Six studies reported views on recommended use of CAM therapies. The two studies published in the U.S. did not stratify recommendations specifically for patients with back pain. Four publications from studies outside the U.S. provided some recommendations on use of CAM therapies specific to persons with back pain. None of the publications encompassing provider or patient views addressed recommendations with regards to the frequency or duration of treatment. These limited publications would suggest that the frequency of utilization may be influenced by the availability of the CAM service, attitudes of differing providers, the practice settings, and the type of CAM therapy.

## Question 3. What are the Usual Costs for These Therapies per Treatment and for the Prescribed Course of Treatment?

Our review identified 18 publications that were associated with costs or economic evaluations related to back pain and the use of CAM within the U.S. One study^5^ provided information on costs and coverage for CAM therapies but did not present results stratified for back pain. Another study^35^ evaluated the use of manual therapy applied by physical therapists but did not present costs in relation to the specific therapies applied. Of the remaining publications, two were based on the same patient population cohort^53,^ ^54^ and two on the same health claims database.^32,^ ^59^ Another study^57^ incorporated data from three different publications and undertook an economic analysis of this combined data. Study characteristics and results are detailed in Appendix C Tables 3 and 4.

A variety of study designs were employed to collect cost related data including: retrospective analyses from administrative databases (n = 7),^16,^ ^32,^ ^36,^ ^39,^ ^59^–^61^ single group prospective design (n = 5),^20,^ ^34,^ ^53,^ ^54,^ ^57^ RCTs (n = 3),^55,^ ^56,^ ^58^ and a case-control design.^37^

The majority of publications (n = 13) focused on costs associated with CAM services in persons with LBP.^16,^ ^20,^ ^32,^ ^37,^ ^39,^ ^53^–^60^ From these LBP studies, four^53^–^56^ included acute pain varying from greater than 7 days ^56^ to less than 10 weeks.^53,^ ^54^ Four studies^16,^ ^32,^ ^39,^ ^58^ did not specify the duration. Three studies evaluated chronic back pain described as recurrent,^59^ chronic^60^ or disabling.^37^ Two studies combined chronic and acute back pain.^20,^ ^57^ For the three studies that did not evaluate costs of CAM services in persons with LBP, two evaluated back pain location unspecified^34,^ ^36^ and one combined neck and back pain;^61^ none of these three studies identified the duration of the pain.

The source of payment for the CAM therapies used in these studies included private health insurance (n = 5),^16,^ ^32,^ ^34,^ ^59,^ ^61^ workers' compensation insurance (n = 4),^36,^ ^37,^ ^39,^ ^60^ and mixed sources including out of pocket (n = 4).^20,^ ^53,^ ^54,^ ^57^ Three studies,^55,^ ^56,^ ^58^ that were randomized trials, had the study or the participants insurance pay for treatments.

### Characteristics of Cost Evaluations for CAM Services

Fifteen of the 18 studies were not true economic analyses, but rather cost identification studies. A single study^57^ undertook a complete cost-effectiveness analysis (CEA) for patients with LBP. The perspective of this analysis was from that of the payer. This CEA had some limitations, as data for complete cost estimates were only available for 38 percent of chronic and 50 percent of acute patients. In addition, this study did not assess actual use of services for referred patients, rather they imputed some costs. This approach was based on previously used methods for charges based on per claimant data and adjusted for proportion of provider charges that were actually reimbursed. It was not clear if this study^57^ included the costs of adverse events related to visiting a chiropractor or M.D.. Although three studies^53,^ ^55,^ ^56^ did provide health outcome change scores and costs, they did not estimate cost-effectiveness ratios; one of these studies^56^ attempted to evaluate adverse events.

Comparators to CAM provider costs. Although selection of a comparator is not necessary in cost identification studies, all but two^39,^ ^61^ undertook comparison of back treatment costs for CAM and non-CAM providers (Table 22). The overwhelming majority of studies (n = 13) evaluated chiropractors as the exclusive CAM provider.^20,^ ^32,^ ^34,^ ^36,^ ^37,^ ^39,^ ^53^–^55,^ ^57^–^59,^ ^61^ One study^56^ evaluated choice of a single alternative provider that may have included a chiropractor, acupuncturist, or massage therapist; another study^16^ included any of four CAM providers (chiropractors, massage therapists, acupuncturists, or NDs) and another^60^ may have included acupuncturists or massage therapists within the “other” category. Similarly, CAM provider costs were compared to a number of conventional practitioners including: M.D.s (n = 11 publications),^16,^ ^20,^ ^32,^ ^34,^ ^36,^ ^37,^ ^53,^ ^54,^ ^56,^ ^59,^ ^60^ orthopedic surgeons or internists,^53,^ ^54^ physical therapists,^55,^ ^60^ combined M.D.s and physical therapists,^58^ and “mixers” of both CAM and conventional providers.^16^

Table 22 Summary of studies evaluating costs in persons with low back pain

Author Year | Study Design Back Pain Cost Study Sample Size | Costs Descriptions | Direct Costs Outcomes | Insurance
Carey^53^ 1995 | SGPS ALBP CID Urban n = 310 Rural n = 296 | Costs in 1995 USD Outpatient costs per episode of care Outpatient costs per episode of LBP including: 1) visits, 2) X-rays and other imaging, 3) medications, 4) PT, and 5) other (D.C.) Data on the charges for outpatient services was based on average state wide charges assigned by a large health insurance carrier | Mean Total Costs Adjusted for baseline function Mean Costs | Proportion that had coverage as a function of practitioner
Sundararajan^54^ 1998 | As above (Carey) D.C. as possible only index provider more than one index provider | As above (Carey) Logistic Regression model to predict cost for seeing only index provider | Adjusted mean cost for seeing only index provider | Not specified
Cherkin^55^ 2003 | RCT ALBP CID n = 1,580/1,633 (97%) D.C. vs PT vs educational booklet | Costs in 1995 USD Costs include all those charged to the HMO: non-study treatments (>15 visits) were covered by the subjects health insurance with a $5 or $10 copayment | Costs per unit for visit: (mean cost per subject) Mean costs over a 2-year period Indirect Costs “Out of pocket expenses” not included | Not applicable as all expenses covered by study
Eisenburg^56^ 2007 | RCT ALBP CID (data available for CEA) Usual Care n = 148 Choice Care n = 296 Usual care (M.D./medication) vs choice care (D.C., AT, MT) | Costs in 2003 USD Costs were assigned using the Medicare reimbursement for encounter and the “Red Book” for prescriptions | Average and median Total costs for treatment: comparing usual care to choice care. 12 weeks Before study enrolment >12 after study enrolment For choice group mean reimbursement to provider | Not applicable all covered by private insurance
Haas^57^ 2005 | SGPS ALBP & CLBP CEA n = 2,827 patients from 69 D.C. and 111 M.D. practices D.C. vs M.D. | Costs in 1995 USD Costs included office based visits, and imputed costs for imaging, surgical consultation, and PT | Total unadjusted costs 3 months acute vs chronic 12 months acute vs chronic 3 months acute vs chronic CER1* pain and disability CER2* pain or disability | Proportion with none or any type of insurance Chronic patients vs acute patients Compared D.C. vs M.D. patients
Kominski^58^ 2005 | RCT LBP (acuity not specified) CID n = 664/681 (97.5%) completed 28-month followup D.C. vs D.C. + PM vs M.D. vs M.D. + PT | Costs expressed as USD (year not specified) for care over 18 months Costs included charges for diagnostic and therapeutic modalities from any provider. Some patients did have to make co-payments. Pharmaceutical costs were not included | Mean costs per total OP costs over 18 months Adjusted mean total costs per treatment Stratified by provider type Relative cost differences | Not applicable; all members of HMO
Lind^16^ 2005 | Retrospective database LBP CID n = 104,358/601,044 (17.4%) had back pain and were eligible for the study Conventional vs CAM only (D.C., AT, ND, MT) vs Mixers (Conventional and CAM) | Costs in 2002 USD Costs included maximum allowed amount by the insurance company; theses costs may have included visits, and procedures allowed by the insurance company policy | Mean costs per visit Mean total expenditures | Not applicable; all members of HMO
Nyiendo^37^ 2005 | Case control Disabling LBP CID D.C. n = 94 M.D. n = 107 D.C. vs M.D. | Costs in USD (year not specified). Costs include treatment, diagnostic tests and drugs. | Direct Costs: All cases: % of total costs D.C. vs M.D.: All cases: Mean dollars per case D.C. vs M.D. Indirect Costs Not evaluated | Not applicable all participants on workers compensation
Stano^20^ 2002 | SGPS ALBP and CLBP CID Total n = 2,872 D.C. n = 1,524 M.D. n = 739 NRM n = 611 RM n = 128 D.C. vs M.D. vs NRM | Costs in 1995 USD Current Procedural Terminology was converted to relative value units for D.C. and M.D. care and 1995 Medicare conversion factor | Direct Costs: First episode mean total payments First episode mean outpatient payments Multiple Episodes: Mean total payment for first 2 episodes Mean outpatient payments for first 2 episodes Indirect Costs: Not evaluated | Proportions of patients with different coverage stratified by provider type
Stano^32^ 1995 | Retrospective database collected from July 1988 to June 1990 LBP CID n = 43,476 patients based on back ICD codes; 6,183 patients and 8,018 episodes of care D.C. vs M.D. | Costs in USD Episode of care includes all health services incurred to treat back condition; in some cases this may involve cost associated with other illnesses. | First episode costs mean total payments First episode costs mean outpatient payments Multiple episodes Mean total payment for first 2 episodes Mean outpatient payments for first 2 episodes | Proportion with additional vs basic coverage.
Smith^59^ 1996 | Retrospective database Recurrent LBP CID Patients with recurrences n = 1,215/7,077 D.C. vs M.D. | Costs in USD for total payments estimated for persons with recurrent episodes. | Costs first episode provider Total costs both 1^st^ and 2^nd^ episodes Costs first and second episode provider Costs for patients with 3 episodes of care | Not reported
Wasiak^39^ 1998 | Retrospective database 1999 to 2002 LBP CID n = 8,894/13,734 D.C. across 7 states | Costs in 1999 USD Costs included visits and all other services performed on the same day and all costs associated with services for chiropractic care. Costs were adjusted to constant year dollars using the medical care component of the Consumer Price Index. | Mean cost for individual (adjusted for geography) for D.C. for 7 states Mean individual cost per visit (adjusted for geography) | Not applicable all on workers compensation
Williams^60^ 1998 | Retrospective database 1988 to 1992 CLBP CID n = 520/29,056 By service type: D.C., PT, Miscellaneous non-medical (AT, MT, other) | Costs in USD Lost time injury costs, subdivided by health care services. Costs were presented in terms of duration of work disability for LBP from worker's compensation claim data from the National Council on Compensation Insurance | D.C. Mean Costs as a function of <30 days, 30–90 days, 91–180 days, >180 days, Miscellaneous (AT, MT, other) Mean Costs <30 days, 30–90 days, 91–180 days, >180 days PT Mean Costs | Not applicable all on workers compensation

Abbreviations: ALBP = acute low back pain; AT = acupuncture therapy; CEA = Cost effectiveness Analysis; CER1* = incremental cost effectiveness ratio with adjusted mean difference in outcomes between D.C. and M.D. with office costs used in the numerator; CER2* = incremental cost effectiveness ratio with adjusted mean difference in outcomes between D.C. and M.D. with total costs used in the numerator; CI = Confidence interval; CID = Cost identification; CLBP = chronic low back pain; CON = Conventional providers; CS = Cost study; D.C. = Doctor of chiropractic; HMO = health maintenance organization; ICD = international classification of diseases; LBP = low back pain; M.D. = Medical doctor; MDF = mean difference; MT = massage therapist; NRM = non-referred medical; OP = osteopathic physician; OS = Orthopedic Surgeon; PCP = primary care provider; PM = Physical modalities; PT = Physical therapist; RCT = randomized controlled trial; SD = standard deviation; SE = standard error; USD = United States dollar

Direct costs for CAM services. The cost perspectives evaluated were predominately from that of the payer, and as such direct costs were collected. All studies included costs of visits to practitioners, but varied with respect to: a) inclusion of imaging or diagnostic tests, b) visits to specialists, c) back surgery costs and d) the use of medications. For studies with the workers' compensation insurance as the payer, some included costs for lost days^36,^ ^60^ and others excluded these.^37,^ ^39^ Studies from other payers such as private insurance could have attributed lost days as indirect costs, but none evaluated these. The studies using health administration databases were prone to including costs associated with other illnesses, due to the manner of establishing an episode of care.^32^

The years for which costs were estimated varied significantly; these included cost estimates from a single study in 1982,^34^ two from 1985,^36,^ ^37^ five from 1995,^20,^ ^53^–^55,^ ^57^ one from 2002,^16^ and one from 2003.^56^ Other studies used a range of years for cost estimates including: a) a two year interval from 1988-1990^32,^ ^59^, b) a four year interval from 1988-1992^60^, c) another from 1997-2001,^61^ and d) from 1998 to 2002.^60^ One study did not specify any year but estimated costs over an 18 month interval.^58^ One study specified costs for each of the years between 1999 to 2002.^39^ In general, half of the cost estimates were based on data over 12 to 25 years and only three studies reported costs within the last 5 years (Table 23).

Table 23 Summary of studies evaluating costs in persons with unspecified back pain or combined neck and back pain

Author Year | Study Design Back Pain Cost Study Sample Size Comparison | Costs Descriptions | Direct Costs Outcomes | Insurance
Jarvis^36^ 1991 | Retrospective database and chart extraction 1986 Combined back pain CID n = 3,062/7,551 (40.6%) M.D. vs D.C. Stratified by ICD | Costs in 1985 USD Costs included costs for care and costs for compensation. | Compensation costs Costs of care Indirect Costs Not evaluated | NA
Shekelle^34^ 1995 | SGPS 3 to 5 year interval Unspecified back pain CID 1,020 episodes of care by 686 persons and 8,825 visits Providers included: D.C., PCP, OS, IT, OP, Other | Costs in 1985 USD Total costs included hospital care, physician services, drugs, services, injections, supplies etc. | Mean cost per visit Mean total cost per episode Mean cost per outpatient episode Indirect Costs Not evaluated | Proportion with none or any type of insurance Chronic patients vs acute patients Compared D.C. vs M.D. patients
Legoretta^61^ 2004 | Retrospective database 1997-2001 Combined neck and back pain CID 707,690 with D.C. coverage/1,001,995 without coverage: from these 141,616 had D.C. coverage and 189,923 did not. Comparison: members of insurance plan with and without D.C. coverage | Costs in USD (year not specified). Costs included outpatient services, imaging methods, lumbar spine surgical procedures, and inpatient stays. Physiotherapy and drug costs were excluded | Total cost per patient over 4 years (all episodes): Average cost per episode over 4 years Indirect Costs Not evaluated | Patients with and without coverage for D.C.

Abbreviations: CID = Cost identification; D.C. = Doctor of chiropractic; HMO = health maintenance organization; ICD = international classification of diseases; IT = internist; M.D. = Medical doctor; OP = osteopathic physician; OS = Orthopedic Surgeon; PCP = primary care provider

A variety of cost measures were used including: a) total costs of care per episode per patient,^20,^ ^34,^ ^36,^ ^39,^ ^53,^ ^56,^ ^60^ b) mean costs for index provider,^54^ c) costs per unit visit,^16,^ ^55^ mean costs over an interval of time,^55,^ ^58,^ ^61^ percentage of total costs,^37^ first episode versus multiple episodes costs,^32^ and first and subsequent episode provider costs.^59^ A single study estimated the incremental cost effectiveness ratio for health outcomes of pain and disability reduction.^57^ Appendix C Table 3 details the dollar values for each of these cost outcomes. Although costs do vary with differing providers, interpretation of these cost differences is problematic in the absence of links to health benefits or harms. There are also problems with the, often implicit, assumption that the effects of the providers and their treatments are equivalent.

Indirect costs for CAM services. The cost perspective for all studies was that of the payer, and as such direct costs were collected and indirect costs were either considered to be of less importance or were intentionally excluded.^55^ No studies evaluated indirect costs with respect to time off work to attend therapy, or the costs associated with any adverse reactions from CAM therapy. The two studies in which the payer was workers' compensation insurance^36,^ ^60^ included time off due to back pain as direct costs to the payer. Sick days taken for back pain in studies that estimated costs from other payers would not have captured these indirect costs to the patient or their employers.

Quality of studies evaluating costs. (Appendix C Table 4) A single study^57^ undertook a formal CEA and methodological quality was evaluated using the Quality of Health Economic Studies (QHES).^90^ This study scored low on criteria related to selection of perspective, specification of economic analyses, justification for these, and disclosing the source of funding for the study. The QHES could not be applied to the remaining studies as they were cost-identification evaluations and not true economic analyses. The limitations in the accuracy of cost estimates for publications using administrative databases^16,^ ^32,^ ^36,^ ^39,^ ^59^–^61^ have been detailed previously. However, we noted that even those studies that employed RCT design, relied upon administrative health data for their cost estimates; as such these high level designs were also prone to the same potential confounding that results from using this source of cost data.^56^

Impact of insurance coverage on costs for CAM services. Three publications^20,^ ^53,^ ^57^ were not based on samples entirely covered by insurance from private health organizations or workers' compensation. One study^53^ indicated the proportion of persons with coverage for urban versus rural chiropractors and primary care providers, and orthopedic surgeons. Another study^57^ reported the proportion of those covered by differing insurance carriers (or lack of coverage) as a function of provider type (chiropractor versus M.D.) and the duration of the LBP (acute versus chronic). The findings of this study would suggest that the duration does not affect the relative proportions of coverage for either chiropractor or M.D.. However, there was a greater proportion of patients who had no coverage seeking chiropractor relative to M.D. services (42 to 47 percent versus 6 to 8 percent). Similarly, a smaller proportion of patients with private or Medicaid insurance had coverage for chiropractic relative to M.D. services for back pain. The third study^20^ reporting the impact of coverage suggested that up to 42 percent of persons with LBP pay out of pocket for chiropractic services. In contrast, those who seek medical services that include referral to a surgeon or physical therapist pay only 3 percent out-of-pocket; those seeking medical services and who are not referred to either a surgeon or physical therapist have slightly higher (7 percent) out of pocket costs.