# Introduction^1^ Appendixes and evidence tables cited in this report are provided electronically at: http://www.ahrq.gov/downloads/pub/evidence/pdf/backpaincam/backcam.pdf

## Background

The high prevalence rates for neck, thoracic, and low back pain (LBP), indicate the importance of this type of musculoskeletal pain as a public health concern. Back pain can occur at any age, and is usually recurrent, with subsequent episodes tending to increase in severity;^2,^ ^3,^ ^63,^ ^64^ this speaks to back pain as an important source of chronic illness in adults. Although, the majority of back pain episodes resolve within a 6 week period, there is a portion of persons with back pain that have significant disability, resulting in loss of working abilities, restriction of daily activities, and a decline in quality of life.^2,^ ^3,^ ^65,^ ^66^ Back pain, although most frequently evaluated in adults, is not limited to this population. Even in adolescents suffering from back pain, a significant proportion (up to 40 percent) will have recurrent episodes of sufficient severity to limit usual activities, including participation in sports.^67^ In general, prevalence rates for back pain are lower in younger adults relative to middle aged adults, and have not been well evaluated in elderly subjects.^68^

Back related pain has a high morbidity burden in adults in the United States (U.S.) and other industrialized countries.^1^–^3^ The 3 month prevalence of neck and back pain within the U.S. adult population is 31 percent;^64^ 34 million with LBP, 9 million with neck pain, and 19 million with both.

A recent review^4^ of the costs associated with back pain indicates that it ranked 6th in U.S. national health costs, and as the 4th most expensive health cost for U.S. employers. Additionally, a study using the human capital approach to evaluate indirect costs for back pain, estimated these to be $19.8 billion; higher than those of headache ($19.6 billion), arthritis ($10.3 billion), and other pain conditions ($11.6 billion) considered in the survey.^66^ In 1995 and 1996 the estimated cost of chronic pain (including lost work days, therapy and disability) was $150 billion to $215 billion USD each year.^69^ This trend of high costs has been observed in other industrialized countries. One cost evaluation undertaken in Sweden demonstrated that the annual total cost for back and neck problems is equivalent to one percent of the gross national product, with the majority of costs due to indirect care and longterm disability.^70^

Treatment approaches for back related pain can be multidimensional and include conventional care, complementary and alternative medicines (CAM), or both. The combined use of conventional and CAM therapies is known as “complementary” therapy; when this combined care is based on high quality evidence of efficacy and safety is known as “integrative care”. The large constellation of treatment modalities that constitute CAM are used widely throughout the U.S. and internationally both by individuals who are healthy and those who have specific health concerns such as back pain.^5,^ ^6^ The use of CAM therapies can include visits to specific practitioners, as well as self-treatment (i.e., when using herbal products, or relaxation techniques). In the literature, CAM therapies are inconsistently defined and this may be an important factor in variation in reported prevalence rates.^62^

In the U.S., there is some evidence to suggest that those suffering from chronic pain are more likely to use CAM therapies or CAM practitioners services, than those without chronic pain.^5,^ ^71^ One of the main reasons that patients seek CAM therapies is for back and neck pain.^6,^ ^12,^ ^71^ One estimate indicates that the adjusted odds ratio predicting use of CAM services is equal to 2.30 (95% CI 1.66 – 3.20) for those with back pain; the only other condition to exceed this value was anxiety.^71^ Moreover, Americans who reported having back pain were more likely to see a CAM practitioner (or self-use CAM) compared to the entire population sampled.^5,^ ^71^

### What is CAM?

Given the preference of many persons with back pain to use CAM therapies or CAM practitioner services in the management of their problem, a better understanding of what constitutes CAM therapies is important. CAM is comprised of a group of therapies that are considered to be outside the scope of treatment of most conventional practitioners or therapies. The number of therapies and practitioners classified as CAM, can vary depending on the country, but a recent classification scheme has been established within the U.S.^72,^ ^73^ These CAM therapies represent diverse health system approaches, health practices, and products that are not presently considered to be conventional.^73^ Conventional medicine in the U.S. is practiced by medical doctors, osteopathic doctors, physical therapists, psychologists and registered nurses.^73^ However, osteopathic physicians do practice osteopathic manipulative therapy which can also be considered CAM in nature. This raises the issue that an increasing number of conventional practitioners are including what have been traditionally categorized as CAM therapies in their current clinical practice. There is some confusion as to whether the practitioner or the therapy should be the basis upon which the treatment is classified as alternative or complementary or conventional. This confusion presents some challenges to understanding utilization of these therapies.

As some of these CAM therapies develop an evidence base and are adopted into the conventional healthcare system as treatment options, the distinction of being CAM may change.^73^ This may present some ambiguity when considering comparisons between alternative and conventional care; consider the case where 100 percent of the population uses the “alternative” therapy, and as such the therapy then becomes conventional.^74^ The World Health Organization has defined CAM as “a broad set of health practices that are not part of a country's own tradition, or not integrated into its dominant health care system”.^75^ As such the definition of what is alternative or complementary may vary by country.

The National Center for Complementary and Alternative Medicine (NCCAM)^73^ classifies most CAM therapies into five domains as follows: 1) manual or mobilization therapies including manipulation and body movement therapies; 2) mind body medicines that include behavioral, psychosocial, and spiritual approaches; 3) chemical or biological based therapies that include the use of natural and biologically based products; 4) energy therapies that use differing methods to alter energy fields around the body; 5) holistic approaches that have an underlying theoretical framework for evaluating and promoting health such as Traditional Chinese Medicine, Homeopathy, and Chiropractic; and finally 6) “home remedies” that can include variants of all the therapies listed previously. From a health services perspective, this latter category is often not clearly identified as CAM therapy.^62^ There is no consensus regarding the classification of these various CAM therapies within the larger domains. However, from a health services research perspective, there is a need to specify the therapies used rather than identify broadly the CAM domains.^62^ There may also be a need to distinguish the “therapist” from the “therapy”. Establishing that a “naturopath” provided a specific type of care such as acupuncture is important; the dose or subtype of therapy may differ between practitioners. Whether the public distinguishes between the therapist and the therapy is not always clear.

### Who Uses CAM?

Historically CAM approaches to health care were marginalized by the medical profession in the U.S. A review of population surveys within industrialized countries suggested that CAM users were predominately female, with higher education and socio-economic status, and of white race.^62^ This is consistent with patterns of use within the U.S.^71,^ ^76^ A bimodal distribution with regards to use of CAM related to low socio-economic status and ethnicity has also been shown; ethnic minorities, who are generally underrepresented in surveys, typically use CAM on a regular basis.^77^

In the early 1990's survey data suggested that respondents did not use CAM for serious medical conditions (denoted as “principle medical conditions”); rather they used it primarily for health promotion and disease prevention.^5,^ ^78^ Amongst the aging American baby boomers, there is increasing awareness that health is not only the “absence of disease”, but incorporates the concepts of wellness and lifestyle.^79^ This is creating a trend towards the increased use of CAM which is anticipated to continue, as these therapies are used to promote health and prevent disease in those who are well. In those who are ill, CAM is used to manage and treat specific health problems.

American attitudes towards CAM therapies have changed in part due to greater media coverage and access to web-based information about specific therapies. Interestingly, chronic back pain patients from urban settings were shown to be willing to try CAM therapies, despite indicating that they knew little about the therapy (with the exception of chiropractic and massage); moreover, no relationship was shown between high expectations for a particular therapy and previous use or knowledge of the therapy.^18^ In the case of chronic back pain, where conventional or allopathic treatments have had limited success, patients are more open to trying CAM therapies. The appeal of many CAM therapies may be due to dissatisfaction with traditional conventional medical therapies that may be perceived as more invasive or less effective such as back surgery versus manipulation. For some, the appeal of some CAM therapies is that they are perceived as emphasizing personal autonomy over one's own health. All of these factors have generated greater interest in using CAM therapies, which in turn has resulted in greater CAM availability within conventional heath care facilities and places of employment, availability of CAM courses in conventional health professional training centers, and changes in reimbursement in health insurance coverage.

### What is CAM use and What are the Behavioral Models Explaining This use?

Health service utilization is a broad term that generally refers to the use of a health provider or health service and is generally understood to indicate a visit to a provider or a health service.^8,^ ^80^ This concept of use has been expanded to include the use of CAM therapies that may or may not be directed by a practitioner, such as the use of supplements or other CAM therapies within the home.^7^ A number of outcomes have been used, predominately from survey-based data, to explore the use of CAM including prevalence rates, costs, patterns of use, changes in use over time, reasons for CAM use, attitudes associated with CAM use, and comparisons of users with non-users.^81^ However, a distinction should be made between outcomes that indicate obtaining a CAM therapy or service and factors that explain why someone chooses to use a CAM therapy or to access a CAM practitioner.

The use of health care services has often been explained by the physical, psychological and social characteristics of the users, the healthcare system, and the providers within the system. The Andersen model of health service utilization (and adapted versions) describes patterns and identifies predictors of use.^8,^ ^82^ This behavioral model for the use of health services, is a multi-disciplinary attempt to integrate economic, healthcare-related, socio-cultural, and psychological factors. The model assumes that there is a sequential relationship between three sets of determinants of use: 1) the predisposition to use services (predisposing); 2) the ability to obtain services (enabling); and, 3) perceived (patient) or evaluated (medical) need. The predisposing component relates to demographic, socio-structural, and attitudinal-belief variables, irrespective of the underlying condition. The enabling component includes both family and community resource variables that are required to seek and obtain care. The need component involves an individual's perception of illness and the limitations that it imposes on daily activity. Health beliefs are attitudes, values and knowledge that people have about health and health services that might influence subsequent perceptions of need and use. Health beliefs in particular can influence use of services in relation to preventative health behaviors. Perceived need by the user may explain care seeking behaviors and adherence to care. Evaluated need as determined by the provider can assist in understanding the type and amount of treatment used.

The Andersen model of healthcare utilization has been expanded to include environmental variables.^8^ This would include characteristics of the healthcare delivery system such as policies, resources, organization and financial arrangements influencing accessibility, availability, and acceptability of the health services. External environmental factors include the economic climate, relative wealth, politics, level of stress and violence, and prevailing norms of the society. Finally, the community level environmental variables can include attributes of the community where one lives that enable them to obtain service (availability of practitioners).

While the Andersen model of healthcare utilization assumes that use necessarily entails a visit to a healthcare provider or health service, Fouladbakhsh and Stommel^7^ have proposed an alternative categorization of CAM therapies and activities and in turn a new model for conceptualizing health service use. Their model not only includes the CAM provider, but also “use” with regards to “products and resources” (i.e., the use of herbs, supplements, self-help manuals, etc.) and CAM practices (individual or communal direction of therapy). The developers of this new model argue that these expanded categories can be integrated with the Andersen model and serve to enhance the framework to improve prediction of CAM use. The new model, adapted specifically for CAM still includes predisposing, enabling, and need factors to explain healthcare use. It also allows for evaluation of the concurrent use of conventional health services.

## Evaluating the Methodological Quality of Studies Addressing Utilization of CAM

Much of the literature evaluating utilization of CAM services is collected from patient or practitioner recall surveys, chart review, or analysis of administrative health claim databases.^83^ Moreover, many studies evaluating utilization employ observational designs without a true control or concurrent group. These study designs and methods of data collection, lend themselves to consistent biases, in particular, recall bias and the limitations of using records from charts or databases that were not designed for research purposes.

Many utilization studies are based on data from questionnaires which rely on self-reported CAM use which results in a number of important biases, including bias related to the selection of participants, recall bias, and reporting biases.^80^ Factors that may affect accuracy of reporting include: 1) recall time-frame, 2) type of utilization, 3) utilization frequency (number of visits, and event repetition), 4) questionnaire design, 5) mode of data collection, and 6) memory aids or probes used to evaluate the quality of survey studies.^84^

Similarly, for studies reporting utilization based on health claim administrative databases or health record review studies, there are a number of limitations to using this retrospective data. For studies within the U.S., it is likely that patients who are not covered or with insufficient medical coverage will be less likely to seek services; as such there is the potential for selection biases despite large claimant samples.^85^ Potential sources of bias include incomplete or miscoded health diagnosis, the type of health treatment, and patient characteristics; this in turn may lead to misclassification and errors with any subsequent linkages.^85,^ ^86^

An alternative approach to evaluating general service use is based on the National Ambulatory Medical Care Survey. This methodology collects service visit characteristics close to the time of each patient encounter.^87^ This allows for standardized collection of visit data immediately after individual patient encounters, minimizes problems of long term provider recall, limits the artifacts of chart documentation focused on insurance reimbursement requirements, and avoids the pitfalls of retrospective administrative data analysis.

The biases identified thus far are related primarily to the methods used to collect outcomes, but there are additional sources related to the design of the studies. Many studies evaluating health service utilization are based on cross-sectional and other observational study designs. These designs are prone to selection, information and reporting biases. Also problematic is the prevalent use of observational study designs that do not have a control group and do not have standardized criteria for assessment.

In the context of evaluating the literature with respect to CAM use and back pain, it is important to consider all of these potential sources of bias. As we expected, there were some challenges when evaluating methodological quality given the differing designs and outcomes.

## Research Questions

The research questions for this systematic review were developed in conjunction with NCCAM, the stakeholder partner for this research. The focus is to evaluate the utilization of CAM therapies, irrespective of the provider (conventional or alternative) for persons with back pain (BP). The efficacy and safety of the various CAM therapies are not evaluated within this study; rather the focus is on patterns of use and costs. Although, the main interest of this review was utilization within the U.S., patterns from Canada, United Kingdom, Europe, Australia, and New Zealand were also evaluated and compared to those in the U.S.

The findings of this evidence review will assist in identifying research priorities for CAM utilization within the U.S. The questions addressed in this review are as follows:

### What complementary and alternative medicine (CAM) therapies are being used for treatment of persons with back pain in the United States? (overarching question)

1) What is the relative utilization for the different CAM therapies?
  i Does the utilization differ by where the BP is anatomically located (i.e., neck, mid-back, low back)?
  ii Which therapies are used as complementary to conventional care and which are used as alternative?
  iii When more than one therapy is used for back pain, how are these combined?
2) What is the utilization that is recommended by different types of healthcare providers?
  i How do these recommendations compare to the actual utilization reported in studies from question one?
  ii How do the recommended and actual utilization reported differ by CAM practitioner type?
3) What are usual costs for these therapies per treatment and for the prescribed course of treatments?
  i How much of this cost is covered by insurance or included in the insurance health plan?