# Appendix E - Partners and Technical Expert Panel

## Task Order Officer

- Margaret Coopey, R.N., M.G.A., M.P.S.
- Agency for Healthcare Research and Quality

## Partners from The National Center for Complementary and Alternative Medicine

- Partap Khalsa, D.C., Ph.D, DABCO
- National Institute of Health
- The National Center for Complementary and Alternative Medicine

- Richard Nahin, M.D.
- National Institute of Health
- The National Center for Complementary and Alternative Medicine

## Technical Expert Panel

- Heather Boon, B.Sc.Phm., Ph.D.
- Leslie Dan Faculty of Pharmacy
- University of Toronto,
- Toronto, ON

- Brian M. Berman, M.D.
- The Center for Integrative Medicine
- University of Maryland School of Medicine
- Baltimore, MD

- William G. Johnson, Ph.D.
- Director, Center for Health Information and Research
- Arizona State University
- Tempe, Arizona

- Max H. Pittler, M.D., Ph.D.
- Senior Research Fellow
- Peninsula Medical School, Complementary Medicine
- Universities of Exeter & Plymouth
- Exeter, U.K.

- Dugald Seely, N.D., M.Sc.
- Director of Research, Department of Clinical Epidemiology
- Canadian College of Naturopathic Medicine
- Toronto, ON

## Peer Reviewers

- Carlo Ammendolia, D.C., M.Sc., Ph.D.
- Director, Spine Clinic, Mount Sinai Hospital
- Assistant Professor, Department of Health Policy, Management and Evaluation
- University of Toronto
- Toronto, ON

- Tim Carey, M.D., M.P.H
- Sheps Center for Health Services Research
- University of North Carolina, Chapel Hill
- Chapel Hill, NC

- Dan Cherkin, Ph.D
- Senior Scientific Investigator
- Group Health Center for Health Studies
- Seattle, WA 98101

- Andrea D. Furlan, M.D., Ph.D.
- Assistant Professor, Division of Psychiatry, Department of Medicine, University of Toronto
- Associate Scientist, Institute for Work & Health
- Clinician-scientist, Toronto Rehabilitation Institute
- Toronto, ON

- Maria A. Hondras, D.C., M.P.H.
- Associate Professor
- Palmer Center for Chiropractic Research
- Davenport, IA

- Dugald Seely, N.D., M.Sc.
- Director of Research
- Department of Clinical Epidemiology
- Canadian College of Naturopathic Medicine
- Toronto, ON