# Appendix D - Excluded Studies

## References

1 Ammendolia C, Bombardier C, Hogg-Johnson S, et al. Views on radiography use for patients with acute low back pain among chiropractors in an Ontario community. J Manipulative Physiol Ther. Oct. 2002;25(8):511-20. Exclusion: CAM, but not utilization or cost. [pmid: 12381973].
2 Arokoski JP, Juntunen M, Luikku J. Use of health-care services, work absenteeism, leisure-time physical activity, musculoskeletal symptoms and physical performance after vocationally oriented medical rehabilitation-description of the courses and a one-and-a-half-year follow-up study with farmers, loggers, police officers and hairdressers. Int J Rehabil Res. Jun. 2002;25(2):119-31. Exclusion: CAM, but not utilization or cost. [pmid: 12021598].
3 Bakker C, Hidding A, van der Linden S, et al. Cost effectiveness of group physical therapy compared to individualized therapy for ankylosing spondylitis. A randomized controlled trial. J Rheumatol. Feb. 1994;21(2):264-8. Exclusion: CAM, but not utilization or cos. [pmid: 8182635].
4 Boudreau LA, Busse JW, McBride G. Chiropractic services in the Canadian Armed Forces: a pilot project. Mil Med. Jun. 2006;171(6):572-6. Exclusion: CAM, but not utilization or cost. [pmid: 16808144].
5 Boylan M. Massage found to be best non-drug treatment in spinal cord injuries pain. Journal of the Australian Traditional Medicine Society. Jun. 2005;11(2):75. Exclusion CAM but not utilization or cost.
6 Brealey S, Burton K, Coulton S, et al. UK Back pain Exercise And Manipulation (UK BEAM) trial—national randomised trial of physical treatments for back pain in primary care: objectives, design and interventions [ISRCTN32683578]. BMC Health Serv Res. Aug. 2003;3(1):16. Exclusion: CAM, but not utilization or cost. [pmid: 12892566]. [pmcid: 194218].
7 Breen A, Carr E, Mann E, et al. Acute back pain management in primary care: a qualitative pilot study of the feasibility of a nurse-led service in general practice. J Nurs Manag. May. 2004;12(3):201-9. Exclusion: Not CAM. [pmid: 15089958].
8 Brinkhaus B, Witt CM, Jena S, et al. Interventions and physician characteristics in a randomized multicenter trial of acupuncture in patients with low-back pain. J Altern Complement Med. Sep. 2006;12(7):649-57. Exclusion: CAM, but not utilization or cos. [pmid: 16970535].
9 Buechler JL. Religious and spiritual coping patterns among individuals with chronic low back pain [Dissertation Abstract 2004-99014-078] 2004.. Exclusion: Full text not available.
10 Cardenas DD, Jensen MP. Treatments for chronic pain in persons with spinal cord injury: A survey study. J Spinal Cord Med. 2006;29(2):109-17. Exclusion: CAM, but not utilization or cost. [pmid: 16739554]. [pmcid: 1864800].
11 Carey TS, Garrett J. Patterns of ordering diagnostic tests for patients with acute low back pain. The North Carolina Back Pain Project. Ann Intern Med. Nov 15. 1996;125(10):807-14. Exclusion: CAM, but not utilization or cost. [pmid: 8928987].
12 Carey TS, Garrett JM, Jackman AM. Beyond the good prognosis. Examination of an inception cohort of patients with chronic low back pain. Spine. Jan. 2000;25(1):115-20. Exclusion: CAM, but not utilization or cost. [pmid: 10647169].
13 Carey TS, Garrett JM. The relation of race to outcomes and the use of health care services for acute low back pain. Spine. Feb 15. 2003;28(4):390-4. Exclusion: CAM, but not utilization or cost. [pmid: 12590217].
14 Chaudhary N, Longworth S, Sell PJ. Management of mechanical low back pain - A survey of beliefs and attitudes in GPs from Leicester and Nottingham. Eur J Gen Pract. 2004;10(2):71-2. Exclusion: CAM, but not utilization or cost. [pmid: 15232529].
15 Chiradejnant A, Latimer J, Maher PCG. Forces applied during manual therapy to patients with low back pain. J Manipulative Physiol Ther. 2002;25(6):362-9. Exclusion: CAM, but not utilization or cost. [pmid: 12183694].
16 Chrubasik S, Kunzel O, Black A, et al. Potential economic impact of using a proprietary willow bark extract in outpatient treatment of low back pain: an open non-randomized study. Phytomedicine. Jul. 2001;8(4):241-51. Exclusion: Non-USA only costs. [pmid: 11515713].
17 Cote P, Clarke J, Deguire S, et al. Chiropractors and return-to-work: the experiences of three Canadian focus groups. J Manipulative Physiol Ther. Jun. 2001;24(5):309-16. Exclusion: CAM, but not utilization or cost. [pmid: 11416820].
18 Crasilneck HB. The use of the Crasilneck Bombardment Technique in problems of intractable organic pain. Am J Clin Hypn. Apr. 1995;37(4):255-66. Exclusion: CAM, but not utilization or cost. [pmid: 7741081].
19 Dagenais S, Ogunseitan O, Haldeman S, et al. Side effects and adverse events related to intraligamentous injection of sclerosing solutions (prolotherapy) for back and neck pain: A survey of practitioners. Arch Phys Med Rehabil. Jul. 2006;87(7):909-13. Exclusion: CAM, but not utilization or cost. [pmid: 16813776].
20 Drivdahl CE, Miser WF. The use of alternative health care by a family practice population. J Am Board Fam Pract. May. 1998;11(3):193-9. Exclusion: Full text not available. [pmid: 9625510].
21 Dunn AS, Towle JJ, McBrearty P, et al. Chiropractic consultation requests in the Veterans Affairs Health Care System: demographic characteristics of the initial 100 patients at the Western New York medical center. J Manipulative Physiol Ther. Jul. 2006;29(6):448-54. Exclusion: CAM, but not utilization or cost. [pmid: 16904490].
22 Eisenberg DM, Kessler RC, Van Rompay MI, et al. Perceptions about complementary therapies relative to conventional therapies among adults who use both: Results from a national survey. Ann Intern Med. 2001;135(5):344-51. Exclusion: Views presented not on topic of CAM for back pain. [pmid: 11529698].
23 Ernst E, Pittler MH. Experts' opinions on complementary/alternative therapies for low back pain. J Manipulative Physiol Ther. Feb. 1999;22(2):87-90. Exclusion: Views presented not on topic of CAM for back pain. [pmid: 10073623].
24 Evans RL, Maiers MJ, Bronfort G. What do patients think? Results of a mixed methods pilot study assessing sciatica patients' interpretations of satisfaction and improvement. J Manipulative Physiol Ther. Oct. 2003;26(8):502-9. Exclusion: CAM, but not utilization or cost. [pmid: 14569216].
25 Falkenbach A, Herold M. Unconventional medicine in Central Europe: a misuse of public health insurance?. J Altern Complement Med. Oct. 1999;5(5):479-81. Exclusion: CAM, but not utilization or cost. [pmid: 10537248].
26 Ferrari R, Russell AS. Survey of general practitioner, family physician, and chiropractor's beliefs regarding the management of acute whiplash patients. Spine. Oct 1. 2004;29(19):2173-7. Exclusion: Views presented not on topic of CAM for back pain. [pmid: 15454712].
27 Foster NE, Thompson KA, Baxter GD, et al. Management of nonspecific low back pain by physiotherapists in Britain and Ireland. A descriptive questionnaire of current clinical practice. Spine. Jul 1. 1999;24(13):1332-42. Exclusion: Views presented not on topic of CAM for back pain. [pmid: 10404576].
28 French H. Management of low back pain in a physiotherapy setting: a retrospective audit of practice. Physiotherapy Ireland. Dec. 2006;27(2):3-12. Exclusion: Views presented not on topic of CAM for back pain.
29 Gatchel RJ, Polatin PB, Noe C, et al. Treatment- and cost-effectiveness of early intervention for acute low-back pain patients: A one-year prospective study. J Occup Rehabil. 2003;13(1):1-9. Exclusion: CAM, but not utilization or cost. [pmid: 12611026].
30 Gordon N, Sobel D. Use of and Interest in Complementary and Alternative Therapies Among Clinicians and Adult Members of the Kaiser Permanente Northern California Region: Results of a 1996 Survey. The Permanente Journal. 1999;3(2):44-55. Exclusion: Views presented not on topic of CAM for back pain.
31 Haas M. Evaluation of physiotherapy using cost-utility analysis. Aust J Physiother. 1993;39(3):211-6. Exclusion: CAM, but not utilization or cost.
32 Hart LG, Deyo RA, Cherkin DC. Physician office visits for low back pain: Frequency, clinical evaluation, and treatment patterns from a U.S. National survey. Spine. 1995;20(1):11-9. Exclusion: CAM, but not utilization or cost. [pmid: 7709270].
33 Hatten AL, Gatchel RJ, Polatin PB, et al. A cost-utility analysis of chronic spinal pain treatment outcomes: Converting SF-36 data into quality-adjusted life years. Clin J Pain. 2006;22(8):700-11. Exclusion: CAM, but not utilization or cost. [pmid: 16988566].
34 Haythornthwaite JA, Wegener S, Benrud-Larson L, et al. Factors associated with willingness to try different pain treatments for pain after a spinal cord injury. Clin J Pain. Jan. 2003;19(1):31-8. Exclusion: Views presented not on topic of CAM for back pain. [pmid: 12514454].
35 Head K, Westaway M, Stratford P. The use of cervical spince manipulations amount Fellows of the The Canadian Academy of Manipulation Therapy. Orthopaedic Division Review 2004; 11–7. Exclusion: Views presented not on topic of CAM for back pain.
36 Hemmila HM. Quality of life and cost of care of back pain patients in Finnish general practice. Spine. Mar 15. 2002;27(6):647-53. Exclusion: Non-USA only costs. [pmid: 11884913].
37 Hemsley S, Broadhurst N, Colquhoun J. Low back pain in mineral sand mine workers. Incidence and management. Aust Fam Physician. Jun. 1998;27(6):503-7. Exclusion: CAM, but not utilization or cost. [pmid: 9648318].
38 Hermoni D, Borkan JM, Pasternak S, et al. Doctor-patient concordance and patient initiative during episodes of low back pain. Br J Gen Pract. Oct. 2000;50(459):809-10. Exclusion: CAM, but not utilization or cost. [pmid: 11127171]. [pmcid: 1313822].
39 Hertzman-Miller RP, Morgenstern H, Hurwitz EL, et al. Comparing the satisfaction of low back pain patients randomized to receive medical or chiropractic care: results from the UCLA low-back pain study. Am J Public Health. Oct. 2002;92(10):1628-33. Exclusion: CAM, but not utilization or cost. [pmid: 12356612]. [pmcid: 1447298].
40 Hessell BW, Herzog W, Conway PJ, et al. Experimental measurement of the force exerted during spinal manipulation using the Thompson technique. J Manipulative Physiol Ther. Oct. 1990;13(8):448-53. Exclusion: CAM, but not utilization or cost. [pmid: 2146356].
41 Hillman M, Wright A, Rajaratnam G, et al. Prevalence of low back pain in the community: implications for service provision in Bradford, UK. J Epidemiol Community Health. Jun. 1996;50(3):347-52. Exclusion: CAM, but not utilization or cost. [pmid: 8935469]. [pmcid: 1060294].
42 Hoeijenbos M, Bekkering T, Lamers L, et al. Cost-effectiveness of an active implementation strategy for the Dutch physiotherapy guideline for low back pain. Health Policy. 2005;75(1):85-98. Exclusion: CAM, but not utilization or cost. [pmid: 16298231].
43 Huge V, Schloderer U, Steinberger M, et al. Impact of a functional restoration program on pain and health-related quality of life in patients with chronic low back pain. Pain Med. Nov. 2006;7(6):501-8. Exclusion: Not CAM. [pmid: 17112363].
44 Jackson JL, Browning R. Impact of national low back pain guidelines on clinical practice. South Med J. 2005;98(2):139-43. Exclusion: CAM, but not utilization or cost. [pmid: 15759941].
45 Jay TC, Jones SL, Coe N, et al. A chiropractic service arrangement for musculoskeletal complaints in industry: A pilot study. Occup Med. 1998;48(6):389-95. Exclusion: CAM, but not utilization or cost.
46 Jensen IB, Bergstrom G, Ljungquist T, et al. A 3-year follow-up of a multidisciplinary rehabilitation programme for back and neck pain. Pain. Jun. 2005;115(3):273-83. Exclusion: CAM, but not utilization or cost. [pmid: 15911154].
47 Kalauokalani D, Cherkin DC, Sherman KJ. A comparison of physician and nonphysician acupuncture treatment for chronic low back pain. Clin J Pain. Sep. 2005;21(5):406-11. Exclusion: Views presented not on topic of CAM for back pain. [pmid: 16093746].
48 Kent P, Keating J. Do primary-care clinicians think that nonspecific low back pain is one condition?. Spine. May 1. 2004;29(9):1022-31. Exclusion: CAM, but not utilization or cost. [pmid: 15105677].
49 Koes BW, van Tulder MW, Ostelo R, et al. Clinical guidelines for the management of low back pain in primary care: an international comparison. Spine. 2001;26(22):2504-13. Exclusion: Practice Guideline not on topic. [pmid: 11707719].
50 Koleck M, Mazaux JM, Rascle N, et al. Psycho-social factors and coping strategies as predictors of chronic evolution and quality of life in patients with low back pain: a prospective study. Eur J Pain. Jan. 2006;10(1):1-11. Exclusion: CAM, but not utilization or cost. [pmid: 16291293].
51 Kolt GS, McEvoy JF. Adherence to rehabilitation in patients with low back pain. Manual Ther. May. 2003;8(2):110-6. Exclusion: Not CAM.
52 Korthals-de Bos IB, Hoving JL, van Tulder MW, et al. Cost effectiveness of physiotherapy, manual therapy, and general practitioner care for neck pain: economic evaluation alongside a randomised controlled trial. BMJ (Clinical research ed). Apr. 2003;326(7395):911. Exclusion Non-USA only costs.
53 Kukurin GW. Chiropractic vs. medical management of work-related back injuries: cost comparison studies of workers compensation cases. Dig Chiropractic Econ. Jan. 1995;37(4):28-34. Exclusion: Full text not available.
54 Kumar K, Malik S, Demeria D. Treatment of chronic pain with spinal cord stimulation versus alternative therapies: cost-effectiveness analysis. Neurosurgery. Jun. 51. 115(1):106-15. Exclusion: Non-USA only costs.
55 Lansinger B, Nordholm L, Sivik T. Characteristics of low back pain patients who do not complete physiotherapeutic treatment. Scand J Caring Sci. 1994;8(3):163-7. Exclusion: CAM, but not utilization or cost. [pmid: 7724924].
56 Leboeuf-Yde C, Hennius B, Rudberg E, et al. Chiropractic in Sweden: a short description of patients and treatment. J Manipulative Physiol Ther. Oct. 1997;20(8):507-10. Exclusion: CAM, but not utilization or cost. [pmid: 9345678].
57 Linde K, Witt CM, Streng A, et al. The impact of patient expectations on outcomes in four randomized controlled trials of acupuncture in patients with chronic pain. Pain. Apr. 2007;128(3):264-71. Exclusion: CAM, but not utilization or cost. [pmid: 17257756].
58 Lloyd A, Scott DA, Akehurst RL, et al. Cost-effectiveness of low-level heat wrap therapy for low back pain. Value Health. Jul. 2004;7(4):413-22. Exclusion: Non-USA only costs. [pmid: 15449633].
59 Lorig KR, Laurent DD, Deyo RA, et al. Can a Back Pain E-mail Discussion Group improve health status and lower health care costs?: A randomized study. Arch Intern Med. Apr 8. 2002;162(7):792-6. Exclusion: CAM, but not utilization or cost. [pmid: 11926853].
60 MacPherson H, Thorpe L, Thomas K. Beyond needling—therapeutic processes in acupuncture care: a qualitative study nested within a low-back pain trial. J Altern Complement Med. Nov. 2006;12(9):873-80. Exclusion: CAM, but not utilization or cost. [pmid: 17109578].
61 Maddison P, Jones J, Breslin A, et al. Improved access and targeting of musculoskeletal services in northwest Wales: Targeted early access to musculoskeletal services (TEAMS) programme. Br Med J. 2004;329(7478):1325-7. Exclusion: CAM, but not utilization or cost. [pmid: 15576743]. [pmcid: 534845].
62 Manca A. United Kingdom back pain exercise and manipulation (UK BEAM) randomised trial: Cost effectiveness of physical treatments for back pain in primary care. Br Med J. 2004;329(7479):1381-5. Exclusion: Non-USA only costs. [pmid: 15556954]. [pmcid: 535455].
63 Manca A, Epstein DM, Torgerson DJ, et al. Randomized trial of a brief physiotherapy intervention compared with usual physiotherapy for neck pain patients: cost-effectiveness analysis. Int J Technol Assess Health Care. 2006;22(1):67-75. Exclusion: Non-USA only costs. [pmid: 16673682].
64 Manca A, Dumville JC, Torgerson DJ, et al. Randomized trial of two physiotherapy interventions for primary care back and neck pain patients: cost effectiveness analysis. Rheumatology (Oxford). Sep. 2007;46(9):1495-501. Exclusion: CAM, but not utilization or cost. [pmid: 17711873].
65 Matheis EN, Tulsky DS, Matheis RJ. The Relation Between Spirituality and Quality of Life Among Individuals With Spinal Cord Injury. Rehabil Psychol. Aug. 2006;51(3):265-71. Exclusion: CAM, but not utilization or cost.
66 McIntosh G, Mayo MC, Stymiest PJ. Implementing CQI: measuring levels of service quality at physiotherapy clinics. Physiother Can. 1994;46(3):178-89. Exclusion: CAM, but not utilization or cost. [pmid: 10142881].
67 Mehling WE. The experience of breath as a therapeutic intervention - psychosomatic forms of breath therapy. A descriptive study about the actual situation of breath therapy in Germany, its relation to medicine, and its application in patients with back pain. Forsch Komplementarmed Klass Naturheilkd. Dec. 2001;8(6):359-67. Exclusion: CAM, but not utilization or cost. [pmid: 11799304].
68 Moffett JK, Torgerson D, Bell-Syer S, et al. Randomised controlled trial of exercise for low back pain: clinical outcomes, costs, and preferences. BMJ. Jul. 1999;319(7205):279-83. Exclusion: CAM, but not utilization or cost. [pmid: 10426734]. [pmcid: 28176].
69 Moffett JK, Jackson DA, Gardiner ED, et al. Randomized trial of two physiotherapy interventions for primary care neck and back pain patients: ‘McKenzie’ vs brief physiotherapy pain management. Rheumatology (Oxford). 2006;45(12):1514-21. Exclusion: CAM, but not utilization or cost. [pmid: 17062645].
70 Morlock RJ, Lafata JE, Nerenz D, et al. Expectations, outcomes, and medical costs in patients with low back pain referred to physical therapy. Disease Management. 2002;5(4):185-8. Exclusion: CAM, but not utilization or cost.
71 Mortimer M, Ahlberg G. MUSIC-Norrtalje Study Group. To seek or not to seek? Care-seeking behaviour among people with low-back pain. Scand J Public Health. 2003;31(3):194-203. Exclusion: CAM, but not utilization or cost. [pmid: 12850973].
72 National Guideline Clearinghouse (NGC). Guideline Summary: Acute low back pain. In: National Guideline Clearinghouse (NGC). [http://www.guideline.gov/summary/summary.aspx?ss=15&doc_id=4112&nbr=3157]. Rockville (MD): [cited 2008]. Available at: http://www.guideline.gov. Exclusion: Practice Guideline not on topic.
73 National Guideline Clearinghouse (NGC). Guideline Summary: Primary care interventions to prevent low back pain in adults: recommendation statement. In: National guideline Clearinghouse (NGC). [http://www.guideline.gov/summary/summary.aspx?doc_id=4772]. Rockville (MD); [cited 2008]. Available at: http://www.guideline.gov. Exclusion: Practice Guideline not on topic.
74 National Guideline Clearinghouse (NGC). Guideline Summary: Chronic neck pain. In: National Guideline Clearinghouse (NGC). [http://www.guideline.gov/summary/summary.aspx?doc_id=8297]. Rockville (MD): [cited 2008]. Available at: http://www.guideline.gov. Exclusion: Practice Guideline not on topic.
75 National Guideline Clearinghouse (NGC). Guideline Summary: Clinical practice guidelines for acupuncture. In: National Guideline Clearinghouse (NGC). [http://www.guideline.gov/summary/summary.aspx?doc_id=9921]. Rockville (MD): [cited 2008]. Available at: http://www.guideline.gov. Exclusion: Practice Guideline not on topic.
76 National Guideline Clearinghouse (NGC). Guideline Summary: Clinical practice guidelines for biofeedback. In: National Guideline Clearinghouse (NGC). [http://www.guideline.gov/summary/summary.aspx?doc_id=9912]. Rockville (MD): [cited 2008]. Available at: http://www.guideline.gov. Exclusion: Practice Guideline not on topic.
77 National Guideline Clearinghouse (NCG). Guideline Summary: Clinical Practice Guidelines for Electrical Stimulation. In: National Guideline Clearinghouse (NGC). [http://www.guideline.gov/summary/summary.aspx?doc_id=9918]. Rockville (MD): [cited 2008]. Available at: http://www.guideline.gov. Exclusion: Practice Guideline not on topic.
78 National Guideline Clearinghouse (NGC). Guideline Summary: Interventional techniques: evidence-based practice guidelines in the management of chronic spinal pain. In: National Guideline Clearinghouse (NGC). [http://www.guideline.gov/summary/summary.aspx?ss=15&doc_id=10531&nbr=5510]. Rockville (MD): [cited 2008]. Available at: http://www.guideline.gov.Exclusion: Practice Guideline not on topic.
79 Neher JO, Borkan JM, Wilkinson MJ, et al. Doctor-patient discussions of alternative medicine for back pain. Scand J Prim Health Care. Dec. 2001;19(4):237-40. Exclusion: Views presented not on topic of CAM for back pain. [pmid: 11822647].
80 Nelson CF, Metz RD, LaBrot T. Effects of a managed chiropractic benefit on the use of specific diagnostic and therapeutic procedures in the treatment of low back and neck pain. J Manipulative Physiol Ther. Oct. 2005;28(8):564-9. Exclusion: CAM, but not utilization or cost. [pmid: 16226623].
81 Niemisto L, Rissanen P, Sarna S, et al. Cost-effectiveness of combined manipulation, stabilizing exercises, and physician consultation compared to physician consultation alone for chronic low back pain: a prospective randomized trial with 2-year follow-up. Spine. 2005;30(10):1109-15. Exclusion: CAM, but not utilization or cost. [pmid: 15897822].
82 Nyiendo J, Haas M, Goldberg B, et al. Pain, disability, and satisfaction outcomes and predictors of outcomes: a practice-based study of chronic low back pain patients attending primary care and chiropractic physicians. J Manipulative Physiol Ther. Sep. 2001;24(7):433-9. Exclusion: CAM, but not utilization or cost. [pmid: 11562650].
83 Orthopaedic Division CPA. Clinical Practice Guideline on the Use of Manipulation or Mobilization in the Treatment of Adults with Mechanical Neck Disorders. Orthopaedic Division Review. 2007;(1). 37–38. Exclusion: Full text not available.
84 Piccininni JJ, Vernon HT. Self-directed patient education in soft-tissue rehabilitation: rationale and analysis of a pilot project. J Manipulative Physiol Ther. Jan. 1997;20(1):41-6. Exclusion: CAM, but not utilization or cost. [pmid: 9004121].
85 Poitras S, Blais R, Swaine B, et al. Management of work-related low back pain: a population-based survey of physical therapists. Phys Ther. Nov. 2005;85(11):1168-81. Exclusion: Not CAM. [pmid: 16253046].
86 Ratcliffe J, Thomas KJ, MacPherson H, et al. A randomised controlled trial of acupuncture care for persistent low back pain: Cost effectiveness analysis. BMJ. Sep. 2006;333(7569):1. Exclusion Non-USA only costs. [pmid: 16809674]. [pmcid: 1488733].
87 Rijken PM, Dekker J. Clinical experience of rehabilitation therapists with chronic diseases: a quantitative approach. Clin Rehabil. Apr. 1998;12(2):143-50. Exclusion: CAM, but not utilization or cost. [pmid: 9619656].
88 Rintala DH, Hart KA, Priebe MM. Pain in persons with spinal cord injury at two points in time: utilization of health care and lifestyle changes... Reprinted from Vol 17 #4, 2004. SCI Psychosocial Process. 2005;18(4):280-91. Exclusion: CAM, but not utilization or cost.
89 Rivero-Arias O, Campbell H, Gray A, et al. Surgical stabilisation of the spine compared with a programme of intensive rehabilitation for the management of patients with chronic low back pain: Cost utility analysis based on a randomised controlled trial. Br Med J. 2005;330(7502):1239-43. Exclusion: CAM, but not utilization or cost. [pmid: 15911536]. [pmcid: 558091].
90 Schweikert B, Jacobi E, Seitz R, et al. Effectiveness and cost-effectiveness of adding a cognitive behavioral treatment to the rehabilitation of chronic low back pain. J Rheumatol. Dec. 2006;33(12):2519-26. Exclusion: CAM, but not utilization or cost. [pmid: 17143986].
91 Sharma R, Haas M, Stano M. Patient attitudes, insurance, and other determinants of self-referral to medical and chiropractic physicians. Am J Public Health. Dec. 2003;93(12):2111-7. Exclusion: CAM, but not utilization or cost. [pmid: 14652343]. [pmcid: 1448161].
92 Shekelle PG, Coulter I, Hurwitz EL, et al. Congruence between decisions to initiate chiropractic spinal manipulation for low back pain and appropriateness criteria in North America. Ann Intern Med. Jul 1. 1998;129(1):9-17. Exclusion: CAM, but not utilization or cost. [pmid: 9653012].
93 Sherman KJ, Hogeboom CJ, Cherkin DC. How traditional Chinese medicine acupuncturists would diagnose and treat chronic low back pain: results of a survey of licensed acupuncturists in Washington State. Complement Ther Med. Sep. 2001;9(3):146-53. Exclusion: Views presented not on topic of CAM for back pain. [pmid: 11926428].
94 Sierpina V, Levine R, Astin J, et al. Use of mind-body therapies in psychiatry and family medicine faculty and residents: attitudes, barriers, and gender differences. Explore. Mar. 2007;3(2):129-35. Exclusion: Views presented not on topic of CAM for back pain. [pmid: 17362848].
95 Sigrell H. Expectations of chiropractic treatment: what are the expectations of new patients consulting a chiropractor, and do chiropractors and patients have similar expectations?. J Manipulative Physiol Ther. Jun. 2002;25(5):300-5. Exclusion: CAM, but not utilization or cost. [pmid: 12072850].
96 Skaggs CD, Prather H, Gross G, et al. Back and pelvic pain in an underserved United States pregnant population: a preliminary descriptive survey. J Manipulative Physiol Ther. Feb. 2007;30(2):130-4. Exclusion: CAM, but not utilization or cost. [pmid: 17320734].
97 Skargren EI, Oberg BE, Carlsson PG, et al. Cost and effectiveness analysis of chiropractic and physiotherapy treatment for low back and neck pain. Six-month follow-up. Spine. Sep. 1997;22(18):2167-77. Exclusion: Non-USA only costs. [pmid: 9322328].
98 Skargren EI, Carlsson PG, Oberg BE. One-year follow-up comparison of the cost and effectiveness of chiropractic and physiotherapy as primary management for back pain. Subgroup analysis, recurrence, and additional health care utilization. Spine. 1998;23(17):1875-83. Exclusion: Non-USA only costs. [pmid: 9762745].
99 Spaeth DG, Pheley AM. Use of osteopathic manipulative treatment by Ohio osteopathic physicians in various specialties. J Am Osteopath Assoc. 2003;103(1):16-26. Exclusion: Views presented not on topic of CAM for back pain. [pmid: 12572632].
100 Stuber K. The safety of chiropractic during pregnancy: A pilot e-mail survey of chiropractors opinions. Clin Chiro. Mar. 2007;10(1):24-35. Exclusion: Views presented not on topic of CAM for back pain.
101 Sullivan MS. Outcomes and costs of health care for low back pain: a comparison of treatment among provider types. [Doctoral Dissertation abstract]. Richmond, Virginia: Virginia Commonwealth University. 1997. Exclusion Full text not available.
102 Swartzman LC, Harshman RA, Burkell J, et al. What accounts for the appeal of complementary/alternative medicine, and what makes complementary/ alternative medicine “alternative”?. Med Decis Making. Sep. 2002;22(5):431-50. Exclusion: Views presented not on topic of CAM for back pain. [pmid: 12365485].
103 Thomas KJ, MacPherson H, Ratcliffe J et al. Longer term clinical and economic benefits of offering acupuncture care to patients with chronic low back pain. Health Technology Assessment 2005, Vol 9 (32). Kent, U.K.: HTA Programme, Project Number 96/40/07. Exclusion: Non-USA only costs.
104 Thompson E, Barron S, Spence D. A preliminary audit investigating remedy reactions including adverse events in routine homeopathic practice. Homeopathy. 2004;93(4):203-9. Exclusion: CAM, but not utilization or cost. [pmid: 15532700].
105 Torstensen TA, Ljunggren AE, Meen HD, et al. Efficiency and costs of medical exercise therapy, conventional physiotherapy, and self-exercise in patients with chronic low back pain. A pragmatic, randomized, single-blinded, controlled trial with 1-year follow-up. Spine. Dec. 1998;23(23):2616-24. Exclusion: Non-USA only costs. [pmid: 9854761].
106 Underwood MR, Vickers MR, Barnett AG. Availability of services to treat patients with acute low back pain. Br J Gen Pract. Aug. 1997;47(421):501-2. Exclusion: CAM, but not utilization or cost. [pmid: 9302790]. [pmcid: 1313080].
107 van Baar ME, Dekker J, Bosveld W. A survey of physical therapy goals and interventions for patients with back and knee pain. Phys Ther. Jan. 1998;78(1):33-42. Exclusion: Views presented not on topic of CAM for back pain. [pmid: 9442194].
108 van de Veen EA, de Vet HC, Pool JJ, et al. Variance in manual treatment of nonspecific low back pain between orthomanual physicians, manual therapists, and chiropractors. J Manipulative Physiol Ther. Feb. 2005;28(2):108-16. Exclusion: CAM, but not utilization or cost. [pmid: 15800510].
109 van Tubergen A, Boonen A, Landewe R, et al. Cost-effectiveness of combined spa-exercise therapy in ankylosing spondylitis: a randomized controlled trial. Arthritis Care Res. Oct. 2002;47(5):459-67. Exclusion: Non-USA only costs.
110 Verhoef MJ, Page SA, Waddell SC. The Chiropractic Outcome Study: pain, functional ability and satisfaction with care. J Manipulative Physiol Ther. May. 1997;20(4):235-40. Exclusion: CAM, but not utilization or cost. [pmid: 9168407].
111 Westmoreland JL, Williams NH, Wilkinson C, et al. Should your GP be an osteopath? Patients' views of an osteopathy clinic based in primary care. Complement Ther Med. Jun. 2007;15(2):121-7. Exclusion: Views presented not on topic of CAM for back pain. [pmid: 17544863].
112 Whitehurst DG, Lewis M, Yao GL, et al. A brief pain management program compared with physical therapy for low back pain: results from an economic analysis alongside a randomized clinical trial. Arthritis Rheum. Apr 15. 2007;57(3):466-73. Exclusion: Non-USA only costs. [pmid: 17394176].
113 Wiesinger GF, Quittan M, Ebenbichler G, et al. Benefit and costs of passive modalities in back pain outpatients: A descriptive study. Eur J Phys Med Rehabil. 1997;7(6):182-6. Exclusion: CAM, but not utilization or cost.
114 Williams NH, Wilkinson C, Russell I, et al. Randomized osteopathic manipulation study (ROMANS): pragmatic trial for spinal pain in primary care. Fam Pract. Dec. 2003;20(6):662-9. Exclusion: Non-USA only costs. [pmid: 14701889].
115 Williams NH, Edwards RT, Linck P, et al. Cost-utility analysis of osteopathy in primary care: Results from a pragmatic randomized controlled trial. [References]. Fam Pract. Nov. 2004;21(6):643-50. Exclusion: Non-USA only costs. [pmid: 15531626].
116 Willich SN, Reinhold T, Selim D, et al. Cost-effectiveness of acupuncture treatment in patients with chronic neck pain. Pain. Nov. 2006;125(12):107-2. Exclusion: Non-USA only costs. [pmid: 16842918].
117 Witt CM, Jena S, Selim D, et al. Pragmatic randomized trial evaluating the clinical and economic effectiveness of acupuncture for chronic low back pain. Am J Epidemiol. Sep. 2006;164(5):487-96. Exclusion: Non-USA only costs. [pmid: 16798792].
118 Witt CM, Brinkhaus B, Reinhold T, et al. Efficacy, effectiveness, safety and costs of acupuncture for chronic pain - results of a large research initiative. Acupunct Med. Dec. 2006;24(Suppl 1):33-9. Exclusion: Non-USA only costs. [pmid: 16618047].