# Appendix C - Evidence Tables

Appendix Table 1. Characteristics of U.S. clinical practice guidelines specific to back pain evaluated for CAM therapies

Author | Title | Scope | Intended Users | Target Population | Primary Outcomes | CAM therapies/Recommendations
National Guideline Clearinghouse (NGC). Guideline Summary ^1^ 2004 | Neck and upper back complaints | diagnosis evaluation management treatment | - advanced practice nurses; - physician assistants; - physicians utilization management | adults with potentially work-related neck and upper back complaints seen in primary care settings | missed work days | CAM therapies:; - manipulation; - heat or cold; Utilization recommendations: none
National Guideline Clearinghouse American College of Occupational and Environmental Medicine ACOEM^2^ 2004, 2007 | Low back complaints | diagnosis evaluation management treatment | - advanced practice nurses; - physician assistants; - physicians; - physicians utilization management | adults with potentially work-related low back complaints seen in primary care settings | missed work days | CAM therapies:; - manipulation; - heat or cold; - relaxation; Utilization recommendations: none
American College of Physicians (ACP) and the American Pain Society (APS)^3^ 2007 | Diagnosis and treatment of low back pain A joint clinical practice guideline from ACP and APS | diagnosis management treatment | - physicians | adults with acute and chronic low back pain not associated with major trauma note: children or adolescents with low back pain; pregnant women; patients with low back pain from sources outside the back; fibromyalgia or other myofascial pain syndromes; and thoracic or cervical back pain are [underlined: not] included | - sensitivity and specificity of diagnostic tests; - pain reduction; - frequency of side effects from medication; - cost | CAM therapies:; - spinal manipulation; - acupuncture; - massage; - yoga; - progressive relaxation; Utilization recommendations: none
Council of Acupuncture and Oriental Medicine Associates (CAOMA), Foundation for Acupuncture Research^4^ 2004 | Acupuncture and electro-acupuncture evidence-based treatment guidelines | treatment | - health care providers; - health plans; - managed care organizations; - nurses; - patients; - physicians; - utilization management | patients with conditions affecting the neuromusculoskeletal system | - frequency of flare-ups or episodes of pain; - duration of flare-ups or episodes of pain; - sensitivity of pain to triggers and aggravating factors; - incidence of paresthesias and stiffness; - range of motion; - strength and endurance; - amount of bruising, discoloration, scars, swelling, tenderness; - medication and aids use; - frequency of relapse; - incidence of hospital visits or other medical interventions | CAM Therapies:; - electro-acupuncture; Utilization recommendations: recommendations are given for acute, sub-acute, chronic, and recurrent flare-up of conditions, including neck, torso and back problems; - effects of acupuncture are cumulative and as such, a single treatment not usually prescribed; - final frequency and duration of treatments dependent on the condition being treated; - recommend 12 – 18 treatments over a 4 to 6 week period
Institute for Clinical Systems Improvement (ICSI)^5^ 2006 | Adult low back pain | diagnosis evaluation management treatment | - advanced practice nurses; - allied health personnel; - health care providers; - health plans; - hospitals; - managed care organizations; - nurses; - physician assistants; - physicians | adult patients age 18 and over in primary care who have symptoms of low back pain or sciatica Note: guideline focuses on acute and chronic management, including indications for medical non-surgical or surgical referral | - number, duration, and intensity of pain episodes and recurrences; - change in functional status (strength, mobility, endurance) associated with low back pain; - time required to return to work; - utilization of health care resources; - diagnostic accuracy of various imaging techniques including lumbar spine computed tomography, magnetic resonance imaging, computed tomography myelography; - patient satisfaction | CAM Therapies:; - ice; - heat; - manipulation; - mobilization; Utilization recommendations: none
Work Loss Data Institute^6^ 2007 | Low back - lumbar & thoracic (acute & chronic) | diagnosis evaluation management treatment | - advanced practice nurses; - health care providers; - health plans; - nurses; - physician assistants; - physicians | workers with low back pain | reliability and value of diagnostic assessments effectiveness of treatment in relieving pain and restoring normal function | CAM Therapies:; - massage; - chiropractor; - physical therapy; Utilization recommendations: none
Work Loss Data Institute^7^ 2007 | Neck and upper back (acute & chronic) | diagnosis evaluation management treatment | - advanced practice nurses; - health care providers; - health plans; - nurses; - physician assistants; - physicians | workers with occupational disorders of the neck and upper back | - diagnostic value of tests; - effectiveness of treatments for relieving pain and restoring normal function | not reported
Academy for Chiropractic Education ^8^ 2007 | Manual medicine guidelines for musculoskeletal injuries | diagnosis evaluation management rehabilitation treatment | - chiropractors; - health care providers; - health plans; - managed care organizations; - patients; - utilization management | individuals with musculoskeletal injuries | not reported | CAM therapies:; - manual therapy; - manipulation; Utilization recommendations: none
Research Commission of the Council on Chiropractic Guidelines and Practice Parameters^9^ 2007 | Chiropractic management of low back pain and low back related leg complaints | | - chiropractors; - chiropractic students and prospective students; - chiropractic educators; - educational institutions; - chiropractic organizations; - third-party payers; - governmental agencies; - patients and prospective patients | | extent and quality of the evidence for or against the use of spinal manipulation/mobilization, physical activity and exercise for treatment of low back pain | CAM therapies:; - manipulation; Utilization recommendations: none
Council on chiropractic practice^10^ 2003 | Vertebral subluxation in chiropractic practice | focused on specific modality in chiropractic | - chiropractors | chiropractors | | CAM Therapies:; - chiropractic; Utilization recommendations: none
California Health Benefits Review Program^11^ 2004 | Report to the 2007-2008 California State Legislature Analysis of Assembly Bill 54 Health Care Coverage: Acupuncture | an analysis of the medical, financial, and public health impacts of Assembly Bill 54, a bill to mandate coverage for group contract holders for expenses incurred as the result of treatment by licensed acupuncturists | - policy makers | policy makers | - medical effectiveness of acupuncture; - cost; - utilization; - public health impacts | CAM Therapies:; - acupuncture; Utilization recommendations: none

Appendix Table 2. Agree scoring for CPG of Electro-acupuncture and utilization

AGREE Question | Final rating | Subscale Score
1 | 4
2 | 2
3 | 3 | 9 / 12
4 | 1
5 | 1
6 | 4 | 6/ 12
7 | 1
8 | 4
9 | 4
10 | 4
11 | 4
12 | 4
13 | 3
14 | 1 | 25 / 32
15 | 3
16 | 2
17 | 4
18 | 1 | 9 / 16
19 | 4
20 | 3
21 | 1 | 8 / 12
22 | 1
23 | 1
24 | Recommend with Provisos

Appendix Table 3. Study characteristics and results for U.S. studies evaluating costs for CAM services in persons with low back pain

Author Year | Study Design (SD) Cost Study (CS) Back Pain (BP) Sample Size (SS) | Payer Cost Perspective Health Outcomes Adverse Events | Direct costs: Indirect costs: | Other Findings With: Insurance Coverage
Carey^12^ 1995 | SD: SGPS June 1992 to March 1993 CS: CID BP: ALBP less than 10 weeks duration and no previous treatment SS: Total: 1,633 310 (urban) 296 (rural) saw D.C. | Payer: Medicaid, Medicare, HMO, workers' compensation Cost perspective: public and private insurance payer Health Outcomes: baseline measures only Adverse Events: not evaluated | Direct costs: (costs in 1995 USD) Outpatient costs per episode of LBP including: 1) visits, 2) X-rays & other imaging, 3) medications, 4) PT, 5) Other (D.C.) Data on the charges for outpatient services was based average state wide charges assigned by a large health insurance carrier Mean Total Costs: Urban D.C.: $808 (95% CI 717–900) Rural D.C.: $554 (95% CI 461–648) Urban PCP: $478 (95% CI 381–575) Rural PCP: $540 (95% CI 455–625) OS: $809 (95% CI 688–930) Adjusted for baseline function Mean Costs: Urban D.C.: $783 (95% CI 698–868) Rural D.C.: $661 (95% CI 524–698) Urban PCP: $508 (95% CI 418–598) Rural PCP: $474 (95% CI 394–555) OS: $746 (95% CI 633–858) Indirect costs: not evaluated | highest costs were for patients seen by D.C. (high number of visits and imaging) and OS (high cost of visits and imaging and PT) with lowest costs seen by HMO Insurance Coverage: Urban D.C.= 25% Rural D.C. = 23% Urban PCP = 10% Rural PCP= 13% OS = 38%
Sundararajan^13^ 1998 | SD, CS and BP as above (Carey) SS: from 1,633 enrolled 1,580 (97%) completed 24 week interview | all as above (Carey) | Direct Costs: Logistic Regression model to predict cost for seeing only index provider 19% (95%) of patients visiting D.C. were likely to see other providers Adjusted mean cost for seeing index provider that could include D.C. only index provider $439 >1 index provider $1,137 Indirect costs: not evaluated | Insurance Coverage: not specified
Cherkin^14^ 2003 | SD: RCT November 1993 to September 1995 CS: CID BP: ALBP of at least 7 days from initial M.D. visit SS: D.C. = 122 PT = 133 Educational booklet=66 | Payer:; - study treatments were paid by the study; - non-study treatments were covered by the subjects health insurance with a $5 or $10 co-payment; Cost Perspective: private insurance payer Health Outcomes:; - Roland Disability Scale score; - Bothersome rating; - Satisfaction with care; Adverse Events: not evaluated | Direct costs:; - costs in 1995 USD; - included all costs to the HMO; Costs per unit for visit: (mean cost per subject) D.C.=$28 ($185) PT=$50 ($221) Educational booklet=$1 ($1) Mean costs over a 2 year period D.C.: $429 PT: $437 Educational Booklet: $153 Indirect costs: “Out of pocket expenses” not included | - total costs of care to the HMO over a 2 year period differed by 2% between D.C. and PT; - the educational booklet group costs were approximately half that of either treatment group; - dysfunction was greater in the educational booklet group at endpoint; Seeking additional care other than index provider D.C.=8% PT=9% Educational booklet =18% Insurance Coverage not applicable
Eisenburg^15^ 2007 | SD: RCT April 2001 to July 2003 CS: CID (data for CEA) BP: ALBP less than 21 days with a score of 3 or greater on a pain scale from 0 to 10 SS: Usual Care = 148 Choice Care = 296 | Payer: Harvard Pilgrim Healthcare and Harvard Vanguard Medical Associates (data from electronic medical record, pharmacy, and claims database First 10 visits did not require co-payment; visits 11 to 15 required 50% co-payment Cost perspective: private insurance payer Health Outcomes:; - Roland Disability Scale score; - Bothersome rating; - Satisfaction with care; Adverse Events: “Did you have problems with your last treatment” | Direct costs: costs in 2003 USD costs were assigned using the Medicare re-imbursement for encounter and the “Red Book” for prescriptions Average Total costs for treatment: [underlined: 12 weeks Before study enrolment] Usual Care (M.D., NSAIDS, Education) Average cost $393 Median Cost $126 Choice Care (D.C., AT, MT) Average Cost $247 Median Cost $131 ≥ [underlined: 12 weeks after study enrolment] Usual Care Average cost $521 Median cost $207 Choice Care Average cost $476 Median cost $185 Mean reimbursement to provider $343 Median reimbursement to provider $244 Indirect costs: not collected | after controlling for pre-study costs, choice of care group cost $99 less primarily due to a reduction in costs for accessing a conventional provider, resulting in an average $244 increase in patient cost after 12 weeks of treatment patients selected massage over chiropractic all participants covered by private insurance
Haas^16^ 2005 | SD: prospective longitudinal study 1994-1996 CS: CEA BP:; - ALBP; - CLBP > than 7 weeks; SS: 2,827 patients from 69 D.C. and 111 M.D. practices | Payer: Private insurance workers' Compensation Medicaid, Medicare, HMO Cost Perspective: mixed public and private payer; - Health Outcomes:; - SF12; - VAS Pain score; - Oswestry Disability questionnaire; - Satisfaction with care; Adverse Events: “Did you have problems with your last treatment” | Direct costs: Costs in 1995 USD and included the following: Office based visits, and imputed costs for imaging, surgical consultation, and PT Total unadjusted costs: [underlined: 3 months Acute vs Chronic] D.C.=$171 (SD $202) / $180+/- $209 M.D.=$141 (SD $183) / $212 +/- $253 [underlined: 12 months Acute vs Chronic] D.C.=$218+/- $305 / $232+/- $311 M.D.=$176 +/- $245 / $281 +/- $355 [underlined: 3 months Acute vs Chronic] CER1* Pain (MDF=10.5)=$25.7/ $13.5 Disability (MDF=8.8)=$23.8/ $16.1 CER2* Pain (MDF = 10.5)=$11.7/ $0.4 Disability (MDF = 8.8)=10.8/ $$0.5 [underlined: 12 months Acute versus Chronic] CER1* Pain (MDF = 7.3)=$31.2 / $21.6 Disability (MDF = 5.4) = $41.7 / $29.2 CER2* Pain (MDF = 7.3) = $12.0 / $0.1 Disability (MDF = 5.4) = $16.1 / $0.1 Indirect costs: not collected | Relative to M.D. total costs for D.C. were: 22% greater for acute patients 16% less for chronic patients Insurance Coverage D.C. Chronic patients: no insurance = 47% health insurance = 39% workers compensation = 6% Medicaid/Oregon Health plan =3% Insurance Coverage M.D. Chronic patients: no insurance = 6% health insurance = 77% workers compensation = 7% Medicaid/Oregon Health plan = 20% Acute patients D.C.: no insurance = 42% health insurance = 42% workers' Compensation = 7% Medicaid/ Oregon Health plan=1% Acute patients M.D.: no insurance = 8% health insurance = 76% workers' Compensation = 10% Medicaid/Oregon Health plan = 11%
Kominski^17^ 2005 | SD: RCT CS: CID BP: LBP (not on workers compensation) SS: 664/681 (97.5%) completed 28 month follow-up | Payer: HMO Health Outcomes:; - SF36; - Pain scale; Adverse Events: not reported | Direct costs:; - costs expressed as USD (year not specified) for care over 18 months; - costs included charges for diagnostic and therapeutic modalities from any provider PT, low back surgery, injection and other outpatient services; - some patients did have to make co-payments; - pharmaceutical costs were not included; Mean costs per treatment 18 months M.D. = $463 M.D. + PT = $765 D.C. = $550 D.C. + PM =$565 Adjusted mean costs M.D. = $369 M.D. + PT = $760 D.C. = $560 D.C. + PM = $579 Relative cost differences D.C. = 71.8% more expensive than M.D. D.C. + PM = 13.5% more expensive than D.C. M.D. + PT = 114.0% more expensive than M.D. Indirect costs: not collected | PT doubled the amount of care relative to M.D. PM did not affect costs for D.C. Insurance Coverage: all members of HMO
Lind^18^ 2005 | SD: Retrospective database for 2002 CS: CID BP: ALBP and CLBP SS: 104,358/601,044 had back pain and were eligible for study | Payer: private insurer in Washington state Cost Perspective: private insurance payer Health Outcomes: not evaluated Adverse events: not evaluated | Direct costs:; - costs 2002 USD; - costs included maximum allowed amount by the insurance company; - costs may have included visits, and procedures allowed by the insurance company policy; CAM providers consisted of D.C., AT, MT, and ND Per visit: CON: $128 (Sd $173) CAM only: $50 (Sd $28) MIX: $84 (Sd $68) Mean Total Expenditures: CON: $506 (Sd $954) CAM only: $342 (Sd $429) MIX: $1,079 (Sd $1,185) Indirect costs: Not evaluated | CAM users have fewer visits not related to back pain and lower annual costs for all reasons Insurance Coverage all members insured
Nyiendo^19^ 1985 | SD: case control CS: CID BP: Disabling LBP SS: 94 patients D.C. 107 patients M.D. | Payer: workers' compensation in Oregon Cost perspective: payer Health Outcomes: not evaluated Adverse events: not evaluated | Direct costs: Costs in 1985 USD Costs include treatment, diagnostic tests and drugs All cases: % of total costs (D.C. vs M.D.) Office visits: 12.2% vs 13.3% Hospital surgery: NA vs 15.5% Physical therapy: 23.1% vs 18.1% Manipulation: 38.4% vs 0.0% All cases: % of total costs (D.C. vs M.D.) Diagnosis: 7.9% vs 20.2% Treatment: 75.8% vs 66.9% Other: 16.3% vs 12.8 % All cases: Mean dollars per case (D.C. vs M.D.) Diagnostics: $161 vs $258 Treatment: $1,551 vs $854 Medical related: $335 vs $163 Total medical: $2,047 vs $1,275 Indirect costs: not evaluated | all participants on workers compensation
Stano^20^ 2002 | SD: SGPS CS: CID BP: ALBP and CLBP Collected from December 1994 to June 1996 SS: 2,872 patients D.C.: 1,524 M.D.: 739 NRM: 611 RM: 128 | Payer:; - no insurance; - private insurance; - workers compensation; Cost Perspective: payers Health Outcomes: measured at baseline only Adverse events: not evaluated | Direct costs: Costs in 1995 USD Current Procedural Terminology was converted to relative value units for D.C. and M.D. care and 1995 Medicare conversion factor Mean costs per patient D.C. = $214 (Sd $284) M.D. = $123 (SD $128) NRM = $103 (Sd $83) RM = $217 (Sd $228) Indirect costs: not evaluated | Insurance Coverage None/ Insurance / workers' compensation D.C.=42%/ 51%/ 7% NRM=7%/ 86%/ 7% RM=3% / 81%/ 16%
Stano^21^ 1996 | SD: Retrospective database July 1988 to June 1990 CS: CID BP: LBP SS: 43,476 patients based on back ICD codes; from this 6,183 patients and 8,018 episodes of care | Payer: private insurance Cost perspective: payer Health Outcomes: severity of condition or disease staging Adverse events: not evaluated | Direct costs: costs in USD episode of care includes all health services incurred to treat back condition; in some cases this may involve cost associated with other illnesses First episode costs mean total payments D.C. = $518; M.D. = $1,020 First episode costs mean outpatient payments D.C. = $447; M.D. = $598 Multiple Episodes: Mean total payment for first 2 episodes D.C. = $635; M.D. = $1,272 Mean outpatient payments for first 2 episodes D.C. = $658; M.D. = $1,505 Indirect costs: not evaluated | Insurance Coverage; - plans of those evaluated had no D.C. restrictions (76%) or some chiropractic restrictions (24%) with respect to total visit dollars; - database analysis is confounded by this potential restriction; - patients choosing D.C. have higher copayments but disproportionately carry comprehensive rather than basic plus insurance coverage
Smith^22^ 1997 | SD, CS as above (Stano) BP: recurrent LBP SS: initial patients with recurrences 1,215 from 7,077 had recurrent episodes | all as above (Stano) | Direct costs: costs in USD for total payments estimated for persons with recurrent episodes First episode provider Total costs both 1^st^ and 2^nd^ episode D.C. = $1,294; M.D. = $2,778 First and second episode provider D.C. = $1,258; M.D. = $2,390 For patients with 3 episodes of care D.C. = $1,038; M.D. = $3,068 Indirect costs: not evaluated | D.C. episodes exhibit longer contact but not higher costs Insurance Coverage: not applicable, all subjects covered
Wasiak^23^ 1998 | SD: Retrospective database 1999 to 2002 CS: CID SS: 8,894 from 13,734 claimants | Payer: private workers' compensation claims database Cost perspective: payer Health Outcomes: not reported Adverse events: not evaluated | Direct costs:; - costs stratified by year from 1999 to 2002 USD; - costs included visits and all other services performed on the same day and all costs associated with services for chiropractic care; - costs adjusted to constant year dollars using the medical care component of the Consumer Price Index; Mean cost for individual (adjusted for geography) for D.C. for 7 states that range from 1999: $350 to $1,162 2000: $298 to $1,240 2001: $274 to $1,103 2002: $259 to $1,478 Indirect costs: not evaluated | Insurance Coverage: all on workers' compensation
Williams^24^ 1998 | SD: Retrospective database CS: CID BP: CLBP Collected from 1988 to 1992 SS: 520 from 29,056 claimants in 4 states | Payer: workers compensation claim data from the National Council on Compensation Insurance Cost Perspective: payer Health Outcomes: not reported Adverse events: not evaluated | Direct costs:; - costs in USD (year not specified); - lost time injury costs, subdivided by health care services; - costs were presented in terms of duration of work disability for low back pain; D.C. Mean Costs <30 days: $286 (n = 53) 30–90 days: $525 (n = 30) 91–180 days: $396 (n = 14) >180 days: $575 (n = 19) Total: $409 (n = 116) Miscellaneous non medical (AT, MT, other) Mean Costs: <30 days: $138 (n = 138) 30–90 days: $448 (n = 94) 91–180 days: $5,547 (n = 52) >180 days: $10,931 (n = 64) Total: $47,403 (n = 348) PT Mean Costs: <30 days: $358 (n = 124) 30–90 days: $965 (n = 118) 91–180 days: $1,231 (n = 50) >180 days: $2,264 (n = 55) Total: $995 (n = 323) Indirect costs: not evaluated | relative to PT costs (20%), D.C. were a smaller percent of overall costs (3%) miscellaneous costs which could have included massage, acupuncture, education, etc) were also provided; difficult to know what proportion of these are truly CAM Insurance Coverage: all covered by workers' compensation

Abbreviations: ALBP=acute low back pain; AT=Acupuncturist; CEA=cost effectiveness analysis; CER1*=incremental cost effectiveness ratio with adjusted mean difference in outcomes between D.C. and M.D. with office costs used in the numerator; CER2*=incremental cost effectiveness ratio with adjusted mean difference in outcomes between D.C. and M.D. with total costs used in the numerator; CI=confidence interval; CID=Cost identification; CON=Conventional providers; D.C.=Doctor of chiropractic; HMO=health maintenance organization; M.D.=Medical doctor; MDF= MT=Massage Therapist; NRM=non-referred medical; OP=Out Patient OS=Orthopedic Surgeon; PCP=primary care provider; PM=Physical modalities; PT=Physical therapist; RM=Referred medical; Sd=standard deviation; SF=Short Form, SGPS=Single group prospective study; USD=United States Dollars; VAS=visual analog scale

Appendix Table 4. Study characteristics and results for studies evaluating costs for CAM services in persons with unspecified or combined back pain

Author Year | Study Design (SD) Cost Study (CS) Back Pain (BP) Sample Size (SS) | Payer Cost Perspective | Direct Costs / Indirect Costs | Other Findings
Jarvis^25^ 1991 | SD: Retrospective database and chart extraction 1986 CS: CID BP: Combined back pain SS: 3,062 from 7,551 files (40.6%) Comparison: M.D. vs D.C. Stratified by disease code | Payer: workers compensation fund of Utah Cost perspective: payer Health Outcomes: not evaluated Adverse Events: not evaluated | Direct Costs: costs in 1985 USD costs included; care and compensation Compensation costs: M.D. = $668.39 D.C. = $68.38 Costs of care: M.D. = $684.15 D.C. = $526.84 costs stratified by ICD9 code for back pain not presented Indirect Costs not evaluated | - mean number of treatment visits greater for D.C. as were the days of care; - compensation costs were much less for the D.C.; Insurance Coverage: all on workers' compensation
Shekelle^26^ 1995 | SD: SGPS 3 to 5 year interval CS: CID BP: Unspecified back pain SS: 1,020 episodes of care by 686 persons and 8,825 visits Comparison D.C. vs PCP vs OS, vs IT vs OP vs Other | Payer: RAND health insurance Cost perspective: payer Health Outcomes: not reported Adverse Events: not evaluated | Direct Costs costs in 1982 USD Total costs included hospital care, physician services, drugs, services, injections, supplies etc. Mean cost per visit. D.C. = $19.45 (SE, 0.15) PCP = $20.21 (SE 1.93) OS = $38.53 (SE 4.16) IT = $21.85 (SE 1.05) OP = $22.18 (SE0.66) Other = $37.66 (SE 2.16) Mean Total cost per episode D.C. = $281 (95% CI, 242–320) PCP = $120 (95% CI, 89–150) OS = $281 (95% CI, 172–390) IT = $218 (95% CI, 143–294) OP = $280 (95% CI, 59–501) Other = $239 (95% CI, 139–339) Mean Outpatient cost per visit D.C. = $281 (95% CI, 242–320) PCP = $120 (95% CI, 89–150) OS = $281 (95% CI, 172–390) IT = $218 (95% CI, 143–294) OP = $280 (95% CI, 59–501) Other = $239 (95% CI, 139–339) Indirect Costs Not evaluated | Insurance Coverage:; - all families covered by 1 of 14 fee for service health plans; - all plans covered chiropractic
Legoretta^27^ 2004 | SD: Retrospective database 1997 to 2001 CS: CID BP: combined neck and back pain SS: 707,690 with D.C. coverage/1,001,995 without coverage: 141,616 had D.C. coverage and 189,923 no D.C. coverage proportion with back pain alone was not specified | Payer: health care managed network in California Cost perspective: payer Health Outcomes: not evaluated Adverse Events: not evaluated | Direct Costs Costs in USD (year not specified). Costs included:; - outpatient services, imaging methods, lumbar spine surgical procedures, and inpatient stays; - physiotherapy and drug costs were excluded; Total cost per patient over 4 years (all episodes): With coverage for D.C. = $522 Without coverage = $567 Average cost per episode over 4 years: With coverage for D.C. = $289 Without coverage = $399 Indirect Costs: not evaluated | Insurance Coverage direct costs

Abbreviations: CID = cost identification; CS = cost study; D.C. = doctor of chiropractic; IT = internist; MT = massage therapist; NRM = non-referred medical; OP = osteopath; OS= orthopedic surgeon; PCP=primary care physician; PM = physical modalities; PT = physical therapist; RM = referred medical; USD=United States dollars

## Reference List for Appendix C

1 National Guideline Clearinghouse (NGC). Guideline Summary: Neck and Upper Back Complaints. In: National Guideline Clearinghouse (NGC). [http://www.guideline.gov/summary/summary.aspx?doc_id=8542]. Rockville (MD): [cited 2008]. Available at: http://www.guideline.gov
2 Elk Grove Village. Low back complaints. National Guideline Clearinghouse. 2004. http://www.guideline.gov/summary/summary.aspx?doc_id=8546&nbr=4755&ss=6&xl=999
3 National Guideline Clearinghouse (NGC). Guideline Summary. Diagnosis and treatment of low back pain: A joint clinical practice guideline from the American College of Physicians and the American Pain Society. In: National Guideline Clearinghouse (NGC). [http://www.guideline.gov/summary/summary.aspx?doc_id=11515&nbr=005968]. Rockville (MD); [cited 2008]. Available at: http://www.guideline.gov
4 National Guideline Clearinghouse (NGC). Guideline Summary. Acupuncture and electroacupuncture: evidence based treatment guidelines. In: National Guideline Clearinghouse (NGC). [http://www.guideline.gov/summary/summary.aspx?doc_id=9343&nbr=5010&ss=6&xl=999]. Rockville (MD): [cited 2008]. Available at: http://www.guideline.gov
5 National Guideline Clearinghouse (NGC). Guideline Summary: Adult low back pain. In: National Guideline Clearinghouse (NGC). [http://www.guideline.gov/summary/summary.aspx?doc_id=9863]. Rockville (MD): [cited 2008]. Available at: http://www.guideline.gov
6 National Guideline Clearinghouse (NGC). Guideline Summary: Low back - lumbar & thoracic (acute & chronic). In: National Guideline Clearinghouse (NGC). [http://www.guideline.gov/summary/summary.aspx?ss=15&doc_id=11024&nbr=5804]. Rockville (MD): [cited 2008]. Available at: http://www.guideline.gov
7 National Guideline Clearinghouse (NGC). Guideline Summary: Neck and upper back (acute & chronic). In: National Guideline Clearinghouse (NGC). [http://www.guideline.gov/summary/summary.aspx?ss=15&doc_id=11025&nbr=5805]. Rockville (MD): [cited 2008]. Available at: http://www.guideline.gov
8 National Guideline Clearinghouse (NGC). Guideline Summary: Manual medicine guidelines for musculoskeletal injuries. In: National Guideline Clearinghouse (NGC). [http://www.guideline.gov/summary/summary.aspx?ss=15&doc_id=10798&nbr=5626]. Rockville (MD): [cited 2008]. Available at: http://www.guideline.gov
9 Council on Chiropractic Guidelines and Practice Parameters (CCGPP) Research Commission. Literature Synthesis: Chiropractic management of low back pain and low back related leg complaints (Final Version). In: Council on Chiropractic Guidelines and Practice Parameters (CCGPP). [http://www.ccgpp.org/lowbackliterature.pdf]. Lexington (SC): [cited 2008]. Available at: www.ccgpp.org/view.htm
10 National Guideline Clearinghouse (NGC). Guideline Summary: Vertebral subluxation in chiropractic practice. In: National Guideline Clearinghouse (NGC). [http://www.guideline.gov/summary/summary.aspx?doc_id=4746]. Rockville (MD): [cited 2008]. Available at: http://www.guideline.gov
11 California Health Benefits Review Program (CHBRP). Analysis of Assembly Bill 54: Health Care Coverage: Acupuncture. Report to California State Legislature 2007-2008. Oakland, CA: 2007. CHBRP 07-07, June 22, 2007.
12 Carey TS, Garrett J, Jackman A, et al. The outcomes and costs of care for acute low back pain among patients seen by primary care practitioners, chiropractors, and orthopedic surgeons. The North Carolina Back Pain Project. N Engl J Med. 1995;333(14):913-7. [pmid: 7666878].
13 Sundararajan V, Konrad TR, Garrett J, et al. Patterns and determinants of multiple provider use in patients with acute low back pain. J Gen Intern Med. 1998;13(8):528-33. [pmid: 9734789]. [pmcid: 1497001].
14 Cherkin DC, Deyo RA, Battie M, et al. A comparison of physical therapy, chiropractic manipulation, and provision of an educational booklet for the treatment of patients with low back pain. N Engl J Med. 1998;339(15):1021-9. [pmid: 9761803].
15 Eisenberg DM, Post DE, Davis RB, et al. Addition of choice of complementary therapies to usual care for acute low back pain: a randomized controlled trial. Spine. 2007;32(2):151-8. [pmid: 17224808].
16 Haas M, Sharma R, Stano M. Cost-effectiveness of medical and chiropractic care for acute and chronic low back pain. J Manipulative Physiol Ther. 2005;28(8):555-63. [pmid: 16226622].
17 Kominski GF, Heslin KC, Morgenstern H, et al. Economic evaluation of four treatments for low-back pain: results from a randomized controlled trial. Med Care. 2005;43(5):428-35. [pmid: 15838406].
18 Lind BK, Lafferty WE, Tyree PT, et al. The role of alternative medical providers for the outpatient treatment of insured patients with back pain. Spine. 2005;30(12):1454-9. [pmid: 15959379].
19 Nyiendo J. Disabling low back Oregon workers' compensation claims. Part III: Diagnostic and treatment procedures and associated costs. J Manipulative Physiol Ther. 1991;14(5):287-97. [pmid: 1833494].
20 Stano M, Haas M, Goldberg B, et al. Chiropractic and medical care costs of low back care: results from a practice-based observational study. Am J Manag Care. 2002;8(9):802-9. [pmid: 12234021].
21 Stano M, Smith M. Chiropractic and medical costs of low back care. Med Care. 1996;34(3):191-204. [pmid: 8628040].
22 Smith M, Stano M. Costs and recurrences of chiropractic and medical episodes of low-back care. J Manipulative Physiol Ther. 1997;20(1):5-12. [pmid: 9004117].
23 Wasiak R, McNeely E. Utilization and costs of chiropractic care for work-related low back injuries: Do payment policies make a difference?. Spine J. 2006;6(2):146-53. [pmid: 16517385].
24 Williams DA, Feuerstein M, Durbin D, et al. Health care and indemnity costs across the natural history of disability in occupational low back pain. Spine. 1998;23(21):2329-36. [pmid: 9820914].
25 Jarvis KB, Phillips RB, Morris EK. Cost per case comparison of back injury claims of chiropractic versus medical management for conditions with identical diagnostic codes. J Occup Med. 1991;33(8):847-52. [pmid: 1834819].
26 Shekelle PG, Markovich M, Louie R. Comparing the costs between provider types of episodes of back pain care. Spine. 1995;20(2):221-6. [pmid: 7716629].
27 Legorreta AP, Metz RD, Nelson CF, et al. Comparative analysis of individuals with and without chiropractic coverage: patient characteristics, utilization, and costs. Arch Intern Med. 2004;164(18):1985-92. [pmid: 15477432].