# Appendix B - Forms/Guides

Tp see the Forms/Guides, please select the link below. This link will take you to a PDF version of the forms.

Forms/Guides