# Appendix A - Search Strategies Detailed

## Ovid MEDLINE(R) <1950 to October Week 4 2007> (Nov05_07)

1 Acupressure.tw.
2 Acupuncture.tw.
3 Alexander Technique.tw.
4 Anthroposophy.tw.
5 (Apitherapy or bee venom).tw.
6 Applied Biomechanics.tw.
7 Applied Kinesiology.tw.
8 Aromatherapy.tw.
9 (art therap$ not “state of the art”).tw.
10 ((autogenic adj3 (therap$ or treatment?)) or passive concentration).tw.
11 (aversion adj2 (therap$ or treatment?)).tw.
12 Ayurved$.tw.
13 bach flower.tw.
14 (Balneotherapy or therapeutic bath$).tw.
15 Biofeedback.tw.
16 Body Electronics.tw.
17 (Bowen adj2 (Therap$ or technique?)).tw.
18 (Breathwork or (breath$ adj (exercis$ or technique?))).tw.
19 Holotropic?.tw.
20 Cell Therapy.tw.
21 (Cheirology or palmistry).tw.
22 chelation.tw.
23 Chiropract$.tw.
24 molecular therap$.tw.
25 ((lumines$ or luminou$) adj2 (treatment? or therap$ or technique?)).tw.
26 Cognitive Therapy.tw.
27 ((colon or colonic) adj2 (hydrotherapy or irrigation)).tw.
28 Contact Reflex Analysis.tw.
29 Craniosacral Therapy.tw.
30 ((crystal? or gemstone?) adj2 (treatment? or therap$)).tw.
31 ((cupping and mugwort) or moxibustion).tw.
32 (Detoxification adj2 (Therap$ or treatment? or technique?)).tw.
33 did?eridoo.tw.
34 (Dream adj2 (Therap$ or analysis)).tw.
35 ((ear adj2 (candling or coning)) or thermal-auricular therapy).tw.
36 (Transcutaneous Electrical Nerve Stimulation or tens or electrotherapy).tw.
37 (Emotional freedom technique? or (tapping and cupping) or thought field therap$).tw.
38 (energy adj2 (medicine or field? or therap$)).tw.
39 (Enzyme adj3 Therap$).tw.
40 (essence? adj2 (therap$ or flower? or treatment?)).tw.
41 (Eye Movement Desensiti?ation or emdr).tw.
42 ((fasting or cleansing) adj2 (therap$ or treatment?)).tw.
43 (Feldenkrais or (body awareness adj2 (therap$ or treatment?))).tw.
44 (Gerson Therapy or coffee enema?).tw.
45 Gestalt Therap$.tw.
46 Guided Imagery.tw.
47 (healing touch or bodywork).tw.
48 Hellerwork.tw.
49 (herbal or herb?).tw.
50 homeopath$.tw.
51 ((humo?r or laughter) adj3 (treatment? or therap$)).tw.
52 Huna.tw.
53 (Hydrogen Peroxide adj2 (Therap$ or treatment?)).tw.
54 (Hydrotherapy or hydropathy).tw.
55 (hyperbaric adj3 (treatment? or therap$ or oxygen$)).tw.
56 (hyperthermia adj (treatment? or therap$)).tw.
57 (hypnotherapy or hypnosis).tw.
58 (iridology or iridodiagnosis).tw.
59 Jaffe-Mellor.tw.
60 Jin Shin Jyutsu.tw.
61 Juice Therapy.tw.
62 Kegel Exercise?.tw.
63 ((Light or helio or photo) adj2 (Therap$ or treatment?)).tw.
64 Macrobiotic?.tw.
65 (((magnet$ adj2 (therap$ or treatment?)) not “mri”) or magnetotherap$).tw.
66 Manual Lymphatic Drainage.tw.
67 marma.tw.
68 (shiatsu or rolfing or massage).tw.
69 medical intuiti$.tw.
70 Meditation.tw.
71 mind body.tw.
72 (Music adj (Therap$ or treatment?)).tw.
73 Nambudripad.tw.
74 (NAET or allergy elimination).tw.
75 Naprapath$.tw.
76 (nasal adj (irrigation or lavage)).tw.
77 Naturopath$.tw.
78 ((Neuro-Linguistic or neuro?linguistic) adj1 Programming).tw.
79 ((neuromuscular or trigger point) adj2 (therap$ or myotherapy)).tw.
80 ((nutri$ or diet$) adj (therap$ or treatment?)).tw.
81 (Orthomolecular or optimum nutrition).tw.
82 ((ozone or oxygen) adj2 (therap$ or treatment?)).tw.
83 Panchakarma.tw.
84 past life.tw.
85 ((pet or animal) adj2 (therap$ or treatment?)).tw.
86 Pilates.tw.
87 (polarity adj2 (medicine or therap$ or treatment?)).tw.
88 pranic.tw.
89 Prayer.tw.
90 Prolotherapy.tw.
91 (QiGong or chi kung).tw.
92 radiance technique?.tw.
93 Rapid Eye Technology.tw.
94 Reflexology.tw.
95 Reiki.tw.
96 (relaxation adj2 (therap$ or treatment? or technique?)).tw.
97 (Somatic Ontology or Structural Integration).tw.
98 Rosen Method.tw.
99 Rubenfeld Synergy.tw.
100 shaman$.tw.
101 (spiritual$ adj3 (healing or therap$ or treatment? or practice?)).tw.
102 Stress Management.tw.
103 Tai Chi.tw.
104 (tao or taoist or taoism or daoism or daoist).tw.
105 (touch adj2 (therapeutic or treatment? or healing or therap$)).tw.
106 ((chinese or oriental) adj2 (medicine or treatment? or healing)).tw.
107 transsage.tw.
108 (Trager adj2 (Method or approach or technique? or work)).tw.
109 (trepan$ or burr hole).tw.
110 (Tuina or tui na).tw.
111 Urani Medicine.tw.
112 (Urine Therapy or urotherapy or urinotherapy).tw.
113 (visuali?ation adj (therap$ or treatment?)).tw.
114 Visceral Manipulation.tw.
115 ((vitamin or megavitamin) adj2 (therap$ or treatment?)).tw.
116 Watsu.tw.
117 Wave Work.tw.
118 (yoga or yogic).tw.
119 johrei.tw.
120 qui gong.tw.
121 speleotherapy.tw.
122 halotherapy.tw.
123 (hopi adj3 candle?).tw.
124 biofield.tw.
125 (holistic adj3 (medicine or healing or treatment? or therap$)).tw.
126 Bioelectromagnetic.tw.
127 kampo.tw.
128 muti.tw.
129 (microcurrent adj2 (therap$ or treatment?)).tw.
130 ((traditional or tibetan or Indian or Chinese or Arabic or African or mongolian) adj2 (medicine or healing)).tw.
131 (Chromatotherapy or colo?r therapy).tw.
132 (kirlian photography or gas discharge visuali#ation).tw.
133 ((complementary or alternative or unconventional or integrative) adj2 (medicine or healing)).tw.
134 ((complementary or unconventional or integrative) adj2 (treatment? or therap$)).tw.
135 or/1–134
136 exp complementary therapies/
137 Formularies, Homeopathic/
138 Pharmacopoeias, Homeopathic/
139 plants, medicinal/
140 Medicine, Herbal/
141 Chiropractic/
142 Acupuncture/
143 Osteopathic Medicine/
144 Electroacupuncture/
145 exp Plant Extracts/
146 exp balneology/
147 exp nutrition therapy/
148 exp phototherapy/
149 exp exercise movement techniques/
150 exp Hyperthermia, Induced/
151 exp venoms/
152 exp Musculoskeletal Manipulations/
153 exp psychotherapy/
154 hydrotherapy/
155 exp oxygen inhalation therapy/
156 exp physical therapy modalities/
157 Ethnopharmacology/
158 Ethnobotany/
159 exp Pharmacognosy/
160 exp oils/
161 Materia Medica/
162 exp self care/
163 spirituality/
164 or/136–163
165 135 or 164
166 exp Neck/
167 exp spine/
168 exp back/
169 Neck Muscles/
170 or/166–169
171 pain/ or pain, intractable/ or pain, referred/
172 (pain$ or ache?).tw.
173 or/171–172
174 170 and 173
175 exp back pain/
176 exp back injuries/ or exp neck injuries/ or exp spinal cord injuries/ or exp spinal injuries/
177 Neck Pain/
178 exp spinal diseases/
179 Sciatica/
180 coccy$.tw.
181 dorsalgia.tw.
182 sciatica.tw.
183 spondyl$.tw.
184 lumbago.tw.
185 facet joint?.tw.
186 arachnoiditis.tw.
187 failed back.tw.
188 (stenosis adj3 spin$).tw.
189 discitis.tw.
190 (dis? adj3 (degener$ or prolapse or hernia$ or bulge or protrusion or extrusion or sequestration or disorder? or disease? or rupture?)).tw.
191 backache?.tw.
192 ((back or neck or spine or spinal or lumb$) adj3 (ache? or pain?)).tw.
193 or/174–192
194 limit 193 to complementary medicine
195 165 and 193
196 or/194–195
197 ut.fs.
198 td.fs.
199 sn.fs.
200 (“use” or “used” or usage or utili?ation).tw.
201 consumption.ti.
202 exp Data Collection/
203 exp Consumer Satisfaction/
204 exp delivery of health care/
205 “quality of health care”/ or “process assessment (health care)”/ or “utilization review”/
206 tu.fs.
207 or/197–206
208 196 and 207
209 limit 208 to yr=“1990 - 2007”
210 animals/ not (animals/ and humans/)
211 209 not 210
212 limit 211 to english language
213 (note or comment or editorial or letter).pt.
214 212 not 213

## AMED (Allied and Complementary Medicine) <1985 to November 2007> Search Strategy (Nov5_07)

1 Acupressure.tw.
2 Acupuncture.tw.
3 Alexander Technique.tw.
4 Anthroposophy.tw.
5 (Apitherapy or bee venom).tw.
6 Applied Biomechanics.tw.
7 Applied Kinesiology.tw.
8 Aromatherapy.tw.
9 (art therap$ not “state of the art”).tw.
10 ((autogenic adj3 (therap$ or treatment?)) or passive concentration).tw.
11 (aversion adj2 (therap$ or treatment?)).tw.
12 Ayurved$.tw.
13 bach flower.tw.
14 (Balneotherapy or therapeutic bath$).tw.
15 Biofeedback.tw.
16 Body Electronics.tw.
17 (Bowen adj2 (Therap$ or technique?)).tw.
18 (Breathwork or (breath$ adj (exercis$ or technique?))).tw.
19 Holotropic?.tw.
20 Cell Therapy.tw.
21 (Cheirology or palmistry).tw.
22 chelation.tw.
23 Chiropract$.tw.
24 molecular therap$.tw.
25 ((lumines$ or luminou$) adj2 (treatment? or therap$ or technique?)).tw.
26 Cognitive Therapy.tw.
27 ((colon or colonic) adj2 (hydrotherapy or irrigation)).tw.
28 Contact Reflex Analysis.tw.
29 Craniosacral Therapy.tw.
30 ((crystal? or gemstone?) adj2 (treatment? or therap$)).tw.
31 ((cupping and mugwort) or moxibustion).tw.
32 (Detoxification adj2 (Therap$ or treatment? or technique?)).tw.
33 did?eridoo.tw.
34 (Dream adj2 (Therap$ or analysis)).tw.
35 ((ear adj2 (candling or coning)) or thermal-auricular therapy).tw.
36 (Transcutaneous Electrical Nerve Stimulation or tens or electrotherapy).tw.
37 (Emotional freedom technique? or (tapping and cupping) or thought field therap$).tw.
38 (energy adj2 (medicine or field? or therap$)).tw.
39 (Enzyme adj3 Therap$).tw.
40 (essence? adj2 (therap$ or flower? or treatment?)).tw.
41 (Eye Movement Desensiti?ation or emdr).tw.
42 ((fasting or cleansing) adj2 (therap$ or treatment?)).tw.
43 (Feldenkrais or (body awareness adj2 (therap$ or treatment?))).tw.
44 (Gerson Therapy or coffee enema?).tw.
45 Gestalt Therap$.tw.
46 Guided Imagery.tw.
47 (healing touch or bodywork).tw.
48 Hellerwork.tw.
49 (herbal or herb?).tw.
50 homeopath$.tw.
51 ((humo?r or laughter) adj3 (treatment? or therap$)).tw.
52 Huna.tw.
53 (Hydrogen Peroxide adj2 (Therap$ or treatment?)).tw.
54 (Hydrotherapy or hydropathy).tw.
55 (hyperbaric adj3 (treatment? or therap$ or oxygen$)).tw.
56 (hyperthermia adj (treatment? or therap$)).tw.
57 (hypnotherapy or hypnosis).tw.
58 (iridology or iridodiagnosis).tw.
59 Jaffe-Mellor.tw.
60 Jin Shin Jyutsu.tw.
61 Juice Therapy.tw.
62 Kegel Exercise?.tw.
63 ((Light or helio or photo) adj2 (Therap$ or treatment?)).tw.
64 Macrobiotic?.tw.
65 (((magnet$ adj2 (therap$ or treatment?)) not “mri”) or magnetotherap$).tw.
66 Manual Lymphatic Drainage.tw.
67 marma.tw.
68 (shiatsu or rolfing or massage).tw.
69 medical intuiti$.tw.
70 Meditation.tw.
71 mind body.tw.
72 (Music adj (Therap$ or treatment?)).tw.
73 Nambudripad.tw.
74 (NAET or allergy elimination).tw.
75 Naprapath$.tw.
76 (nasal adj (irrigation or lavage)).tw.
77 Naturopath$.tw.
78 ((Neuro-Linguistic or neuro?linguistic) adj1 Programming).tw.
79 ((neuromuscular or trigger point) adj2 (therap$ or myotherapy)).tw.
80 ((nutri$ or diet$) adj (therap$ or treatment?)).tw.
81 (Orthomolecular or optimum nutrition).tw.
82 ((ozone or oxygen) adj2 (therap$ or treatment?)).tw.
83 Panchakarma.tw.
84 past life.tw.
85 ((pet or animal) adj2 (therap$ or treatment?)).tw.
86 Pilates.tw.
87 (polarity adj2 (medicine or therap$ or treatment?)).tw.
88 pranic.tw.
89 Prayer.tw.
90 Prolotherapy.tw.
91 (QiGong or chi kung).tw.
92 radiance technique?.tw.
93 Rapid Eye Technology.tw.
94 Reflexology.tw.
95 Reiki.tw.
96 (relaxation adj2 (therap$ or treatment? or technique?)).tw.
97 (Somatic Ontology or Structural Integration).tw.
98 Rosen Method.tw.
99 Rubenfeld Synergy.tw.
100 shaman$.tw.
101 (spiritual$ adj3 (healing or therap$ or treatment? or practice?)).tw.
102 Stress Management.tw.
103 Tai Chi.tw.
104 (tao or taoist or taoism or daoism or daoist).tw.
105 (touch adj2 (therapeutic or treatment? or healing or therap$)).tw.
106 ((chinese or oriental) adj2 (medicine or treatment? or healing)).tw.
107 transsage.tw.
108 (Trager adj2 (Method or approach or technique? or work)).tw.
109 (trepan$ or burr hole).tw.
110 (Tuina or tui na).tw.
111 Urani Medicine.tw.
112 (Urine Therapy or urotherapy or urinotherapy).tw.
113 (visuali?ation adj (therap$ or treatment?)).tw.
114 Visceral Manipulation.tw.
115 ((vitamin or megavitamin) adj2 (therap$ or treatment?)).tw.
116 Watsu.tw.
117 Wave Work.tw.
118 (yoga or yogic).tw.
119 johrei.tw.
120 qui gong.tw.
121 speleotherapy.tw.
122 halotherapy.tw.
123 (hopi adj3 candle?).tw.
124 biofield.tw.
125 (holistic adj3 (medicine or healing or treatment? or therap$)).tw.
126 Bioelectromagnetic.tw.
127 kampo.tw.
128 muti.tw.
129 (microcurrent adj2 (therap$ or treatment?)).tw.
130 ((traditional or tibetan or Indian or Chinese or Arabic or African or mongolian) adj2 (medicine or healing)).tw.
131 (Chromatotherapy or colo?r therapy).tw.
132 (kirlian photography or gas discharge visuali#ation).tw.
133 ((complementary or alternative or unconventional or integrative) adj2 (medicine or healing)).tw.
134 ((complementary or unconventional or integrative) adj2 (treatment? or therap$)).tw.
135 or/1–134
136 exp complementary medicine/
137 acupuncture/ or chiropractic/
138 exp homeopathic drugs/
139 exp plant extracts/
140 exp plants medicinal/
141 Osteopathy/
142 physical medicine/
143 hyperthermia induced/
144 exp Oxygen inhalation therapy/
145 exp psychotherapy/
146 spirituality/
147 exp physical therapy modalities/
148 or/136–147
149 135 or 148
150 exp neck/
151 exp spine/
152 exp back/
153 Neck Muscles/
154 or/150–153
155 pain/ or pain, intractable/
156 (pain$ or ache?).tw.
157 or/155–156
158 154 and 157
159 exp backache/
160 back injuries/ or exp neck injuries/ or exp spinal cord injuries/ or spinal injuries/
161 Neck Pain/
162 exp spinal disease/
163 Sciatica/
164 coccy$.tw.
165 dorsalgia.tw.
166 sciatica.tw.
167 spondyl$.tw.
168 lumbago.tw.
169 (dis? adj3 (degener$ or prolapse or hernia$ or bulge or protrusion or extrusion or sequestration or disorder? or disease? or rupture?)).tw.
170 facet joint?.tw.
171 arachnoiditis.tw.
172 failed back.tw.
173 (stenosis adj3 spin$).tw.
174 discitis.tw.
175 ((back or neck or spine or spinal or lumb$) adj3 (ache? or pain?)).tw.
176 backache?.tw.
177 or/158–176
178 149 and 177
179 limit 178 to yr=“1990 - 2007”
180 limit 179 to english language
181 (editorial or letter or comment).pt.
182 180 not 181

## EBM Reviews - Cochrane Central Register of Controlled Trials <4th Quarter 2007> Search Strategy (Nov05_07)

1 Acupressure.tw.
2 Acupuncture.tw.
3 Alexander Technique.tw.
4 Anthroposophy.tw.
5 (Apitherapy or bee venom).tw.
6 Applied Biomechanics.tw.
7 Applied Kinesiology.tw.
8 Aromatherapy.tw.
9 (art therap$ not “state of the art”).tw.
10 ((autogenic adj3 (therap$ or treatment?)) or passive concentration).tw.
11 (aversion adj2 (therap$ or treatment?)).tw.
12 Ayurved$.tw.
13 bach flower.tw.
14 (Balneotherapy or therapeutic bath$).tw.
15 Biofeedback.tw.
16 Body Electronics.tw.
17 (Bowen adj2 (Therap$ or technique?)).tw.
18 (Breathwork or (breath$ adj (exercis$ or technique?))).tw.
19 Holotropic?.tw.
20 Cell Therapy.tw.
21 (Cheirology or palmistry).tw.
22 chelation.tw.
23 Chiropract$.tw.
24 molecular therap$.tw.
25 ((lumines$ or luminou$) adj2 (treatment? or therap$ or technique?)).tw.
26 Cognitive Therapy.tw.
27 ((colon or colonic) adj2 (hydrotherapy or irrigation)).tw.
28 Contact Reflex Analysis.tw.
29 Craniosacral Therapy.tw.
30 ((crystal? or gemstone?) adj2 (treatment? or therap$)).tw.
31 ((cupping and mugwort) or moxibustion).tw.
32 (Detoxification adj2 (Therap$ or treatment? or technique?)).tw.
33 did?eridoo.tw.
34 (Dream adj2 (Therap$ or analysis)).tw.
35 ((ear adj2 (candling or coning)) or thermal-auricular therapy).tw.
36 (Transcutaneous Electrical Nerve Stimulation or tens or electrotherapy).tw.
37 (Emotional freedom technique? or (tapping and cupping) or thought field therap$).tw.
38 (energy adj2 (medicine or field? or therap$)).tw.
39 (Enzyme adj3 Therap$).tw.
40 (essence? adj2 (therap$ or flower? or treatment?)).tw.
41 (Eye Movement Desensiti?ation or emdr).tw.
42 ((fasting or cleansing) adj2 (therap$ or treatment?)).tw.
43 (Feldenkrais or (body awareness adj2 (therap$ or treatment?))).tw.
44 (Gerson Therapy or coffee enema?).tw.
45 Gestalt Therap$.tw.
46 Guided Imagery.tw.
47 (healing touch or bodywork).tw.
48 Hellerwork.tw.
49 (herbal or herb?).tw.
50 homeopath$.tw.
51 ((humo?r or laughter) adj3 (treatment? or therap$)).tw.
52 Huna.tw.
53 (Hydrogen Peroxide adj2 (Therap$ or treatment?)).tw.
54 (Hydrotherapy or hydropathy).tw.
55 (hyperbaric adj3 (treatment? or therap$ or oxygen$)).tw.
56 (hyperthermia adj (treatment? or therap$)).tw.
57 (hypnotherapy or hypnosis).tw.
58 (iridology or iridodiagnosis).tw.
59 Jaffe-Mellor.tw.
60 Jin Shin Jyutsu.tw.
61 Juice Therapy.tw.
62 Kegel Exercise?.tw.
63 ((Light or helio or photo) adj2 (Therap$ or treatment?)).tw.
64 Macrobiotic?.tw.
65 (((magnet$ adj2 (therap$ or treatment?)) not “mri”) or magnetotherap$).tw.
66 Manual Lymphatic Drainage.tw.
67 marma.tw.
68 (shiatsu or rolfing or massage).tw.
69 medical intuiti$.tw.
70 Meditation.tw.
71 mind body.tw.
72 (Music adj (Therap$ or treatment?)).tw.
73 Nambudripad.tw.
74 (NAET or allergy elimination).tw.
75 Naprapath$.tw.
76 (nasal adj (irrigation or lavage)).tw.
77 Naturopath$.tw.
78 ((Neuro-Linguistic or neuro?linguistic) adj1 Programming).tw.
79 ((neuromuscular or trigger point) adj2 (therap$ or myotherapy)).tw.
80 ((nutri$ or diet$) adj (therap$ or treatment?)).tw.
81 (Orthomolecular or optimum nutrition).tw.
82 ((ozone or oxygen) adj2 (therap$ or treatment?)).tw.
83 Panchakarma.tw.
84 past life.tw.
85 ((pet or animal) adj2 (therap$ or treatment?)).tw.
86 Pilates.tw.
87 (polarity adj2 (medicine or therap$ or treatment?)).tw.
88 pranic.tw.
89 Prayer.tw.
90 Prolotherapy.tw.
91 (QiGong or chi kung).tw.
92 radiance technique?.tw.
93 Rapid Eye Technology.tw.
94 Reflexology.tw.
95 Reiki.tw.
96 (relaxation adj2 (therap$ or treatment? or technique?)).tw.
97 (Somatic Ontology or Structural Integration).tw.
98 Rosen Method.tw.
99 Rubenfeld Synergy.tw.
100 shaman$.tw.
101 (spiritual$ adj3 (healing or therap$ or treatment? or practice?)).tw.
102 Stress Management.tw.
103 Tai Chi.tw.
104 (tao or taoist or taoism or daoism or daoist).tw.
105 (touch adj2 (therapeutic or treatment? or healing or therap$)).tw.
106 ((chinese or oriental) adj2 (medicine or treatment? or healing)).tw.
107 transsage.tw.
108 (Trager adj2 (Method or approach or technique? or work)).tw.
109 (trepan$ or burr hole).tw.
110 (Tuina or tui na).tw.
111 Urani Medicine.tw.
112 (Urine Therapy or urotherapy or urinotherapy).tw.
113 (visuali?ation adj (therap$ or treatment?)).tw.
114 Visceral Manipulation.tw.
115 ((vitamin or megavitamin) adj2 (therap$ or treatment?)).tw.
116 Watsu.tw.
117 Wave Work.tw.
118 (yoga or yogic).tw.
119 johrei.tw.
120 qui gong.tw.
121 speleotherapy.tw.
122 halotherapy.tw.
123 (hopi adj3 candle?).tw.
124 biofield.tw.
125 (holistic adj3 (medicine or healing or treatment? or therap$)).tw.
126 Bioelectromagnetic.tw.
127 kampo.tw.
128 muti.tw.
129 (microcurrent adj2 (therap$ or treatment?)).tw.
130 ((traditional or tibetan or Indian or Chinese or Arabic or African or mongolian) adj2 (medicine or healing)).tw.
131 (Chromatotherapy or colo?r therapy).tw.
132 (kirlian photography or gas discharge visuali#ation).tw.
133 ((complementary or alternative or unconventional or integrative) adj2 (medicine or healing)).tw.
134 ((complementary or unconventional or integrative) adj2 (treatment? or therap$)).tw.
135 or/1–134
136 exp complementary therapies/
137 Formularies, Homeopathic/
138 Pharmacopoeias, Homeopathic/
139 plants, medicinal/
140 Medicine, Herbal/
141 Chiropractic/
142 Acupuncture/
143 Osteopathic Medicine/
144 Electroacupuncture/
145 exp Plant Extracts/
146 exp balneology/
147 exp nutrition therapy/
148 exp phototherapy/
149 exp exercise movement techniques/
150 exp Hyperthermia, Induced/
151 exp venoms/
152 exp Musculoskeletal Manipulations/
153 exp psychotherapy/
154 hydrotherapy/
155 exp oxygen inhalation therapy/
156 exp physical therapy modalities/
157 Ethnopharmacology/
158 Ethnobotany/
159 exp Pharmacognosy/
160 exp oils/
161 Materia Medica/
162 exp self care/
163 spirituality/
164 or/136–163
165 135 or 164
166 exp Neck/
167 exp spine/
168 exp back/
169 Neck Muscles/
170 or/166–169
171 pain/ or pain, intractable/ or pain, referred/
172 (pain$ or ache?).tw.
173 or/171–172
174 170 and 173
175 exp back pain/
176 exp back injuries/ or exp neck injuries/ or exp spinal cord injuries/ or exp spinal injuries/
177 Neck Pain/
178 exp spinal diseases/
179 Sciatica/
180 coccy$.tw.
181 dorsalgia.tw.
182 sciatica.tw.
183 spondyl$.tw.
184 lumbago.tw.
185 facet joint?.tw.
186 arachnoiditis.tw.
187 failed back.tw.
188 (stenosis adj3 spin$).tw.
189 discitis.tw.
190 (dis? adj3 (degener$ or prolapse or hernia$ or bulge or protrusion or extrusion or sequestration or disorder? or disease? or rupture?)).tw.
191 backache?.tw.
192 ((back or neck or spine or spinal or lumb$) adj3 (ache? or pain?)).tw.
193 or/174–192
194 165 and 193
195 limit 194 to yr=“1990 - 2007”

## CINAHL - Cumulative Index to Nursing & Allied Health Literature <1982 to October Week 4 2007> Search Strategy (Nov5_07)

1 Acupressure.tw.
2 Acupuncture.tw.
3 Alexander Technique.tw.
4 Anthroposophy.tw.
5 (Apitherapy or bee venom).tw.
6 Applied Biomechanics.tw.
7 Applied Kinesiology.tw.
8 Aromatherapy.tw.
9 (art therap$ not “state of the art”).tw.
10 ((autogenic adj3 (therap$ or treatment?)) or passive concentration).tw.
11 (aversion adj2 (therap$ or treatment?)).tw.
12 Ayurved$.tw.
13 bach flower.tw.
14 (Balneotherapy or therapeutic bath$).tw.
15 Biofeedback.tw.
16 Body Electronics.tw.
17 (Bowen adj2 (Therap$ or technique?)).tw.
18 (Breathwork or (breath$ adj (exercis$ or technique?))).tw.
19 Holotropic?.tw.
20 Cell Therapy.tw.
21 (Cheirology or palmistry).tw.
22 chelation.tw.
23 Chiropract$.tw.
24 molecular therap$.tw.
25 ((lumines$ or luminou$) adj2 (treatment? or therap$ or technique?)).tw.
26 Cognitive Therapy.tw.
27 ((colon or colonic) adj2 (hydrotherapy or irrigation)).tw.
28 Contact Reflex Analysis.tw.
29 Craniosacral Therapy.tw.
30 ((crystal? or gemstone?) adj2 (treatment? or therap$)).tw.
31 ((cupping and mugwort) or moxibustion).tw.
32 (Detoxification adj2 (Therap$ or treatment? or technique?)).tw.
33 did?eridoo.tw.
34 (Dream adj2 (Therap$ or analysis)).tw.
35 ((ear adj2 (candling or coning)) or thermal-auricular therapy).tw.
36 (Transcutaneous Electrical Nerve Stimulation or tens or electrotherapy).tw.
37 (Emotional freedom technique? or (tapping and cupping) or thought field therap$).tw.
38 (energy adj2 (medicine or field? or therap$)).tw.
39 (Enzyme adj3 Therap$).tw.
40 (essence? adj2 (therap$ or flower? or treatment?)).tw.
41 (Eye Movement Desensiti?ation or emdr).tw.
42 ((fasting or cleansing) adj2 (therap$ or treatment?)).tw.
43 (Feldenkrais or (body awareness adj2 (therap$ or treatment?))).tw.
44 (Gerson Therapy or coffee enema?).tw.
45 Gestalt Therap$.tw.
46 Guided Imagery.tw.
47 (healing touch or bodywork).tw.
48 Hellerwork.tw.
49 (herbal or herb?).tw.
50 homeopath$.tw.
51 ((humo?r or laughter) adj3 (treatment? or therap$)).tw.
52 Huna.tw.
53 (Hydrogen Peroxide adj2 (Therap$ or treatment?)).tw.
54 (Hydrotherapy or hydropathy).tw.
55 (hyperbaric adj3 (treatment? or therap$ or oxygen$)).tw.
56 (hyperthermia adj (treatment? or therap$)).tw.
57 (hypnotherapy or hypnosis).tw.
58 (iridology or iridodiagnosis).tw.
59 Jaffe-Mellor.tw.
60 Jin Shin Jyutsu.tw.
61 Juice Therapy.tw.
62 Kegel Exercise?.tw.
63 ((Light or helio or photo) adj2 (Therap$ or treatment?)).tw.
64 Macrobiotic?.tw.
65 (((magnet$ adj2 (therap$ or treatment?)) not “mri”) or magnetotherap$).tw.
66 Manual Lymphatic Drainage.tw.
67 marma.tw.
68 (shiatsu or rolfing or massage).tw.
69 medical intuiti$.tw.
70 Meditation.tw.
71 mind body.tw.
72 (Music adj (Therap$ or treatment?)).tw.
73 Nambudripad.tw.
74 (NAET or allergy elimination).tw.
75 Naprapath$.tw.
76 (nasal adj (irrigation or lavage)).tw.
77 Naturopath$.tw.
78 ((Neuro-Linguistic or neuro?linguistic) adj1 Programming).tw.
79 ((neuromuscular or trigger point) adj2 (therap$ or myotherapy)).tw.
80 ((nutri$ or diet$) adj (therap$ or treatment?)).tw.
81 (Orthomolecular or optimum nutrition).tw.
82 ((ozone or oxygen) adj2 (therap$ or treatment?)).tw.
83 Panchakarma.tw.
84 past life.tw.
85 ((pet or animal) adj2 (therap$ or treatment?)).tw.
86 Pilates.tw.
87 (polarity adj2 (medicine or therap$ or treatment?)).tw.
88 pranic.tw.
89 Prayer.tw.
90 Prolotherapy.tw.
91 (QiGong or chi kung).tw.
92 radiance technique?.tw.
93 Rapid Eye Technology.tw.
94 Reflexology.tw.
95 Reiki.tw.
96 (relaxation adj2 (therap$ or treatment? or technique?)).tw.
97 (Somatic Ontology or Structural Integration).tw.
98 Rosen Method.tw.
99 Rubenfeld Synergy.tw.
100 shaman$.tw.
101 (spiritual$ adj3 (healing or therap$ or treatment? or practice?)).tw.
102 Stress Management.tw.
103 Tai Chi.tw.
104 (tao or taoist or taoism or daoism or daoist).tw.
105 (touch adj2 (therapeutic or treatment? or healing or therap$)).tw.
106 ((chinese or oriental) adj2 (medicine or treatment? or healing)).tw.
107 transsage.tw.
108 (Trager adj2 (Method or approach or technique? or work)).tw.
109 (trepan$ or burr hole).tw.
110 (Tuina or tui na).tw.
111 Urani Medicine.tw.
112 (Urine Therapy or urotherapy or urinotherapy).tw.
113 (visuali?ation adj (therap$ or treatment?)).tw.
114 Visceral Manipulation.tw.
115 ((vitamin or megavitamin) adj2 (therap$ or treatment?)).tw.
116 Watsu.tw.
117 Wave Work.tw.
118 (yoga or yogic).tw.
119 johrei.tw.
120 qui gong.tw.
121 speleotherapy.tw.
122 halotherapy.tw.
123 (hopi adj3 candle?).tw.
124 biofield.tw.
125 (holistic adj3 (medicine or healing or treatment? or therap$)).tw.
126 Bioelectromagnetic.tw.
127 kampo.tw.
128 muti.tw.
129 (microcurrent adj2 (therap$ or treatment?)).tw.
130 ((traditional or tibetan or Indian or Chinese or Arabic or African or mongolian) adj2 (medicine or healing)).tw.
131 (Chromatotherapy or colo?r therapy).tw.
132 (kirlian photography or gas discharge visuali#ation).tw.
133 ((complementary or alternative or unconventional or integrative) adj2 (medicine or healing)).tw.
134 ((complementary or unconventional or integrative) adj2 (treatment? or therap$)).tw.
135 or/1–134
136 exp Alternative Therapies/
137 research, alternative therapies/ or research, chiropractic/
138 Homeopathic Agents/
139 exp Plants, Medicinal/
140 exp Alternative Health Personnel/
141 exp Plant Extracts/
142 Chiropractic Practice/
143 Osteopathy/
144 balneology/ or exp hydrotherapy/ or exp hyperthermia, induced/ or exp massage/ or exp phototherapy/ or hyperoxygenation/ or exp oxygen therapy/
145 exp Venoms/
146 exp Psychotherapy/
147 Energy Field/
148 iridology/
149 photochemotherapy/ or exp photodynamic therapy/ or exp diet therapy/
150 exp Alternative Health Personnel/
151 self care/ or self medication/
152 exp Oils/
153 nutritional support/ or exp dietary supplementation/
154 Spirituality/
155 or/136–154
156 135 or 155
157 exp Neck/
158 exp spine/
159 exp back/
160 neck muscles/
161 or/157–160
162 pain/ or chronic pain/ or muscle pain/ or referred pain/
163 (pain$ or ache?).tw.
164 or/162–163
165 161 and 164
166 exp Back Pain/
167 exp back injuries/ or exp neck injuries/ or exp spinal cord injuries/ or exp spinal injuries/
168 neck pain/
169 sciatica/
170 exp Spinal Diseases/
171 coccy$.tw.
172 dorsalgia.tw.
173 sciatica.tw.
174 spondyl$.tw.
175 lumbago.tw.
176 (dis? adj3 (degener$ or prolapse or hernia$ or bulge or protrusion or extrusion or sequestration or disorder? or disease? or rupture?)).tw.
177 facet joint?.tw.
178 arachnoiditis.tw.
179 failed back.tw.
180 (stenosis adj3 spin$).tw.
181 discitis.tw.
182 ((back or neck or spine or spinal or lumb$) adj3 (ache? or pain?)).tw.
183 or/165–182
184 156 and 183
185 ut.fs.
186 td.fs.
187 tu.fs.
188 (“use” or “used” or usage or utili?ation).tw.
189 consumption.ti.
190 exp Data Collection/
191 exp Consumer Satisfaction/
192 “quality of health care”/ or “process assessment (health care)”/ or “utilization review”/
193 exp health care delivery/
194 Trend Studies/
195 or/185–194
196 184 and 195
197 limit 196 to yr=“1990 - 2007”
198 limit 197 to english
199 (letter or editorial).pt.
200 198 not 199

## EMBASE <1980 to 2007 Week 44> Search Strategy (Nov5_07)

1 Acupressure.tw.
2 Acupuncture.tw.
3 Alexander Technique.tw.
4 Anthroposophy.tw.
5 (Apitherapy or bee venom).tw.
6 Applied Biomechanics.tw.
7 Applied Kinesiology.tw.
8 Aromatherapy.tw.
9 (art therap$ not “state of the art”).tw.
10 ((autogenic adj3 (therap$ or treatment?)) or passive concentration).tw.
11 (aversion adj2 (therap$ or treatment?)).tw.
12 Ayurved$.tw.
13 bach flower.tw.
14 (Balneotherapy or therapeutic bath$).tw.
15 Biofeedback.tw.
16 Body Electronics.tw.
17 (Bowen adj2 (Therap$ or technique?)).tw.
18 (Breathwork or (breath$ adj (exercis$ or technique?))).tw.
19 Holotropic?.tw.
20 Cell Therapy.tw.
21 (Cheirology or palmistry).tw.
22 chelation.tw.
23 Chiropract$.tw.
24 molecular therap$.tw.
25 ((lumines$ or luminou$) adj2 (treatment? or therap$ or technique?)).tw.
26 Cognitive Therapy.tw.
27 ((colon or colonic) adj2 (hydrotherapy or irrigation)).tw.
28 Contact Reflex Analysis.tw.
29 Craniosacral Therapy.tw.
30 ((crystal? or gemstone?) adj2 (treatment? or therap$)).tw.
31 ((cupping and mugwort) or moxibustion).tw.
32 (Detoxification adj2 (Therap$ or treatment? or technique?)).tw.
33 did?eridoo.tw.
34 (Dream adj2 (Therap$ or analysis)).tw.
35 ((ear adj2 (candling or coning)) or thermal-auricular therapy).tw.
36 (Transcutaneous Electrical Nerve Stimulation or tens or electrotherapy).tw.
37 (Emotional freedom technique? or (tapping and cupping) or thought field therap$).tw.
38 (energy adj2 (medicine or field? or therap$)).tw.
39 (Enzyme adj3 Therap$).tw.
40 (essence? adj2 (therap$ or flower? or treatment?)).tw.
41 (Eye Movement Desensiti?ation or emdr).tw.
42 ((fasting or cleansing) adj2 (therap$ or treatment?)).tw.
43 (Feldenkrais or (body awareness adj2 (therap$ or treatment?))).tw.
44 (Gerson Therapy or coffee enema?).tw.
45 Gestalt Therap$.tw.
46 Guided Imagery.tw.
47 (healing touch or bodywork).tw.
48 Hellerwork.tw.
49 (herbal or herb?).tw.
50 homeopath$.tw.
51 ((humo?r or laughter) adj3 (treatment? or therap$)).tw.
52 Huna.tw.
53 (Hydrogen Peroxide adj2 (Therap$ or treatment?)).tw.
54 (Hydrotherapy or hydropathy).tw.
55 (hyperbaric adj3 (treatment? or therap$ or oxygen$)).tw.
56 (hyperthermia adj (treatment? or therap$)).tw.
57 (hypnotherapy or hypnosis).tw.
58 (iridology or iridodiagnosis).tw.
59 Jaffe-Mellor.tw.
60 Jin Shin Jyutsu.tw.
61 Juice Therapy.tw.
62 Kegel Exercise?.tw.
63 ((Light or helio or photo) adj2 (Therap$ or treatment?)).tw.
64 Macrobiotic?.tw.
65 (((magnet$ adj2 (therap$ or treatment?)) not “mri”) or magnetotherap$).tw.
66 Manual Lymphatic Drainage.tw.
67 marma.tw.
68 (shiatsu or rolfing or massage).tw.
69 medical intuiti$.tw.
70 Meditation.tw.
71 mind body.tw.
72 (Music adj (Therap$ or treatment?)).tw.
73 Nambudripad.tw.
74 (NAET or allergy elimination).tw.
75 Naprapath$.tw.
76 (nasal adj (irrigation or lavage)).tw.
77 Naturopath$.tw.
78 ((Neuro-Linguistic or neuro?linguistic) adj1 Programming).tw.
79 ((neuromuscular or trigger point) adj2 (therap$ or myotherapy)).tw.
80 ((nutri$ or diet$) adj (therap$ or treatment?)).tw.
81 (Orthomolecular or optimum nutrition).tw.
82 ((ozone or oxygen) adj2 (therap$ or treatment?)).tw.
83 Panchakarma.tw.
84 past life.tw.
85 ((pet or animal) adj2 (therap$ or treatment?)).tw.
86 Pilates.tw.
87 (polarity adj2 (medicine or therap$ or treatment?)).tw.
88 pranic.tw.
89 Prayer.tw.
90 Prolotherapy.tw.
91 (QiGong or chi kung).tw.
92 radiance technique?.tw.
93 Rapid Eye Technology.tw.
94 Reflexology.tw.
95 Reiki.tw.
96 (relaxation adj2 (therap$ or treatment? or technique?)).tw.
97 (Somatic Ontology or Structural Integration).tw.
98 Rosen Method.tw.
99 Rubenfeld Synergy.tw.
100 shaman$.tw.
101 (spiritual$ adj3 (healing or therap$ or treatment? or practice?)).tw.
102 Stress Management.tw.
103 Tai Chi.tw.
104 (tao or taoist or taoism or daoism or daoist).tw.
105 (touch adj2 (therapeutic or treatment? or healing or therap$)).tw.
106 ((chinese or oriental) adj2 (medicine or treatment? or healing)).tw.
107 transsage.tw.
108 (Trager adj2 (Method or approach or technique? or work)).tw.
109 (trepan$ or burr hole).tw.
110 (Tuina or tui na).tw.
111 Urani Medicine.tw.
112 (Urine Therapy or urotherapy or urinotherapy).tw.
113 (visuali?ation adj (therap$ or treatment?)).tw.
114 Visceral Manipulation.tw.
115 ((vitamin or megavitamin) adj2 (therap$ or treatment?)).tw.
116 Watsu.tw.
117 Wave Work.tw.
118 (yoga or yogic).tw.
119 johrei.tw.
120 qui gong.tw.
121 speleotherapy.tw.
122 halotherapy.tw.
123 (hopi adj3 candle?).tw.
124 biofield.tw.
125 (holistic adj3 (medicine or healing or treatment? or therap$)).tw.
126 Bioelectromagnetic.tw.
127 kampo.tw.
128 muti.tw.
129 (microcurrent adj2 (therap$ or treatment?)).tw.
130 ((traditional or tibetan or Indian or Chinese or Arabic or African or mongolian) adj2 (medicine or healing)).tw.
131 (Chromatotherapy or colo?r therapy).tw.
132 (kirlian photography or gas discharge visuali#ation).tw.
133 ((complementary or alternative or unconventional or integrative) adj2 (medicine or healing)).tw.
134 ((complementary or unconventional or integrative) adj2 (treatment? or therap$)).tw.
135 or/1–134
136 exp psychiatric treatment/
137 exp alternative medicine/
138 exp traditional medicine/
139 exp Acupuncture/
140 homeopathy/
141 ayurvedic drug/ or homeopathic agent/
142 meditation/
143 transcendental meditation/
144 exp physical medicine/
145 exp Medicinal Plant/
146 exp Plant Extract/
147 exp plant medicinal product/ or ayurvedic drug/ or homeopathic agent/
148 exp Venom/
149 exp diet therapy/
150 exp edible oil/
151 chelation therapy/
152 phytotherapy/
153 exp self care/
154 religion/
155 or/136–154
156 135 or 155
157 exp Back/
158 exp neck/
159 or/157–158
160 pain/ or chronic pain/ or intractable pain/
161 (pain$ or ache?).tw.
162 or/160–161
163 159 and 162
164 exp Backache/
165 Neck Pain/
166 exp spine injury/
167 exp neck injury/
168 exp Spine Disease/
169 Ischialgia/
170 coccy$.tw.
171 dorsalgia.tw.
172 sciatica.tw.
173 spondyl$.tw.
174 lumbago.tw.
175 facet joint?.tw.
176 arachnoiditis.tw.
177 failed back.tw.
178 (stenosis adj3 spin$).tw.
179 discitis.tw.
180 (dis? adj3 (degener$ or prolapse or hernia$ or bulge or protrusion or extrusion or sequestration or disorder? or disease? or rupture?)).tw.
181 backache?.tw.
182 ((back or neck or spine or spinal or lumb$) adj3 (ache? or pain?)).tw.
183 or/163–182
184 156 and 183
185 (“use” or “used” or usage or utili?ation).tw.
186 consumption.ti.
187 exp Consumer Satisfaction/
188 exp delivery of health care/
189 “quality of health care”/ or “process assessment (health care)”/ or “utilization review”/
190 health survey/
191 patient participation/ or patient satisfaction/
192 health care delivery/
193 trend study/
194 health care utilization/
195 or/185–194
196 184 and 195
197 limit 196 to yr=“1990 - 2007”
198 human.sh.
199 nonhuman.sh.
200 animal.sh.
201 animal experiment.sh.
202 199 or 200 or 201
203 198 and 202
204 or/202–203
205 197 not 204
206 limit 205 to english language
207 editorial/ or letter/ or note/
208 (editorial or letter or note).pt.
209 or/207–208
210 206 not 209

## PsycINFO <1985 to November Week 1 2007> Search Strategy (Nov15_07)

1 exp alternative medicine/
2 exp biofeedback/
3 dietary supplements/
4 holistic health/
5 exp hypnotherapy/
6 massage/
7 exp “medicinal herbs and plants”/
8 exp religious practices/
9 spirituality/
10 osteopathic medicine/
11 phototherapy/
12 exp relaxation therapy/
13 or/1–12
14 Acupressure.tw.
15 Acupuncture.tw.
16 Alexander Technique.tw.
17 Anthroposophy.tw.
18 (Apitherapy or bee venom).tw.
19 Applied Biomechanics.tw.
20 Applied Kinesiology.tw.
21 Aromatherapy.tw.
22 (art therap$ not “state of the art”).tw.
23 ((autogenic adj3 (therap$ or treatment?)) or passive concentration).tw.
24 (aversion adj2 (therap$ or treatment?)).tw.
25 Ayurved$.tw.
26 bach flower.tw.
27 (Balneotherapy or therapeutic bath$).tw.
28 Biofeedback.tw.
29 Body Electronics.tw.
30 (Bowen adj2 (Therap$ or technique?)).tw.
31 (Breathwork or (breath$ adj (exercis$ or technique?))).tw.
32 Holotropic?.tw.
33 Cell Therapy.tw.
34 (Cheirology or palmistry).tw.
35 chelation.tw.
36 Chiropract$.tw.
37 molecular therap$.tw.
38 ((lumines$ or luminou$) adj2 (treatment? or therap$ or technique?)).tw.
39 Cognitive Therapy.tw.
40 ((colon or colonic) adj2 (hydrotherapy or irrigation)).tw.
41 Contact Reflex Analysis.tw.
42 Craniosacral Therapy.tw.
43 ((crystal? or gemstone?) adj2 (treatment? or therap$)).tw.
44 ((cupping and mugwort) or moxibustion).tw.
45 (Detoxification adj2 (Therap$ or treatment? or technique?)).tw.
46 did?eridoo.tw.
47 (Dream adj2 (Therap$ or analysis)).tw.
48 ((ear adj2 (candling or coning)) or thermal-auricular therapy).tw.
49 (Transcutaneous Electrical Nerve Stimulation or tens or electrotherapy).tw.
50 (Emotional freedom technique? or (tapping and cupping) or thought field therap$).tw.
51 (energy adj2 (medicine or field? or therap$)).tw.
52 (Enzyme adj3 Therap$).tw.
53 (essence? adj2 (therap$ or flower? or treatment?)).tw.
54 (Eye Movement Desensiti?ation or emdr).tw.
55 ((fasting or cleansing) adj2 (therap$ or treatment?)).tw.
56 (Feldenkrais or (body awareness adj2 (therap$ or treatment?))).tw.
57 (Gerson Therapy or coffee enema?).tw.
58 Gestalt Therap$.tw.
59 Guided Imagery.tw.
60 (healing touch or bodywork).tw.
61 Hellerwork.tw.
62 (herbal or herb?).tw.
63 homeopath$.tw.
64 ((humo?r or laughter) adj3 (treatment? or therap$)).tw.
65 Huna.tw.
66 (Hydrogen Peroxide adj2 (Therap$ or treatment?)).tw.
67 (Hydrotherapy or hydropathy).tw.
68 (hyperbaric adj3 (treatment? or therap$ or oxygen$)).tw.
69 (hyperthermia adj (treatment? or therap$)).tw.
70 (hypnotherapy or hypnosis).tw.
71 (iridology or iridodiagnosis).tw.
72 Jaffe-Mellor.tw.
73 Jin Shin Jyutsu.tw.
74 Juice Therapy.tw.
75 Kegel Exercise?.tw.
76 ((Light or helio or photo) adj2 (Therap$ or treatment?)).tw.
77 Macrobiotic?.tw.
78 (((magnet$ adj2 (therap$ or treatment?)) not “mri”) or magnetotherap$).tw.
79 Manual Lymphatic Drainage.tw.
80 marma.tw.
81 (shiatsu or rolfing or massage).tw.
82 medical intuiti$.tw.
83 Meditation.tw.
84 mind body.tw.
85 (Music adj (Therap$ or treatment?)).tw.
86 Nambudripad.tw.
87 (NAET or allergy elimination).tw.
88 Naprapath$.tw.
89 (nasal adj (irrigation or lavage)).tw.
90 Naturopath$.tw.
91 ((Neuro-Linguistic or neuro?linguistic) adj1 Programming).tw.
92 ((neuromuscular or trigger point) adj2 (therap$ or myotherapy)).tw.
93 ((nutri$ or diet$) adj (therap$ or treatment?)).tw.
94 (Orthomolecular or optimum nutrition).tw.
95 ((ozone or oxygen) adj2 (therap$ or treatment?)).tw.
96 Panchakarma.tw.
97 past life.tw.
98 ((pet or animal) adj2 (therap$ or treatment?)).tw.
99 Pilates.tw.
100 (polarity adj2 (medicine or therap$ or treatment?)).tw.
101 pranic.tw.
102 Prayer.tw.
103 Prolotherapy.tw.
104 (QiGong or chi kung).tw.
105 radiance technique?.tw.
106 Rapid Eye Technology.tw.
107 Reflexology.tw.
108 Reiki.tw.
109 (relaxation adj2 (therap$ or treatment? or technique?)).tw.
110 (Somatic Ontology or Structural Integration).tw.
111 Rosen Method.tw.
112 Rubenfeld Synergy.tw.
113 shaman$.tw.
114 (spiritual$ adj3 (healing or therap$ or treatment? or practice?)).tw.
115 Stress Management.tw.
116 Tai Chi.tw.
117 (tao or taoist or taoism or daoism or daoist).tw.
118 (touch adj2 (therapeutic or treatment? or healing or therap$)).tw.
119 ((chinese or oriental) adj2 (medicine or treatment? or healing)).tw.
120 transsage.tw.
121 (Trager adj2 (Method or approach or technique? or work)).tw.
122 (trepan$ or burr hole).tw.
123 (Tuina or tui na).tw.
124 Urani Medicine.tw.
125 (Urine Therapy or urotherapy or urinotherapy).tw.
126 (visuali?ation adj (therap$ or treatment?)).tw.
127 Visceral Manipulation.tw.
128 ((vitamin or megavitamin) adj2 (therap$ or treatment?)).tw.
129 Watsu.tw.
130 Wave Work.tw.
131 (yoga or yogic).tw.
132 johrei.tw.
133 qui gong.tw.
134 speleotherapy.tw.
135 halotherapy.tw.
136 (hopi adj3 candle?).tw.
137 biofield.tw.
138 (holistic adj3 (medicine or healing or treatment? or therap$)).tw.
139 Bioelectromagnetic.tw.
140 kampo.tw.
141 muti.tw.
142 (microcurrent adj2 (therap$ or treatment?)).tw.
143 ((traditional or tibetan or Indian or Chinese or Arabic or African or mongolian) adj2 (medicine or healing)).tw.
144 (Chromatotherapy or colo?r therapy).tw.
145 (kirlian photography or gas discharge visuali#ation).tw.
146 ((complementary or alternative or unconventional or integrative) adj2 (medicine or healing)).tw.
147 ((complementary or unconventional or integrative) adj2 (treatment? or therap$)).tw.
148 or/14–147
149 148 or 13
150 spinal column/ or exp spinal cord/
151 “back (anatomy)”/
152 “neck (anatomy)”/
153 or/150–152
154 exp pain/
155 (pain$ or ache?).tw.
156 pain management/
157 or/154–156
158 153 and 157
159 exp back pain/
160 coccy$.tw.
161 dorsalgia.tw.
162 sciatica.tw.
163 spondyl$.tw.
164 lumbago.tw.
165 facet joint?.tw.
166 arachnoiditis.tw.
167 failed back.tw.
168 (stenosis adj3 spin$).tw.
169 discitis.tw.
170 (dis? adj3 (degener$ or prolapse or hernia$ or bulge or protrusion or extrusion or sequestration or disorder? or disease? or rupture?)).tw.
171 backache?.tw.
172 ((back or neck or spine or spinal or lumb$) adj3 (ache? or pain?)).tw.
173 exp spinal cord injuries/
174 or/158–173
175 149 and 174
176 limit 175 to yr=“1990 - 2007”
177 limit 176 to english language
178 limit 177 to human

## Index to Chiropractic Literature (ICL)

### Searched February 4, 2008

[underlined: S1] Subject:“BACK PAIN / THERAPY” OR Article Title:“back pain” OR Subject:“BACK PAIN / REHABILITATION”, Year: from 1990 to 2008 586 2008-02-04 08:42:55

[underlined: S2] All Fields:utilization OR All Fields:rates OR Subject:“UTILIZATION REVIEW”, Year: from 1990 to 2008, Publication Type:Article 66 2008-02-04 08:46:16

[underlined: S3] All Fields:utilization OR All Fields:rates OR Subject:“UTILIZATION REVIEW”, Year: from 1990 to 2008, Publication Type:Clinical Trial 3 2008-02-04 08:48:27

[underlined: S4] All Fields:utilization OR All Fields:rates OR Subject:“UTILIZATION REVIEW”, Year: from 1990 to 2008, Publication Type:Randomized Controlled Trial 3 2008-02-04 08:48:51

[underlined: S5] S2 OR S3 OR S4 72 2008-02-04 08:49:09

[underlined: S6] S1 AND S5 8 2008-02-04 08:49:17

[underlined: S7] All Fields:Usage, Year: from 1990 to 2008 27 2008-02-04 09:15:02

[underlined: S8] S2 OR S3 OR S4 OR S7 96 2008-02-04 09:15:23

[underlined: S9] S1 AND S8 10 2008-02-04 09:15:43

Separate Search:

Subject:“CHIROPRACTIC / UTILIZATION” OR Subject:“CHIROPRACTIC / UTILIZATION / CANADA” OR Subject:“CHIROPRACTIC / UTILIZATION / NEW YORK”, Year: from 1990 to 2008

Separate Search:

Subject:“CHIROPRACTIC / STATISTICS & NUMERICAL DATA” OR Subject:“CHIROPRACTIC / TRENDS / CANADA” OR Subject:“CHIROPRACTIC / TRENDS”, Year: from 1990 to 2008

ACUBRIEFS

Search Terms: low back pain (subject heading) OR neck pain (keyword in Title)

Agricola

Search Terms: Back pain

Micromedex

Search Terms: back

Hom-Inform

Search Terms: Spin* OR Spondy* OR Back* OR complementary (in all fields); Use OR Usage (in title); Utilization (in all fields)

### Other Search Sources

New York Academy of Medicine Grey Literature Database

Search Terms: CAM OR alternative medicine OR complementary medicine

Bandolier

Search Terms: Complementary and alternative therapies (subject)

National Library of Health: Complementary and Alternative Medicine Specialist Library

Search Terms(back pain)

Specific Web Sites Searched

http://www.ifebp.org/

http://www.ebri.org/

http://www.iscebs.org/

http://www.greatwestlife.com

https://www.kaiserpermanente.org/

http://www.kff.org/

http://www.iscmr.org/

http://theintegratorblog.com/site/

http://healthpromotionjournal.com

http://www.compmed.umm.edu/default.asp

http://www.fraserinstitute.org/

http://www.osher.ucsf.edu/

http://www.landmarkhealthcare.com/

http://www.ccachiro.org

http://www.aaaomonline.org/

http://www.academyhealth.org

http://www.landmarkhealthcare.com/

http://www.cms.hhs.gov

http://www.ncqa.org/

http://www.guideline.gov/

Search Engine Searches

Google

Dogpile

Complete Planet

Scirus

Search Terms:

Back pain cam

Back pain alternative medicine

Back pain complementary medicine