# Appendixes

Appendix A - Search Strategies Detailed

Appendix B - Forms/Guides

Appendix C - Evidence Tables

Appendix D - Excluded Studies

Appendix E - Partners and Technical Expert Panel