# List of Acronyms and Abbreviations

Acronym or Abbreviation | Definition
ACOG | American College of Obstetricians and Gynecologists
AFI | Amniotic Fluid Index
AHRQ | Agency for Healthcare Research and Quality
AMOR-IPAT | Active management of risk in pregnancy at term
BMI | Body Mass Index
CDC | Centers for Disease Control
CDMR | Cesarean section on maternal request
CPI | Consumer Price Index
EPC | Evidence-based Practice Center
ICN | Intensive care nursery
IUFD | In utero fetal demise
IUGR | Intra-uterine growth restriction
MeSH | Medical Subject Headings
MFMU | Maternal-Fetal Medicine Units
NICU | Neonatal intensive care unit
NNH | Number needed to harm
NNT | Number needed to treat
NST | Nonstress Test
OVD | Operative vaginal delivery
PROM | Premature rupture of membranes
RCT | Randomized controlled trial
SVD | Spontaneous vaginal delivery
TEP | Technical Expert Panel
UCSF | University of California, San Francisco
UK | United Kingdom
UL-OTD | Upper limit of optimal delivery time
US | United States