# References and Included Studies

1 Bueno B, San-Frutos L, Perez-Medina T, Barbancho C, Troyano J, Bajo J. The labor induction: integrated clinical and sonographic variables that predict the outcome. J Perinatol. 3. 2007;27(1):4-8. [pmid: 17180126].
2 Tan PC, Suguna S, Vallikkannu N, Hassan J. Ultrasound and clinical predictors for Caesarean delivery after labour induction at term. Aust N Z J Obstet Gynaecol. Dec. 2006;46(6):505-509. [pmid: 17116055].
3 Caughey AB, Nicholson JM, Cheng YW, Lyell DJ, Washington AE. Induction of labor and cesarean delivery by gestational age. Am J Obstet Gynecol. Sep. 2006;195(3):700-705. [pmid: 16949399].
4 Edris FE, von Dadelszen P, Ainsworth LM, Liston RM. Predictors of cesarean section following elective post-dates induction of labor in nullipara with uncomplicated singleton vertex pregnancies. Saudi Med J. Aug. 2006;27(8):1167-1172. [pmid: 16883446].
5 Peregrine E, O'Brien P, Omar R, Jauniaux E. Clinical and ultrasound parameters to predict the risk of cesarean delivery after induction of labor. Obstet Gynecol. Feb. 2006;107(2 Pt 1):227-233. [pmid: 16449105].
6 Alchalabi HA, Obeidat BR, Jallad MF, Khader YS. Induction of labor and perinatal outcome: the impact of the amniotic fluid index. Eur J Obstet Gynecol Reprod Biol. Dec. 2006;129(2):124-127. [pmid: 16360261].
7 Nielsen PE, Howard BC, Hill CC, Larson PL, Holland RH, Smith PN. Comparison of elective induction of labor with favorable Bishop scores versus expectant management: a randomized clinical trial. J Matern Fetal Neonatal Med. Jul. 2005;18(1):59-64. [pmid: 16105793].
8 Gelisen O, Caliskan E, Dilbaz S, et al. Induction of labor with three different techniques at 41 weeks of gestation or spontaneous follow-up until 42 weeks in women with definitely unfavorable cervical scores. Eur J Obstet Gynecol Reprod Biol. Jun 1. 2005;120(2):164-169. [pmid: 15925045].
9 Glantz JC. Elective induction vs. spontaneous labor associations and outcomes. J Reprod Med. Apr. 2005;50(4):235-240. [pmid: 15916205].
10 Simon CE, Grobman WA. When has an induction failed. Obstet Gynecol. Apr. 2005;105(4):705-709. [pmid: 15802394].
11 Luthy DA, Malmgren JA, Zingheim RW. Cesarean delivery after elective induction in nulliparous women: the physician effect. Am J Obstet Gynecol. Nov. 2004;191(5):1511-1515. [pmid: 15547518].
12 Nuthalapaty FS, Rouse DJ, Owen J. The association of maternal weight with cesarean risk, labor duration, and cervical dilation rate during labor induction. Obstet Gynecol. Mar. 2004;103(3):452-456. [pmid: 14990405].
13 Garite TJ, Casal D, Garcia-Alonso A, et al. Fetal fibronectin: a new tool for the prediction of successful induction of labor. Am J Obstet Gynecol. Dec. 1996;175(6):1516-1521. [pmid: 8987935].
14 Johnson DP, Davis NR, Brown AJ. Risk of cesarean delivery after induction at term in nulliparous women with an unfavorable cervix. Am J Obstet Gynecol. Jun. 2003;188(6):1565-1569. discussion 1569–1572. [pmid: 12824994].
15 Heinberg EM, Wood RA, Chambers RB. Elective induction of labor in multiparous women. Does it increase the risk of cesarean section. J Reprod Med. May. 2002;47(5):399-403. [pmid: 12063879].
16 Gabriel R, Darnaud T, Chalot F, Gonzalez N, Leymarie F, Quereux C. Transvaginal sonography of the uterine cervix prior to labor induction. Ultrasound Obstet Gynecol. Mar. 2002;19(3):254-257. [pmid: 11896946].
17 Cammu H, Martens G, Ruyssinck G, Amy JJ. Outcome after elective labor induction in nulliparous women: a matched cohort study. Am J Obstet Gynecol. Feb. 2002;186(2):240-244. [pmid: 11854642].
18 Ecker JL, Chen KT, Cohen AP, Riley LE, Lieberman ES. Increased risk of cesarean delivery with advancing maternal age: indications and associated factors in nulliparous women. Am J Obstet Gynecol. Oct. 2001;185(4):883-887. [pmid: 11641671].
19 Ware V, Raynor BD. Transvaginal ultrasonographic cervical measurement as a predictor of successful labor induction. Am J Obstet Gynecol. May. 2000;182(5):1030-1032. [pmid: 10819818].
20 Seyb ST, Berka RJ, Socol ML, Dooley SL. Risk of cesarean delivery with elective induction of labor at term in nulliparous women. Obstet Gynecol. Oct. 1999;94(4):600-607. [pmid: 10511367].
21 Prysak M, Castronova FC. Elective induction versus spontaneous labor: a case-control analysis of safety and efficacy. Obstet Gynecol. Jul. 1998;92(1):47-52. [pmid: 9649091].
22 Robson S, Pridmore B, Dodd J. Outcomes of induced labour. Aust N Z J Obstet Gynaecol. Feb. 1997;37(1):16-19. [pmid: 9075541].
23 Alberico S, Fadalti M, Grimaldi E, De Seta F, Mazza S, Guaschino S. Eligibility criteria for labor induction with prostaglandins. Clin Exp Obstet Gynecol. 1997;24(2):61-66. [pmid: 9342463].
24 A clinical trial of induction of labor versus expectant management in postterm pregnancy. The National Institute of Child Health and Human Development Network of Maternal-Fetal Medicine Units. Am J Obstet Gynecol. Mar1994;170(3):716–723.
25 Wigton TR, Wolk BM. Elective and routine induction of labor. A retrospective analysis of 274 cases. J Reprod Med. Jan. 1994;39(1):21-26. [pmid: 8169911].
26 Abou el-Leil LA, Nasrat AA, Fayed HM. Prostaglandin E2 vaginal pessaries in the grandmultipara with an unripe cervix, a comparison of different parity groups. Int J Gynaecol Obstet. Feb. 1993;40(2):119-122. [pmid: 8094680].
27 Hannah ME, Hannah WJ, Hellmann J, Hewson S, Milner R, Willan A. Induction of labor as compared with serial antenatal monitoring in post-term pregnancy. A randomized controlled trial. The Canadian Multicenter Post-term Pregnancy Trial Group. N Engl J Med. Jun 11. 1992;326(24):1587-1592. [pmid: 1584259].
28 Macer JA, Macer CL, Chan LS. Elective induction versus spontaneous labor: a retrospective study of complications and outcome. Am J Obstet Gynecol. Jun. 1992;166(6 Pt 1):1690-1696. discussion 1696–1697. [pmid: 1615976].
29 Schreyer P, Bar-Natan N, Sherman DJ, Arieli S, Caspi E. Fetal breathing movements before oxytocin induction in prolonged pregnancies. Am J Obstet Gynecol. Sep. 1991;165(3):577-581. [pmid: 1892182].
30 Boyd ME, Usher RH, McLean FH, Kramer MS. Obstetric consequences of postmaturity. Am J Obstet Gynecol. Feb. 1988;158(2):334-338. [pmid: 3277431].
31 Lampe LG. Elective induction of labour in the obstetrical practice. Acta Chir Hung. 1986;27(3):143-149. [pmid: 3825406].
32 Arulkumaran S, Gibb DM, TambyRaja RL, Heng SH, Ratnam SS. Failed induction of labour. Aust N Z J Obstet Gynaecol. Aug. 1985;25(3):190-193. [pmid: 3866556].
33 Orhue AA, Unuigbe JA, Ezimokhai M, Ojo VA. Outcome of induced labor in 931 term pregnancies. Obstet Gynecol. Jul. 1984;64(1):108-114. [pmid: 6738933].
34 Belsky DH. Statistical observations on the elective induction of labor with oxytocin. J Am Osteopath Assoc. Apr. 1982;81(8):524-530. [pmid: 7042662].
35 Goeschen K, Pakzad S. Risks occurring in birth induction without considering cervix maturity. J Perinat Med. 1980;8(1):27-37. [pmid: 7365668].
36 Williams RM, Craft I. Caesarean section following modern induction of labour. Br J Clin Pract. Mar 1979;33(3):80–81, 84.
37 McBride WG, Lyle JG, Black B, Brown C, Thomas DB. A study of five year old children born after elective induction of labour. Med J Aust. Oct 1. 1977;2(14):456-459. [pmid: 600145].
38 Wilson PD, Philpott RH. Induction of labour in Black patients. S Afr Med J. Mar 24. 1976;50(13):498-502. [pmid: 1265545].
39 Ben-Haroush A, Glickman H, Yogev Y, Kaplan B, Feldberg D, Hod M. Induction of labor in pregnancies with suspected large-for-gestational-age fetuses and unfavorable cervix. Eur J Obstet Gynecol Reprod Biol. Oct 15. 2004;116(2):182-185. [pmid: 15358461].
40 Onifade A. Induction of labour. West Afr Med J. Jun. 1970;19(3):105-108. [pmid: 5482328].
41 Williams MC, Krammer J, O'Brien WF. The value of the cervical score in predicting successful outcome of labor induction. Obstet Gynecol. Nov. 1997;90(5):784-789. [pmid: 9351765].
42 Heffner LJ, Elkin E, Fretts RC. Impact of labor induction, gestational age, and maternal age on cesarean delivery rates. Obstet Gynecol. Aug. 2003;102(2):287-293. [pmid: 12907101].
43 Buist R. Induction of labour: indications and obstetric outcomes in a tertiary referral hospital. N Z Med J. Jul 9. 1999;112(1091):251-253. [pmid: 10448982].
44 Xenakis EM, Piper JM, Conway DL, Langer O. Induction of labor in the nineties: conquering the unfavorable cervix. Obstet Gynecol. Aug. 1997;90(2):235-239. [pmid: 9241300].
45 Chan LY, Fu L, Leung TN, Wong SF, Lau TK. Obstetric outcomes after cervical ripening by multiple doses of vaginal prostaglandin E2. Acta Obstet Gynecol Scand. Jan. 2004;83(1):70-74. [pmid: 14678088].
46 Heimstad R, Romundstad PR, Eik-Nes SH, Salvesen KA. Outcomes of pregnancy beyond 37 weeks of gestation. Obstet Gynecol. Sep. 2006;108(3 Pt 1):500-508. [pmid: 16946207].
47 van Gemund N, Hardeman A, Scherjon SA, Kanhai HH. Intervention rates after elective induction of labor compared to labor with a spontaneous onset. A matched cohort study. Gynecol Obstet Invest. 2003;56(3):133-138. [pmid: 14530612].
48 Boulvain M, Marcoux S, Bureau M, Fortier M, Fraser W. Risks of induction of labour in uncomplicated term pregnancies. Paediatr Perinat Epidemiol. Apr. 2001;15(2):131-138. [pmid: 11383577].
49 Rizzo N, Farina A, Santarsiero G, et al. Correlation among amniotic fluid index (AFI), cesarean section rate, and labor length in inducted pregnancies beyond 41 weeks' gestation with unfavorable cervix. Am J Perinatol. 2000;17(6):319-324. [pmid: 11144315].
50 Yeast JD, Jones A, Poskin M. Induction of labor and the relationship to cesarean delivery: A review of 7001 consecutive inductions. Am J Obstet Gynecol. Mar. 1999;180(3 Pt 1):628-633. [pmid: 10076139].
51 Saunders N, Amis S, Marsh M. The prognostic value of fetal ultrasonography before induction of labour. Br J Obstet Gynaecol. Nov. 1992;99(11):903-906. [pmid: 1450140].
52 Morgan MA, Thurnau GR. Efficacy of the fetal-pelvic index in patients requiring labor induction. Am J Obstet Gynecol. Sep. 1988;159(3):621-625. [pmid: 3048100].
53 Dodd JM, Crowther CA, Robinson JS. Morning compared with evening induction of labor: a nested randomized controlled trial. A nested randomized controlled trial. Obstet Gynecol. Aug. 2006;108(2):350-360. [pmid: 16880306].
54 Ahner R, Egarter C, Kiss H, et al. Fetal fibronectin as a selection criterion for induction of term labor. Am J Obstet Gynecol. Nov. 1995;173(5):1513-1517. [pmid: 7503193].
55 Egarter C, Kofler E, Fitz R, Husslein P. Is induction of labor indicated in prolonged pregnancy? Results of a prospective randomised trial. Gynecol Obstet Invest. 1989;27(1):6-9. [pmid: 2646187].
56 Dhall K, Mittal SC, Kumar A. Evaluation of preinduction scoring systems. Aust N Z J Obstet Gynaecol. Nov. 1987;27(4):309-311. [pmid: 3453668].
57 Wing DA, Tran S, Paul RH. Factors affecting the likelihood of successful induction after intravaginal misoprostol application for cervical ripening and labor induction. Am J Obstet Gynecol. Jun. 2002;186(6):1237-1240. discussion 1240–1233. [pmid: 12066104].
58 Pandis GK, Papageorghiou AT, Ramanathan VG, Thompson MO, Nicolaides KH. Preinduction sonographic measurement of cervical length in the prediction of successful induction of labor. Ultrasound Obstet Gynecol. Dec. 2001;18(6):623-628. [pmid: 11844202].
59 Heimstad R, Skogvoll E, Mattsson LA, Johansen OJ, Eik-Nes SH, Salvesen KA. Induction of labor or serial antenatal fetal monitoring in postterm pregnancy: a randomized controlled trial. Obstet Gynecol. Mar. 2007;109(3):609-617. [pmid: 17329511].
60 Vrouenraets FP, Roumen FJ, Dehing CJ, van den Akker ES, Aarts MJ, Scheve EJ. Bishop score and risk of cesarean delivery after induction of labor in nulliparous women. Obstet Gynecol. Apr. 2005;105(4):690-697. [pmid: 15802392].
61 Dublin S, Lydon-Rochelle M, Kaplan RC, Watts DH, Critchlow CW. Maternal and neonatal outcomes after induction of labor without an identified indication. Am J Obstet Gynecol. Oct. 2000;183(4):986-994. [pmid: 11035351].
62 Maslow AS, Sweeny AL. Elective induction of labor as a risk factor for cesarean delivery among low-risk women at term. Obstet Gynecol. Jun. 2000;95(6 Pt 1):917-922. [pmid: 10831992].
63 Amano K, Saito K, Shoda T, Tani A, Yoshihara H, Nishijima M. Elective induction of labor at 39 weeks of gestation: a prospective randomized trial. J Obstet Gynaecol Res. Feb. 1999;25(1):33-37. [pmid: 10067011].
64 Melton LJ 3rd, Gallenberg MM, Noller KL. Effect of elective induction on birth weight. Mayo Clin Proc. Oct. 1979;54(10):646-650. [pmid: 480989].
65 Tylleskar J, Finnstrom O, Leijon I, Hedenskog S, Ryden G. Spontaneous labor and elective induction—a prospective randomized study. I. Effects on mother and fetus. Acta Obstet Gynecol Scand. 1979;58(6):513-518. [pmid: 45068].
66 Martin DH, Thompson W, Pinkerton JH, Watson JD. A randomized controlled trial of selective planned delivery. Br J Obstet Gynaecol. Feb. 1978;85(2):109-113. [pmid: 626718].
67 Cole RA, Howie PW, Macnaughton MC. Elective induction of labour. A randomised prospective trial. Lancet. Apr 5. 1975;1(7910):767-770. [pmid: 48000].
68 Booth JH, Kurdyak VB. Elective induction of labour: a controlled study. Can Med Assoc J. Aug 1. 1970;103(3):245-248. [pmid: 5433906].
69 Hoffman MK, Vahratian A, Sciscione AC, Troendle JF, Zhang J. Comparison of labor progression between induced and noninduced multiparous women. Obstet Gynecol. May. 2006;107(5):1029-1034. [pmid: 16648407].
70 Nooh A, Baghdadi S, Raouf S. Induction of labour: how close to the evidence-based guidelines are we. J Obstet Gynaecol. Jul. 2005;25(5):451-454. [pmid: 16183578].
71 Wilailak S, Saropala N, Chaturachinda K. Elective induction of labor: Ramathibodi Hospital (Jan–Jun, 1990). J Med Assoc Thai. Jan. 1993;76(Suppl 1):44-47. [pmid: 8113655].
72 Ekman G, Perssen PH, Ulmsten U, Wingerup L. The impact on labor induction of intracervically applied PGE2-gel, related to gestational age in patients with an unripe cervix. Acta Obstet Gynecol Scand Suppl. 1983;113:173-175. [pmid: 6574676].
73 Anderson MM. The state of the cervix, and surgical induction of labour. J Obstet Gynaecol Br Commonw. Oct. 1965;72(5):711-716. [pmid: 5842319].
74 Dyson DC, Miller PD, Armstrong MA. Management of prolonged pregnancy: induction of labor versus antepartum fetal testing. Am J Obstet Gynecol. Apr. 1987;156(4):928-934. [pmid: 3472467].
75 Vierhout ME, Out JJ, Wallenburg HC. Elective induction of labor: a prospective clinical study, I: Obstetric and neonatal effects. J Perinat Med. 1985;13(4):155-162. [pmid: 4057031].
76 Mukherjee S, Sood M. Towards a safer motherhood. J Indian Med Assoc. Mar 1995;93(3):98–100, 189.
77 Kaufman KE, Bailit JL, Grobman W. Elective induction: an analysis of economic and health consequences. Am J Obstet Gynecol. Oct. 2002;187(4):858-863. [pmid: 12388964].
78 Herbst MA. Treatment of suspected fetal macrosomia: a cost-effectiveness analysis. Am J Obstet Gynecol. Sep. 2005;193(3 Pt 2):1035-1039. [pmid: 16157107].
79 Senecal J, Xiong X, Fraser WD. Effect of fetal position on second-stage duration and labor outcome. Obstet Gynecol. Apr. 2005;105(4):763-772. [pmid: 15802403].
80 Cheng YW, Shaffer BL, Caughey AB. Associated factors and outcomes of persistent occiput posterior position: A retrospective cohort study from 1976 to 2001. J Matern Fetal Neonatal Med. Sep. 2006;19(9):563-568. [pmid: 16966125].
81 Rayburn WF, Zhang J. Rising rates of labor induction: present concerns and future strategies. Obstet Gynecol. Jul. 2002;100(1):164-167. [pmid: 12100818].
82 Martin JA, Hamilton BE, Sutton PD, Ventura SJ, Menacker F, Kirmeyer S. Births: final data for 2004. Natl Vital Stat Rep. Sep 29. 2006;55(1):1-101.
83 Grobman WA. Elective induction: When? Ever. Clin Obstet Gynecol. Jun. 2007;50(2):537-546. [pmid: 17513939].
84 Zhang J, Yancey MK, Henderson CE. U.S. national trends in labor induction, 1989-1998. J Reprod Med. Feb. 2002;47(2):120-124. [pmid: 11883350].
85 Lydon-Rochelle MT, Cardenas V, Nelson JC, Holt VL, Gardella C, Easterling TR. Induction of Labor in the Absence of Standard Medical Indications: Incidence and Correlates. Med Care. Jun. 2007;45(6):505-512. [pmid: 17515777].
86 Hilder L, Costeloe K, Thilaganathan B. Prolonged pregnancy: evaluating gestation-specific risks of fetal and infant mortality. Br J Obstet Gynaecol. Feb. 1998;105(2):169-173. [pmid: 9501781].
87 Caughey AB, Washington AE, Laros RK Jr. Neonatal complications of term pregnancy: rates by gestational age increase in a continuous, not threshold, fashion. Am J Obstet Gynecol. Jan. 2005;192(1):185-190. [pmid: 15672023].
88 American College of Obstetricians and Gynecologists (ACOG). Induction of labor. Washington, DC: American College of Obstetricians and Gynecologists (ACOG); 1999 Nov. 10 p. ACOG practice bulletin; no. 10.
89 Vahratian A, Zhang J, Troendle JF, Sciscione AC, Hoffman MK. Labor progression and risk of cesarean delivery in electively induced nulliparas. Obstet Gynecol. Apr. 2005;105(4):698-704. [pmid: 15802393].
90 Sanchez-Ramos L, Olivier F, Delke I, Kaunitz AM. Labor induction versus expectant management for postterm pregnancies: a systematic review with meta-analysis. Obstet Gynecol. Jun. 2003;101(6):1312-1318. [pmid: 12798542].
91 Gulmezoglu AM, Crowther CA, Middleton P. Induction of labour for improving birth outcomes for women at or beyond term. Cochrane Database Syst Rev. 2006(4):CD004945.
92 Bost BW. Cesarean delivery on demand: what will it cost. Am J Obstet Gynecol. Jun. 2003;188(6):1418-1421. discussion 1421–1413. [pmid: 12824972].
93 Silver RM, Landon MB, Rouse DJ, et al. Maternal morbidity associated with multiple repeat cesarean deliveries. Obstet Gynecol. Jun. 2006;107(6):1226-1232. [pmid: 16738145].
94 Grobman WA, Gersnoviez R, Landon MB, et al. Pregnancy outcomes for women with placenta previa in relation to the number of prior cesarean deliveries. Obstet Gynecol. Dec. 2007;110(6):1249-1255. [pmid: 18055717].
95 Kohli P, Zlatnik M, Little S, Caughey A. Bleeding Previa: What Are The Risks?. Am J Obstet Gynecol. 2006;195:S113.
96 Smith GC, Pell JP, Dobbie R. Caesarean section and risk of unexplained stillbirth in subsequent pregnancy. Lancet. Nov 29. 2003;362(9398):1779-1784. [pmid: 14654315].
97 Smith LP, Nagourney BA, McLean FH, Usher RH. Hazards and benefits of elective induction of labor. Am J Obstet Gynecol. Mar 1. 1984;148(5):579-585. [pmid: 6538386].
98 Caughey AB, Musci TJ. Complications of term pregnancies beyond 37 weeks of gestation. Obstet Gynecol. Jan. 2004;103(1):57-62. [pmid: 14704245].
99 Caughey AB, Stotland NE, Escobar GJ. What is the best measure of maternal complications of term pregnancy: ongoing pregnancies or pregnancies delivered. Am J Obstet Gynecol. Oct. 2003;189(4):1047-1052. [pmid: 14586353].
100 Kjos SL, Henry OA, Montoro M, Buchanan TA, Mestman JH. Insulin-requiring diabetes in pregnancy: a randomized trial of active induction of labor and expectant management. Am J Obstet Gynecol. Sep. 1993;169(3):611-615. [pmid: 8372870].
101 Gonen O, Rosen DJ, Dolfin Z, Tepper R, Markov S, Fejgin MD. Induction of labor versus expectant management in macrosomia: a randomized study. Obstet Gynecol. Jun. 1997;89(6):913-917. [pmid: 9170464].
102 Villar J, Carroli G, Zavaleta N, et al. Maternal and neonatal individual risks and benefits associated with caesarean delivery: multicentre prospective study. BMJ. Nov 17. 2007;335(7628):1025. [pmid: 17977819].
103 Norwitz ER, Snegovskikh VV, Caughey AB. Prolonged pregnancy: when should we intervene. Clin Obstet Gynecol. Jun. 2007;50(2):547-557. [pmid: 17513940].
104 Kim L, Kaimal A, Cheng Y, Delaney S, Child A, Caughey A. Preeclampsia is a risk factor for cesarean delivery in the setting of induction of labor. Am J Obstet Gynecol. 2007;197:S105.
105 Assessing the Quality and Applicability of Included Studies in Agency for Healthcare Research and Quality. Methods Reference Guide for Comparative Effectiveness Reviews, [Draft posted Nov. 2007]. Rockville, MD. Available at: www.ahrq.gov/downloads/pub/contract/rfp0910001.doc - 2008-08-18.
106 West SL, King V, Carey TS, et al. Systems to Rate the Strength of Scientific Evidence. Evidence Report, Technology Assessment No. 47. (Prepared by the Research Triangle Institute-University of North Carolina Evidence-based Practice Center under Contract No. 290-97-0011). AHRQ Publication No. 02-E016. Rockville, MD: Agency for Healthcare Research and Quality. April 2002.
107 Viswanathan M, Visco A, Hartmann K, et al. Cesarean Delivery on Maternal Request. Evidence Report/Technology Assessment No. 133. (Prepared by the RTI International-University of North Carolina Evidence-Based Practice Center under Contract No. 290-02-0016.) AHRQ Publication No. 06-E009. Rockville, MD: Agency for Healthcare Research and Quality March 2006.
108 Hedges L, Olkin I. Statistical Methods for Meta-Analysis. First ed. San Diego: Academic Press; 1985.
109 Higgins J, Thompson S. Quantifying heterogeneity in a meta-analysis. Stat Med. Jun 15. 2002;21(11):1539-1558. [pmid: 12111919].
110 Review Manager (RevMan). Version 4.2 for Windows ed. Copenhagen: The Nordic Cochrane Center, The Cochrane Collaboration; 2003.
111 Cooper H, Hedges L. The Handbook of Research Synthesis. New York: Russell Sage Foundation; 1994.
112 Hannah ME, Huh C, Hewson SA, Hannah WJ. Postterm pregnancy: putting the merits of a policy of induction of labor into perspective. Birth. Mar. 1996;23(1):13-19. [pmid: 8703252].
113 Leijon I, Finnstrom O, Hedenskog S, Ryden G, Tylleskar J. Spontaneous labor and elective induction—a prospective randomized study. II. Bilirubin levels in the neonatal period. Acta Obstet Gynecol Scand. 1980;59(2):103-106. [pmid: 7405545].
114 Leijon I, Finnstrom O, Hedenskog S, Ryden G, Tylleskar J. Spontaneous labour and elective induction—a prospective randomized study. Behavioural assessment and neurological examination in the newborn period. Acta Paediatr Scand. Jul. 1979;68(4):553-560. [pmid: 463537].
115 Lampe LG, Komaromy B, Gaal J. Selective planned induction of labor. Acta Chir Acad Sci Hung. 1980;21(1):43-53. [pmid: 7197448].
116 Out JJ, Vierhout ME, Verhage F, Duivenvoorden HJ, Wallenburg HC. Elective induction of labor: a prospective clinical study, II: Psychological effects. J Perinat Med. 1985;13(4):163-170. [pmid: 4057032].
117 Out JJ, Vierhout ME, Wallenburg HC. Breast-feeding following spontaneous and induced labour. Eur J Obstet Gynecol Reprod Biol. Dec. 1988;29(4):275-279. [pmid: 3229541].
118 Stotland NE, Hopkins LM, Caughey AB. Gestational weight gain, macrosomia, and risk of cesarean birth in nondiabetic nulliparas. Obstet Gynecol. Oct. 2004;104(4):671-677. [pmid: 15458884].
119 Greenberg MB, Cheng YW, Hopkins LM, Stotland NE, Bryant AS, Caughey AB. Are there ethnic differences in the length of labor. Am J Obstet Gynecol. Sep. 2006;195(3):743-748. [pmid: 16949407].
120 Greenberg MB, Cheng YW, Sullivan M, Norton ME, Hopkins LM, Caughey AB. Does length of labor vary by maternal age. Am J Obstet Gynecol. Oct. 2007;197(4):428. e421–427. [pmid: 17904990].
121 Hopkins LM, Caughey AB, Glidden DV, Laros RK Jr. Racial/ethnic differences in perineal, vaginal and cervical lacerations. Am J Obstet Gynecol. Aug. 2005;193(2):455-459. [pmid: 16098870].
122 Crane JM. Does the length of labor vary by maternal age?. Am J Obstet Gynecol. 2007;197(428):e1-7.
123 Gopalani S, Bennett K, Critchlow C. Factors predictive of failed operative vaginal delivery. Am J Obstet Gynecol. Sep. 2004;191(3):896-902. [pmid: 15467561].
124 Bianco A, Stone J, Lynch L, Lapinski R, Berkowitz G, Berkowitz RL. Pregnancy outcome at age 40 and older. Obstet Gynecol. Jun. 1996;87(6):917-922. [pmid: 8649698].
125 Weinstein MC, Stason WB. Foundations of cost-effectiveness analysis for health and medical practices. N Engl J Med. Mar 31. 1977;296(13):716-721. [pmid: 402576].
126 Siegel JE, Weinstein MC, Russell LB, Gold MR. Recommendations for reporting cost-effectiveness analyses. Panel on Cost-Effectiveness in Health and Medicine. Jama. Oct 23–30. 1996;276(16):1339-1341. [pmid: 8861994].
127 Smith GC. Life-table analysis of the risk of perinatal death at term and post term in singleton pregnancies. Am J Obstet Gynecol. Feb. 2001;184(3):489-496. [pmid: 11228508].
128 Gilbert WM, Nesbitt TS, Danielsen B. Associated factors in 1611 cases of brachial plexus injury. Obstet Gynecol. Apr. 1999;93(4):536-540. [pmid: 10214829].
129 Nesbitt TS, Gilbert WM, Herrchen B. Shoulder dystocia and associated risk factors with macrosomic infants born in California. Am J Obstet Gynecol. Aug. 1998;179(2):476-480. [pmid: 9731856].
130 Caughey AB, Stotland NE, Washington AE, Escobar GJ. Maternal and obstetric complications of pregnancy are associated with increasing gestational age at term. Am J Obstet Gynecol. Feb. 2007;196(2):155. e151–156. [pmid: 17306661].
131 Alexander JM, MC DD, Leveno KJ. Prolonged pregnancy: induction of labor and cesarean births. Obstet Gynecol. Jun. 2001;97(6):911-915. [pmid: 11384695].
132 Alexander JM, McIntire DD, Leveno KJ. Forty weeks and beyond: pregnancy outcomes by week of gestation. Obstet Gynecol. Aug. 2000;96(2):291-294. [pmid: 10908780].
133 Boulet SL, Alexander GR, Salihu HM, Pass M. Macrosomic births in the united states: determinants, outcomes, and proposed grades of risk. Am J Obstet Gynecol. May. 2003;188(5):1372-1378. [pmid: 12748514].
134 Dargaville PA, Copnell B. The epidemiology of meconium aspiration syndrome: incidence, risk factors, therapies, and outcome. Pediatrics. May. 2006;117(5):1712-1721. [pmid: 16651329].
135 Rouse DJ, Owen J, Goldenberg RL, Cliver SP. The effectiveness and costs of elective cesarean delivery for fetal macrosomia diagnosed by ultrasound. Jama. Nov 13. 1996;276(18):1480-1486. [pmid: 8903259].
136 Bochner CJ, Williams J 3rd, Castro L, Medearis A, Hobel CJ, Wade M. The efficacy of starting postterm antenatal testing at 41 weeks as compared with 42 weeks of gestational age. Am J Obstet Gynecol. Sep. 1988;159(3):550-554. [pmid: 3421252].
137 Harper MA, Byington RP, Espeland MA, Naughton M, Meyer R, Lane K. Pregnancy-related death and health care services. Obstet Gynecol. Aug. 2003;102(2):273-278. [pmid: 12907099].
138 Farquhar PH. Utility assessment methods. Mgmt Sci. 1984;30:1283-1300.
139 Torrance GW. Measurement of health state utilities for economic appraisal. J Health Econ. Mar. 1986;5(1):1-30. [pmid: 10311607].
140 Kuppermann M, Nease RF, Learman LA, Gates E, Blumberg B, Washington AE. Procedure-related miscarriages and Down syndrome-affected births: implications for prenatal testing based on women's preferences. Obstet Gynecol. Oct. 2000;96(4):511-516. [pmid: 11004350].
141 Caughey AB, Angeja A, Vargas J, Gomez R, Washington AE. Quantitative Evaluation of Preference for Mode of Delivery in Pregnant Chilean Women. Med Decis Making. 2003;23:634.
142 Goeree R, Hannah M, Hewson S. Cost-effectiveness of induction of labour versus serial antenatal monitoring in the Canadian Multicentre Postterm Pregnancy Trial. CMAJ. May 1. 1995;152(9):1445-1450. [pmid: 7728693].
143 Gold MR, Siegel JE, Russell LB, Weinstein MC. Cost-Effectiveness in Health and Medicine. New York, NY: Oxford University Press; 1996.
144 Sanchez-Ramos L, Bernstein S, Kaunitz AM. Expectant management versus labor induction for suspected fetal macrosomia: a systematic review. Obstet Gynecol. Nov. 2002;100(5 Pt 1):997-1002. [pmid: 12423867].
145 Sande HA, Tuveng J, Fonstelien T. A prospective randomized study of induction of labor. Int J Gynaecol Obstet. Aug. 1983;21(4):333-336. [pmid: 6141089].
146 Nicholson JM, Kellar LC, Cronholm PF, Macones GA. Active management of risk in pregnancy at term in an urban population: an association between a higher induction of labor rate and a lower cesarean delivery rate. Am J Obstet Gynecol. Nov. 2004;191(5):1516-1528. [pmid: 15547519].
147 Nicholson JM, Yeager DL, Macones G. A preventive approach to obstetric care in a rural hospital: association between higher rates of preventive labor induction and lower rates of cesarean delivery. Ann Fam Med. Jul-Aug. 2007;5(4):310-319. [pmid: 17664497].
148 Nicholson JM, Kellar LC, Kellar GM. The impact of the interaction between increasing gestational age and obstetrical risk on birth outcomes: evidence of a varying optimal time of delivery. J Perinatol. Jul. 2006;26(7):392-402. [pmid: 16801956].
149 Nicholson J, Caughey A, Parry S, Macones G. Prospective Randomized Trial of the Active Management of Risk in Pregnancy at Term: improved birth outcomes from prostaglandin-assisted preventive labor induction. Am J Obstet Gynecol. 2007;197:S37.
150 Hatfield AS, Sanchez-Ramos L, Kaunitz AM. Sonographic cervical assessment to predict the success of labor induction: a systematic review with metaanalysis. Am J Obstet Gynecol. Aug. 2007;197(2):186-192. [pmid: 17689645].
151 Bishop EH. Pelvic Scoring for Elective Induction. Obstet Gynecol. Aug. 1964;24:266-268. [pmid: 14199536].
152 Weiss JL, Malone FD, Emig D, et al. Obesity, obstetric complications and cesarean delivery rate—a population-based screening study. Am J Obstet Gynecol. Apr. 2004;190(4):1091-1097. [pmid: 15118648].
153 Wolf FM, Gruppen LD, Billi JE. Differential diagnosis and the competing-hypotheses heuristic. A practical approach to judgment under uncertainty and Bayesian probability. Jama. May 17. 1985;253(19):2858-2862. [pmid: 3989960].
154 Stotland NE, Washington AE, Caughey AB. Prepregnancy body mass index and the length of gestation at term. Am J Obstet Gynecol. Oct. 2007;197(4):378. e371–375. [pmid: 17904967].
155 Caughey AB. Cost-effectiveness analysis of prenatal diagnosis: methodological issues and concerns. Gynecol Obstet Invest. 2005;60(1):11-18. [pmid: 15692215].
156 Little SE, Caughey AB. Acyclovir prophylaxis for pregnant women with a known history of herpes simplex virus: a cost-effectiveness analysis. Am J Obstet Gynecol. Sep. 2005;193(3 Pt 2):1274-1279. [pmid: 16157151].
157 Menacker F, Curtin SC. Trends in cesarean birth and vaginal birth after previous cesarean, 1991-99. Natl Vital Stat Rep. Dec 27. 2001;49(13):1-16.
158 Hamilton B, Martin J, Ventura S. Births: preliminary data for 2006. Natl Vital Stat Rep. 2007;56:1-18. [pmid: 18277471].
159 U.S. Department of Health and Human Services: Office of Disease Prevention and Health Promotion. Healthy People 2010. Nasnewsletter. 2000;15:3.
160 Stotland NE, Caughey AB, Breed E, Escobar GJ. Macrosomia in a large managed care cohort: maternal risk factors and complications. International Journal of Gynecology and Obstetrics. 2004;87(3):220-226. [pmid: 15548393].
161 Ogden CL, Carroll MD, Curtin LR, McDowell MA, Tabak CJ, Flegal KM. Prevalence of overweight and obesity in the United States, 1999-2004. Jama. Apr 5. 2006;295(13):1549-1555. [pmid: 16595758].
162 Meikle SF, Steiner CA, Zhang J, Lawrence WL. A national estimate of the elective primary cesarean delivery rate. Obstet Gynecol. Apr. 2005;105(4):751-756. [pmid: 15802401].
163 NIH State-of-the-Science Conference Statement on Cesarean Delivery on Maternal Request. NIH Consens Sci Statements. March 27–29 2006;23:1–29.
164 Murthy K, Grobman WA, Lee TA, Holl JL. Association between rising professional liability insurance premiums and primary cesarean delivery rates. Obstet Gynecol. Dec. 2007;110(6):1264-1269. [pmid: 18055719].
165 Rouse DJ, Owen J, Hauth JC. Active-phase labor arrest: oxytocin augmentation for at least 4 hours. Obstet Gynecol. Mar. 1999;93(3):323-328. [pmid: 10074971].
166 Rouse DJ, Owen J, Savage KG, Hauth JC. Active phase labor arrest: revisiting the 2-hour minimum. Obstet Gynecol. Oct. 2001;98(4):550-554. [pmid: 11576566].
167 Myers D, Cheng Y, Shaffer B, Kaimal A, Bianco K, Caughey A. Active Phase Arrest: Who Will Deliver Vaginally?. Am J Obstet Gynecol. 2006;195:S91.
168 Breart G, Goujard J, Maillard F, Chavigny C, Rumeau-Rouquette C, Sureau C. [Comparison of 2 obstetrical attitudes vis-a-vis inducing labor at term. Randomized study]. J Gynecol Obstet Biol Reprod (Paris). 1982;11(1):107-112. [pmid: 7096941].