# Acknowledgments

We thank Marilyn Tinsley at the Stanford University Lane Library for her help with the literature searches. We also acknowledge with much gratitude our expert advisors and peer reviewers who are listed in Appendix E.