# Systematic Review of Elective Induction of Labor

We conducted a systematic review of the published literature to evaluate maternal, fetal and neonatal risks of elective induction of labor compared with expectant management, and to evaluate the predictors of failed induction of labor. In this chapter, we present our methods for this review and the results.

## Systematic Review Methods

### Topic Development

The topic for this report was nominated by the American College of Obstetricians and Gynecologists (ACOG). The Key Questions were developed from an initial set of Key Questions provided by AHRQ with the input from ACOG, the Stanford-UCSF Evidence-Based Practice Center, and the Technical Expert Panel (TEP).

### Search Strategy

We searched MEDLINE^®^ using medical subject headings (MeSH) keywords to identify all published studies on elective induction of labor (indexed January 1, 1966 to May 21, 2007) in humans. We performed title searches to identify additional potentially relevant English-language articles (indexed through June 6, 2007). We also manually reviewed the reference lists of included articles and bibliographies of systematic reviews to identify additional relevant articles. Appendix A provides the details of our search strategy.

### Study Selection

To address Key Questions 1 and 2, an article had to compare outcomes in women who had undergone induction of labor without a specific indication prior to 42 weeks gestational age with women who were either managed expectantly or had spontaneous labor.

We defined elective induction of labor as an induction of labor at or after 37 weeks and prior to 42 weeks of gestation without either a maternal or fetal indication for the induction. While it has become increasingly common to induce women at 41 0/7 weeks of gestation and to call this practice a “post-dates induction”, the most recent ACOG guideline defines postterm as 42 weeks of gestation and beyond.^88^ Studies in which we could determine that at least 20 percent of the women were at 42 weeks of gestation and beyond were considered to be postterm. Certain preventive indications such as induction to prevent macrosomia, preeclampsia, or intrauterine growth restriction (IUGR) have not been recognized as medical indications of labor; therefore, studies where women were induced for the prevention of any of these conditions were considered elective.

We included studies on elective induction of labor only if the article reported mode of delivery (cesarean, spontaneous vaginal or operative vaginal deliveries), or maternal or neonatal outcomes. Studies were considered to have reported maternal infection if they reported chorioamnionitis, endomyometritis, post-partum fever, or “maternal infection” (without providing specific detail).

To address Key Question 3, we included all studies on induction of labor (irrespective of whether the induction was elective or indicated and whether there was a comparison group) if the article reported predictors of success or failure for induction. We sought to identify maternal characteristics that would predict higher rates of a successful labor induction. For this analysis, we evaluated predictors such as maternal age, parity, race/ethnicity, obesity, obstetric history, gestational age, and cervical status. We excluded articles that specifically studied different methods of induction (for example, articles that compared the use of prostaglandins, oxytocin, and mechanical dilation such as Foley bulb etc. as different methods for inducing labor).

Study design. We included randomized controlled trials (RCT), cohort studies, and case-control studies. We excluded commentaries, case studies, letters, and reviews. Because most RCTs of elective induction compared elective induction of labor to expectant management and most of the observational studies compared elective induction of labor to spontaneous labor, we included both types of study designs but analyzed them separately. As noted in the introduction, because the comparison between elective induction of labor and spontaneous labor is fundamentally flawed, we present these findings primarily to demonstrate the current state of the existing literature as well as to explore the differential findings between the RCTs and the observational studies.

Patient population. We excluded articles addressing postterm pregnancy (greater than or equal to 42 weeks gestational age), prior cesarean deliveries, multiple gestations, medical or obstetrical complications of pregnancy such as preeclampsia, diabetes mellitus, isoimmunization, fetal anomalies or abnormal antepartum testing.

Other exclusion criteria. We included duplicate articles of the same study only once in our analyses. We excluded articles for which the data reported were not usable for our analyses (e.g., an article reporting only the odds ratio without providing the number of events and sample size for outcomes or predictors of interest would have been excluded).

### Data Extraction

Two authors independently reviewed the title and abstract of all studies retrieved from our search to assess whether the article met inclusion criteria. Conflicts regarding whether or not an article should undergo full text review were resolved by re-review and discussion. The full text of articles not previously excluded were reviewed independently by two authors. Each reviewer extracted the following information from each included study: Study period, location and setting of study, whether or not the induction was elective or indicated, method utilized to achieve labor induction, study design, definition of a successful induction, inclusion and exclusion criteria (for elective induction of labor studies), mode of delivery, maternal and neonatal outcomes for all patients with stratification by parity (for studies on elective induction of labor), predictors of a successful or failed induction (for all induction of labor studies) and quality assessment variables. All articles were reviewed and data was entered into pre-tested forms (Appendix B).

### Quality Assessment and Applicability of Included Studies

We evaluated the extent to which the included studies were designed to address the Key Questions. Some studies of elective induction of labor have key methodologic flaws limiting the ability to adequately answer our Key Questions. Thus, our quality assessments were based primarily on the extent to which the included studies were designed prospectively, ensured that intervention and control patients were similar with respect to the key factors affecting cesarean delivery rates (e.g., maternal age, parity, body mass index, cervical stage, gestational age) and were adequately powered to evaluate relatively rare outcomes of interest for both mothers and neonates. The literature reports inconsistent findings on the association between induction of labor and cesarean delivery: RCTs have reported decreases or no differences in cesarean delivery among women who were induced, whereas older observational studies have reported increased rates of cesarean delivery among induced women.^12,^ ^22,^ ^86^ One explanation for this contradictory evidence is that most observational studies did not control for gestational age as a confounder in their analysis. Induction of labor is likely to occur more often with increasing gestational age, and increasing gestational age is itself a risk factor for cesarean delivery.^98,^ ^99^ Another important consideration for study design is the protective effect that induction of labor confers on key outcomes of interest (e.g., cesarean delivery, preeclampsia). For example, the risk of preeclampsia increases as gestational age increases; if a woman undergoes induced labor at an earlier gestational age rather than waiting to go into spontaneous labor, any study that examines the effect of induced labor on preeclampsia will show reduced rates of preeclampsia in the induced group, since the risk for that group has now been eliminated.

As discussed in Chapter 1, since most RCTs compare induction of labor to expectant management, RCTs are the preferred study design for assessing the effects of induction of labor. Observational studies may not always control for gestational age in their analyses; and the clinical decision is whether to end the pregnancy now (at a particular gestational age) or wait until a later gestational age (i.e. expectant management) (Figure 1.1B). However, most observational studies compare induction of labor at a particular gestational age with spontaneous labor at the same gestational age (Figure 1.1A) which is not an appropriate comparison since this method does not address implications of the clinical decision being made. Since most RCTs compare induction of labor to expectant management, the effects of this clinical question are examined; alternatively, observational studies that compare induction of labor at a specific gestational age to spontaneous labor at a later gestational age also provide useful evidence.

We based our approach to evaluating the quality and applicability of the included articles on established AHRQ guidelines including the “Guide for Conducting Comparative Effectiveness Reviews”^105^ and “Systems to Rate the Strength of Scientific Evidence”^106^ and recent AHRQ reports including the review of elective cesarean by Viswanathan et al.^107^ Using these sources, we developed specific criteria for evaluating the quality of the individual included studies and rating their applicability to each of our Key Questions as good, fair, or poor. This rating system does not attempt to assess the comparative validity of studies across different design strata. For example, a “fair” RCT is not judged to have the same methodological quality as a “fair” observational study. Thus, both study design and quality grade should be considered when interpreting the methodological quality of a study. Appendix B presents the quality assessment and applicability forms.

In the sections that follow on quality and applicability rating, we describe our iterative approach to rating each study—first, rating the quality of the individual study and then rating the applicability of each study to the Key Questions. Two abstractors independently rated each article on each of the categories as indicated on the quality and applicability assessment forms. We reconciled differences by consensus and assigned the overall scores as described below.

#### Specific aspects of quality rating - randomized controlled trials

Comparison group. One of the key design aspects of studies of elective induction of labor is that they have the appropriate comparison group of expectant management. This group includes all women managed expectantly, both those who went into spontaneous labor as well as those who were induced for other reasons. As long as the study had the appropriate comparison group, it was assigned an initial quality rating of good. However, if it did not utilize this comparison group, but instead excluded women who were eventually induced, it received an overall poor quality rating despite other aspects of the quality assessment.

Randomization approach and implementation. Because parity is such a critical predictor of outcomes after induction of labor, we sought to evaluate the extent to which the included studies stratified randomization by parity. We also sought to identify whether the experimental and control groups appeared to be balanced in important, identifiable confounding factors, our assumption being that if such variables were similar, other, unidentifiable potential confounders would also likely be similar. If studies described the approach to randomization, there was no major flaw in randomization, randomization was stratified by parity or only included one parity group, and achieved a balance of select characteristics in the two groups, studies would maintain their good quality rating; if any of these items were not met, the quality rating of studies would be reduced by one level. If good balance in the populations was not achieved, but authors utilized multivariable analyses to control for potential confounding, the study maintained its quality rating.

Measurement of outcomes: Masking and loss to follow-up. Because neither the women being electively induced nor the providers caring for them can be masked to this event, this item was relevant only to the assessment of the outcomes. Thus, we evaluated two components of outcome assessment: Masking of the assessors (e.g. data abstractors) and loss to follow-up. While we believe masking to the assessment of outcomes is important, we felt that in this setting it should not lead to a lower overall quality rating, thus we evaluated this aspect of the study design, but did not lower the quality rating as a result. Because of the immediate nature of many of the outcomes, we did not specifically reduce the quality rating if a study did not specifically report the loss to follow-up. However, as with masking, we evaluated the study as to its reporting of loss to follow-up. Further, even if it was not reported, we were able to assess the actual loss to follow-up by comparing the number of subjects recruited to those with results. We suspected that most of the follow-up would be short term with respect to both maternal and neonatal outcomes and that with short term follow-up greater than or equal to 90 percent, the study would maintain its quality rating. With less than 90 percent follow-up in the short term, either immediately postpartum or at the postpartum visit, the study quality level rating would be reduced one quality rating level from good to fair or fair to poor. If a study reported only outcomes that would occur in the immediate peripartum period, then the study was only evaluated for follow-up in that time period.

Sample size. This item was intended to identify whether the study population was large enough to have adequate power. We utilized both the actual sample size as well as whether any sample size calculations were performed and the study recruited the projected sample size to evaluate this component of quality. If a sample size calculation was performed a priori, then the study maintained its overall quality rating level. However, if no sample size calculation was conducted during the study design, we estimated that in order to identify a 50 percent difference in cesarean delivery from a baseline rate of 20 percent with a two-sided alpha of 0.05, that 400 subjects would be needed. Thus, studies with less than 400 subjects were downgraded one quality rating level, unless they actually found a statistically significant difference in their primary outcome or they conducted a sample size calculation post hoc that justified their actual sample size.

Statistical analysis. This item was intended to examine whether the investigators analyzed the data from their study appropriately and examined whether intention-to-treat analyses were conducted, if investigators controlled for confounding if necessary, and conducted stratified analyses by parity if necessary. While statistical analysis is important, we did not think that this topic should dominate all of the other quality criteria, so even if all of the responses to the statistical quality items were negative, this reduced the overall quality rating at most one level.

#### Specific aspects of quality rating - observational studies

Comparison group. Again, given the importance of the appropriate comparison group of expectant management which includes all women managed expectantly, both those who went into spontaneous labor as well as those who were induced for other reasons, if a study had the appropriate comparison group, it would begin with a good quality rating (this was relevant only for Key Questions 1 and 2). However, if it did not utilize this comparison group, but instead excluded women who were eventually induced, it received a poor quality rating overall despite other aspects of the quality assessment. For observational studies that were utilized to examine Key Question 3 or Key Question 4, the response to this item had no effect on the quality related to the study's ability to address those Key Questions.

Study design. Specifically, because the randomized trials were all prospective, and prospective identification of elective induction of labor is intrinsically going to be superior to retrospective identification of such patients we included this item. Further, to ensure that both identifiable and potentially unidentifiable characteristics and potential confounders were similar between the two groups, we examined this issue. Finally, because follow-up of study participants is important for the reduction of bias due to self-selection, this item was included for evaluation as well. If the study was prospective, had comparable study groups in terms of patient characteristics (or controlled for potential confounding), and maintained a follow-up rate of 90 percent or better, it maintained its quality rating. If the study was retrospective, its quality rating level was reduced from good to fair. If the study did not have comparable study groups or utilize multivariable analyses to control for confounding, its quality rating was reduced from good to fair or fair to poor. Regarding loss to follow-up, this was only evaluated in prospective studies. Because of the immediate nature of many of the outcomes, we did not specifically reduce the quality rating if a study did not specifically report the loss to follow-up, though we did evaluate this component as it should be included. Further, even if it was not reported, we were able to assess the actual loss to follow-up by comparing the number of subjects recruited to those with results. We suspected that most of the follow-up would be short term with respect to both maternal and neonatal outcomes and that with short term follow-up greater than or equal to 90 percent, the study would maintain its quality rating. With less than 90 percent follow-up in the short term, either immediately postpartum or at the postpartum visit, the study quality level rating would be reduced one quality rating level from good to fair or fair to poor. If a study reported only outcomes that would occur in the immediate peripartum period, then the study was only evaluated for follow-up in that time period.

Sample size. We used this item to identify whether the study population was large enough to have adequate power. We utilized both the actual sample size as well as whether any sample size calculations were performed to evaluate this component of quality. If a sample size calculation was performed a priori, then the study maintained its overall quality rating level. However, if no sample size calculation was conducted during the study design, we estimated that in order to identify a 50 percent difference in cesarean delivery from a baseline rate of 20 percent with a two-sided alpha of 0.05, that 400 subjects would be needed. Thus, studies with less than 400 subjects were downgraded one quality rating level, unless they actually found a statistically significant difference in their primary outcome or they conducted a sample size calculation post hoc that justified their actual sample size.

Statistical analysis. We used this item to examine whether the investigators analyzed the data from their study appropriately and whether they controlled for confounding by utilizing multivariable analyses and performed stratified analyses by parity (if necessary). While statistical analysis is important, we did not think that this topic should dominate all of the other quality criteria, so even if all of the responses to the statistical quality metrics were negative, we reduced the overall quality rating at most one level.

Specific aspects of applicability ratings. In addition to evaluating the quality of each of the included studies, we evaluated the extent to which each included study was applicable to our Key Questions. While Key Questions 1 and 2 examined maternal and neonatal outcomes in the setting of elective induction of labor, Key Question 3 examined predictors of success and Key Question 4 examined how induction of labor success was defined. Thus, for key questions 1 and 2 it was important that the study be one of elective induction of labor and utilize the appropriate comparison group of expectant management. For key question 3, any study including women undergoing induction of labor could shed some light on the predictors of a successful induction of labor, though we thought the applicability would be stronger in studies on elective induction of labor. For key question 4, any study defining labor induction success seemed to be applicable to the question. The specific factors that we considered to evaluate applicability are noted below:

Topics covered. Many studies only provided data on a few of the outcomes of interest for any of the Key Questions. Thus, by definition, if the study did not examine an outcome, we did not consider it applicable to that outcome.

Comparison group. If the comparison group for studies examining components of either Key Question 1 or 2 was not expectant management, then the study was deemed to have poor applicability for these two Key Questions.

Elective induction of labor. While studies needed to specifically address elective induction of labor by definition for Key Questions 1 or 2, there were also studies that examined induction of labor in women with indications for Key Question 3. If the study was not of women with an elective induction of labor, then the applicability was deemed fair for Key Question 3; however, if it was of elective induction of labor, then it was rated as having good applicability to Key Question 3.

Timing of study. Because clinical care changes over time and, in particular, the overall cesarean delivery rate has changed significantly from the 1970s and early 1980s to the current time, studies in which the clinical care was provided prior to 1985 were downgraded one step in applicability if they also did not utilize more recent labor induction techniques mentioned below. Of note, while the cesarean delivery rate has continued to rise over the past 10 to 15 years, the rise has not been nearly as rapid as it was between 1970 and 1985, which was why that time period was chosen. For studies that did not report the specific time period in which the study was conducted, we assumed that studies published in 1990 and beyond met this criterion.

Location of study. Because the clinical environment and in particular, the medical malpractice environment is particularly unique within the U.S., any study not conducted in the U.S. was downgraded by one step in applicability.

Labor induction method. In particular, the use of prostaglandin agents and Foley catheter balloons for cervical ripening have led to improved success of induction of labor. Thus, we downgraded the applicability of any studies in which prostaglandins or other cervical ripening agents were not utilized in induction of labor regardless of when the study was conducted. For studies which did not specifically report methods of induction, we deferred to the timing of the study as these methods are more recent developments.

Less than 41 weeks gestational age. ACOG continues to define postterm pregnancy as 42 completed weeks of gestation and beyond; however, there is an increasing trend for the threshold of 41 0/7 weeks being more commonly accepted as a time for labor induction to be indicated. Thus, some clinicians and policymakers deem pregnancies less than 41 weeks as the group of interest for elective induction of labor. Thus, we considered the applicability of studies to this population. If a study was conducted on only women prior to 41 weeks gestation or included women prior to 41 weeks and conducted a stratified analysis, it was considered to have good applicability to this group of women. Thus, the overall applicability rating determined from the other items would be maintained to women less than 41 weeks of gestation. If it included women less than 41 weeks, but did not stratify, or if it did not include women less than 41 weeks of gestation, it was considered to have poor applicability to women less than 41 weeks of gestation.

Overall quality and applicability rating of the literature for the key questions. The overall grade for strength of evidence reflects a global assessment that takes the required domains of both quality and applicability of the individual studies directly into account. In addition, we considered the consistency of the results of the included studies and volume of the literature to rate the overall quality for each of the Key Questions. Consistent with the AHRQ guidelines in the “Guide for Conducting Comparative Effectiveness Reviews”, we assigned a grade of high, moderate, low, or insufficient to each of the outcomes. A grade other than insufficient implied that there was enough evidence available to estimate a point estimate of the effect of either elective induction of labor or a predictor on the success of induction of labor. However, in cases where there was either no evidence or the evidence was too inconsistent or underpowered to draw a conclusion, we assigned a grade of insufficient. For example, if there were two small randomized trials that examined the effect of induction of labor on a maternal outcome and both had an odds ratio point estimate that had clinical implications, but even when combined was still statistically insignificant, we considered this as insufficient evidence. Another example of insufficient evidence would be in the case of two studies where each found a statistically significant effect, but in the opposite direction.

### Data Synthesis

To evaluate the maternal and neonatal risks of elective induction versus expectant management (Key Questions 1 and 2), we computed two summary effect sizes for each outcome of interest reported by more than four studies: A summary odds ratio and a summary risk difference. Both summary effect sizes were computed using random effects models. We present the summary odds ratio as the primary outcome metric in our figures and text, and we also provide the summary risk difference when applicable. We present the figures showing the summary risk difference in Appendix C.

We also conducted univariate analysis to evaluate the effect of the following variables on our outcomes of interest: Year (1990 and earlier versus after 1990), country (U.S. versus non-U.S.), and setting (academic, community hospital, both, or multi-center).

To evaluate the predictors of cesarean delivery (Key Question 3), we computed the summary odds ratio and risk difference for predictors that were reported in more than four studies. Predictors that were reported in fewer studies are presented in tabular format.

We assessed the statistical heterogeneity for all computed summary effects by calculating the Q statistic (designated Q statistics with p <0. 05 as heterogeneous) and I^2^ statistic (designated I^2^ statistics greater than 50 percent as heterogeneous).^108,^ ^109^ The I^2^ statistic measures the extent of inconsistency among the studies' results, which is interpreted as the approximate proportion of total variation in study estimates due to heterogeneity rather than sampling error.^110^

We performed sensitivity analyses to evaluate the robustness of our results. We removed each study individually to evaluate that study's effect on the summary estimates. We conducted a cumulative analysis after ordering studies by year, to determine if there was a trend over time. We defined study year as the year in which the study was started; if this was not reported, then we used the publication year for the study year.

We assessed publication bias by visual inspection of funnel plots to evaluate the association between the sample size of a study and the likelihood of that study reporting a statistically significant outcome. We also calculated the fail safe N (the number of missing studies that would be required to change a significant summary effect to one that was not statistically significant).^111^ We performed analyses using Comprehensive Meta-Analysis v.2 software (Biostat, NJ, U.S.A.).

### Peer Review

A draft of this evidence report was reviewed by experts in obstetrics and gynecology, meta-analysis, and decision analysis, and by representatives of AHRQ (Appendix E). We provided a detailed response to each of their comments and incorporated changes into the final version of this Evidence Report. However, the findings and conclusions are those of the authors, who are responsible for the content of the report.

## Systematic Review Results

Our search strategy yielded 3,722 published articles. After title and abstract review, 392 articles were retrieved for full text review. Of these, an additional 316 articles were excluded (Appendix D) leaving 76 unique studies (10 articles were duplicate reports); 34 articles compared elective induction of labor with a control group and 42 additional articles addressed any induction of labor reporting on predictors of failed induction (Figure 2.1).

Figure 2.1 Literature search

The results are presented in three sections: 1) elective induction of labor studies; 2) predictors of cesarean delivery; and 3) definitions of failed induction. In the first section we present a general description of our included studies, quality assessment of studies, followed by our synthesis of maternal outcomes (Key Question 1) and neonatal outcomes (Key Question 2). In the second section we present a general description of our included studies, quality assessment, and predictors of cesarean delivery (Key Question 3), followed by the definition of successful or failed induction (Key Question 4) reported in our included studies.

### Elective Induction of Labor Studies

General description of included studies. We identified 34 studies comparing maternal or perinatal outcomes in women with elective induction of labor to either expectant management or spontaneous labor. Of these, 11 were randomized controlled trials (RCTs) (Table 2.1) and the remaining were observational studies (Table 2.2).

Table 2.1 RCTs of elective induction of labor: Study information

Article | Year of Publication | Study Period | Location | Setting | Control Group | Sample Size | | Induction Method | Study Rating | Applicability to KQ1 and/or KQ2 | Applicability to KQ 1 and/or KQ2 for GA<41 weeks | Applicability to KQ3
| | | | | | Control Group | Induced Labor
Amano et al.^63^ ^±^ | 1999 | NS | Japan | Academic Center | SL | 72 | 63 | Oxytocin, AROM, PGE_2_ gel, some laminaria tents | Poor | Poor | Poor | -
Cole et al.^67^ | 1975 | NS | Scotland | Academic Center | EM | 117 | 111 | Oxytocin, AROM | Poor | Poor | Poor | Poor
Dyson et al.^74^ ^*^ | 1987 | 1983-1985 | United States | Community Hospital | EM | 150 | 152 | Oxytocin, AROM, PGE_2_ gel | Fair | Fair | Poor | Fair
Egarter et al.^55^ ^*#^ | 1989 | NS | Austria | Academic Center | EM | 165 | 180 | PGE_2_ gel | Poor | Fair | Poor | Fair
Gelisen et al.^8^ | 2005 | NS | Turkey | Academic Center | EM | 300 | 300 | Oxytocin, Misoprostol, Foley catheter | Fair | Fair | Poor | -
Hannah et al.^27,^ ^112^ | 1992 | Nov 1985–Dec 1995 | Canada | Multi-Center | EM | 1706 | 1701 | Oxytocin, AROM, PGE_2_ gel | Good | Fair | Poor | -
Heimstad et al.^59^ | 2007 | Sep 2002–Jul 2004 | Norway | Academic Center | EM | 254 | 254 | Oxytocin, AROM, Misoprostol | Fair | Fair | Poor | -
Martin et al.^66^ | 1978 | NS | Ireland | NS | SL | 92 | 92 | Oxytocin, AROM | Poor | Poor | Poor | Poor
Nielsen et al.^7^ ^*^ | 2005 | 1999-2002 | United States | Academic Center | EM | 110 | 116 | Oxytocin, AROM (either or both) | Fair | Fair | Poor | Fair
NICHHD^24^ ^≠+^ | 1994 | Dec 1987–Jul 1989 | United States | Multi-Center | EM | 174 | 264 | Oxytocin, AROM, PGE_2_ gel | Good | Good | Poor | Good
Tylleskar et al.^65^ and Leijon et al.^113,^ ^114^ ^±^ | 1979 | NS | Sweden | Multi-Center | EM | 41 | 43 | Oxytocin, AROM | Poor | Poor | Poor | Poor

Note: KQ=Key Question; GA=gestational age; NS=NS; SL=spontaneous labor; AROM=artificial rupture of membranes; PGE_2_=prostaglandin; EM=expectant management

± Nulliparous women only;

* Also reports predictors of Cesarean section in the setting of induction of labor;

# Also reports predictors of vaginal delivery within 24 hours in the setting of induction of labor;

≠ Also reports predictors of vaginal delivery within 12 hours in the setting of induction of labor

+ This RCT compared expectant management to two groups with different methods of induction; we combined the data from the two methods for our analysis since we were not comparing different methods of induction

Table 2.2 Observational studies of elective induction of labor: Study information

Article | Year of Publication | Study Period | Location | Setting | Control Group | Sample Size | | Induction Method | Study Rating | Applicability to KQ1 and/or KQ2 | Applicability to KQ 1 and/or KQ2 for GA<41 weeks | Applicability to KQ3
| | | | | | Control Group | Induced Labor
Belsky^34^ | 1982 | Sep 1979–Oct 1980 | United States | Community Hospital | SL | 918 | 35 | Oxytocin | Poor | Poor | Poor | -
Booth and Kurdyak^68^ | 1970 | Jan 1962–Sep 1967 | Canada | NS | SL | 213 | 213 | Oxytocin, Spartocin, AROM | Poor | Poor | Poor | Poor
Boulvain et al.^48^ ^×^ | 2001 | Jan 1990–Dec 1995 | Canada | Academic Center | SL | 3353 | 531 | Oxytocin, AROM PGE_2_ gel | Poor | Poor | Poor | -
Cammu et al.^17^ ^±^ | 2002 | 1996-1997 | Belgium | Academic Center and Community Hospital | SL | 7683 | 7683 | NS | Poor | Poor | Poor | -
Dublin et al.^61^ | 2000 | 1989-1993 | United States | Academic Center and Community Hospital | SL | 9648 | 2886 | NS | Poor | Poor | Poor | Fair
Glantz^9^ | 2005 | 1998-1999 | United States | NS | SL | 10608 | 1241 | Oxytocin, PGE_2_ gel | Poor | Poor | Poor | -
Heinberg et al.^15^ ^††^ | 2002 | 1994-2000 | United States | Community Hospital | SL | 304 | 304 | Oxytocin, PGE_2_ gel | Poor | Poor | Poor | Good
Hoffman et al.^69^ ^††^ | 2006 | Jan 2002–Mar 2004 | United States | Academic Center | SL | 1885 | 796 | Oxytocin, AROM, PGE_2_ gel, Foley catheter | Poor | Poor | Poor | Good
Lampe^31^ and Lampe et al.^115^ | 1986 | NS | Hungary | Academic Center | SL | 2750 | 2020 | Oxytocin, AROM | Poor | Poor | Poor | -
Luthy et al. ^11^ ^*^ ^±^ | 2004 | 1999-2000 | United States | Academic Center and Community Hospital | SL | 2673 | 542 | NS | Poor | Poor | Poor | Fair
Macer et al.^28^ ^*‡^ | 1992 | Jan 1990–Dec 1990 | United States | Community Hospital | SL | 253 | 253 | Oxytocin, AROM PGE_2_ gel | Poor | Poor | Poor | Good
Maslow and Sweeny^62^ | 2000 | 1997-1998 | United States | NS | SL | 872 | 263 | NS | Poor | Poor | Poor | Good
McBride et al.^37^ | 1977 | 1970-1971 | Australia | NS | SL | 32 | 69 | Oxytocin, AROM | Poor | Poor | Poor | -
Melton et al.^64^ | 1979 | Jan 1976–Dec 1976 | United States | Academic Center and Community Hospital | SL | 63 | 63 | Oxytocin, AROM, PGE_2_ gel | Poor | Poor | Poor | -
Mukherjee and Sood^76^ | 1995 | 1992-1993 | India | Academic Center | SL | 100 | 100 | Oxytocin, AROM | Poor | Poor | Poor | Poor
Prysak and Castronova^21^ | 1998 | 1995-1996 | United States | NS | SL | 461 | 461 | Oxytocin, AROM | Poor | Poor | Poor | Good
Robson et al.^22^ | 1997 | Jul 1994–Jun 1995 | Australia | Academic Center | SL | 1092 | 146 | Oxytocin, AROM PGE_2_ gel | Poor | Poor | Poor | Fair
Seyb et al.^20^ ^±^ | 1999 | Nov 1996–Jun 1997 | United States | Academic Center | SL | 1124 | 143 | Oxytocin | Poor | Poor | Poor | Good
van Gemund et al.^47^ | 2003 | 1997-1999 | United States | Academic Center | SL | 122 | 122 | Oxytocin, AROM PGE_2_ gel | Poor | Poor | Poor | Fair
Vierhout et al.^75^ and Out et al.^116,^ ^117^ | 1985 | May 1980 – Sep 1981 | Netherlands | Academic Center | SL | 156 | 184 | Oxytocin, AROM | Poor | Poor | Poor | -
Vrouenraets et al.^60^ ^*±^ | 2005 | 2000-2002 | Netherlands | NS | SL | 765 | 189 | Oxytocin, AROM, PGE_2_ gel | Poor | Poor | Poor | Fair
Wilailak et al.^71^ ^*^ | 1993 | Jan 1990–Jun 1990 | Thailand | NS | SL | 249 | 262 | Oxytocin, AROM | Poor | Poor | Poor | Poor
Yeast et al.^50^ | 1999 | 1990-1997 | United States | NS | SL | 4086 | 197 | PGE_2_ gel | Poor | Poor | Poor | Good

KQ=Key Question; GA=gestational age; SL=spontaneous labor; NS=not specified; AROM=artificial rupture of membranes; PGE_2_=prostaglandin

* Also reports predictors of Cesarean section in the setting of induction of labor

‡ Also reports predictors of spontaneous vaginal delivery in the setting of induction of labor

× Also reports predictors of overall vaginal delivery in the setting of induction of labor

± Study conducted among nulliparous women only;

†† Study conducted among multiparous women only

RCTs. In nine (82 percent) RCTs, women who were expectantly managed were designated as the control group, and in two RCTs the control group was women who had spontaneous labor (i.e., women in the control arm who were induced later were either excluded from the analysis or analyzed as the induction group). In one study, the patient population was restricted to only nulliparous women;^63^ for the remaining studies, inclusion was not restricted on the basis of parity. The oldest of these studies was conducted in 1975 and the most recent in 2005. Seventy-three percent of these studies were conducted outside the U.S. (Canada, Europe, Turkey, and Japan). About half the studies were conducted in an academic setting and about a third in either a community hospital or across multiple centers; two articles did not report the setting of the study. Most of the studies were small to medium-sized and only one study had a sample size of more than 1,000 patients^27^ (Table 2.1).

Observational studies. Elective induction of labor was assessed in 23 observational studies; only one cohort study compared elective induction of labor with expectant management^31^ while the remaining studies compared elective induction with spontaneous labor (Table 2.2). The oldest of these studies was conducted in 1962 and the most recent one in 2006. Four studies were conducted among only nulliparous women^11,^ ^17,^ ^20,^ ^60^ and two among only multiparous women.^15,^ ^69^ A little less than half of the studies were conducted outside the U.S. (Canada, Australia, India, Thailand, Belgium, Hungary and the Netherlands). Eight studies were conducted in an academic setting, three in a community hospital, and four in both types of centers; the remaining studies did not report study setting. Most studies were small to medium-sized; 10 studies had sample sizes of more than 1,000 women (Table 2.2).

### Overall Quality and Applicability of Included Studies

The overall quality of the studies included in this review was generally poor. However, there were some good and fair quality prospective RCTs addressing Key Questions 1 and 2 (Figure 2.2 and Table 2.1). As seen in Figure 2.2, most of the RCTs compared induction of labor with expectant management, though several actually excluded women who ended up being induced from the comparison group to reframe their study as comparing elective induction of labor to spontaneous labor. Most of the studies were small (less than 400 subjects) or medium (400 to 1000 subjects) in size and a minority of them had conducted sample size calculations to determine whether they had adequate power to address the primary question of the study.

Figure 2.2 Quality assessment of RCTs of elective induction of labor

The vast majority of the observational studies addressing Key Questions 1 and 2 utilized a spontaneous labor group as a comparison group, so were rated as poor quality (Figure 2.3 and Table 2.2). As seen in Figure 2.3, most of the studies did not compare induction of labor with expectant management which resulted in their getting a poor quality rating. Similar to the RCTs, most of the studies were small (less than 400 subjects) or medium, (400 to 1000 subjects) in size and a minority of them had conducted sample size calculations to determine whether they had adequate power to address the primary question of the study.

Figure 2.3 Quality assessment of observational studies of elective induction of labor

For Key Question 3, no comparison group was needed, so there were more fair and good quality studies (Tables 2.1 and 2.2 and Appendix C, Tables 1 and 2). However, the overall strength of evidence for most components of the Key Questions was low or insufficient because of the relatively small number of studies addressing the outcomes and the poor quality of the studies.

There was considerable heterogeneity among the studies on elective induction of labor which, similar to the quality rating, led to primarily poor applicability ratings as well. Again, to address Key Questions 1 and 2 it was important to have the appropriate comparison group of expectant management, so the vast majority of the observational studies had poor applicability to these questions (Table 2.2). The most likely source of heterogeneity was the time during which the studies were conducted. Obstetric management has changed significantly over the past 30 years as has the baseline cesarean delivery rate. Because several of the RCTs were older, their applicability was downgraded as well. Study country, type of hospital, variation in geographic practice patterns, variation among clinicians, gestational age of the women included, initial Bishop score (cervical assessment for induction favorability), parity, maternal age, and study design are additional possible sources of heterogeneity. However, because the data on these variables, except for study design, were not reported consistently, we could not explore these potential sources of heterogeneity in our analyses.

### Key Question 1: What evidence describes the maternal risks of elective induction versus expectant management?

As noted in Figure 2.4, few studies reported mode of delivery and maternal outcomes of interest. Since cesarean, spontaneous, and operative vaginal deliveries are correlated, we present results for only cesarean and operative vaginal deliveries. In this section, we present the detailed results of our evidence synthesis first for the randomized, controlled trials, followed by the observational studies. At the end of this section, we summarize the evidence addressing Key Question 1.

Figure 2.4 Maternal outcomes reported

#### Randomized controlled trials of elective induction of labor

##### Mode of delivery: Cesarean delivery

Elective induction of labor versus expectant management. Nine RCTs compared elective induction of labor to expectant management, with cesarean delivery as the primary outcome. The studies included a total of 6,138 women: 3,017 in the expectant management group and 3,121 in the elective induction of labor group. The overall cesarean delivery rate among the women who were induced and those who were expectantly managed was 11 percent and 14 percent, respectively. When compared to women who were expectantly managed, women who had elective induction of labor were at lower risk for cesarean delivery (Odds ratio (OR) 1.22; 95 percent CI 1.07–1.39, Figure 2.5 and risk difference 0.02 (95 percent CI: 0.002 to 0.04), Appendix C Figure 1; one study^65^ could not be included in the calculation of the summary odds ratio because it reported zero cesarean deliveries for both groups). The test for heterogeneity revealed that these studies were relatively homogenous (Figure 2.5). There was some evidence of publication bias for this outcome: The fail-safe N required to reduce publication bias was seven studies. Considering the quality of the body of evidence and its applicability to care in the U.S. today, the evidence for elective induction of labor and cesarean delivery was rated as moderate because of the size and number of studies and consistency of the findings.

Figure 2.5 RCTs of elective induction of labor versus expectant management: Cesarean delivery

The majority of these prospective RCTs were in women at or beyond 41 0/7 weeks of gestation. In this subgroup, there was a statistically significant increase in cesarean delivery in the women managed expectantly (OR 1.21, 95 percent CI 1.01–1.46) and the evidence for this subgroup was also rated as moderate because of the size and number of studies and consistency of the findings. Only three trials^55,^ ^65,^ ^67^ were conducted among women with gestational age less than 41 weeks; no other trials reported results stratified by gestational age less than 41 weeks. All of these RCTs reported no statistically significant difference in risk of cesarean delivery between women undergoing elective induction of labor versus those who were expectantly managed (Figure 2.6 and Appendix C Figure 2). However all of these articles were rated as being of poor quality primarily due to their small sample size. Thus, the overall evidence for elective induction of labor prior to 41 weeks of gestation was rated as insufficient.

Figure 2.6 RCTs of elective induction of labor versus expectant management: Cesarean delivery, stratified by gestational age

Two studies individually reported significant differences in cesarean delivery between the women who were electively induced and those who were managed expectantly. The study by Dyson et al.^74^ reported the highest odds of cesarean delivery among women who were expectantly managed. This was a medium sized study, rated fair quality, with 352 women randomized at 41 weeks of gestation to induction of labor (n=152) versus expectant management with antenatal fetal testing (n=150). The rates of cesarean delivery in the study were 14.5 percent in the induction group as compared to 27.3 percent in the expectant management group (P<0.01). The principle cause of this difference appeared to be cesarean delivery for fetal distress, which was 1.3 percent in the induced group and 14.0 percent in the expectant management group (P<0.01).

The study by Hannah et al.,^27^ conducted in Canada and published in 1992, was the largest randomized trial included in our analysis, and was rated as good quality. It included 1,701 women in the induction of labor group and 1,706 women in the expectant management group. This study reported a significantly higher risk of cesarean delivery among women who were managed expectantly than those who were induced (24.5 percent vs. 21.2 percent, P=0.03). When this study was removed during sensitivity analysis, the summary effect changed to no difference in the summary odds of cesarean delivery between induced labor and expectant management (OR 1.24; 95 percent CI: 0.99–1.55, P=0.061).

We were interested in the extent to which changes in practice over time affected the rates of cesarean delivery among women with expectant versus induced labor. When we stratified the studies to those conducted in or prior to 1990 and those conducted after 1990, there was no difference in the odds of cesarean delivery for either of the two groups (Figure 2.7 and Appendix C Figure 3).

Figure 2.7 RCTs of elective induction of labor versus expectant management: Cesarean delivery, stratified by study year

We were also interested in the extent to which geographic variations in practice patterns may have affected the rates of cesarean delivery among women with expectant versus induced labor. Six RCTs, including 5,172 women, were conducted outside of the U.S. (in Austria, Norway, Sweden, Turkey, Canada, and the United Kingdom) and three RCTs, including 966 women, were conducted in the U.S. (Figure 2.8 and Appendix C Figure 4). We found that the odds of cesarean delivery were higher in women who were expectantly managed compared to elective induction of labor in studies conducted outside the U.S. (OR 1.21; 95 percent CI 1.05–1.40) but were not different in studies conducted in the U.S. (OR 1.28; 95 percent CI 0.65–2.49, Figure 2.8 and Appendix C Figure 4). This is likely due to the effect of the Canadian study by Hannah et al. (cesarean delivery rate between the induced labor and expectant management groups was 21 percent versus 25 percent, respectively and OR 1.21; 95 percent CI 1.03–1.42, P=0.02).^27^

Figure 2.8 RCTs of elective induction of labor versus expectant management: Cesarean delivery, stratified by study location

Relatively little RCT data addressed the question of whether parity affects the comparative cesarean delivery rate between expectant management and induced labor. Three RCTs^7,^ ^55,^ ^74^ reported cesarean delivery as an outcome specifically among nulliparous women. These studies included a total of 506 nulliparous women: 256 in the expectant management group and 250 in the elective induction of labor group. There was no statistically significant difference in the risk of cesarean delivery between the two groups (OR 1.67; 95 percent CI: 0.81–3.46, P=0.17). Thus, there was insufficient information to draw any conclusions about the effect of elective induction on nulliparous women specifically.

The same three RCTs^7,^ ^55,^ ^74^ also reported cesarean delivery among a total of 367 multiparous women. In all three studies, the rate of cesarean deliveries was low, with one study reporting no events among the women who were expectantly managed and only one among the women who underwent induced labor.^55^ In the other two studies, there were three and two cesarean deliveries, respectively, among the women who were electively managed and only one and two among those who were induced.^7,^ ^74^ Thus, there was insufficient information to draw any conclusions about the effect of elective induction on multiparous women.

Elective induction of labor versus spontaneous labor. One RCT compared the cesarean delivery rate among women with elective induction of labor and those with spontaneous labor.^66^ This trial was conducted Ireland and published in 1978. They included 92 women in each arm and reported only one cesarean delivery in the spontaneous labor group and four in the elective induction of labor group. When we included this study in our synthesis of elective induction of labor versus expectant management, women with induced labor remained at lower risk for cesarean delivery (OR 1.21; 95 percent CI: 1.03–1.44, P=0.023 and risk difference 0.014; 95 percent CI: -0.005 to 0.033, P=0.16). The studies remained relatively homogeneous (heterogeneity statistics for summary odds ratio: Q-value 8.89, P-value 0.35, I-squared 9.97; heterogeneity statistics for summary risk difference: Q-value 14.02, p-value 0.12, I-squared statistics 35.79).

One RCT compared the cesarean delivery rate among nulliparous women undergoing elective induction of labor to the rate in women who had spontaneous labor.^63^ This study, conducted in Japan in 1999, randomized 194 women to elective induction of labor at 39 weeks versus expectant management up to 42 weeks. Ninety-eight women were randomized to the induction of labor; however, 35 went into labor prior to 39 weeks and were excluded from the analysis. 96 women were randomized to the expectant management group and 10 were induced for obstetric reasons (postterm, nonreassuring antenatal testing). Additionally, 14 women delivered prior to 39 weeks and were excluded as well. This left 63 women who were electively induced compared to 72 women who went into spontaneous labor beyond 39 weeks of gestation. The rate of cesarean delivery was not different between the two groups, 6.4 percent in those induced and 5.6 percent in the spontaneous labor group. No RCTs compared elective induction of labor to spontaneous labor among multiparous women.

Mode of delivery: Operative vaginal delivery. Six RCTs^7,^ ^27,^ ^55,^ ^59,^ ^65,^ ^67^ reported the rate of operative vaginal delivery (including both vacuum-assisted vaginal delivery and forceps delivery, Figure 2.9) in women who underwent elective induction of labor or expectant management. The overall rate of operative vaginal delivery was the similar in both groups (13 percent versus 12 percent, respectively). There was no difference in the risk of operative vaginal delivery between women who were expectantly managed and those who had elective induction of labor (OR 0.91; 95 percent CI 0.79–1.04, Figure 2.9; and risk difference -0.01 (-0.03 to +0.01), Appendix C Figure 5). Three RCTs reported the risk of operative vaginal delivery among women who were induced at less than 41 weeks gestational age and found no difference between women who were induced and women who were expectantly managed (OR 0.71, 95 percent CI: 0.41–1.21, P=0.21). Over time, there was an increased risk of operative vaginal delivery for the induced labor group when compared with the expectant management group; in the oldest study conducted in 1975, ^67^ the odds ratio was 0.65 (95 percent CI: 0.36–1.17) and in the latest study conducted in 2005,^59^ the odds ratio was 0.83 (95 percent CI: 0.48–1.42), which was not statistically significant (Figure 2.10). There was no change in the overall effect sizes in sensitivity analysis and there was no evidence of publication bias for this outcome. Because of the consistency, quality, and number of individual studies, the overall evidence for this outcome was determined to be moderate. With respect to the stratified analyses at 41 0/7 weeks of gestation, the overall evidence was rated as low. The evidence examining the effect on operative vaginal delivery before 41 0/7 weeks was considered insufficient.

Figure 2.9 RCTs of elective induction of labor versus expectant management: Operative vaginal delivery

Figure 2.10 RCTs of elective induction of labor versus expectant management: Operative vaginal delivery, stratified by study year

Egarter et al.^55^ reported operative vaginal delivery rates among nulliparous and multiparous women. Among the nulliparous women, 3 of 88 (3.4 percent) women in the expectant labor group and 3 of 99 (3.0 percent) women in the elective induction of labor group had operative vaginal deliveries. Among the multiparous women, none of the 77 women in the expectant management group and only 1 of 81 women in the elective induction of labor group had operative vaginal deliveries.

No RCTs reported operative vaginal delivery when comparing elective induction of labor to spontaneous labor.

Maternal outcomes: Postpartum hemorrhage. Only one RCT, including 254 women in each arm of the study, examined the risk of postpartum hemorrhage associated with elective induction of labor when compared with expectant management.^46^ The rate of postpartum hemorrhage was the similar in both groups (12 percent versus 13 percent, respectively). Postpartum hemorrhage was not reported separately by parity.

No RCTs reported postpartum hemorrhage rates comparing elective induction of labor with spontaneous labor.

Maternal outcomes: Maternal infection. Three RCTs reported the risk of maternal infection associated with elective induction of labor when compared with expectant management.^7,^ ^24,^ ^27^ The studies included a total of 4,073 women: 1,991 in the expectant management arm and 2,082 in the elective induction of labor arm. There was no difference in the risk of maternal infection between the two groups (OR 1.06; 95 percent CI: 0.78–1.43 and risk difference 0.005 (-0.006 to +0.02)). Maternal infection rates were not reported separately by parity.

Other maternal outcomes. Seven RCTs reported other maternal outcomes including length of labor, perineal lacerations, and blood transfusion (Tables 2.3 and 2.4). There were no notable differences in these outcomes, though these findings were from small studies. Specifics regarding these outcomes are noted in the summary section at the end of the section on Key Question 1.

Table 2.3 RCTs of elective induction of labor studies: Other maternal outcomes^†^

Study | Sample size | | Labor mean hours (SD) | 3^rd^/4^th^ degree perineal laceration % | Blood Transfusion % | Prolonged 1^st^ Stage Labor % | Prolonged 2^nd^ Stage Labor %
| CG | EIOL
Elective induction of labor versus expectant management
Cole et al.^67^ | 117 | 111 | EM=7.0 (3.4) EIOL=6.4 (3.1) | NR | NR | NR | NR
Dyson et al.^74^ | 150 | 152 | EM=12.5 (5.9) EIOL=10.5 (5.2) (p <0.01) | NR | NR | NR | NR
Egarter et al.^55^ | 165 | 180 | EM=8.48 EIOL=6.18 | NR | NR | NR | NR
Heimstad et al.^59^ | 254 | 254 | NR | EM=5.9 EIOL=7.1 (P=0.6) | NR | EM=4.3 EIOL=2.4 (P=0.23) | EM=9.4 EIOL=6.3 (P=0.19)
NICHHD^24^ | 174 | 264 | NR | NR | EM=1.7 EIOL=0.75 | NR | NR
Tylleskar et al.^65^ and Leijon et al.^113,^ ^114^ | 41 | 43 | SL=6.49 EIOL=4.89 | NR | NR | NR | NR
Elective induction of labor versus spontaneous labor
Martin et al.^66^ | 92 | 92 | SL=6.9 (0.4) EIOL=8.3 (0.52) (P<0.05) | NR | NR | NR | NR

CG=control group; EIOL=elective induction of labor group; EM=expectant management; SL=spontaneous labor; NR=not reported; if an individual article reported P-values for a specific outcome, those P-values have been shown in the table.

† Oligohydramnios, active second stage of labor less than 15 minutes, active second stage of labor more than 60 minutes, labor less than 3 hours, emergency abdominal delivery for worrying fetal heart rate, shoulder dystocia, rupture of membranes over 24 hours before delivery, abruptio placentae, and mean blood loss after vaginal delivery were each reported by one study. Mean maternal hospital stay (days), uterine hypertonus or hyperactivity, and placental retention were each reported by two studies.

Table 2.4 RCTs of elective induction of labor studies: Other maternal outcomes among multiparous women^†^

Study | Sample Size | | Labor mean hours (SD)
| SL Group | EIOL Group
Dyson et al.^74^ | 150 | 152 | EM=8.0 (3.7); EIOL=6.5 (3.1), P<0.05
Egarter et al.^55^ | 165 | 180 | EM=6.2 (3.8); EIOL=5.3 (3.3)
Tylleskar et al.^65^ and Leijon et al.^113,^ ^114^ | 41 | 43 | SL=5.3 (2.5); EIOL=4.0 (1.8)

SL=spontaneous labor; EIOL=elective induction of labor group; EM=expectant management; if an individual article reported P-values for a specific outcome, those P-values have been shown in the table.

† mean uterine activity at 6 cm (Montevideo units) and bleeding during third stage of labor (ml) were each reported by one study.

#### Observational Studies of Elective Induction of Labor

Unlike RCTs which usually designated expectant management as the control group, most observational studies chose women who presented with spontaneous labor as the control group. While there was only one cohort study which compared elective induction of labor to expectant management, there were 21 observational studies which assessed the risk of elective induction of labor compared with spontaneous labor. Because this comparison did not specifically answer Key Questions 1 and 2 which were to address elective induction of labor versus expectant management, studies of this type were considered to provide additional relevant evidence, but were considered separately. We report our synthesis of these studies below, first for mode of delivery and then by maternal outcomes.

##### Mode of delivery: Cesarean delivery

Elective induction of labor versus expectant management. We found only one retrospective cohort study, published in 1986, comparing elective induction of labor with expectant management that reported cesarean delivery as an outcome.^31^ Women who were electively induced were compared to those who had not been electively induced who either went into spontaneous labor or were induced postterm at 42 weeks of gestation. The rate of cesarean delivery was 1.0 percent in the women who were electively induced and 6.7 percent in those expectantly managed. Additionally, the authors found better neonatal outcomes in the induced group as well a lower rate of 5-minute Apgar scores 7 or less (3.7 percent versus 17.6 percent), lower overall neonatal morbidity (3.4 percent versus 7.0 percent), and neonatal mortality (0.5 percent versus 1.7 percent).

Elective induction of labor versus spontaneous labor. Twelve observational studies reported cesarean delivery rates comparing women with elective induction of labor with spontaneous labor.^21,^ ^22,^ ^28,^ ^34,^ ^47,^ ^48,^ ^50,^ ^61,^ ^62,^ ^68,^ ^71,^ ^75^ The rate of cesarean delivery was six (standard error 0.6) percent among the spontaneous labor group and eight (standard error 1.3) percent in the elective induction group. All, except two,^34,^ ^68^ of the studies reported a consistently lower risk of cesarean delivery among women who underwent spontaneous labor compared with women who had an elective induction of labor (Figure 2.11 and Appendix C Figure 6). When we combined these studies, women who underwent spontaneous labor were less likely to have a cesarean delivery when compared with women who were electively induced (OR 0.63; 95 percent CI: 0.49–0.79, Figure 2.11; and risk difference -0.03 (-0.04 to -0.01), Appendix C Figure 6). These studies were highly heterogeneous (Figure 2.11 and Appendix C Figure 6). Seven of the studies reported individual effect sizes that were not statistically significant for the risk of cesarean delivery between the two groups. When each of these studies was removed sequentially in sensitivity analysis, the summary effect size became statistically significant with a decreased risk of cesarean delivery for women who underwent spontaneous labor compared with elective induction of labor. There was no indication of significant publication bias.

Figure 2.11 Observational studies of elective induction of labor versus spontaneous labor: Cesarean delivery

Ten retrospective studies^11,^ ^17,^ ^21,^ ^28,^ ^47,^ ^48,^ ^50,^ ^60^–^62^ and one prospective cohort study^20^ reported the risk of cesarean delivery among nulliparous women comparing those who had elective induction of labor to women in spontaneous labor. The twelve studies included a total of 33,168 women: 22,317 who had spontaneous labor and 10,851 who had elective induction of labor (Figure 2.12). The risk of cesarean delivery was consistently and significantly lower in the spontaneous labor group compared with the elective induction of labor group in all but two of the studies^28^ ^21^ (Figure 2.12 and Appendix C Figure 7). The overall rate of cesarean delivery in the spontaneous group was nine (s.e.1.0) percent compared with 19 (s.e. 2.4) percent in the group electively induced. When we combined these studies, women who had spontaneous labor had an almost 50 percent reduction in the odds of cesarean delivery compared to women who were electively induced (OR 0.48; 95 percent CI 0.41–0.56, Figure 2.12; and risk difference -0.09 (-0.12 to -0.67), Appendix C Figure 7). These results remained the same when studies were stratified by location: There was a lower risk of cesarean delivery among women who had spontaneous labor compared with those who were electively induced for studies conducted within the U.S. and those conducted outside the U.S. (Appendix C Figures 8 and 9). There was considerable heterogeneity among the studies. These results remained significant during sensitivity analysis and there was no significant indication of publication bias.

Figure 2.12 Observational studies of elective induction of labor versus spontaneous labor: Cesarean delivery among nulliparous women

Nine observational studies reported cesarean delivery among multiparous women comparing spontaneous labor with elective induction of labor. The studies included a total of 20,617 women: 16,081 who underwent spontaneous labor and 4,536 who had elective induction of labor (Figure 2.13). For these multiparous women, there was a lower risk of cesarean delivery among women who had spontaneous labor compared with women who were electively induced (OR 0.78; 95 percent CI 0.63–0.65, Figure 2.13; and risk difference -0.005 (-0.01 to 0.0, Appendix C Figure 10). In sensitivity analysis, when we removed one study at a time, when the study by Hoffman et al.^69^ was excluded, there was no longer a statistically significant difference in risk of cesarean delivery between the two groups (OR 0.83; 95 percent CI: 0.66–1.05, P=0.12) as this study was large and had one of the largest clinical effect sizes. This outcome showed some evidence of publication bias (fail-safe N was eight studies).

Figure 2.13 Observational studies of elective induction of labor versus spontaneous labor: Cesarean delivery among multiparous women

Thus, overall, these observational studies found that induction of labor was associated with a higher rate of cesarean delivery. This difference persisted among both nulliparous and multiparous women.

##### Mode of delivery: Operative vaginal delivery

Elective induction of labor versus expectant management. The only observational study comparing elective induction of labor with expectant management that reported operative vaginal delivery (forceps- or vacuum-assisted vaginal delivery) as an outcome measure was by Lampe out of Hungary in 1986.^31^ There was no significant difference in the rate of operative vaginal delivery between the women who were electively induced and those who were expectantly managed [0.74 percent (15 / 2020) and 0.94 percent (26 / 2750), respectively].

Elective induction of labor versus spontaneous labor. Seven observational studies reported operative vaginal delivery as an outcome comparing spontaneous labor with electively induced labor. The seven retrospective studies were conducted between 1970 and 1999. They included a total of 22,670 women: 19,684 in the spontaneous labor group and 4,607 electively induced (Figure 2.14). The overall rate of operative vaginal delivery in the two groups was similar: 15 (s.e. 3.0) percent in the spontaneous labor group and 17 (s.e. 2.3) percent in the elective induction of labor group. When these studies were combined, there was no difference in the risk of operative vaginal delivery between women in the spontaneous labor group and women who had an elective induction of labor (OR 0.91; 95 percent CI: 0.78–1.05, Figure 2.14; and risk difference -0.01 (-0.03 to 0.004, Appendix C Figure 11). These studies were moderately homogenous (Figure 2.14) and indicated the existence of publication bias (fail-safe N was 1).

Figure 2.14 Observational studies of elective induction of labor versus spontaneous labor: Operative vaginal delivery

Four observational studies reported operative vaginal deliveries comparing spontaneous labor with electively induced labor in nulliparous women (Figure 2.15). The studies included a total of 16,520 nulliparous women: 8,548 women in the spontaneous labor group and 7,972 women who had elective induction of labor (Figure 2.15). When we combined these studies, women in the spontaneous labor group were less likely to have operative vaginal delivery than women who were electively induced (OR0.89; 95 percent CI 0.83–0.95, P<0.01, Figure 2.16; and risk difference -0.02 (-0.04 to -0.01, P=0.001), Appendix C Figure 12). These studies were fairly homogeneous (Figure 2.15 and Appendix C Figure 12). In sensitivity analysis, removing the study by Cammu et al.^17^ resulted in there being no difference in operative vaginal delivery between the two groups (OR 0.98; 95 percent CI: 0.70–1.37, P=0.895).

Figure 2.15 Observational studies of elective induction of labor versus spontaneous labor: Operative vaginal delivery among nulliparous women

Figure 2.16 Neonatal outcomes reported

Three observational studies reported operative vaginal delivery as an outcome of interest when comparing elective induction of labor with spontaneous labor for multiparous women.^15,^ ^28,^ ^69^ When we combined these studies, there was no difference in the risk of operative vaginal delivery between the two groups of women (OR 0.96; 95 percent CI: 0.62–1.49, P=0.86; and risk difference -0.003 (-0.047 to 0.041, P=0.90). These studies were highly heterogeneous (Q-value 5.275, P-value 0.07, I-squared 62.085).

Maternal outcomes: Postpartum hemorrhage. Three observational studies reported postpartum hemorrhage in women who had elective induction of labor and those who underwent spontaneous labor.^28,^ ^68,^ ^76^ The studies included 566 women in each group. There was no difference in the risk of postpartum hemorrhage between the two groups for either the case-control or cohort studies (OR 0.68; 95 percent CI 0.25–1.87, P=0.45).

No studies reported postpartum hemorrhage among nulliparous women and only one study reported it among multiparous women.^68^ Booth et al. reported a postpartum hemorrhage rate of two percent among women who underwent spontaneous labor and 4 percent for those women who had elective induction of labor.

Other maternal outcomes. Several other outcomes were reported by our included studies; most of these were reported by one or two of the studies and are shown in Tables 2.5 to 2.7.

Table 2.5 Observational studies of elective induction of labor: Other maternal outcomes^†^

Study | Sample Size | | 1^st^ Stage Labor mean hours (SD) | 2^nd^ Stage Labor mean minutes (SD) | 3^rd^/4^th^ degree perineal laceration % | Endomyometritis % | Chorioamnionitis % | Urinary infection %
| Control | EIOL
Lampe^31^ and Lampe et al.^115^ | 2750 | 2020 | EIOL=4.58 | EIOL=26 | NR | NR | NR | NR
Booth and Kurdyak^68^ | 213 | 213 | NR | NR | NR | SL=0.46 EIOL=0.46 | NR | SL=3.3 EIOL=2.8
Macer et al.^28^ | 253 | 253 | SL=7.2 (5.2) EIOL=6.0 (3.1) (P=0.008) | SL=39 (44) EIOL=44 (61) | SL=7.5 EIOL=7.5 | SL=2.77 EIOL=2.37 | SL=2.4 EIOL=1.6 | NR
McBride et al.^37^ | 32 | 38 | SL=5.8 (2.4) EIOL=3.6 (2.5) | SL=30.1 (25.4) EIOL=26 (24) | NR | NR | NR | NR
Mukherjee et al.^76^ | 100 | 100 | NR | NR | NR | NR | SL=5 EIOL=0 | NR
Vierhout et al.^75^ and Out et al.^116,^ ^117^ | 156 | 184 | SL=6.28 EIOL=4.90 | SL=18.7 EIOL=22.1 | NR | NR | NR | NR

EIOL=elective induction of labor group; SL=spontaneous labor; NR=not reported; if an individual article reported P-values for a specific outcome, those P-values have been shown in the table.

† Antepartum hemorrhage, median hospital stay, bilirubin levels of 15 mg/dL or more during hospital stay, mild superficial phlebitis, cervical lacerations, 3rd stage hemorrhage, dystocia, shoulder dystocia, any birth injury, scalp injury, postpartum neurological complications, “medication for pain relief (not strictly epidural)”, rupture of membranes >24 hours, mean duration of ruptured membranes, and women's psychological outcomes were each reported by one study. Receiving epidural was reported by two studies.

Table 2.6 Observational studies of elective induction of labor in nulliparous women: Other maternal outcomes^†^

Study | Sample Size | | Chorioamnionitis % | 1^st^ stage of labor mean hours (SD) | 2^nd^ stage of labor mean hours (SD) | Mean hospital stay days (SD) | Time of ruptured membranes mean hours (SD) | Epidural use %
| SL | EIOL
Cammu et al.^17^ | 7683 | 7683 | NR | NR | NR | NR | NR | SL=57.6 EIOL=79.8
Luthy et al.^11^ | 2673 | 542 | SL=2.4 EIOL=2 (P=0.608) | NR | NR | NR | NR | NR
Macer et al.^28^ | 77 | 77 | NR | SL=9.9 (5.1) EIOL=7.2 (3.2) | SL=1.5 (0.88) EIOL=1.53 (0.85) | NR | SL=7.6 (5.5) EIOL=7.7 (5.3) | NR
Maslow et al.^62^ | 349 | 103 | NR | NR | NR | NR | NR | SL=50 EIOL=64 P<0.05
Seyb et al.^20^ | 1124 | 143 | SL=6.3 EIOL=7 | NR | NR | SL=1.8 EIOL=2.0 | NR | SL=79 EIOL=93
Vierhout et al.^75^ and Out et al.^116,^ ^117^ | 156 | 184 | NR | SL=8.0 (3.4) EIOL=5.8 (2.3) | SL=0.63 (0.37) EIOL=0.62 (0.3) | NR | NR | NR
Vrouenraets et al.^60^ | 765 | 189 | NR | NR | SL=0.67 (0.44) EIOL=0.61 (0.42) | SL=2.7 (2.0) EIOL=3.5 (2.1) | SL=13.9 (16.7) EIOL=9.9 (10.5) | SL=3 EIOL=11

SL=spontaneous labor group; EIOL=elective induction of labor group; NR=not reported; if an individual article reported P-values for a specific outcome, those P-values have been shown in the table.

† Abnormal position, mean labor, mean labor for term births only, vaginal delivery within 8 hours, intrapartum fever, intrapartum abruption, mean uterine activity at 6 cm (Motevideo units), and bleeding during third stage of labor were each reported by one study.

Table 2.7 Observational studies of elective induction of labor in multiparous women: Other maternal outcomes^†^

Study | Sample Size | | 1^st^ stage of labor mean hours (SD) | 2^nd^ stage of labor mean minutes (SD) | Mean time of ruptured membranes Mean hours (SD) | Endomyometritis % | Mean length of hospital stay (days)
| SL | EIOL
Booth & Kurdyak^68^ | 213 | 213 | NR | NR | NR | SL=0.47 EIOL=0.47 | NR
Heinberg et al.^15^ | 304 | 304 | NR | NR | NR | NR | SL=1.6 EIOL=1.76 P=0.0118
Macer et al.^28^ | 253 | 253 | SL=6.4 (5.0) EIOL=5.7 (3.0) | SL=26 (30) EIOL=31 (56) | SL=3.9 (4.9) EIOL=4.6 (2.9) | NR | NR
Vierhout et al.^75^ and Out et al.^110,^ ^111^ | 156 | 184 | SL=5.7 (2.8) EIOL=4.5 (2.0) | SL=12 (8) EIOL=15 (11) | NR | NR | NR

SL=spontaneous labor; EIOL=elective induction of labor group; NR=not reported; if an individual article reported P-values for a specific outcome, those P-values have been shown in the table.

† Vaginal delivery within 8 hours, epidural use, and reported labor/delivery/postpartum complications were each reported by one study.

### Summary of evidence addressing Key Question 1: What evidence describes the maternal risks of elective induction versus expectant management?

Cesarean delivery. Of the nine RCTs that compared cesarean delivery among women who had elective induction of labor with those with expectant management, the combined summary odds ratio favored elective induction of labor. Expectant management of pregnancy was associated with a 22 percent increase in cesarean delivery (OR=1.22; 95 percent CI 1.07–1.39, P=0.003) and an absolute risk difference of nearly two percent (95 percent CI: 0.2 percent to 4 percent, P=0.033). Three trials reported no difference in risk of cesarean delivery among women who were induced at less than 41 weeks gestational age (OR 1.73, 95 percent CI: 0.67–4.5, P=0.026) but all of these trials were of poor quality. Only three studies addressed whether parity affected the risk of cesarean delivery between expectant management and electively induced labor; these studies reported no difference in risk for nulliparas and there was insufficient information to draw any conclusions on the risk for multiparas. When we stratified the studies to those conducted in or prior to 1990 and those conducted after 1990, there was no statistically significant difference in the odds of cesarean delivery for either of the two groups. When we stratified the analysis by country, we found that the odds of cesarean delivery were higher in women who were expectantly managed compared to elective induction of labor in studies conducted outside the U.S. (OR 1.21; 95 percent CI 1.05–1.40) but were not different in studies conducted in the U.S. (OR 1.28; 95 percent CI 0.65–2.49). The strength of evidence was weaker in observational studies, which showed women with elective induction of labor had a higher odds of cesarean delivery compared to women in spontaneous labor. The principal reason for this difference in findings between the two types of studies is likely the different control groups used by the included studies. Since the clinical scenario faced by practitioners is induction of labor now versus expectant management with either induction or spontaneous labor at a later date, gestational age is an important confounding factor which may bias the estimate of effect on induction when induction is compared to spontaneous labor. Considering the quality of the body of evidence and its applicability to care in the U.S. today, the evidence for elective induction of labor and cesarean delivery was rated as moderate. However, with respect to elective induction of labor prior to 41 weeks of gestation, the overall evidence was considered insufficient.

Operative vaginal delivery. Most of the six RCTs that examined the effect of elective induction of labor on operative vaginal delivery were small to medium-sized studies (only one study had 1700 women in each arm). The summary odds of operative vaginal delivery were not statistically significantly different between women who were electively induced or expectantly managed (OR=0.91; 95 percent CI 0.79–1.04, P=0.18). Three RCTs reported no risk in operative vaginal delivery among women who were induced at less than 41 weeks gestational age (OR 0.71, 95 percent CI: 0.41–1.21, P=0.21), but all of these trials were of poor quality. For the seven observational studies, there was no significant difference in the risk of operative vaginal delivery between women in spontaneous labor compared to elective labor induction (OR=0.91; 95 percent CI 0.78–1.05, P=0.18). Although the observational studies involved more women, the strength of evidence for this outcome was considered relatively weak secondary to a high degree of heterogeneity among these studies. However, given the consistency of the findings in the studies for a lack of difference in the risk of operative vaginal delivery, the overall evidence regarding the relationship between elective induction of labor and operative vaginal delivery at 41 weeks of gestation was rated as moderate. The evidence examining the effect on operative vaginal delivery before 41 weeks was considered insufficient.

Length of labor. None of the included studies evaluated “prolonged labor” as a primary outcome. One RCT from Norway of 508 women evaluated “prolonged first and second stages of labor” and they found no statistically significant difference between women who were electively induced or expectantly managed. Four observational studies examined “mean duration of first and second stages of labor.” Only one of these studies^28^ that included 253 women in each group found a significant difference in mean first stage of labor in women who had elective induction of labor compared to spontaneous labor (6.0 versus 7.2 hours, respectively; P=0.008); the others reported no difference in length of labor. Given the limited evidence further information is needed to evaluate the effect of elective labor induction on the duration of labor. No studies reported or compared the median duration of labor. Thus, the overall strength of evidence addressing length of labor and elective induction of labor was considered insufficient.

Maternal infections. Six studies (three RCTs and three observational) reported presence or absence of maternal infection; however, none provided detailed quantitative data such as risk ratios or risk differences. Four studies (two RCTs, two observational) provided some evidence that elective induction is not associated with increased risk of chorioamnionitis and two observational studies provided some evidence that elective induction is not associated with increased risk of endomyometritis. Thus, given the consistency in these findings, but the modest amount of available data, the overall strength of evidence regarding maternal infections was rated as low.

Maternal blood loss and hemorrhage. Four studies (one RCT and three observational) evaluated the association between postpartum hemorrhage and elective induction and found no association. However, these studies likely lacked adequate statistical power to detect a difference. One RCT examined rates of blood transfusion between elective induction (2/265 [0.75 percent]) versus expectant management (3/175 [1.7 percent]) and found no statistically significant difference. No studies reported mean estimated blood loss as an outcome of interest. Thus, given the minimal amount of data and the lack of statistical power to examine this question, the overall evidence regarding maternal blood loss was rated as insufficient.

Other outcomes. Two studies (one RCT and one observational) reported on serious perineal lacerations and did not observe an association between elective induction and third or fourth degree perineal lacerations. No studies addressed the risk of hysterectomy, evidence of injury to internal organs, or wound complications after elective induction of labor. Given the lack of available data to address any of these other outcomes, the evidence regarding other maternal outcomes was all rated as insufficient.

### Key Question 2: What evidence describes the fetal/neonatal risks of elective induction versus expectant management?

The included studies reported on only a few of the neonatal outcomes that we had hoped to evaluate (Figure 2.16). However, the majority of these results were reported by less than five of the included studies. In this section, we present the detailed results of our evidence synthesis for those outcomes reported by more than four studies. We first present the evidence from the RCTs, then the observational studies. At the end of this section, we summarize the evidence addressing Key Question 2.

#### Randomized Controlled Trials of Elective Induction of Labor

Neonatal outcomes: 5-minute Apgar score less than 7. Four RCTs reported the rate of neonatal Apgar score at 5-minutes less than 7 in studies comparing expectant management with elective induction of labor. The total number of women included in these studies was 4,434, with 2,212 in the expectant management group and 2,222 in the elective induction of labor group. The study by Nielsen et al.^7^ reported that no neonates had a 5-minute Apgar score of less than 7 and so was not included in the calculation of summary odds ratio. There was no difference in the risk between women in the expectant management group and those in the elective induction of labor group of having neonates born with 5-minute Apgar score less than 7 (OR 1.18; 95 percent CI: 0.67–2.06, Figure 2.17; and risk difference 1.18 (0.67–2.06), Appendix Figure 13). None of the RCTs reported this outcome among women who were induced at less than 41 weeks gestation.

Figure 2.17 RCTs of elective induction of labor versus expectant management: 5-minute Apgar score less than 7

Neonatal outcomes: Meconium-stained amniotic fluid. Six RCTs reported data on the presence of meconium-stained amniotic fluid as an outcome, comparing elective induction of labor with expectant management. The studies included a total of 5,478 women, with 2,698 women in the expectant management group and 2,780 women in the elective induction of labor group (Figure 2.18). The overall rate of meconium-stained amniotic fluid in the expectant management group was 29 percent (S.E. 0.04) compared with 17 percent (S.E. 0.06) in the elective induction of labor group. When combined, these studies showed that the presence of meconium-stained amniotic fluid was more likely to occur in the expectant management group compared with the elective induction of labor group (OR 2.04; 95 percent CI: 1.34–3.09, P=0.001, Figure 2.18; and risk difference 0.11 (0.06–0.17, P<0.01), Appendix C Figure 14). There was a consistently significant effect for all of the individual studies.

Figure 2.18 RCTs of elective induction of labor versus expectant management: Meconium-stained amniotic fluid

The study by Cole et al. was the smallest study with 228 women and reported the largest effect size with women in the expectant management group being nearly 14 times more likely to have presence of meconium-stained amniotic fluid.^67^ It was also the only trial to report the presence of meconium among women who were induced at less than 41 weeks gestational age. The overall summary effects were fairly robust: They remained significant during sensitivity analysis. The results did not suggest the presence of significant publication bias (fail-safe N was 82).

One RCT reported the presence of meconium-stained amniotic fluid when comparing elective induction of labor with spontaneous labor.^66^ Martin et al. included a total of 184 women in their trial (92 in each arm); they reported a significantly increased risk of meconium-stained amniotic fluid among women who had spontaneous labor compared with women who underwent elective induction of labor (OR 4.89; 95 percent CI: 1.34–17.76).

One RCT of nulliparous women reported the presence of meconium-stained amniotic fluid.^61^ In the electively induced women the rate was 3.2 percent versus 19.4 percent in the women with spontaneous labor (P=0.004). We did not find any RCTs of multiparous women that reported this outcome.

Neonatal outcomes: Meconium aspiration syndrome. Five RCTs reported data on meconium aspiration syndrome.^8,^ ^24,^ ^27,^ ^59,^ ^74^ These studies included a total of 5,248 women, with 2,577 women in the expectant management group and 2,671 women in the elective induction of labor group. Overall, there was no difference in the risk of meconium aspiration syndrome to neonates between the two groups of women (OR 1.39; 95 percent CI 0.71–2.72, P=0.34, Figure 2.19; and risk difference 0.009 (-0.005 to +0.024), P=0.21, Appendix C Figure 15). Notably, the odds ratio reported by the 1983 study by Dyson et al.^74^ was 13.72 and that of the 2005 study by Gelisen et al. was 1.36^9^—suggesting the possibility of a trend toward decreasing risk of meconium aspiration over time. However, when we grouped the studies by year (1990 or earlier versus after 1990), there was no difference in the combined summary odds ratio (OR 1.5; 95 percent CI: 0.49–4.54, P=0.48 and OR 1.5; 95 percent CI: 0.35–6.27, P=0.59, respectively).

Figure 2.19 RCTs of elective induction of labor versus expectant management: Meconium aspiration syndrome

Neonatal intensive care unit (NICU) admissions. Three RCTs reported data on NICU admissions.^7,^ ^8,^ ^59^ Heimstad et al.^59^ reported 18 NICU admissions among the expectant management group of 254 women (7 percent) and 14 among the elective induction of labor group of 254 women (5.5 percent). Gelisen et al.^8^ reported 15 NICU admissions among the expectant management group of 300 women (5 percent) and 13 among the elective induction of labor group of 300 women (4.3 percent). When the two studies were combined, there was no difference in the odds of NICU admissions between the two groups (OR 1.24; 95 percent CI: 0.73–2.09, P=0.43). Nielsen et al.^7^ reported no admissions to the NICU for either group of women.

One RCT^63^ reported data on NICU admissions in nulliparous women. The study was inadequately powered to examine this association with 0 percent of neonates in the elective induction arm being admitted to the NICU versus 2 percent of the spontaneous labor neonates.

Neonatal deaths. Six RCTs reported data on neonatal deaths.^24,^ ^27,^ ^55,^ ^59,^ ^67,^ ^74^ Neonatal deaths were a rare occurrence overall with only four neonatal deaths among women in the expectant management group and none in the elective induction of labor group.

Other neonatal outcomes. The other neonatal outcomes that were reported in fewer studies are shown in Table 2.8.

Table 2.8 RCTs of elective induction of labor versus expectant management: Other neonatal outcomes^†^

Study | Sample Size | | Birthweight >4500 grams % | LGA % | Meanbirthweight grams (SD) | UAph < 7.0 % | UAph < 7.1 % | Fetal Distress % | Transient tachypnea of the newborn % | UA base excess < -12 % | Neonatal Jaundice %
| EM | EIOL
Cole et al.^67^ | 117 | 111 | NR | NR | NR | NR | NR | NR | EM=1.7 EIOL=1.8 | NR | EM=5.1 EIOL=10.9
Dyson et al.^74^ | 150 | 152 | NR | EM=28.2 EIOL=19.1 | NR | NR | NR | NR | NR | NR | NR
Hannah et al.^27,^ ^112^ | 1706 | 1701 | EM=5.5 EIOL=4.6 | NR | NR | NR | EM=1.7 EIOL=1.4 | EM=12.8 EIOL=10.3 | EM=4.5 EIOL=5.6 | NR | NR
Heimstad et al.^59^ | 254 | 254 | EM=16.9 EIOL=11.0 P=0.06 | NR | NR | EM=3.80 EIOL=6.33 P=0.22 | EM=0.84 EIOL=1.27 P=0.69 | NR | EM=14.6 EIOL=16.9 P=0.47 | EM=1.69 EIOL=2.53 P=0.55 | NR
Nielsen et al.^7^ | 110 | 116 | NR | NR | EM=3504 (438) EIOL=3459 (347) P=0.006 | NR | NR | NR | NR | NR | NR
NICHHD^24^ | 174 | 264 | EM=3.4 EIOL=1.5 | NR | NR | NR | NR | NR | NR | NR | NR

Table 2.81 RCTs of elective induction of labor versus expectant management: Other neonatal outcomes^†^

Study | Sample Size | | Resuscitation % | Phototherapy % | Neonatal polycythemia % | Neonatal Seizures % | Suspected Sepsis % | Proven Sepsis % | Hypoglycemia %
| EM | EIOL
Hannah et al. ^27,^ ^112^ | 1706 | 1701 | NR | NR | EM=1.0 EIOL=0.8 | EM=0.3 EIOL=0.2 | EM=7.1 EIOL=6.9 | EM=0.2 EIOL=0.5 | EM=2.7 EIOL=3.0
Heimstad et al. ^59^ | 254 | 254 | EM=3.1 EIOL=4.7 P=0.50 | EM=3.9 EIOL=3.1 P=0.64 | EM=0.39 EIOL=0.39 | NR | EM=2.76 EIOL=3.54 | EM=2.36 EIOL=0.39 | EM=3.94 EIOL=3.15 P=0.64
NICHHD^24^ | 174 | 264 | NR | NR | NR | EM=0.57 EIOL=0.75 | NR | NR | NR

EM=expectant management; EIOL=elective induction of labor group; NR=not reported; if an individual article reported P-values for a specific outcome, those P-values have been shown in the table.

† Birthweight less than 2500 grams, fetal anomaly, and cord prolapse were each reported by one study.

#### Observational studies of elective induction of labor

Neonatal Outcomes: 5-minute Apgar Score less than 7. Nine observational studies compared elective induction of labor to spontaneous labor and reported 5-minute Apgar score less than 7^22,^ ^28,^ ^47,^ ^48,^ ^50,^ ^61^ ^21,^ ^34,^ ^68^ This outcome was a rare event in both groups. Overall, the rate of 5-minute Apgar score less than 7 was 0.5 percent in both groups (P=0.723). The studies included a total of 31,275 women with 25,768 in the spontaneous labor group and 5,507 women in the elective induction of labor group. All except one of the studies^50^ reported a higher, though not statistically significant, risk of 5-minute Apgar score less than 7 among women who had spontaneous labor. When these studies were combined, there was no difference in the risk of 5-minute Apgar score less than 7 between groups. Removing the study by Yeast et al.^50^ in sensitivity analysis did not change the results. These studies appeared relatively homogeneous (Figure 2.20 and Appendix C Figure 16) and did not indicate the presence of significant publication bias (fail-safe N was zero).

Figure 2.20 Observational studies of elective induction of labor versus spontaneous labor: 5-minute Apgar score less than 7

Neonatal outcomes: Meconium-stained amniotic fluid. Four observational studies comparing women who had elective induction of labor to women who were in spontaneous labor reported data on the presence of meconium-stained amniotic fluid. These studies included a total of 13,624 women: 10,179 in the spontaneous labor group and 3,445 in the elective induction of labor group. When these studies were combined, the risk of meconium-stained amniotic fluid was higher in women who underwent spontaneous labor than those who were electively induced (OR 2.16; 95 percent CI 1.24–3.75, Figure 2.21; and risk difference 0.06 (0.01–0.12), Appendix C Figure 17). These studies showed a high degree of heterogeneity.

Figure 2.21 Observational studies of elective induction of labor versus spontaneous labor: Meconium-stained amniotic fluid

Two observational studies^11,^ ^60^ also reported this outcome among nulliparous women when comparing elective induction of labor with spontaneous labor. In the prospective study by Vrouenraets et al.,^60^ the presence of meconium-stained amniotic fluid was almost the same in both groups (19 percent versus 17 percent, respectively). In the retrospective study by Luthy et al.,^11^ the presence of meconium-stained amniotic fluid was higher in the elective induction of labor group compared with the spontaneous labor group (16 percent versus 23 percent). We did not find any studies in multiparous women that reported this outcome.

NICU admissions. Six observational studies reported data on NICU admissions comparing elective induction of labor with spontaneous labor (Figure 2.22). The studies included a total of 17,381 women: 15,004 in the spontaneous labor group and 2,377 in the elective induction of labor group. Overall there was no significant difference in the risk of NICU admissions between the two groups (OR 0.97; 95 percent CI 0.61–1.55, Figure 2.22; and risk difference 0.001 (-0.02 to +0.02), Appendix C Figure 18).

Figure 2.22 Observational studies of elective induction of labor versus spontaneous labor: NICU admissions

Three observational studies among nulliparous women reported NICU admissions.^17,^ ^50,^ ^60^ Vrouenraets et al.^60^ reported a higher rate of NICU admissions among women with spontaneous labor (14.8 percent) versus women with elective induction (25.9 percent). In a large cohort of more than 4,000 women, though only 197 women had elective induction of labor, Yeast et al.^50^ reported a small difference in NICU admissions with 6.3 percent of the neonates born as a result of spontaneous labor and 5.1 percent of the neonates born as a result of an elective induction of labor admitted to the NICU. In contrast, an even larger cohort from France of more than 15,000 women found that 10.7 percent of the neonates were admitted to the NICU in the setting of induced labor as compared to 9.4 percent of the neonates in the setting of spontaneous labor (P=0.009).^17^

One retrospective cohort studies among multiparous women reported NICU admissions.^50^ The study by Yeast et al., found a slight reduction in NICU admissions from 3.8 percent of neonates born in the setting of spontaneous labor down to 1.9 percent of neonates born in the setting of elective induction of labor (P<0.005).^50^

Neonatal deaths. Four observational studies reported neonatal deaths.^21,^ ^31,^ ^34,^ ^76^ All but one of the studies reported higher numbers of neonatal deaths in the spontaneous group compared with the elective induction of labor group. Mukherjee et al.^76^ reported six (6 percent) neonatal deaths in the spontaneous labor group and one (1 percent) in the elective induction group. Lampe et al.^31^ also reported 6 (0.22 percent) neonatal deaths in the spontaneous labor group compared with one (0.05 percent) in the elective induction group and Belsky et al.^34^ reported two (0.2 percent) stillbirths in the spontaneous labor group and none in the elective induction group. Prysak et al.^21^ reported no neonatal deaths in either group.

One study among nulliparous women reported six neonatal deaths within the first week in each of the groups.^17^

Other neonatal outcomes. Several other neonatal outcomes were reported by fewer studies (Tables 2.9 to 2.11).

Table 2.9 Observational studies of elective induction of labor versus spontaneous labor: Other neonatal outcomes^†^

Study | Sample Size | | Fetal Distress % | Birthweight <2500 grams % | LGA % | Resuscitation % | UAph < 7.15 % | Proven Sepsis % | Hyperbilirubinemia % | Phototherapy % | Breastfeeding %
| SL | EIOL
Booth and Kurdyak^68^ | 213 | 213 | NR | SL=0.93 EIOL=0.47 | NR | NR | NR | SL=0.47 EIOL=0.0 | SL=3.3 EIOL=5.5 | NR | NR
Macer et al.^28^ | 253 | 253 | SL=1.2 EIOL=3.2 | NR | NR | NR | NR | NR | NR | NR | NR
Prysak and Castronova^21^ | 461 | 461 | NR | NR | SL=19.8 EIOL=24.3 | NR | NR | NR | NR | NR | NR
Wilailak et al.^71^ | 249 | 262 | NR | SL=2.4 EIOL=6.5 | NR | NR | NR | NR | NR | NR | NR
Belsky^34^ | 918 | 35 | NR | SL=3.8 EIOL=2.9 | NR | EIOL=0 | NR | NR | NR | NR | NR
Boulvain et al.^48^ | 3353 | 531 | NR | NR | NR | SL=13.7 EIOL=16.2 | NR | NR | NR | SL=11.9 EIOL=14.3 | NR
Mukherjee and Sood^76^ | 100 | 100 | SL=11 EIOL=15 | NR | NR | SL=5 EIOL=1 | NR | NR | SL=0 EIOL=2 | NR | NR
Dublin et al.^61^ | 9648 | 2886 | NR | SL=0.6 EIOL=0.7 | NR | NR | NR | NR | NR | NR | NR
Van Gemund^47^ | 122 | 122 | NR | NR | NR | NR | SL=12 EIOL=18 | NR | NR | NR | NR
Vierhout et al.^75^ and Out et al.^116,^ ^117^ | 156 | 184 | NR | NR | NR | NR | SL=4.52 EIOL=7.18 | NR | SL=6.4 EIOL=9.8 | SL=2.6 EIOL=4.9 | SL=88.6 EIOL=72.4

LGA=large for gestational age; UAph=Umbilical Arterial pH; SL=spontaneous labor; EIOL=elective induction of labor group; NR=not reported; if an individual article reported P-values for a specific outcome, those P-values have been shown in the table.

† “trauma”, mean and median birthweight, brachial plexus injury, intracranial hemorrhage, Apgar score less than 4 at five minutes, mechanical ventilation, verbal and non-verbal scores, cord prolapse, and neonatal jaundice were each reported by one study. Birthweight greater than 4000 grams and NICU length of stay were reported by two studies.

Table 2.10 Cohort studies of elective induction of labor versus spontaneous labor in nulliparous women: Other neonatal outcomes

Study | Sample Size | | Birthweight >4000 grams | Birthweight >4500 grams | Apgar score <7 at 5 minutes | UAph<7.15 | Median birthweight in grams (range)
| SL Group | Elective Induction Group
Luthy et al.^11^ | 2673 | 542 | SL=8.3% EIOL=23.8% (P<0.001) | NR | NR | NR | NR
Vierhout et al.^75^ and Out et al.^116,^ ^117^ | 156 | 184 | NR | NR | NR | SL=12.5% EIOL=17.2% | SL=3375 (2573–4379) EIOL= 3400 (2260–4410)
Vrouenraets et al.^60^ | 765 | 189 | SL=9% EIOL=15.3% | SL=0.9% EIOL=0.5% | NR | NR | NR
Yeast et al.^50^ | 4086 | 197 | SL=6.6% EIOL=8.6% (P<0.01) | NR | SL=0.8% EIOL=2% (P<0.01) | NR | NR

Umbilical Arterial pH; SL=spontaneous labor; EIOL=elective induction of labor group; NR=not reported; if an individual article reported P-values for a specific outcome, those P-values have been shown in the table.

Table 2.11 Cohort studies of elective induction of labor versus spontaneous labor in multiparous women: Other neonatal outcomes

Study | Sample Size | | Birthweight >4000 grams % | Birthweight <2500 grams % | Median birthweight in grams (range) | Apgar score <7 at 5 minutes % | UAph<7.1 %
| SL Group | EIOL Group
Vierhout et al.^75^ and Out et al.^116,^ ^117^ | 156 | 184 | NR | NR | SL= 3486 (2710–4540) EIOL= 3468 (2530–4410) | SL=1.74 EIOL=2.44 | SL=4.35 EIOL=4.88
Yeast et al.^50^ | 4086 | 197 | SL=11.1 EIOL=7.8 (P<0.05) | SL=1.4 EIOL=0.6 (P<0.05) | NR | SL=0.7 EIOL=0.0 (P<0.05) | NR

SL=spontaneous labor; EIOL=elective induction of labor group; NR=not reported; if an individual article reported P-values for a specific outcome, those P-values have been shown in the table.

### Summary of evidence addressing Key Question 2: What evidence describes the fetal/neonatal risks of elective induction versus expectant management?

Meconium stained amniotic fluid. There were six randomized controlled studies with a total of 5,478 women that examined whether the presence of meconium-stained amniotic fluid is associated with elective induction of labor. Women who were expectantly managed were more likely to have meconium stained amniotic fluid than those electively induced (OR 2.04; 95 percent CI 1.34–3.09). However, a high degree of heterogeneity exists among these studies. Only one randomized controlled trial evaluated this outcome among women who were induced at less than 41 weeks gestation and found a lower risk for the presence of meconium among women who were electively induced. Given the consistency of the findings and the quality of the individual studies, the overall evidence regarding the presence of meconium was rated as moderate.

Meconium aspiration syndrome. Five randomized controlled trials which ranged in size from 300 to 3000 participants and were of poor to good quality, provided somewhat conflicting results regarding the effect of elective induction on meconium aspiration syndrome. While two of the studies found higher rates of meconium aspiration in the setting of expectant management, these differences were not quite statistically significant and the other three studies found no difference. Overall, there was no difference in the risk of meconium aspiration syndrome to neonates between the two groups of women (OR 1.39; 95 percent CI 0.71–2.72). Thus, more data are needed to further evaluate the presence and strength of this association and the overall evidence regarding meconium aspiration was considered low.

Apgar score less than 7 at 5 minutes. Thirteen studies (four RCTs and nine observational) provided relatively good strength of evidence that the rate of 5-minute Apgar score less than 7 was no different between women with elective induction of labor compared to expectant management/spontaneous labor. The summary odds ratio from the RCTs was 1.18 (95 percent CI: 0.67–2.06). None of the RCTs reported this outcome among women who were induced at less than 41 weeks gestation. Given the relatively wide confidence interval, the fact that this outcome is relatively uncommon and maybe lacking adequate power, and the individual quality ratings of the studies, the overall evidence regarding this outcome was rated as low.

Umbilical arterial pH and umbilical arterial base excess. One good and one fair RCT provided evidence that elective induction of labor was not associated with higher rates of neonatal acidemia as measured by umbilical cord gases indicated by umbilical arterial pH (<7.0 or <7.1) and umbilical arterial base excess (<-12). However, with such little evidence on a relatively uncommon outcome, the overall evidence was rated as insufficient.

Fetal distress. While two poor quality smaller observational studies reported no difference in rates of fetal distress, one large, good quality, RCT reported lower rates of fetal distress favoring elective induction of labor. We rated the overall strength of evidence as insufficient because of the disagreement between the study findings and that only one study was an RCT of good quality.

Respiratory distress syndrome. One poor quality large cohort study involving 4,472 women did not observe any cases of respiratory distress syndrome in either group. The evidence addressing this outcome was rated as insufficient because of the lack of any good quality, RCT evidence.

Transient tachypnea of the newborn. Three fair to good quality RCTs provided evidence that the risk of transient tachypnea of the newborn was not different in women who had elective induction as compared to expectant management. Because of the consistency of the evidence and the individual quality ratings, the overall strength of evidence was rated as low.

Neonatal sepsis. Two good quality, large RCTs examined both the risk of suspected neonatal sepsis and culture-proven sepsis. These two studies did not find that the rates of suspected neonatal sepsis were different in women with elective induction versus expectant management. Given the consistency of these two RCTs, the evidence was rated as low.

Hypoxic-ischemic encephalopathy. No studies designated hypoxic-ischemic encephalopathy as an outcome of interest and the evidence was rated as insufficient.

Birthweight. One RCT involving 302 women reported that the rate of large-for-gestational-age (LGA) neonates was lower in women who were electively induced compared to expectant management. However, three poor quality observational studies provided conflicting results regarding the effect of elective induction of labor on rates of birthweight greater than 4,000 grams.

Three fair to good quality RCTs provided evidence that elective induction of labor reduces the rate of macrosomia (birthweight greater than 4,500 grams). Four observational studies provided conflicting data regarding the effect of elective induction of incidence of birthweight less than 2,500 grams. The overall evidence that elective induction of labor reduces LGA and macrosomia was rated as low because of the small number of studies for each outcome.

Neonatal seizures. Two RCTs (one large and good quality and one medium sized and fair quality) reported no difference in the risk of neonatal seizure between women who were electively induced or expectantly managed. The evidence was rated as low because of the small number of studies.

Hypoglycemia. Two RCTs (one large and good quality and one medium sized and fair quality) provided evidence that hypoglycemia was not associated with elective induction of labor and the evidence was rated as low because of the small number of studies.

Neonatal jaundice. Three poor to fair quality studies (two small RCTs and one larger observational case-control) provided evidence that the risk of neonatal jaundice was not higher in women undergoing elective induction of labor; the overall evidence was rated as low because of the small number of studies.

Neonatal polycythemia. Two relatively large RCTs provided evidence that the risk of neonatal polycythemia was not different between comparison groups (elective labor induction versus expectant management) and the evidence was rated as low because of the small number of studies.

Breastfeeding. One relatively small, poor quality, cohort study from the Netherlands provided evidence of higher rates of breastfeeding in women who had spontaneous labor than those who had induction of labor. The overall evidence was rated as insufficient.

### Key Question 3: What is the evidence that certain physical conditions/patient characteristics (e.g., parity, cervical dilatation, previous pregnancy outcome) are predictive of a successful induction of labor?

Because patient characteristics such as parity, cervical dilatation, and maternal age are correlated, the best way to evaluate the extent to which these characteristics predict successful induction of labor would be to perform a meta-regression.^108^ Specifically, to answer Key Question 3, we planned a regression analysis with successful induction of labor as the dependent variable and a list of well-established key maternal and obstetric factors (e.g., maternal age, parity, gestational age at delivery, Bishop score)^42,^ ^118^–^122^ as the independent variables. We were unable to perform such an analysis because the included studies typically did not report data in a suitable format and because the definition of successful induction of labor was so varied that we were unable to abstract data for a consistent outcome (see Table 2.15). Instead, since studies more typically reported the predictors of cesarean delivery (i.e. failed induction), we synthesized those data (i.e., predictors of cesarean delivery, given that women had induced labor).

Table 2.15 Definition of Induction of Labor Success

Definition | n/N (%)
Vaginal delivery | 44/76 (57.9%)^1^–^44^
Spontaneous vaginal delivery | 16/76 (21.1%)^11,^ ^15,^ ^22,^ ^25,^ ^27,^ ^28,^ ^31,^ ^43,^ ^45^–^52^
Vaginal delivery within 24 hours | 9/76 (11.8%)^1,^ ^5,^ ^13,^ ^53^–^58^
Not Specified | 17/76 (22.4%)^59^–^75^
Miscellaneous Definitions Used: Vaginal delivery within 6 hours Vaginal delivery within 12 hours Vaginal delivery within 18 hours Labor within 12 hours Active Labor Achieved Delivery within 48 hours of scheduled induction | 1/76 (1.3 %) ^76^ 1/76 (1.3 %) ^24^ 1/76 (1.3 %) ^13^ 1/76 (1.3 %) ^41^ 1/76 (1.3 %) ^44^ 1/76 (1.3 %) ^25^

Note: Fourteen studies report more than one measure of induction of labor success. ^1,^ ^5,^ ^11,^ ^13,^ ^15,^ ^22,^ ^24,^ ^25,^ ^27,^ ^28,^ ^31,^ ^41,^ ^43,^ ^44^

Predictors of cesarean delivery. Forty-one studies reported data on predictors of cesarean delivery (Figure 2.23).^2,^ ^4^–^7,^ ^10^–^12,^ ^14,^ ^16,^ ^18,^ ^19,^ ^23,^ ^25,^ ^26,^ ^28^–^30,^ ^32,^ ^33,^ ^35,^ ^39,^ ^40,^ ^43^–^46,^ ^49,^ ^51^–^56,^ ^60,^ ^70^–^74,^ ^123^ One reported data on emergency cesarean delivery and so was not included in our synthesis.^36^ Seventeen of these 41 studies also reported predictors of successful induction (either overall vaginal delivery (including both spontaneous and operative), spontaneous vaginal delivery, or vaginal delivery in 24 hours);^5,^ ^23,^ ^25,^ ^28,^ ^29,^ ^43^–^46,^ ^49,^ ^51,^ ^54^–^56,^ ^72,^ ^124^ additionally, five studies reported only predictors of successful induction;^1,^ ^24,^ ^38,^ ^48,^ ^57^ one reported predictors of both failed induction and successful induction^58^ and one study reported data on failed induction.^41^ We present the general description of all these studies (Appendix Tables 1 and 2) as well as other predictors of cesarean delivery not reported below (Appendix Tables 3 to 5) and predictors of induction success and failure (other than cesarean delivery) (Appendix Tables 6 to 9) in Appendix C.

Figure 2.23 Cesarean delivery predictors reported

Parity. Three RCTs and 20 cohort studies reported both nulliparity and multiparity as a predictor of cesarean delivery among women who underwent induction of labor. In general, most studies reported lower cesarean delivery rates among multiparous than nulliparous women. In the RCTs, the rate of cesarean deliveries among nulliparous women was 11 percent compared with two percent in multiparous women. When we combined the data from the RCTs, there was a decreased risk of cesarean delivery among the multiparous women when compared with the nulliparous women (OR 0.21; 95 percent CI: 0.06–0.72, P=0.01). Of note, when we looked at the absolute difference in risk there was a lower rate among multiparous women, though this absolute difference in risk was not statistically significant (-0.09 (-0.21 to +0.04), P=0.16).

Among the cohort studies, the rate of cesarean delivery was 28 percent among the nulliparous women compared with 10 percent among the multiparous women. When we combined the cohort studies, there was a decreased risk of cesarean delivery among the multiparous women when compared to the nulliparous women (OR 0.27; 95 percent CI: 0.16–0.45, Figure 2.24 risk difference -0.19 (-0.27 to -0.12), Appendix C Figure 19). The studies were highly heterogeneous. Five of the studies reported individual effect sizes that were not significantly different for risk of cesarean delivery between the two groups of women. In sensitivity analysis, when we removed each of these studies, the risk of cesarean delivery became significantly lower in multiparous women.

Figure 2.24 Cesarean deliveries (following induction) by parity: Cohort studies

We further assessed parity as a predictor of cesarean delivery rates in the RCTs that compared elective induction of labor with expectant management. We analyzed nulliparity as a predictor of cesarean delivery between induced labor and expectant management in two ways: first we examined the effect of nulliparity among the expectant management group and induction of labor group separately (Figure 2.25); then we calculated a weighted mean nulliparity rate for the studies and assessed its relationship to the risk of cesarean delivery (Figure 2.26). The mean nulliparity rate among the expectant management group was 51 percent compared with 53 percent in the elective induction of labor group. The overall weighted mean nulliparity rate for the studies was 51 percent. We did not find a significant relationship between nulliparity and the odds of cesarean delivery between the two groups in our included RCTs.

Figure 2.25 Nulliparity in expectant management and elective induction of labor groups and cesarean delivery odds ratio between the two groups

Figure 2.26 Mean nulliparity rate and cesarean delivery odds ratio between the two groups

Cervical status: Bishop score. Twelve cohort studies examined the cervical status using the Bishop score at the time of labor induction and the association with cesarean delivery. Most of these studies dichotomized the Bishop scores using three, four, or five as thresholds (Table 2.12). One study,^7^ included only women with a Bishop score of greater than four and performed a stratified analysis of subjects with Bishop scores between four and eight versus greater than eight. While these studies may differ by study design or patient population, all reported that the frequency of cesarean delivery is inversely related to Bishop scores such that a higher rate of cesarean delivery was observed in women with a lower Bishop score compared to women with more favorable cervix as represented by higher Bishop scores.

Table 2.12 Cesarean deliveries (following induction of labor) by Bishop score

Article | Bishop score n/N (%)
| <5 | >=5 | <=5 | >5 | <4 | >=4 | <=3 | > 3 | >=4 and <8 | >=8
Alberico S^23^ | 21/100 (21.0) | 5/33 (15.2) | NR | NR | NR | NR | NR | NR | NR | NR
Orhue AAE^33^ | 46/271 (16.9) | 41/660 (6.2) | NR | NR | NR | NR | NR | NR | NR | NR
Tan PC^2^ | 17/50 (34.0) | 18/102 (17.6) | NR | NR | NR | NR | NR | NR | NR | NR
Arulkumaran S^32^ | NR | NR | NR | NR | 41/85 (48.2) | 132/972 (13.6) | NR | NR | NR | NR
Dhall K^56^ | NR | NR | NR | NR | 16/47 (34.0) | 22/153 (14.4) | NR | NR | NR | NR
Dodd JM^53^ | NR | NR | NR | NR | NR | 46/240 (19.2) | 105/380 (27.6) | NR | NR | NR
Xenakis EMJ^44^ | NR | NR | NR | NR | NR | NR | 59/202 (29.2) | 59/395 (14.9) | NR | NR
Gabriel R^16^ | NR | NR | 43/133 (32.3) | 10/46 (21.7) | NR | NR | NR | NR | NR | NR
Macer JA^28^ | NR | NR | 14/61 (22.9) | 23/192 (11.9) | NR | NR | NR | NR | NR | NR
Schreyer P^29^ | NR | NR | 3/34 (8.8) | 1/27 (3.7) | NR | NR | NR | NR | NR | NR
Nielsen PE^7^ | NR | NR | NR | NR | NR | NR | NR | NR | 6/65 (9.2) | 2/51 (3.9)

NR: not reported; Ware et al.^19^ reported a cesarean delivery rate of 50 percent among women with Bishop scores <=4 and 15 percent among women with Bishop scores >4.

Maternal age. Two observational studies examined the association between maternal age and cesarean delivery among women undergoing induction of labor. A prospective cohort study by Tan and colleagues^2^ was conducted in Malaysia between January 2003 and August 2004. This study included 152 women who had an induction of labor. In this cohort, there was no significant difference in cesarean delivery rates between women who were less than 35 years (24.0 percent) compared with women who were greater than or equal to 35 years (19 percent) of age. In another prospective study conducted between 1974 and 1981, Orhue and colleagues^33^ examined 1,775 women who had induction of labor in Nigeria and found that maternal age greater than 35 years was not associated with increased cesarean delivery; 71 of 844 (8.4 percent) women with age less than or equal to 35 years had cesarean delivery compared to 89 of 931 (9.6 percent) women with age greater than 35 years.

Seven RCTs comparing elective induction of labor with expectant management reported mean age of the women included in their trials. Mean age of the women did not appear to predict the odds ratio of cesarean delivery between induced labor versus expectant management in these studies (Figure 2.27).

Figure 2.27 Mean maternal age in RCTs as a predictor of the odds of cesarean delivery between induced labor and expectant management

Maternal body-mass index. One prospective cohort study conducted in England between 2001 and 2003 examined maternal body-mass index as a predictor of cesarean delivery in the setting of IOL. The authors reported that women with a BMI greater than 29 kg/m^2^ had a higher frequency of cesarean delivery (15/32, 47 percent) compared to women with a BMI less than 30kg/m^2^ (65/235, 28 percent).^5^

Gestational age at delivery. Four cohort studies examined gestational age at delivery as a predictor of cesarean delivery in women who underwent induction of labor compared to spontaneous labor. Overall, there was a trend of increasing frequency of cesarean delivery with increasing gestational age (Table 2.13). One large retrospective cohort study of 6,985 women, conducted in Canada, observed that cesarean frequency increased from 18.5 percent when delivery occurred between 39 and 40 weeks gestation to 23.9 percent at 41 weeks gestation, and was as high as 44.6 percent when delivery occurred during 42 weeks and beyond.^30^ Similarly, another cohort study reported women who delivered at 40 weeks or less also had a cesarean frequency (18.9 percent) lower than that of women who delivered at greater than 40 weeks (27.4 percent).^2^

Table 2.13 Cesarean deliveries (following induction of labor) by gestational age

Article | Gestational age (weeks) n/N (%)
| 41 | Greater than or equal to 42 | Less than or equal to 40 | Greater than 40
Boyd ME^30^ | 328/1367 (23.9) | 150/336 (44.6) | 977/5282 (18.5) | Not reported
Caughey A^3^ | 147/821 (18) | Not reported | 281/1633 (17.2) | Not reported
Heimstad R^46^ | 69/349 (19.8) | 129/599 (21.6) | 207/1552 (13) | Not reported
Tan PC^2^ | Not reported | Not reported | 15/79 (18.9) | 20/73 (27.4)

Amniotic fluid index. The amniotic fluid index (AFI) is the sum of the deepest vertical measurement of the amniotic fluid in the four quadrants of the uterus with a normal range of five to 20. Three cohort studies evaluated the association between AFI and cesarean delivery among women undergoing induction of labor. They reported conflicting results: While one study from England ^6^ reported that women with an amniotic fluid index (AFI) less than or equal to five had a higher frequency of cesarean delivery (39.4 percent) compared to women with an AFI greater than 5 (14 percent), two other cohort studies report otherwise (Table 2.14). These two smaller studies ^2,^ ^49^ reported that women with a low AFI had lower cesarean delivery (5.0 percent, 9.5 percent, respectively for the two studies) compared to women with a normal AFI greater than 5 or 6 (9.5 percent, 26.7 percent, respectively for the two studies).

Table 2.14 Cesarean deliveries (following induction of labor) by amniotic fluid index (AFI)

Article | Amniotic fluid index n/N (%)
| <=5 | >5 | <=6 | >6
Alchalabi HA ^6^ | 26/66 (39.4) | 16/114 (14.0) | Not reported | Not reported
Tan PC ^2^ | 1/17 (5.9) | 34/135 (25.2) | Not reported | Not reported
Rizzo N ^49^ | Not reported | Not reported | 2/21 (9.5) | 16/60 (26.7)

### Summary of evidence assessing Key Question 3: What is the evidence that certain physical conditions/patient characteristics (e.g., parity, cervical dilatation, previous pregnancy outcome) are predictive of a successful induction of labor?

Parity. Twenty-three studies examined parity as a predictor of cesarean delivery in women undergoing induction of labor. In three RCTs, there was a decreased risk of cesarean delivery among the multiparous women when compared with the nulliparous women (OR 0.21; 95 percent CI: 0.06–0.72). Among the 20 cohort studies, the rate of cesarean delivery was 28 percent among the nulliparous women compared with 10 percent among the multiparous women. When we combined the cohort studies, there was a decreased risk of cesarean delivery among the multiparous women when compared to the nulliparous women (OR 0.27; 95 percent CI 0.16–0.45). The overall evidence regarding this predictor was rated as high.

Cervical status. Twelve studies measured Bishop scores to evaluate cervical status as a predictor of cesarean delivery in women undergoing induction of labor. These studies differed by study design and patient population; however, all reported that the frequency of cesarean delivery was inversely related to Bishop scores such that a higher rate of cesarean delivery was observed in women with a lower Bishop score compared to women with more favorable cervix as represented by higher Bishop scores. The overall evidence evaluating this predictor was rated as moderate.

Maternal age. Two observational studies presented conflicting data to support maternal age as a predictor of cesarean delivery. Thus, the direction of effect could not be adequately determined based on the current literature reviewed and the evidence was rated as insufficient.

Maternal body-mass index. We identified one small prospective cohort study that examined maternal body-mass index as a predictor of cesarean delivery in the setting of induction of labor. The authors found that women with a BMI greater than or equal to 30kg/m^2^ had a higher frequency of cesarean delivery. We rated the strength of evidence as insufficient given the small-sized, single study of the topic.

Gestational age. Four cohort studies had consistent evidence to support that increasing gestational age was associated with increased rates of cesarean delivery in the setting of induction of labor and the strength of evidence was rated as moderate.

Amniotic fluid index. Three studies presented conflicting results regarding the level of amniotic fluid index at time of induction and its effect on mode of delivery. The evidence was insufficient to support any conclusions regarding the direction of effect.

### Key Question 4: Definition of Successful Labor Induction

We evaluated the definition of successful labor induction from each of the 76 included studies. 59 (78 percent) studies specified how a successful labor induction was defined (Table 2.15).

There are two principal means of defining successful induction of labor: Based on mode of delivery or having achieved the active phase of labor. We argue that the latter is more appropriate. The fundamental reason why induction of labor may lead to a cesarean delivery is through failure to achieve the active phase of labor, whereas a cesarean delivery during labor is common for two biologic reasons: Fetal intolerance of labor or cephalo-pelvic disproportion. Since the fetus continues to grow and the utero-placental unit only becomes more senescent with increasing gestational age, an elective induction of labor should only reduce the potential impact of both of these issues. Thus, if a cesarean delivery occurs in the setting of induction of labor, the most appropriate causal pathway is via the failure to achieve active phase of labor. Of the 76 included studies, only one utilized this definition to define success.^44^

Forty-four (58 percent) of the included studies defined success as achieving a vaginal delivery anytime after the onset of the induction of labor. (This was often inverted in that an induction was considered a failure when it lead to a cesarean delivery.) Other definitions of success included a spontaneous vaginal delivery or achieving a vaginal delivery in a specific amount of time, most commonly 24 hours, but also 6, 12, or 18 hours. One study defined induction of labor success as the onset of labor within 12 hours.^24^ Only one study defined induction of labor success as achieving active labor.^44^