# Appendix E: Technical Expert Panel and Peer Reviewers

## Technical Expert Panel

William A. Grobman, M.D., M.B.A., Associate Professor, Division of Maternal-Fetal Medicine, Department of Medicine, Obstetrics & Gynecology, Northwestern University.

George A. Macones, M.D., M.S.C.E., Mitchell and Elaine Yanow Professor, Obstetrics and Gynecology Chairman, Department of Obstetrics and Gynecology, Washington University in St. Louis.

Susan Meikle, M.D. M.S.P.H., Senior Medical Officer, Office of Research on Women's Health, Office of the Director, NIH.

James M. Nicholson, M.D. M.S.C.E., Assistant Professor, Department of Family Medicine and Community Health, 2 Gates, Hospital of the University of Pennsylvania.

Patrick S. Ramsey, M.D., Associate Professor of Obstetrics and Gynecology, Obstetrics and Gynecology Chair Office, University of Alabama at Birmingham.

Laura E. Riley, M.D., Assistant Professor of Obstetrics, Gynecology and Reproductive Biology, Harvard Medical School, Harvard University.

Julian N. Robinson, M.D., Associate Clinical Professor of Obstetrics, Gynecology and Reproductive Biology, Harvard Medical School, Harvard University.

Dwight J. Rouse, M.D., M.S.P.H., Associate Professor, Obstetrics and Gynecology Maternal and Fetal Medicine, Kirkland Clinic, University of Alabama at Birmingham.

Andrew J. Satin, M.D., F.A.C.O.G., Chair Department of Obstetrics and Gynecology, Johns Hopkins Bayview Medical Center; Vice Chair/Deputy Director, Department of Gynecology and Obstetrics, Johns Hopkins University School of Medicine.

Deborah A. Wing, M.D., Associate Professor and Division Director, Department of Obstetrics and Gynecology, Division of Maternal Fetal Medicine, University of California, Irvine.

Jun “Jim” Zhang, Ph.D., M.D., Senior Investigator, Epidemiology Branch, National Institute of Child Health and Human Development, National Institutes of Health.

## Peer Reviewers

Leah Albers, C.N.M., Dr.P.H., F.A.C.N.M., F.A.A.N., Professor, U.N.M. College of Nursing, University of New Mexico, Albuquerque, N.M.

Tekoa King, R.N., M.P.H., C.N.M., Deputy Editor of the Journal of Midwifery & Women's Health and Associate Professor in the Department of Obstetrics, Gynecology and Reproductive Health, University of California San Francisco.

Donna R Halloran, M.D., M.S.P.H., Assistant Professor of Pediatrics, Saint Louis University.

Nancy O'Reilly, M.H.S., Manager, Practice Bulletins, American College of Obstetricians and Gynecologists.

Stephen Ratcliffe, M.D., M.S.P.H., Director, Lancaster Pennsylvania Residency Program. Family and Community Medicine, Lancaster General Hospital, Lancaster, Pennsylvania.