# Appendix D: List of Excluded Studies

## Article Reason for exclusion

A randomized control study of oxytocin augmentation of labour. 1. Obstetric outcome. Br J Obstet Gynaecol. 1988 Jan;95(1):104–7. Not a study of elective induction of labor or predictors of success in the setting of induced labor
Adams JL. The use of obstetrical procedures in the care of low-risk women. Women Health. Spring. 1983;8(1):25-34. Not a study of elective induction of labor or predictors of success in the setting of induced labor. [pmid: 6868624].
Adelstein P, Fedrick J, Howat P, Robinson R, Turnbull AC. Obstetric practice and infant morbidity. Br J Obstet Gynaecol. Oct. 1977;84(10):721-5. Not a study of elective induction of labor or predictors of success in the setting of induced labor. [pmid: 921906].
Akyol D, Mungan T, Unsal A, Yuksel K. Prelabour rupture of the membranes at term—no advantage of delaying induction for 24 hours. Aust N Z J Obstet Gynaecol. Aug. 1999;39(3):291-5. Not a study of elective induction of labor or predictors of success in the setting of induced labor. [pmid: 10554936].
Albers LL, Savitz DA. Hospital setting for birth and use of medical procedures in low-risk women. J Nurse Midwifery. Nov–Dec. 1991;36(6):327-33. Not a study of elective induction of labor or predictors of success in the setting of induced labor. [pmid: 1757818].
Alexander JM, Lucas MJ, Ramin SM, McIntire DD, Leveno KJ. The course of labor with and without epidural analgesia. Am J Obstet Gynecol. Mar. 1998;178(3):516-20. Not a study of elective induction of labor or predictors of success in the setting of induced labor. [pmid: 9539519].
Alexander JM, McIntire DD, Leveno KJ. Forty weeks and beyond: pregnancy outcomes by week of gestation. Obstet Gynecol. Aug. 2000;96(2):291-4. Not a study of elective induction of labor or predictors of success in the setting of induced labor. [pmid: 10908780].
Allen VM, O'Connell CM, Baskett TF. Maternal morbidity associated with cesarean delivery without labor compared with induction of labor at term. Obstet Gynecol. Aug. 2006;108(2):286-94. Not a study of elective induction of labor or predictors of success in the setting of induced labor. [pmid: 16880297].
Al-Taani M. Pregnancies past the estimated date of confinement: labour and delivery outcome. East Mediterr Health J. Sep–Nov. 2003;9(56):955-60. Data not usable. [pmid: 16450525].
Anderson AB, Turnbull AC, Baird D. The influence of induction of labour on caesarean section rate, duration of labour and perinatal mortality in Aberdeen primigravidae between 1938 and 1966. J Obstet Gynaecol Br Commonw. Aug. 1968;75(8):800-11. Not a study of elective induction of labor or predictors of success in the setting of induced labor. [pmid: 5673322].
Anderson T. Induction of labour for suspected fetal macrosomia. Pract Midwife. Feb. 2000;3(2):10-1. Ineligible Study Design.
Arulkumaran S, Gibb DM, Heng SH, Ratnam SS. Perinatal outcome of induced labour. Asia Oceania J Obstet Gynaecol. Mar. 1985;11(1):33-7. Not a study of elective induction of labor or predictors of success in the setting of induced labor. [pmid: 4040358].
Bahn SA, Jacobson J, Petersen F. Maternal and neonatal outcome following prolonged labor induction. Obstet Gynecol. Sep. 1998;92(3):403-7. Not a study of elective induction of labor or predictors of success in the setting of induced labor. [pmid: 9721779].
Bakketeig LS, Petersen SO, Bersjo P. Statistical comparison in a controlled trial of elective induction of labor. Acta Obstet Gynecol Scand. 1980;59(2):191-2. Ineligible Study Design. [pmid: 6967671].
Barda G, Arbel-Alon S, Bernstein D, Zakut H, Menczer J. Pregnancy and delivery in a group of Israeli teenagers. A case-controlled study. Clin Exp Obstet Gynecol. 1998;25(12):32-5. Not a study of elective induction of labor or predictors of success in the setting of induced labor. [pmid: 9743876].
Barros FC, Velez Mdel P. Temporal trends of preterm birth subtypes and neonatal outcomes. Obstet Gynecol. May. 2006;107(5):1035-41. Data not usable. [pmid: 16648408].
Baruffi G, Dellinger WS Jr, Strobino DM, Rudolph A, Timmons RG, Ross A. Patterns of obstetric procedures use in maternity care. Obstet Gynecol. Oct. 1984;64(4):493-8. Not a study of elective induction of labor or predictors of success in the setting of induced labor. [pmid: 6483297].
Baxter S. Orgasm and labour in primiparae. J Psychosom Res. Oct. 1974;18(5):357-60. Not a study of elective induction of labor or predictors of success in the setting of induced labor. [pmid: 4435707].
Beard R, Boyd I, Holt E. A study of cervical vibration in induced labour. J Obstet Gynaecol Br Commonw. Nov. 1973;80(11):966-9. Not a study of elective induction of labor or predictors of success in the setting of induced labor. [pmid: 4752987].
Beard R, Steer PJ. Induction of labour and perinatal mortality. Br Med J. Aug 20. 1977;2(6085):516-7. Ineligible Study Design. [pmid: 890377].
Beazley JM, Alderman B. Neonatal hyperbilirubinaemia following the use of oxytocin in labour. Br J Obstet Gynaecol. Apr. 1975;82(4):265-71. Not a study of elective induction of labor or predictors of success in the setting of induced labor. [pmid: 1125148].
Beazley JM, Alderman B. The ‘inductograph’—a graph describing the limits of the latent phase of induced labour in low risk situations. Br J Obstet Gynaecol. Jul. 1976;83(7):513-7. Not a study of elective induction of labor or predictors of success in the setting of induced labor. [pmid: 952780].
Beazley JM. Controlled parturition. Br J Hosp Med. 1977 Mar;17(3):237–8, 41–4. Ineligible Study Design
Beebe LA, Rayburn WF, Beaty CM, Eberly KL, Stanley JR, Rayburn LA. Indications for labor induction. Differences between university and community hospitals. J Reprod Med. Jun. 2000;45(6):469-75. Not a study of elective induction of labor or predictors of success in the setting of induced labor. [pmid: 10900580].
Behague DP, Victora CG, Barros FC. Consumer demand for caesarean sections in Brazil: informed decision making, patient choice, or social inequality? A population based birth cohort study linking ethnographic and epidemiological methods. BMJ. Apr 20. 2002;324(7343):942-5. Not a study of elective induction of labor or predictors of success in the setting of induced labor. [pmid: 11964338].
Beilin Y, Friedman F Jr, Andres LA, Hossain S, Bodian CA, Andres LA, Hossain S, Bodian CA. The effect of the obstetrician group and epidural analgesia on the risk for cesarean delivery in nulliparous women. Acta Anaesthesiol Scand. Sep. 2000;44(8):959-64. Not a study of elective induction of labor or predictors of success in the setting of induced labor. [pmid: 10981573].
Belfrage P, Fernstrom I, Hallenberg G. Routine or selective ultrasound examinations in early pregnancy. Obstet Gynecol. May. 1987;69(5):747-50. Not a study of elective induction of labor or predictors of success in the setting of induced labor. [pmid: 3554057].
Ben-Haroush A, Yogev Y, Bar J, Glickman H, Kaplan B, Hod M. Indicated labor induction with vaginal prostaglandin E2 increases the risk of cesarean section even in multiparous women with no previous cesarean section. J Perinat Med. 2004;32(1):31-6. Data not usable. [pmid: 15008383].
Ben-Haroush A, Yogev Y, Glickman H, Bar J, Kaplan B, Hod M. Mode of delivery in pregnancies with premature rupture of membranes at or before term following induction of labor with vaginal prostaglandin E2. Am J Perinatol. Jul. 2004;21(5):263-8. Not a study of elective induction of labor or predictors of success in the setting of induced labor. [pmid: 15232758].
Bergsjo P, Halle C. Duration of the second stage of labor. Acta Obstet Gynecol Scand. 1980;59(3):193-6. Not a study of elective induction of labor or predictors of success in the setting of induced labor. [pmid: 7424495].
Bianco A, Stone J, Lynch L, Lapinski R, Berkowitz G, Berkowitz RL. Pregnancy outcome at age 40 and older. Obstet Gynecol. Jun. 1996;87(6):917-22. Not a study of elective induction of labor or predictors of success in the setting of induced labor. [pmid: 8649698].
Black BP, McBride WG. Children born after elective induction of labour. Med J Aust. Oct 6. 1979;2(7):362-3. No eligible outcomes. [pmid: 514187].
Bodner-Adler B, Bodner K, Pateisky N, Kimberger O, Chalubinski K, Mayerhofer K, et al. Influence of labor induction on obstetric outcomes in patients with prolonged pregnancy: a comparison between elective labor induction and spontaneous onset of labor beyond term. Wien Klin Wochenschr. Apr. 2005;117(78):287-92. Post-term. [pmid: 15926620].
Brinsden PR, Clark AD. Postpartum haemorrhage after induced and spontaneous labour. Br Med J. Sep 23. 1978;2(6141):855-6. Not a study of elective induction of labor or predictors of success in the setting of induced labor. [pmid: 309347].
Browne DS. Induction of labour. Med J Aust. Nov 19. 1977;2(21):721. Not a study of elective induction of labor or predictors of success in the setting of induced labor. [pmid: 607132].
Buchan PC. Pathogenesis of neonatal hyperbilirubinaemia after induction of labour with oxytocin. Br Med J. Nov 17. 1979;2(6200):1255-7. Not a study of elective induction of labor or predictors of success in the setting of induced labor. [pmid: 519401].
Bueno B, San-Frutos L, Salazar F, Perez-Medina T, Engels V, Archilla B, et al. Variables that predict the success of labor induction. Acta Obstet Gynecol Scand. Nov. 2005;84(11):1093-7. Duplicate of Included Study. [pmid: 16232178].
Caliskan E, Dilbaz S, Gelisen O, Dilbaz B, Ozturk N, Haberal A. Unsucessful labour induction in women with unfavourable cervical scores: predictors and management. Aust N Z J Obstet Gynaecol. Dec. 2004;44(6):562-7. Method of induction study. [pmid: 15598298].
Callen P, Goldsworthy S, Graves L, Harvey D, Mellows H, Parkinson C. Mode of delivery and the lecithin/sphingomyelin ratio. Br J Obstet Gynaecol. Dec. 1979;86(12):965-8. Not a study of elective induction of labor or predictors of success in the setting of induced labor. [pmid: 526455].
Cary AJ. Intervention rates in spontaneous term labour in low risk nulliparous women. Aust N Z J Obstet Gynaecol. Feb. 1990;30(1):46-51. Not a study of elective induction of labor or predictors of success in the setting of induced labor. [pmid: 2346451].
Caseby NG. Epidural analgesia for the surgical induction of labour. Br J Anaesth. Oct. 1974;46(10):747-51. Not a study of elective induction of labor or predictors of success in the setting of induced labor. [pmid: 4621198].
Caughey AB, Bishop JT. Maternal complications of pregnancy increase beyond 40 weeks of gestation in low-risk women. J Perinatol. Sep. 2006;26(9):540-5. Not a study of elective induction of labor or predictors of success in the setting of induced labor. [pmid: 16837930].
Chalmers I, Campbell H, Turnbull AC. Use of oxytocin and incidence of neonatal jaundice. Br Med J. Apr 19. 1975;2(5963):116-8. Not a study of elective induction of labor or predictors of success in the setting of induced labor. [pmid: 1125700].
Chalmers I, Lawson JG, Turnbull AC. Evaluation of different approaches to obstetric care: Part II. Br J Obstet Gynaecol. Dec. 1976;83(12):930-3. Not a study of elective induction of labor or predictors of success in the setting of induced labor. [pmid: 1009032].
Chalmers JA, Prakash A. Optimal dosage of buccal oxytocin for the induction of labor. Am J Obstet Gynecol. Sep 15. 1971;111(2):227-32. Method of induction study. [pmid: 5098592].
Chan BC, Lao TT. Influence of parity on the obstetric performance of mothers aged 40 years and above. Hum Reprod. Mar. 1999;14(3):833-7. Not a study of elective induction of labor or predictors of success in the setting of induced labor. [pmid: 10221722].
Chance GW. Elective delivery, premature rupture of the membranes and the respiratory distress syndrome. Can Med Assoc J. Feb 9. 1980;122(3):265-7. Not a study of elective induction of labor or predictors of success in the setting of induced labor. [pmid: 7370819].
Chandra S, Crane JM, Hutchens D, Young DC. Transvaginal ultrasound and digital examination in predicting successful labor induction. Obstet Gynecol. Jul. 2001;98(1):2-6. Data not usable. [pmid: 11430948].
Chang TC, Tan KT, Neow P, Yeo GS. Computerised analysis of foetal heart rate variation: prediction of adverse perinatal outcome in patients undergoing prostaglandin induction of labour at term. Ann Acad Med Singapore. Nov. 1997;26(6):772-5. Not a study of elective induction of labor or predictors of success in the setting of induced labor. [pmid: 9522978].
Chanrachakul B, Herabutya Y. Postterm with favorable cervix: is induction necessary?. Eur J Obstet Gynecol Reprod Biol. Feb 10. 2003;106(2):154-7. Not a study of elective induction of labor or predictors of success in the setting of induced labor. [pmid: 12551783].
Chattopadhyay SK, Sengupta BS, Edrees YB. Intracervical application of prostaglandin E2 tablets for elective induction of labor in grand multiparae: a prospective controlled study. Eur J Obstet Gynecol Reprod Biol. Jun. 1986;22(12):7-15. Not a study of elective induction of labor or predictors of success in the setting of induced labor. [pmid: 3522309].
Chen WH, Lai HC, Tang YH, Liu HS. Fetal Doppler hemodynamic changes in spontaneous versus prostaglandin E1-induced active labor. Acta Obstet Gynecol Scand. Aug. 1999;78(7):599-604. Not a study of elective induction of labor or predictors of success in the setting of induced labor. [pmid: 10422906].
Cheng YW, Shaffer BL, Caughey AB. Associated factors and outcomes of persistent occiput posterior position: A retrospective cohort study from 1976 to 2001. J Matern Fetal Neonatal Med. Sep. 2006;19(9):563-8. Not a study of elective induction of labor or predictors of success in the setting of induced labor. [pmid: 16966125].
Cheng YW, Shaffer BL, Caughey AB. The association between persistent occiput posterior position and neonatal outcomes. Obstet Gynecol. Apr. 2006;107(4):837-44. Not a study of elective induction of labor or predictors of success in the setting of induced labor. [pmid: 16582120].
Chew WC, Swann IL. Influence of simultaneous low amniotomy and oxytocin infusion and other maternal factors on neonatal jaundice: a prospective study. Br Med J. Jan 8. 1977;1(6053):72-3. Not a study of elective induction of labor or predictors of success in the setting of induced labor. [pmid: 832018].
Chia YT, Arulkumaran S, Soon SB, Norshida S, Ratnam SS. Induction of labour: does internal tocography result in better obstetric outcome than external tocography. Aust N Z J Obstet Gynaecol. May. 1993;33(2):159-61. Not a study of elective induction of labor or predictors of success in the setting of induced labor. [pmid: 8216115].
Chigbu CO, Ezeome IV, Okezie AO, Oyefara B. Induction of labor on request in a resource-poor setting. Int J Gynaecol Obstet. Apr 18 2007. Data not usable
Chua S, Arulkumaran S. Intrapartum care. Aust N Z J Obstet Gynaecol. Feb. 1997;37(1):25-35. Not a study of elective induction of labor or predictors of success in the setting of induced labor. [pmid: 9075543].
Clinch J. Induction of labour—a six year review. Br J Obstet Gynaecol. May. 1979;86(5):340-2. Not a study of elective induction of labor or predictors of success in the setting of induced labor. [pmid: 465381].
Cnattingius R, Hoglund B, Kieler H. Emergency cesarean delivery in induction of labor: an evaluation of risk factors. Acta Obstet Gynecol Scand. May. 2005;84(5):456-62. Data not usable. [pmid: 15842210].
Combs CA, Murphy EL, Laros RK Jr. Cost-benefit analysis of autologous blood donation in obstetrics. Obstet Gynecol. Oct. 1992;80(4):621-625. Not a study of elective induction of labor or predictors of success in the setting of induced labor. [pmid: 1407883].
Combs CA, Singh NB, Khoury JC. Elective induction versus spontaneous labor after sonographic diagnosis of fetal macrosomia. Obstet Gynecol. Apr. 1993;81(4):492-496. Not a study of elective induction of labor or predictors of success in the setting of induced labor. [pmid: 8459954].
Conway DL, Adkins WB, Schroeder B, Langer O. Isolated oligohydramnios in the term pregnancy: is it a clinical entity?. J Matern Fetal Med. Jul–Aug. 1998;7(4):197-200. Not a study of elective induction of labor or predictors of success in the setting of induced labor. [pmid: 9730487].
Conway DL, Langer O. Elective delivery of infants with macrosomia in diabetic women: reduced shoulder dystocia versus increased cesarean deliveries. Am J Obstet Gynecol. May. 1998;178(5):922-5. Not a study of elective induction of labor or predictors of success in the setting of induced labor. [pmid: 9609560].
Cooley S, Lissoni D, Geary M, Keane D. Does fetal head position at the term plus 12 scan influence induction, labor and delivery outcome?. J Perinat Med. 2004;32(3):258-9. Not a study of elective induction of labor or predictors of success in the setting of induced labor. [pmid: 15188801].
Coonrod DV, Bay RC, Kishi GY. The epidemiology of labor induction: Arizona, 1997. Am J Obstet Gynecol. Jun. 2000;182(6):1355-62. Not a study of elective induction of labor or predictors of success in the setting of induced labor. [pmid: 10871449].
Cope E. Induction of labour. Practitioner. Feb. 1967;198(184):207-16. Ineligible Study Design. [pmid: 6038978].
Crane JM, Young DC, Butt KD, Bennett KA, Hutchens D. Excessive uterine activity accompanying induced labor. Obstet Gynecol. Jun. 2001;97(6):926-31. Not a study of elective induction of labor or predictors of success in the setting of induced labor. [pmid: 11384698].
Cromi A, Ghezzi F, Tomera S, Scandroglio S, Colombo G, Bolis P. Cervical ripening with a Foley catheter: the role of pre- and postripening ultrasound examination of the cervix. Am J Obstet Gynecol. 2007 Jan;196(1):41 e1–7. Not a study of elective induction of labor or predictors of success in the setting of induced labor
Danon D, Ben-Haroush A, Yogev Y, Bar J, Hod M, Pardo J. Prostaglandin E2 induction of labor for isolated oligohydramnios in women with unfavorable cervix at term. Fetal Diagn Ther. 2007;22(1):75-9. Not a study of elective induction of labor or predictors of success in the setting of induced labor. [pmid: 17003561].
Daskalakis G, Thomakos N, Hatziioannou L, Mesogitis S, Papantoniou N, Antsaklis A. Sonographic cervical length measurement before labor induction in term nulliparous women. Fetal Diagn Ther. 2006;21(1):34-8. Not a study of elective induction of labor or predictors of success in the setting of induced labor. [pmid: 16354972].
de Hemptinne D, Thiery M, Vroman S, Martens S. Uterine contractility in spontaneous and induced labour. Z Geburtshilfe Perinatol. Aug. 1976;180(4):275-8. Not a study of elective induction of labor or predictors of success in the setting of induced labor. [pmid: 983199].
DeMott RK, Sandmire HF. The Green Bay cesarean section study. II. The physician factor as a determinant of cesarean birth rates for failed labor. Am J Obstet Gynecol. Jun. 1992;166(6 Pt 1):1799-806. discussion 806–10. Not a study of elective induction of labor or predictors of success in the setting of induced labor. [pmid: 1615989].
Dowding VM, Duignan NM, Henry GR, MacDonald DW. Induction of labour, birthweight and perinatal mortality by day of the week. Br J Obstet Gynaecol. May. 1987;94(5):413-9. Not a study of elective induction of labor or predictors of success in the setting of induced labor. [pmid: 3580324].
D'Souza SW, Black P, Macfarlane T, Richards B. The effect of oxytocin in induced labour on neonatal jaundice. Br J Obstet Gynaecol. Feb. 1979;86(2):133-8. Not a study of elective induction of labor or predictors of success in the setting of induced labor. [pmid: 427052].
Duff C, Sinclair M. Exploring the risks associated with induction of labour: a retrospective study using the NIMATS database. Northern Ireland Maternity System. J Adv Nurs. Feb. 2000;31(2):410-7. Post-term. [pmid: 10672100].
Ekman G, Persson PH, Ulmsten U. Induction of labor in postterm pregnant women. Int J Gynaecol Obstet. Feb. 1986;24(1):47-52. Not a study of elective induction of labor or predictors of success in the setting of induced labor. [pmid: 2874070].
Elferink-Stinkens PM, Brand R, le Cessie S, Van Hemel OJ. Large differences in obstetrical intervention rates among Dutch hospitals, even after adjustment for population differences. Eur J Obstet Gynecol Reprod Biol. Sep. 1996;68(12):97-103. Not a study of elective induction of labor or predictors of success in the setting of induced labor. [pmid: 8886689].
Elferink-Stinkens PM, Van Hemel OJ, Brand R. Differences in obstetrical intervention rates between Dutch hospitals. Eur J Obstet Gynecol Reprod Biol. Mar 15. 1994;53(3):165-73. Not a study of elective induction of labor or predictors of success in the setting of induced labor. [pmid: 8200463].
Elghorori MR, Hassan I, Dartey W, Abdel-Aziz E, Bradley M. Comparison between subjective and objective assessments of the cervix before induction of labour. J Obstet Gynaecol. Aug. 2006;26(6):521-6. Data not usable. [pmid: 17000497].
Enkola K, Pulkkinen MO. Induction of human labor at term: uterine activity, inducibility, duration and neonatal jaundice. Acta Physiol Hung. 1985;65(3):281-8. Not a study of elective induction of labor or predictors of success in the setting of induced labor. [pmid: 4040311].
Evans SE, Crawford JS, Stevens ID, Durbin GM, Daya H. Fluid therapy for induced labour under epidural analgesia: biochemical consequences for mother and infant. Br J Obstet Gynaecol. Apr. 1986;93(4):329-33. Not a study of elective induction of labor or predictors of success in the setting of induced labor. [pmid: 3964608].
Ezra Y, McParland P, Farine D. High delivery intervention rates in nulliparous women over age 35. Eur J Obstet Gynecol Reprod Biol. Oct. 1995;62(2):203-7. Not a study of elective induction of labor or predictors of success in the setting of induced labor. [pmid: 8582496].
Farr SL, Jamieson DJ, Rivera HV, Ahmed Y, Heilig CM. Risk Factors for Cesarean Delivery Among Puerto Rican Women. Obstet Gynecol. Jun. 2007;109(6):1351-7. Not a study of elective induction of labor or predictors of success in the setting of induced labor. [pmid: 17540807].
Fedrick J, Yudkin P. Obstetric practice in the Oxford Record Linkage Study Area 1965-72. Br Med J. Mar 27. 1976;1(6012):738-40. Not a study of elective induction of labor or predictors of success in the setting of induced labor. [pmid: 944067].
Feinstein U, Sheiner E, Levy A, Hallak M, Mazor M. Risk factors for arrest of descent during the second stage of labor. Int J Gynaecol Obstet. Apr. 2002;77(1):7-14. Not a study of elective induction of labor or predictors of success in the setting of induced labor. [pmid: 11929650].
Fenton DW, Speedie J, Duncan SL. Does cervical ripening with PGE2 affect subsequent uterine activity in labour?. Acta Obstet Gynecol Scand. 1985;64(1):27-30. Not a study of elective induction of labor or predictors of success in the setting of induced labor. [pmid: 3883690].
Ferguson JE 2nd, Newberry YG, DeAngelis GA, Finnerty JJ, Agarwal S, Turkheimer E. The fetal-pelvic index has minimal utility in predicting fetal-pelvic disproportion. Am J Obstet Gynecol. Nov. 1998;179(5):1186-92. Not a study of elective induction of labor or predictors of success in the setting of induced labor. [pmid: 9822498].
Fields H. Induction of labor: methods, hazards, complications and contraindications. Hosp Top. Dec. 1968;46(12):63-6. Ineligible Study Design. [pmid: 5743237].
Fitzpatrick M, McQuillan K, O'Herlihy C. Influence of persistent occiput posterior position on delivery outcome. Obstet Gynecol. Dec. 2001;98(6):1027-31. Not a study of elective induction of labor or predictors of success in the setting of induced labor. [pmid: 11755548].
Flaksman RJ, Vollman JH, Benfield DG. Iatrogenic prematurity due to elective termination of the uncomplicated pregnancy: a major perinatal health care problem. Am J Obstet Gynecol. Dec 15. 1978;132(8):885-8. Not a study of elective induction of labor or predictors of success in the setting of induced labor. [pmid: 736060].
Fleissig A. Prevalence of procedures in childbirth. BMJ. Feb 20. 1993;306(6876):494-5. Not a study of elective induction of labor or predictors of success in the setting of induced labor. [pmid: 8448462].
Fok WY, Chan LY, Tsui MH, Leung TN, Lau TK, Chung TK. When to induce labor for post-term? A study of induction at 41 weeks versus 42 weeks. Eur J Obstet Gynecol Reprod Biol. Apr 1. 2006;125(2):206-10. Post-term. [pmid: 16139416].
Foley ME, Alarab M, Daly L, Keane D, Rath A, O'Herlihy C. The continuing effectiveness of active management of first labor, despite a doubling in overall nulliparous cesarean delivery. Am J Obstet Gynecol. Sep. 2004;191(3):891-5. Not a study of elective induction of labor or predictors of success in the setting of induced labor. [pmid: 15467560].
Foong LC, Vanaja K, Tan G, Chua S. Membrane sweeping in conjunction with labor induction. Obstet Gynecol. Oct. 2000;96(4):539-42. Not a study of elective induction of labor or predictors of success in the setting of induced labor. [pmid: 11004355].
Frost O. Augmentation of labour in the primigravid patient. Ethiop Med J. Oct. 1984;22(4):193-201. Not a study of elective induction of labor or predictors of success in the setting of induced labor. [pmid: 6479159].
Frost O. Induction of labour in a nondoctor maternity unit. Cent Afr J Med. Nov. 1978;24(11):229-31. Not a study of elective induction of labor or predictors of success in the setting of induced labor. [pmid: 743733].
Fuchs K, Wapner R. Elective cesarean section and induction and their impact on late preterm births. Clin Perinatol. Dec. 2006;33(4):793-801. abstract viii. Ineligible Study Design. [pmid: 17148005].
Garzetti GG, Ciavattini A, La Marca N, De Cristofaro F. Longitudinal measurement of amniotic fluid index in term pregnancies and its association with intrapartum fetal distress. Gynecol Obstet Invest. 1997;44(4):234-8. Not a study of elective induction of labor or predictors of success in the setting of induced labor. [pmid: 9415520].
Gerhardstein LP, Allswede MT, Sloan CT, Lorenz RP. Reduction in the rate of cesarean birth with active management of labor and intermediate-dose oxytocin. J Reprod Med. Jan. 1995;40(1):4-8. Not a study of elective induction of labor or predictors of success in the setting of induced labor. [pmid: 7722974].
Gibb DM, Arulkumaran S, Heng SH, Ratnam SS. Characteristics of induced labour. Asia Oceania J Obstet Gynaecol. Mar. 1985;11(1):27-31. Duplicate of Included Study. [pmid: 4015518].
Glantz JC. Labor induction rate variation in upstate New York: what is the difference?. Birth. Sep. 2003;30(3):168-74. Ineligible Study Design. [pmid: 12911799].
Goeree R, Hannah M, Hewson S. Cost-effectiveness of induction of labour versus serial antenatal monitoring in the Canadian Multicentre Postterm Pregnancy Trial. CMAJ. May 1. 1995;152(9):1445-50. No eligible outcomes. [pmid: 7728693].
Goldberg CC, Kallen MA, McCurdy CM, Miller HS. Effect of intrapartum use of oxytocin on estimated blood loss and hematocrit change at vaginal delivery. Am J Perinatol. Aug. 1996;13(6):373-6. Not a study of elective induction of labor or predictors of success in the setting of induced labor. [pmid: 8865985].
Gonen O, Rosen DJ, Dolfin Z, Tepper R, Markov S, Fejgin MD. Induction of labor versus expectant management in macrosomia: a randomized study. Obstet Gynecol. Jun. 1997;89(6):913-7. Not a study of elective induction of labor or predictors of success in the setting of induced labor. [pmid: 9170464].
Gonen R, Degani S, Ron A. Prediction of successful induction of labor: comparison of transvaginal ultrasonography and the Bishop score. Eur J Ultrasound. Aug. 1998;7(3):183-7. Not a study of elective induction of labor or predictors of success in the setting of induced labor. [pmid: 9700213].
Gopalani S, Bennett K, Critchlow C. Factors predictive of failed operative vaginal delivery. Am J Obstet Gynecol. Sep. 2004;191(3):896-902. Not a study of elective induction of labor or predictors of success in the setting of induced labor. [pmid: 15467561].
Grant JM. Induction of labour confers benefits in prolonged pregnancy. Br J Obstet Gynaecol. Feb. 1994;101(2):99-102. Ineligible Study Design. [pmid: 8305406].
Graves BW, DeJoy SA, Heath A, Pekow P. Maternal body mass index, delivery route, and induction of labor in a midwifery caseload. J Midwifery Womens Health. Jul–Aug. 2006;51(4):254-9. Data not usable. [pmid: 16814219].
Hack M, Fanaroff AA, Klaus MH, Mendelawitz BD, Merkatz IR. Neonatal respiratory distress following elective delivery. A preventable disease?. Am J Obstet Gynecol. Sep 1. 1976;126(1):43-7. Other. [pmid: 961745].
Hallak M, Bottoms SF. Induction of labor in patients with term premature rupture of membranes. Effect on perinatal outcome. Fetal Diagn Ther. May–Jun. 1999;14(3):138-42. Not a study of elective induction of labor or predictors of success in the setting of induced labor. [pmid: 10364663].
Halpern SH, Breen TW, Campbell DC, Muir HA, Kronberg J, Nunn R, et al. A multicenter, randomized, controlled trial comparing bupivacaine with ropivacaine for labor analgesia. Anesthesiology. Jun. 2003;98(6):1431-5. Not a study of elective induction of labor or predictors of success in the setting of induced labor. [pmid: 12766654].
Hamad SA, el-Domiaty BA, Philips DA, Nayel SA. Neonatal hyperbilirubinemia in oxytocin augmented labour. Asia Oceania J Obstet Gynaecol. Mar. 1985;11(1):69-73. Not a study of elective induction of labor or predictors of success in the setting of induced labor. [pmid: 4015521].
Hannah ME, Hodnett ED, Willan A, Foster GA, Di Cecco R, Helewa M. Prelabor rupture of the membranes at term: expectant management at home or in hospital? The TermPROM Study Group. Obstet Gynecol. Oct. 2000;96(4):533-8. Not a study of elective induction of labor or predictors of success in the setting of induced labor. [pmid: 11004354].
Hannah ME, Huh C, Hewson SA, Hannah WJ. Postterm pregnancy: putting the merits of a policy of induction of labor into perspective. Birth. Mar. 1996;23(1):13-9. Duplicate of Included Study. [pmid: 8703252].
Harlap S, Kaufman R, Prywes R, Davies AM, Sterk VV, Weiskopf P. Patterns of obstetric intervention in a total population. A report from the Jerusalem perinatal study. Isr J Med Sci. Oct. 1971;7(10):1115-27. Not a study of elective induction of labor or predictors of success in the setting of induced labor. [pmid: 5143178].
Hatch MC. Maternal deaths associated with induction of labor. N Y State J Med. Feb 15. 1969;69(4):599-602. Ineligible Study Design. [pmid: 5252432].
Haukkamaa M, Purhonen M, Teramo K. The monitoring of labor by telemetry. J Perinat Med. 1982;10(1):17-22. Not a study of elective induction of labor or predictors of success in the setting of induced labor. [pmid: 7062228].
Hauth JC, Hankins GD, Gilstrap LC 3rd. Uterine contraction pressures achieved in parturients with active phase arrest. Obstet Gynecol. Sep. 1991;78(3 Pt 1):344-7. Not a study of elective induction of labor or predictors of success in the setting of induced labor. [pmid: 1876362].
Hemminki E, Saarikoski S. Ambulation and delayed amniotomy in the first stage of labor. Eur J Obstet Gynecol Reprod Biol. Jul. 1983;15(3):129-39. Not a study of elective induction of labor or predictors of success in the setting of induced labor. [pmid: 6617932].
Hendricks CH. The control of labor. Gynecol Invest. 1970;1(Suppl):37-54. Ineligible Study Design. [pmid: 5504513].
Hess PE, Pratt SD, Soni AK, Sarna MC, Oriol NE. An association between severe labor pain and cesarean delivery. Anesth Analg. Apr. 2000;90(4):881-6. Not a study of elective induction of labor or predictors of success in the setting of induced labor. [pmid: 10735793].
Higgins J, Gleeson R, Holohan M, Cooney C, Darling M. Maternal and neonatal hyponatraemia: a comparison of Hartmanns solution with 5% dextrose for the delivery of oxytocin in labour. Eur J Obstet Gynecol Reprod Biol. Sep. 1996;68(12):47-8. Method of induction study. [pmid: 8886680].
Hin LY, Lau TK, Rogers M, Chang AM. Antepartum and intrapartum prediction of cesarean need: risk scoring in singleton pregnancies. Obstet Gynecol. Aug. 1997;90(2):183-6. Not a study of elective induction of labor or predictors of success in the setting of induced labor. [pmid: 9241289].
Horrigan TJ. Physicians who induce labor for fetal macrosomia do not reduce cesarean delivery rates. J Perinatol. Mar. 2001;21(2):93-6. Not a study of elective induction of labor or predictors of success in the setting of induced labor. [pmid: 11324367].
Howie P. Induction of labour—does it save babies?. Nurs Mirror. Mar 30. 1978;146(13):21-4. Not a study of elective induction of labor or predictors of success in the setting of induced labor. [pmid: 246557].
Howie PW, McNay MB, McIlwaine GM, Macnaughton MC. Induction of labour and perinatal mortality. Br Med J. Apr 9. 1977;1(6066):974-5. Ineligible Study Design. [pmid: 851811].
Hoy J, Venn A, Halliday J, Kovacs G, Waalwyk K. Perinatal and obstetric outcomes of donor insemination using cryopreserved semen in Victoria, Australia. Hum Reprod. Jul. 1999;14(7):1760-4. Not a study of elective induction of labor or predictors of success in the setting of induced labor. [pmid: 10402384].
Hueston WJ, McClaflin RR, Claire E. Variations in cesarean delivery for fetal distress. J Fam Pract. Nov. 1996;43(5):461-7. Not a study of elective induction of labor or predictors of success in the setting of induced labor. [pmid: 8917145].
Induction of labour. Br Med J. 1979 Aug 18;2(6187):407–8. Ineligible Study Design
Induction of labour. Eur J Obstet Gynecol Reprod Biol. 1983 Aug;15(4–6):319–32. Ineligible Study Design
Jarvelin MR, Hartikainen-Sorri AL, Rantakallio P. Labour induction policy in hospitals of different levels of specialisation. Br J Obstet Gynaecol. Apr. 1993;100(4):310-5. Not a study of elective induction of labor or predictors of success in the setting of induced labor. [pmid: 8494831].
Jazayeri A, Heffron JA, Phillips R, Spellacy WN. Macrosomia prediction using ultrasound fetal abdominal circumference of 35 centimeters or more. Obstet Gynecol. Apr. 1999;93(4):523-6. Not a study of elective induction of labor or predictors of success in the setting of induced labor. [pmid: 10214826].
Jeffares MJ. A multifactorial survey of neonatal juandice. Br J Obstet Gynaecol. Jun. 1977;84(6):452-5. Not a study of elective induction of labor or predictors of success in the setting of induced labor. [pmid: 889741].
Jensen DM, Damm P, Sorensen B, Molsted-Pedersen L, Westergaard JG, Klebe J, et al. Clinical impact of mild carbohydrate intolerance in pregnancy: a study of 2904 nondiabetic Danish women with risk factors for gestational diabetes mellitus. Am J Obstet Gynecol. Aug. 2001;185(2):413-9. Not a study of elective induction of labor or predictors of success in the setting of induced labor. [pmid: 11518901].
Jensen DM, Damm P, Sorensen B, Molsted-Pedersen L, Westergaard JG, Ovesen P, et al. Pregnancy outcome and prepregnancy body mass index in 2459 glucose-tolerant Danish women. Am J Obstet Gynecol. Jul. 2003;189(1):239-44. Not a study of elective induction of labor or predictors of success in the setting of induced labor. [pmid: 12861169].
Jensen DM, Ovesen P, Beck-Nielsen H, Molsted-Pedersen L, Sorensen B, Vinter C, et al. Gestational weight gain and pregnancy outcomes in 481 obese glucose-tolerant women. Diabetes Care. Sep. 2005;28(9):2118-22. No eligible outcomes. [pmid: 16123476].
Jensen H, Agger AO, Rasmussen KL. The influence of prepregnancy body mass index on labor complications. Acta Obstet Gynecol Scand. Oct. 1999;78(9):799-802. Not a study of elective induction of labor or predictors of success in the setting of induced labor. [pmid: 10535344].
Johnson EB, Reed SD, Hitti J, Batra M. Increased risk of adverse pregnancy outcome among Somali immigrants in Washington state. Am J Obstet Gynecol. Aug. 2005;193(2):475-82. Not a study of elective induction of labor or predictors of success in the setting of induced labor. [pmid: 16098873].
Johnson JD, Aldrich M, Angelus P, Stevenson DK, Smith DW, Herschel MJ, et al. Oxytocin and neonatal hyperbilirubinemia. Studies of bilirubin production. Am J Dis Child. Nov. 1984;138(11):1047-50. Not a study of elective induction of labor or predictors of success in the setting of induced labor. [pmid: 6496421].
Johnson JM, Harman CR, Lange IR, Manning FA. Biophysical profile scoring in the management of the postterm pregnancy: an analysis of 307 patients. Am J Obstet Gynecol. Feb. 1986;154(2):269-73. Not a study of elective induction of labor or predictors of success in the setting of induced labor. [pmid: 3511711].
Johnson N, Lilford R, Guthrie K, Thornton J, Barker M, Kelly M. Randomised trial comparing a policy of early with selective amniotomy in uncomplicated labour at term. Br J Obstet Gynaecol. Mar. 1997;104(3):340-6. Not a study of elective induction of labor or predictors of success in the setting of induced labor. [pmid: 9091013].
Joseph KS, Young DC, Dodds L, O'Connell CM, Allen VM, Chandra S, et al. Changes in maternal characteristics and obstetric practice and recent increases in primary cesarean delivery. Obstet Gynecol. Oct. 2003;102(4):791-800. Not a study of elective induction of labor or predictors of success in the setting of induced labor. [pmid: 14551010].
Kabiru W, Raynor BD. Obstetric outcomes associated with increase in BMI category during pregnancy. Am J Obstet Gynecol. Sep. 2004;191(3):928-32. Data not usable. [pmid: 15467566].
Kalish RB, McCullough L, Gupta M, Thaler HT, Chervenak FA. Intrapartum elective cesarean delivery: a previously unrecognized clinical entity. Obstet Gynecol. Jun. 2004;103(6):1137-41. Not a study of elective induction of labor or predictors of success in the setting of induced labor. [pmid: 15172844].
Kassis A, Mazor M, Leiberman JR, Cohen A, Insler V. Management of post-date pregnancy: a case control study. Isr J Med Sci. Feb. 1991;27(2):82-6. Not a study of elective induction of labor or predictors of success in the setting of induced labor. [pmid: 2004889].
Kaul B, Vallejo MC, Ramanathan S, Mandell G, Phelps AL, Daftary AR. Induction of labor with oxytocin increases cesarean section rate as compared with oxytocin for augmentation of spontaneous labor in nulliparous parturients controlled for lumbar epidural analgesia. J Clin Anesth. Sep. 2004;16(6):411-4. Method of induction study. [pmid: 15567643].
Kramer MS, Rouleau J, Baskett TF, Joseph KS. Amniotic-fluid embolism and medical induction of labour: a retrospective, population-based cohort study. Lancet. Oct 21. 2006;368(9545):1444-8. Not a study of elective induction of labor or predictors of success in the setting of induced labor. [pmid: 17055946].
Kreiser D, el-Sayed YY, Sorem KA, Chitkara U, Holbrook RH Jr, Druzin ML. Decreased amniotic fluid index in low-risk pregnancy. J Reprod Med. Aug. 2001;46(8):743-6. Not a study of elective induction of labor or predictors of success in the setting of induced labor. [pmid: 11547649].
Krohn MA, Hitti J. Characteristics of women with clinical intra-amniotic infection who deliver preterm compared with term. Am J Epidemiol. Jan 15. 1998;147(2):111-6. Not a study of elective induction of labor or predictors of success in the setting of induced labor. [pmid: 9456999].
Kulkarni SK, Matadial L. Prolonged pregnancy—a rational approach to management. West Indian Med J. Dec. 1986;35(4):314-7. Not a study of elective induction of labor or predictors of success in the setting of induced labor. [pmid: 3564454].
Ladfors L, Tessin I, Mattsson LA, Eriksson M, Seeberg S, Fall O. Risk factors for neonatal sepsis in offspring of women with prelabor rupture of the membranes at 34–42 weeks. J Perinat Med. 1998;26(2):94-101. Not a study of elective induction of labor or predictors of success in the setting of induced labor. [pmid: 9650129].
Lampe LG, Komaromy B, Gaal J. Selective planned induction of labor. Acta Chir Acad Sci Hung. 1980;21(1):43-53. Duplicate of Included Study. [pmid: 7197448].
Lange AP. Induction of labour. Dan Med Bull. Apr. 1984;31(2):89-108. Ineligible Study Design. [pmid: 6373168].
Laor D, Seidman DS, Yaffe H, Voss E, Diamant YZ, Gale R. A prospective study of the active management of labor in women of high parity. Eur J Obstet Gynecol Reprod Biol. Feb. 1989;30(2):111-5. Not a study of elective induction of labor or predictors of success in the setting of induced labor. [pmid: 2703098].
Le Guennec JC, Bard H, Teasdale F, Doray B. Elective delivery and the neonatal respiratory distress syndrome. Can Med Assoc J. Feb 9. 1980;122(3):307-9. Not a study of elective induction of labor or predictors of success in the setting of induced labor. [pmid: 7370827].
Le Ray C, Carayol M, Zeitlin J, Breart G, Goffinet F. Level of perinatal care of the maternity unit and rate of cesarean in low-risk nulliparas. Obstet Gynecol. Jun. 2006;107(6):1269-77. Not a study of elective induction of labor or predictors of success in the setting of induced labor. [pmid: 16738151].
Lea SJ, Lea C. Influence of certain aspects of management of labour upon time and mode of delivery. Midwives Chron. Oct. 1987;100(1197):309-12. Not a study of elective induction of labor or predictors of success in the setting of induced labor. [pmid: 3683230].
Leaphart WL, Meyer MC, Capeless EL. Labor induction with a prenatal diagnosis of fetal macrosomia. J Matern Fetal Med. Mar–Apr. 1997;6(2):99-102. Not a study of elective induction of labor or predictors of success in the setting of induced labor. [pmid: 9086425].
Leeman L, Leeman R. A Native American community with a 7% cesarean delivery rate: does case mix, ethnicity, or labor management explain the low rate?. Ann Fam Med. May–Jun. 2003;1(1):36-43. Not a study of elective induction of labor or predictors of success in the setting of induced labor. [pmid: 15043178].
Leeson TJ, smith A. Induction of labour and perinatal mortality. Br Med J. May 21. 1977;1(6072):1354-5. Ineligible Study Design. [pmid: 861633].
Leighton BL, Halpern SH, Wilson DB. Lumbar sympathetic blocks speed early and second stage induced labor in nulliparous women. Anesthesiology. Apr. 1999;90(4):1039-46. Not a study of elective induction of labor or predictors of success in the setting of induced labor. [pmid: 10201675].
Leijon I, Finnstrom O, Hedenskog S, Ryden G, Tylleskar J. Spontaneous labor and elective induction—a prospective randomized study. II. Bilirubin levels in the neonatal period. Acta Obstet Gynecol Scand. 1980;59(2):103-6. Duplicate of Included Study. [pmid: 7405545].
Leijon I, Finnstrom O, Hedenskog S, Ryden G, Tylleskar J. Spontaneous labour and elective induction—a prospective randomized study. Behavioural assessment and neurological examination in the newborn period. Acta Paediatr Scand. Jul. 1979;68(4):553-60. Duplicate of Included Study. [pmid: 463537].
Leveno KJ, Cunningham FG, Nelson S, Roark M, Williams ML, Guzick D, et al. A prospective comparison of selective and universal electronic fetal monitoring in 34,995 pregnancies. N Engl J Med. Sep 4. 1986;315(10):615-9. Not a study of elective induction of labor or predictors of success in the setting of induced labor. [pmid: 3736600].
Leveno KJ, Cunningham FG, Pritchard JA. Cesarean section: an answer to the House of Horne. Am J Obstet Gynecol. Dec 15. 1985;153(8):838-44. Not a study of elective induction of labor or predictors of success in the setting of induced labor. [pmid: 4073153].
Lilienthal CM, Ward JP. Medical induction of labour. J Obstet Gynaecol Br Commonw. Apr. 1971;78(4):317-21. Not a study of elective induction of labor or predictors of success in the setting of induced labor. [pmid: 5314740].
Lillie EW. Advances in obstetrics. Practitioner. Oct. 1973;211(264):451-8. Ineligible Study Design. [pmid: 4747645].
Locatelli A, Vergani P, Toso L, Verderio M, Pezzullo JC, Ghidini A. Perinatal outcome associated with oligohydramnios in uncomplicated term pregnancies. Arch Gynecol Obstet. Jan. 2004;269(2):130-3. Not a study of elective induction of labor or predictors of success in the setting of induced labor. [pmid: 12928935].
Lubarsky SL, Schiff E, Friedman SA, Mercer BM, Sibai BM. Obstetric characteristics among nulliparas under age 15. Obstet Gynecol. Sep. 1994;84(3):365-8. Not a study of elective induction of labor or predictors of success in the setting of induced labor. [pmid: 8058232].
Lumley J. Antepartum fetal heart rate tests and induction of labour. Women Health. Fall–Winter. 1982;7(34):9-28. Ineligible Study Design. [pmid: 7168191].
Lyndrup J, Legarth J, Weber T, Nickelsen C, Guldbaek E. Predictive value of pelvic scores for induction of labor by local PGE2. Eur J Obstet Gynecol Reprod Biol. Oct 23. 1992;47(1):17-23. Not a study of elective induction of labor or predictors of success in the setting of induced labor. [pmid: 1426507].
Lyndrup J, Weber T, Legarth J, Nickelsen C, Guldbaek E. Prediction of mode of delivery and ‘DisFIL score’ following induction of labor by local PGE2. Eur J Obstet Gynecol Reprod Biol. Nov. 1993;52(1):11-9. Data not usable. [pmid: 8119469].
MacDonald D. Surgical induction of labor. Am J Obstet Gynecol. Jul 15. 1970;107(6):908-11. Not a study of elective induction of labor or predictors of success in the setting of induced labor. [pmid: 5429019].
Maclnnis DR. Elective induction. N S Med Bull. Feb. 1970;49(1):10-1. Ineligible Study Design. [pmid: 5262951].
Macnaughton MC. Management of labor—British style. Clin Obstet Gynecol. Mar. 1982;25(1):137-44. Not a study of elective induction of labor or predictors of success in the setting of induced labor. [pmid: 7067194].
MacVicar J. Acceleration and augmentation of labour. Scott Med J. Nov. 1973;18(6):201-14. Not a study of elective induction of labor or predictors of success in the setting of induced labor. [pmid: 4593899].
MacVicar J. Failed induction of labour. J Obstet Gynaecol Br Commonw. Nov. 1971;78(11):1007-9. Not a study of elective induction of labor or predictors of success in the setting of induced labor. [pmid: 5124556].
Magann EF, Chauhan SP, Nevils BG, McNamara MF, Kinsella MJ, Morrison JC. Management of pregnancies beyond forty-one weeks' gestation with an unfavorable cervix. Am J Obstet Gynecol. Jun. 1998;178(6):1279-87. Post-term. [pmid: 9662313].
Magann EF, Kinsella MJ, Chauhan SP, McNamara MF, Gehring BW, Morrison JC. Does an amniotic fluid index of </=5 cm necessitate delivery in high-risk pregnancies? A case-control study. Am J Obstet Gynecol. Jun. 1999;180(6 Pt 1):1354-9. Not a study of elective induction of labor or predictors of success in the setting of induced labor. [pmid: 10368471].
Magann EF, McNamara MF, Whitworth NS, Chauhan SP, Thorpe RA, Morrison JC. Can we decrease postdatism in women with an unfavorable cervix and a negative fetal fibronectin test result at term by serial membrane sweeping?. Am J Obstet Gynecol. Oct. 1998;179(4):890-4. Not a study of elective induction of labor or predictors of success in the setting of induced labor. [pmid: 9790365].
Main EK, Moore D, Farrell B, Schimmel LD, Altman RJ, Abrahams C, et al. Is there a useful cesarean birth measure? Assessment of the nulliparous term singleton vertex cesarean birth rate as a tool for obstetric quality improvement. Am J Obstet Gynecol. Jun. 2006;194(6):1644-51. discussion 51–2. Data not usable. [pmid: 16643812].
Maisels MJ, Rees R, Marks K, Friedman Z. Elective delivery of the term fetus. An obstetrical hazard. JAMA. Nov 7. 1977;238(19):2036-9. Other. [pmid: 410962].
Mancuso S, Ferrazzani S, De Carolis S, Carducci B, De Santis L, Caruso A. Term and postterm low-risk pregnancies: management schemes for the reduction of high rates of cesarean section. Minerva Ginecol. Mar. 1996;48(3):95-8. Not a study of elective induction of labor or predictors of success in the setting of induced labor. [pmid: 8684694].
Martel M, Wacholder S, Lippman A, Brohan J, Hamilton E. Maternal age and primary cesarean section rates: a multivariate analysis. Am J Obstet Gynecol. Feb. 1987;156(2):305-8. Not a study of elective induction of labor or predictors of success in the setting of induced labor. [pmid: 3826165].
Martin JN Jr, Sessums JK, Howard P, Martin RW, Morrison JC. Alternative approaches to the management of gravidas with prolonged-postterm-postdate pregnancies. J Miss State Med Assoc. Apr. 1989;30(4):105-11. Post-term. [pmid: 2657073].
Mathews TJ. Trends in stimulation and induction of labor 1989-1995. Stat Bull Metrop Insur Co. Oct–Dec. 1997;78(4):20-6. Ineligible Study Design. [pmid: 9357077].
Mawdsley SD, Baskett TF. Outcome of the next labour in women who had a vaginal delivery in their first pregnancy. BJOG. Jul. 2000;107(7):932-4. Not a study of elective induction of labor or predictors of success in the setting of induced labor. [pmid: 10901567].
McNay MB, McIlwaine GM, Howie PW, Macnaughton MC. Perinatal deaths: analysis by clinical cause to assess value of induction of labour. Br Med J. Feb 5. 1977;1(6057):347-50. Other. [pmid: 837094].
Michlin R, Oettinger M, Odeh M, Khoury S, Ophir E, Barak M, et al. Maternal obesity and pregnancy outcome. Isr Med Assoc J. Jan. 2000;2(1):10-3. Not a study of elective induction of labor or predictors of success in the setting of induced labor. [pmid: 10892363].
Miller F. Uterine activity, labor management, and perinatal outcome. Semin Perinatol. Apr. 1978;2(2):181-6. Ineligible Study Design. [pmid: 734452].
Moore LE, Rayburn WF. Elective induction of labor. Clin Obstet Gynecol. Sep. 2006;49(3):698-704. Ineligible Study Design. [pmid: 16885673].
Morgan MA, Thurnau GR, Fishburne JI Jr. The fetal-pelvic index as an indicator of fetal-pelvic disproportion: a preliminary report. Am J Obstet Gynecol. Sep. 1986;155(3):608-13. Not a study of elective induction of labor or predictors of success in the setting of induced labor. [pmid: 3529966].
Morgan MA, Thurnau GR. Efficacy of the fetal-pelvic index for delivery of neonates weighing 4000 grams or greater: a preliminary report. Am J Obstet Gynecol. May. 1988;158(5):1133-7. Not a study of elective induction of labor or predictors of success in the setting of induced labor. [pmid: 3285685].
Morita N, Matsushima N, Ogata N, Saeki K, Ishibashi M, Komukai H, et al. Nationwide description of live Japanese births by day of the week, hour, and location. J Epidemiol. Jul. 2002;12(4):330-5. Not a study of elective induction of labor or predictors of success in the setting of induced labor. [pmid: 12395874].
Muhlen-Schulte L, Wade K. Intervention in childbirth and neonatal responsiveness. Community Health Stud. 1988;12(1):69-81. Not a study of elective induction of labor or predictors of success in the setting of induced labor. [pmid: 3370947].
Muldoon MJ. A prospective study of intrauterine infection following surgical induction of labour. J Obstet Gynaecol Br Commonw. Nov. 1968;75(11):1144-50. Not a study of elective induction of labor or predictors of success in the setting of induced labor. [pmid: 4973235].
Mutlu Meydanli M, Caliskan E, Haberal A. Prediction of adverse outcome associated with vaginal misoprostol for labor induction. Eur J Obstet Gynecol Reprod Biol. Oct 10. 2003;110(2):143-8. Data not usable. [pmid: 12969573].
Myles TD, Santolaya J. Maternal and neonatal outcomes in patients with a prolonged second stage of labor. Obstet Gynecol. Jul. 2003;102(1):52-8. Not a study of elective induction of labor or predictors of success in the setting of induced labor. [pmid: 12850607].
Nassar AH, Fayyumy R, Saab W, Mehio G, Usta IM. Grandmultiparas in modern obstetrics. Am J Perinatol. Aug. 2006;23(6):345-9. Not a study of elective induction of labor or predictors of success in the setting of induced labor. [pmid: 16841276].
Nicholson JM, Kellar LC, Cronholm PF, Macones GA. Active management of risk in pregnancy at term in an urban population: an association between a higher induction of labor rate and a lower cesarean delivery rate. Am J Obstet Gynecol. Nov. 2004;191(5):1516-28. Not a study of elective induction of labor or predictors of success in the setting of induced labor. [pmid: 15547519].
Niswander KR, Turoff BB, Romans J. Developmental status of children delivered through elective induction of labor. Results of a 4-year follow-up study. Obstet Gynecol. Jan. 1966;27(1):15-20. No eligible outcomes. [pmid: 5900643].
Novakov-Mikic A, Ivanovic L, Dukanac J. Transvaginal ultrasonography of uterine cervix in prediction of the outcome of labour induction. Med Pregl. Nov–Dec. 2000;53(1112):569-78. Not a study of elective induction of labor or predictors of success in the setting of induced labor. [pmid: 11320742].
Oats JN, Abell DA, Andersen HM, Beischer NA. Obesity in pregnancy. Compr Ther. Apr. 1983;9(4):51-5. Not a study of elective induction of labor or predictors of success in the setting of induced labor. [pmid: 6851465].
O'Connor RA. Induction of labour—not how but why? Br J Hosp Med. 1994 Dec 14–1995 Jan 17;52(11):559–63. Not a study of elective induction of labor or predictors of success in the setting of induced labor
O'Driscol K, Carroll CJ, Coughlan M. Selective induction of labour. Br Med J. Dec 27. 1975;4(5999):727-9. Not a study of elective induction of labor or predictors of success in the setting of induced labor. [pmid: 1240015].
O'Driscoll K, Foley M, MacDonald D. Active management of labor as an alternative to cesarean section for dystocia. Obstet Gynecol. Apr. 1984;63(4):485-90. Not a study of elective induction of labor or predictors of success in the setting of induced labor. [pmid: 6700893].
Opaneye AA. Labour and delivery after a prolonged interval between the present and the last pregnancy. Br J Obstet Gynaecol. Dec. 1983;90(12):1180-2. Not a study of elective induction of labor or predictors of success in the setting of induced labor. [pmid: 6652054].
Ottervanger HP, Keirse MJ, Smit W, Holm JP. Controlled comparison of induction versus expectant care for prelabor rupture of the membranes at term. J Perinat Med. 1996;24(3):237-42. Not a study of elective induction of labor or predictors of success in the setting of induced labor. [pmid: 8827572].
Out JJ, Vierhout ME, Verhage F, Duivenvoorden HJ, Wallenburg HC. Characteristics and motives of women choosing elective induction of labour. J Psychosom Res. 1986;30(3):375-80. No eligible outcomes. [pmid: 3735181].
Out JJ, Vierhout ME, Verhage F, Duivenvoorden HJ, Wallenburg HC. Elective induction of labor: a prospective clinical study, II: Psychological effects. J Perinat Med. 1985;13(4):163-70. Duplicate of Included Study. [pmid: 4057032].
Out JJ, Vierhout ME, Wallenburg HC. Breast-feeding following spontaneous and induced labour. Eur J Obstet Gynecol Reprod Biol. Dec. 1988;29(4):275-9. Duplicate of Included Study. [pmid: 3229541].
Paterson-Brown S, Fisk NM, Edmonds DK, Rodeck CH. Preinduction cervical assessment by Bishop's score and transvaginal ultrasound. Eur J Obstet Gynecol Reprod Biol. Jun 5. 1991;40(1):17-23. Not a study of elective induction of labor or predictors of success in the setting of induced labor. [pmid: 1855604].
Patton LL, English EC, Hambleton JD. Childbirth preparation and outcomes of labor and delivery in primiparous women. J Fam Pract. Apr. 1985;20(4):375-8. Not a study of elective induction of labor or predictors of success in the setting of induced labor. [pmid: 3981097].
Peleg D, Hannah ME, Hodnett ED, Foster GA, Willan AR, Farine D. Predictors of cesarean delivery after prelabor rupture of membranes at term. Obstet Gynecol. Jun. 1999;93(6):1031-5. Data not usable. [pmid: 10362176].
Peregrine E, O'Brien P, Jauniaux E. Impact on delivery outcome of ultrasonographic fetal head position prior to induction of labor. Obstet Gynecol. Mar. 2007;109(3):618-25. Duplicate of Included Study. [pmid: 17329512].
Peregrine E, O'Brien P, Jauniaux E. Ultrasound detection of nuchal cord prior to labor induction and the risk of Cesarean section. Ultrasound Obstet Gynecol. Feb. 2005;25(2):160-4. Not a study of elective induction of labor or predictors of success in the setting of induced labor. [pmid: 15543520].
Phillip H, Fletcher H, Reid M. The impact of induced labour on postpartum blood loss. J Obstet Gynaecol. Jan. 2004;24(1):12-5. Method of induction study. [pmid: 14675973].
Phillips WR, Rice GA, Layton RH. Audit of obstetrical care and outcome in family medicine, obstetrics, and general practice. J Fam Pract. Jun. 1978;6(6):1209-16. Not a study of elective induction of labor or predictors of success in the setting of induced labor. [pmid: 660124].
Pinkerton JH, Carson M. Caesarean section after surgical induction of labour. J Obstet Gynaecol Br Commonw. Dec. 1968;75(12):1287-90. Ineligible Study Design. [pmid: 5702364].
Pinkerton JH, Martin DH, Thompson W. Selective planned induction in conditions of civil strife. Lancet. Jan 25. 1975;1(7900):197-8. Ineligible Study Design. [pmid: 47423].
Pinkerton JH. Fetal rights. The first Belfast Royal Maternity Hospital Perinatal Lecture. Ulster Med J. Apr. 1985;54(1):30-40. Not a study of elective induction of labor or predictors of success in the setting of induced labor. [pmid: 3909579].
Pinkerton JH. Induction of labour on behalf of the fetus. J Ir Med Assoc. Nov 10. 1973;66(21):592-6. Ineligible Study Design. [pmid: 4756936].
Poma PA. Effects of obstetrician characteristics on cesarean delivery rates. A community hospital experience. Am J Obstet Gynecol. Jun. 1999;180(6 Pt 1):1364-72. Not a study of elective induction of labor or predictors of success in the setting of induced labor. [pmid: 10368473].
Postpartum haemorrhage after induced and spontaneous labour. Br Med J. 1978 Oct 21;2(6145):1162. Not a study of elective induction of labor or predictors of success in the setting of induced labor
Prolonged pregnancy: the management debate. BMJ. 1988 Sep 17;297(6650):715–7. Not a study of elective induction of labor or predictors of success in the setting of induced labor
Ramanathan G, Yu C, Osei E, Nicolaides KH. Ultrasound examination at 37 weeks' gestation in the prediction of pregnancy outcome: the value of cervical assessment. Ultrasound Obstet Gynecol. Dec. 2003;22(6):598-603. Not a study of elective induction of labor or predictors of success in the setting of induced labor. [pmid: 14689532].
Ramsewak S, Roopnarinesingh S, Robinson J. Another look at the effects of advanced maternal age. West Indian Med J. Jun. 1991;40(2):86-8. Not a study of elective induction of labor or predictors of success in the setting of induced labor. [pmid: 1897227].
Rane SM, Guirgis RR, Higgins B, Nicolaides KH. Models for the prediction of successful induction of labor based on pre-induction sonographic measurement of cervical length. J Matern Fetal Neonatal Med. May. 2005;17(5):315-22. Post-term. [pmid: 16147844].
Rane SM, Guirgis RR, Higgins B, Nicolaides KH. The value of ultrasound in the prediction of successful induction of labor. Ultrasound Obstet Gynecol. Oct. 2004;24(5):538-49. Data not usable. [pmid: 15386612].
Reis FM, Gervasi MT, Florio P, Bracalente G, Fadalti M, Severi FM, et al. Prediction of successful induction of labor at term: role of clinical history, digital examination, ultrasound assessment of the cervix, and fetal fibronectin assay. Am J Obstet Gynecol. Nov. 2003;189(5):1361-7. Data not usable. [pmid: 14634569].
Rhoades DA, Latza U, Mueller BA. Risk factors and outcomes associated with nuchal cord. A population-based study. J Reprod Med. Jan. 1999;44(1):39-45. Not a study of elective induction of labor or predictors of success in the setting of induced labor. [pmid: 9987738].
Richards MP. The induction and acceleration of labour: some benefits and complications. Early Hum Dev. Oct. 1977;1(1):3-17. Ineligible Study Design. [pmid: 399461].
Rindfuss RR, Gortmaker SL, Ladinsky JL. Elective induction and stimulation of labor and the health of the infant. Am J Public Health. Sep. 1978;68(9):872-7. Not a study of elective induction of labor or predictors of success in the setting of induced labor. [pmid: 686212].
Rindfuss RR, Ladinsky JL. Patterns of births: implications for the incidence of elective induction. Med Care. Aug. 1976;14(8):685-93. No eligible outcomes. [pmid: 785127].
Rinehart BK, Terrone DA, Hudson C, Isler CM, Larmon JE, Perry KG Jr. Lack of utility of standard labor curves in the prediction of progression during labor induction. Am J Obstet Gynecol. Jun. 2000;182(6):1520-6. Not a study of elective induction of labor or predictors of success in the setting of induced labor. [pmid: 10871474].
Ritchie JW, Boyle DD. The active management of labour. Br J Hosp Med. Jul. 1981;26(1):61-5. Not a study of elective induction of labor or predictors of success in the setting of induced labor. [pmid: 7272550].
Rizzo N, Farina A, Santarsiero G, Di Luzio L, Vitarelli M, Bovicelli A, et al. Amniotic fluid index and labor length of pregnancies induced beyond 41 weeks of gestation with unfavorable cervix. Gynecol Obstet Invest. 2000;49(4):244-8. Duplicate of Included Study. [pmid: 10828707].
Roach VJ, Rogers MS. Pregnancy outcome beyond 41 weeks gestation. Int J Gynaecol Obstet. Oct. 1997;59(1):19-24. Post-term. [pmid: 9359441].
Roberts A. Midwifery. 1. Induction of labour. Nurs Mirror. Jul 8. 1981;153(2):xxi-xxv. Ineligible Study Design. [pmid: 6911656].
Roberts CL, Taylor L, Henderson-Smart D. Trends in births at and beyond term: evidence of a change?. Br J Obstet Gynaecol. Sep. 1999;106(9):937-42. Not a study of elective induction of labor or predictors of success in the setting of induced labor. [pmid: 10492105].
Robertson EG. Induction of labour. Br Med J. Aug 15. 1970;3(5719):405. Ineligible Study Design. [pmid: 5451601].
Rogers R, Gilson GJ, Miller AC, Izquierdo LE, Curet LB, Qualls CR. Active management of labor: does it make a difference?. Am J Obstet Gynecol. Sep. 1997;177(3):599-605. Other. [pmid: 9322630].
Rojansky N, Tanos V, Reubinoff B, Shapira S, Weinstein D. Effect of epidural analgesia on duration and outcome of induced labor. Int J Gynaecol Obstet. Mar. 1997;56(3):237-44. Not a study of elective induction of labor or predictors of success in the setting of induced labor. [pmid: 9127155].
Roman H, Verspyck E, Vercoustre L, Degre S, Col JY, Firmin JM, et al. Does ultrasound examination when the cervix is unfavorable improve the prediction of failed labor induction?. Ultrasound Obstet Gynecol. Apr. 2004;23(4):357-62. Not a study of elective induction of labor or predictors of success in the setting of induced labor. [pmid: 15065185].
Rosen R. Planned early birth vs. expectant management for PROM. Am Fam Physician. Jul 1. 2006;74(1):79-80. Ineligible Study Design. [pmid: 16850550].
Rouse DJ, Owen J, Hauth JC. Criteria for failed labor induction: prospective evaluation of a standardized protocol. Obstet Gynecol. Nov. 2000;96(5 Pt 1):671-7. Not a study of elective induction of labor or predictors of success in the setting of induced labor. [pmid: 11042299].
Rovas L, Sladkevicius P, Strobel E, Valentin L. Three-dimensional power Doppler ultrasound assessment of the cervix for the prediction of successful induction of labor with prostaglandin in prolonged pregnancy. J Ultrasound Med. Jul. 2005;24(7):933-9. Post-term. [pmid: 15972707].
Rozenberg P, Chevret S, Chastang C, Ville Y. Comparison of digital and ultrasonographic examination of the cervix in predicting time interval from induction to delivery in women with a low Bishop score. BJOG. Feb. 2005;112(2):192-6. Not a study of elective induction of labor or predictors of success in the setting of induced labor. [pmid: 15663583].
Rozenberg P, Goffinet F, Hessabi M. Comparison of the Bishop score, ultrasonographically measured cervical length, and fetal fibronectin assay in predicting time until delivery and type of delivery at term. Am J Obstet Gynecol. Jan. 2000;182(1 Pt 1):108-13. Not a study of elective induction of labor or predictors of success in the setting of induced labor. [pmid: 10649164].
Russo JN, Kosar WP. Elective inductions at Hartford Hospital. Trans N Engl Obstet Gynecol Soc. 1964;18:33-41. No eligible outcomes. [pmid: 5832971].
Russo JN, Kosar WP. The use of intramuscular oxytocin for the elective induction of labor. Am J Obstet Gynecol. Jan 15. 1967;97(2):203-7. Data not usable. [pmid: 5297367].
Sabir N, Dicle O, Yurdakul B, Akkemik B. Can magnetic resonance imaging predict the success of parturition in oxytocin-induced pregnant women?. Eur Radiol. 2000;10(5):768-71. Not a study of elective induction of labor or predictors of success in the setting of induced labor. [pmid: 10823630].
Sande HA, Tuveng J, Fonstelien T. A prospective randomized study of induction of labor. Int J Gynaecol Obstet. Aug. 1983;21(4):333-6. Data not usable. [pmid: 6141089].
Santana W, Meyer A, Flake D, Neher JO. Clinical inquiries. What are the risks and benefits of elective induction for uncomplicated term pregnancies?. J Fam Pract. Nov. 2006;55(11):983-5. Ineligible Study Design. [pmid: 17090359].
Schulman H, Farmakides G. Role of the unfavorable cervix in the induction of labor. Clin Obstet Gynecol. Mar. 1987;30(1):50-5. Ineligible Study Design. [pmid: 3472699].
Schwarcz RL, Belizan JM, Cifuentes JR, Cuadro JC, Marques MB, Caldeyro-Barcia R. Fetal and maternal monitoring in spontaneous labors and in elective inductions. A comparative study. Am J Obstet Gynecol. Oct 10. 1974;120(3):356-62. No eligible outcomes. [pmid: 4413458].
Sciscione A, Hoffman MK, DeLuca S, O'Shea A, Benson J, Pollock M, et al. Fetal fibronectin as a predictor of vaginal birth in nulliparas undergoing preinduction cervical ripening. Obstet Gynecol. Nov. 2005;106(5 Pt 1):980-5. Not a study of elective induction of labor or predictors of success in the setting of induced labor. [pmid: 16260515].
Searing KA. Induction vs. post-date pregnancies. Exploring the controversy of who's really at risk. AWHONN Lifelines. Apr–May. 2001;5(2):44-8. Ineligible Study Design. [pmid: 11982276].
Seffah JD, Armah JO. Amniotic fluid index for screening late pregnancies. East Afr Med J. Jun. 1999;76(6):348-51. Not a study of elective induction of labor or predictors of success in the setting of induced labor. [pmid: 10750525].
Seitchik J, Castillo M. Oxytocin augmentation of dysfunctional labor. III. Multiparous patients. Am J Obstet Gynecol. Apr 1. 1983;145(7):777-80. Not a study of elective induction of labor or predictors of success in the setting of induced labor. [pmid: 6837656].
Seitchik J, Castillo M. Oxytocin augmentation of dysfunctional labor. II. Uterine activity data. Am J Obstet Gynecol. Mar 1. 1983;145(5):526-9. Not a study of elective induction of labor or predictors of success in the setting of induced labor. [pmid: 6338720].
Seitchik J, Holden AE, Castillo M. Spontaneous rupture of the membranes, functional dystocia, oxytocin treatment, and the route of delivery. Am J Obstet Gynecol. Jan. 1987;156(1):125-30. Not a study of elective induction of labor or predictors of success in the setting of induced labor. [pmid: 3799746].
Semczuk M, Lopucka M. Evaluation of cervix condition according to Bishop score in post term pregnancy. Ann Univ Mariae Curie Sklodowska [Med]. 1986;41:125-31. Not a study of elective induction of labor or predictors of success in the setting of induced labor.
Seneviratne HR, de Silva GD, de Silva MV, Rudra T. Obstetric performance, perinatal outcome and risk of infection to the newborn in spontaneous and artificial rupture of membranes during labour. Ceylon Med J. Mar. 1998;43(1):11-5. Not a study of elective induction of labor or predictors of success in the setting of induced labor. [pmid: 9624837].
Setna F, Chatterjee TK, Black MD. An assessment of the safety of surgical induction of labour. J Obstet Gynaecol Br Commonw. Apr. 1967;74(2):262-5. Not a study of elective induction of labor or predictors of success in the setting of induced labor. [pmid: 6022377].
Sharma U, Idnani N, Saxena S. Eftects of obstetrical interference on the newborn. Indian J Pediatr. May. 1978;45(364):143-53. Not a study of elective induction of labor or predictors of success in the setting of induced labor. [pmid: 721224].
Shaw KJ, Medearis AL, Horenstein J, Walla CA, Paul RH. Selective labor induction in postterm patients. Observations and outcomes. J Reprod Med. Feb. 1992;37(2):157-61. Data not usable. [pmid: 1538361].
Sheikh GN, Prysor-Jones D. The duration of induced labour. J Obstet Gynaecol Br Commonw. Dec. 1970;77(12):1070-6. Not a study of elective induction of labor or predictors of success in the setting of induced labor. [pmid: 5493611].
Sheiner E, Levy A, Feinstein U, Hallak M, Mazor M. Risk factors and outcome of failure to progress during the first stage of labor: a population-based study. Acta Obstet Gynecol Scand. Mar. 2002;81(3):222-6. Not a study of elective induction of labor or predictors of success in the setting of induced labor. [pmid: 11966478].
Sheiner E, Levy A, Katz M, Mazor M. Short stature—an independent risk factor for Cesarean delivery. Eur J Obstet Gynecol Reprod Biol. Jun 1. 2005;120(2):175-8. Not a study of elective induction of labor or predictors of success in the setting of induced labor. [pmid: 15925047].
Sima DG, Neligan GA. Factors affecting the increasing incidence of severe non-haemolytic neonatal jaundice. Br J Obstet Gynaecol. Nov. 1975;82(11):863-7. Not a study of elective induction of labor or predictors of success in the setting of induced labor. [pmid: 1191600].
Simhayoff N, Sheiner E, Levy A, Hammel RD, Mazor M, Hallak M. To induce or not to induce labor: a macrosomic dilemma. Gynecol Obstet Invest. 2004;58(3):121-5. Primarily addressed women with existing medical or obstetric complications. [pmid: 15467303].
Simpson KR, Poole JH. Labor induction & augmentation. Knowing when, and how, to assist women in labor. AWHONN Lifelines. Dec. 1998;2(6):39-42. Ineligible Study Design. [pmid: 9934024].
Simpson KR. Elective preterm birth. MCN Am J Matern Child Nurs. Jan–Feb. 2006;31(1):68. Ineligible Study Design. [pmid: 16371837].
Singhi S, Singh M. Erythrocytic osmotic fragility in neonates born following oxytocin infusion during labour. Indian J Med Res. Dec. 1980;72:843-5. Not a study of elective induction of labor or predictors of success in the setting of induced labor. [pmid: 7228189].
Sivasuriya M, Tan KL, Salmon YM, Karim SM. Neonatal serum bilirubin levels in spontaneous and induced labour. Br J Obstet Gynaecol. Aug. 1978;85(8):619-23. Not a study of elective induction of labor or predictors of success in the setting of induced labor. [pmid: 687542].
Smith LP, Nagourney BA, McLean FH, Usher RH. Hazards and benefits of elective induction of labor. Am J Obstet Gynecol. Mar 1. 1984;148(5):579-585. Post-term. [pmid: 6538386].
Smith GC, Dellens M, White IR, Pell JP. Combined logistic and Bayesian modeling of cesarean section risk. Am J Obstet Gynecol. Dec. 2004;191(6):2029-34. Ineligible Study Design. [pmid: 15592287].
Sobande AA, Albar HM. Outcome of induced labour in pregnancies at 41 weeks gestation and over in Saudi Arabia. East Mediterr Health J. May. 2003;9(3):316-23. Post-term. [pmid: 15751924].
Soliman SR, Burrows RF. Cesarean section: analysis of the experience before and after the National Consensus Conference on Aspects of Cesarean Birth. CMAJ. Apr 15. 1993;148(8):1315-20. Not a study of elective induction of labor or predictors of success in the setting of induced labor. [pmid: 8462053].
Stewart P, Calder AA. Cervical ripening. Br J Obstet Gynaecol. Oct. 1981;88(10):1071-2. Ineligible Study Design. [pmid: 6945119].
Sweeny AL. Elective induction versus spontaneous labor: a case-control analysis of safety and efficacy. Obstet Gynecol. Dec. 1998;92(6):1056-7. Ineligible Study Design. [pmid: 9840575].
Tam WH, Tai SM, Rogers MS. Prediction of cervical response to prostaglandin E2 using fetal fibronectin. Acta Obstet Gynecol Scand. Nov. 1999;78(10):861-5. Data not usable. [pmid: 10577614].
Tan YY, Yeo GS. Impaired glucose tolerance in pregnancy—is it of consequence?. Aust N Z J Obstet Gynaecol. Aug. 1996;36(3):248-55. Not a study of elective induction of labor or predictors of success in the setting of induced labor. [pmid: 8883744].
Tannirandorn Y, Jumrustanasan T. A comparative study of membrane stripping and nonstripping for induction of labor in uncomplicated term pregnancy. J Med Assoc Thai. Mar. 1999;82(3):229-233. Not a study of elective induction of labor or predictors of success in the setting of induced labor. [pmid: 10410476].
Taylor HA. Induction of labor vs. antenatal monitoring in post-term pregnancy. Am Fam Physician. May 15. 1997;55(7):2428-31. Ineligible Study Design. [pmid: 9166140].
The obstetrician's dilemma. Med J Aust. 1976 Dec 4;2(23):855. Ineligible Study Design
Thiery M, Martens G, Parewijck W. Induction of labour and postpartum haemorrhage. Br Med J. May 26. 1979;1(6175):1422. Ineligible Study Design. [pmid: 312677].
Thiery M, Vroman S, Vanderheyden K, De Hemptinne D, Derom R, Van Kets H, et al. The fetal effect of prostaglandin F 2 applied in the elective induction of labor at term. J Reprod Med. Dec. 1972;9(6):314-26. Method of induction study. [pmid: 4648910].
Traynor JD, Dooley SL, Seyb S, Wong CA, Shadron A. Is the management of epidural analgesia associated with an increased risk of cesarean delivery?. Am J Obstet Gynecol. May. 2000;182(5):1058-62. Not a study of elective induction of labor or predictors of success in the setting of induced labor. [pmid: 10819827].
Tuck SM, Cardozo LD, Studd JW, Gibb DM, Cooper DJ. Obstetric characteristics in different racial groups. Br J Obstet Gynaecol. Oct. 1983;90(10):892-7. Not a study of elective induction of labor or predictors of success in the setting of induced labor. [pmid: 6626489].
Turnbull AC, Anderson AB. Induction of labour. J Obstet Gynaecol Br Commonw. Dec. 1967;74(6):849-54. Not a study of elective induction of labor or predictors of success in the setting of induced labor. [pmid: 6066462].
Turner MJ, Brassil M, Gordon H. Active management of labor associated with a decrease in the cesarean section rate in nulliparas. Obstet Gynecol. Feb. 1988;71(2):150-4. Not a study of elective induction of labor or predictors of success in the setting of induced labor. [pmid: 3336547].
Turner MJ, Fox R, Brassil M, Gleeson R, Gordon H. Induction of labour postdates in primiparae using vaginal prostaglandin tablets. Ir J Med Sci. Jan. 1990;159(1):6-9. Not a study of elective induction of labor or predictors of success in the setting of induced labor. [pmid: 2318607].
Ugwumadu A. Induction of labour confers benefits in prolonged pregnancy. Br J Obstet Gynaecol. Jan. 1995;102(1):79-81. Ineligible Study Design. [pmid: 7833326].
Unger C, Zimmermann R, Huch A, Huch R. Does labor start too late?. J Perinat Med. 1996;24(6):661-7. Not a study of elective induction of labor or predictors of success in the setting of induced labor. [pmid: 9120750].
Vahratian A, Zhang J, Troendle JF, Sciscione AC, Hoffman MK. Labor progression and risk of cesarean delivery in electively induced nulliparas. Obstet Gynecol. Apr. 2005;105(4):698-704. Did not utilize prostaglandins for cervical ripening. [pmid: 15802393].
van Enk A, Doornbos HP, Nordbeck HJ. Some characteristics of labor in ethnic minorities in Amsterdam. Int J Gynaecol Obstet. Dec. 1990;33(4):307-11. Not a study of elective induction of labor or predictors of success in the setting of induced labor. [pmid: 1979283].
Venturini P, Contu G, Mazza V, Facchinetti F. Induction of labor in women with oligohydramnios. J Matern Fetal Neonatal Med. Feb. 2005;17(2):129-32. Not a study of elective induction of labor or predictors of success in the setting of induced labor. [pmid: 16076620].
Vergani P, Ceruti P, Strobelt N, Locatelli A, D'Oria P, Mariani S. Transabdominal amnioinfusion in oligohydramnios at term before induction of labor with intact membranes: a randomized clinical trial. Am J Obstet Gynecol. Aug. 1996;175(2):465-70. Not a study of elective induction of labor or predictors of success in the setting of induced labor. [pmid: 8765270].
Vorherr H. Induction and stimulation of labor. Obstet Gynecol Annu. 1974;3(0):283-344. Ineligible Study Design. [pmid: 4607755].
Watson WJ, Stevens D, Welter S, Day D. Factors predicting successful labor induction. Obstet Gynecol. Dec. 1996;88(6):990-2. Not a study of elective induction of labor or predictors of success in the setting of induced labor. [pmid: 8942840].
Weber DO. At Saddleback Memorial, care maps detail birth process interventions, cutting C-section rate and raising VBACs. Strateg Healthc Excell. May. 1997;10(5):7-9. Ineligible Study Design.
Weekes AR, Beazley JM. Neonatal serum bilirubin levels following the use of prostaglandin E2 in labour. Prostaglandins. Oct. 1975;10(4):699-714. Not a study of elective induction of labor or predictors of success in the setting of induced labor. [pmid: 1197797].
Weeks JW, Pitman T, Spinnato JA 2nd. Fetal macrosomia: does antenatal prediction affect delivery route and birth outcome?. Am J Obstet Gynecol. Oct. 1995;173(4):1215-9. Not a study of elective induction of labor or predictors of success in the setting of induced labor. [pmid: 7485323].
Weiss G, Goldsmith LT. Relaxin and the cervix. Front Horm Res. 2001;27:105-12. Ineligible Study Design. [pmid: 11450422].
Wells J. Effect on the newborn of induced versus spontaneous labor. Obstet Gynecol. Oct. 1965;26(4):580-4. Not a study of elective induction of labor or predictors of success in the setting of induced labor. [pmid: 5889778].
Wu BT, Wan M, Zhao X. Labor induction—methods, outcome and inductograph. Chin Med J (Engl). Apr. 1987;100(4):323-6. Not a study of elective induction of labor or predictors of success in the setting of induced labor. [pmid: 3115699].
Xenakis EM, Piper JM, Field N, Conway D, Langer O. Preeclampsia: is induction of labor more successful?. Obstet Gynecol. Apr. 1997;89(4):600-3. Primarily addressed women with existing medical or obstetric complications. [pmid: 9083320].
Yang SH, Roh CR, Kim JH. Transvaginal ultrasonography for cervical assessment before induction of labor. J Ultrasound Med. Mar. 2004;23(3):375-82. quiz 84–5. Not a study of elective induction of labor or predictors of success in the setting of induced labor. [pmid: 15055785].
Yogev Y, Ben-Haroush A, Gilboa Y, Chen R, Kaplan B, Hod M. Induction of labor with vaginal prostaglandin E2. J Matern Fetal Neonatal Med. Jul. 2003;14(1):30-4. Not a study of elective induction of labor or predictors of success in the setting of induced labor. [pmid: 14563089].
Yudkin P, Frumar AM, Anderson AB, Turnbull AC. A retrospective study of induction of labour. Br J Obstet Gynaecol. Apr. 1979;86(4):257-65. Not a study of elective induction of labor or predictors of success in the setting of induced labor. [pmid: 435409].
Yudkin P. Problems in assessing effects of induction of labour on perinatal mortality. Br J Obstet Gynaecol. Aug. 1976;83(8):603-7. Not a study of elective induction of labor or predictors of success in the setting of induced labor. [pmid: 952790].
Yudkin PL, Redman CW. Caesarean section dissected, 1978-1983. Br J Obstet Gynaecol. Feb. 1986;93(2):135-44. Not a study of elective induction of labor or predictors of success in the setting of induced labor. [pmid: 3947589].
Zamzami TY. A comparison of induction with vaginal prostaglandin E2 versus spontaneous of labor in grand multiparous women. Arch Gynecol Obstet. Dec. 2005;273(3):176-9. Not a study of elective induction of labor or predictors of success in the setting of induced labor. [pmid: 16160873].
Ziadeh SM, Sunna E. Obstetric and perinatal outcome of pregnancies with term labour and meconium-stained amniotic fluid. Arch Gynecol Obstet. Sep. 2000;264(2):84-7. Not a study of elective induction of labor or predictors of success in the setting of induced labor. [pmid: 11045329].