# Appendix C: Additional Analyses for Systematic Review

Figure 1. Randomized controlled trials of elective induction of labor versus expectant management: cesarean delivery (risk difference)

Figure 2. Randomized controlled trials of elective induction of labor versus expectant management: cesarean delivery, stratified by gestational age (risk difference)

Figure 3. Randomized controlled trials of elective induction of labor versus expectant management: cesarean delivery, stratified by study year (risk difference)

Figure 4. Randomized controlled trials of elective induction of labor versus expectant management: cesarean delivery, stratified by study location (risk difference)

Figure 5. Randomized controlled trials of elective induction of labor versus expectant management: operative vaginal delivery (risk difference)

Figure 6. Observational studies of elective induction of labor versus expectant management: cesarean delivery (risk difference)

Figure 7. Observational studies of elective induction of labor versus spontaneous labor: cesarean delivery among nulliparous women (risk difference)

Figure 8. Observational studies of elective induction of labor versus spontaneous labor: cesarean delivery among nulliparous women stratified by study location (odds ratio)

Figure 9. Observational studies of elective induction of labor versus spontaneous labor: cesarean delivery among nulliparous women stratified by study location (risk difference)

Figure 10. Observational studies of elective induction of labor versus spontaneous labor: cesarean delivery among multiparous women (risk difference)

Figure 11. Observational studies of elective induction of labor versus spontaneous labor: operative vaginal delivery (risk difference)

Figure 12. Observational studies of elective induction of labor versus spontaneous labor: operative vaginal delivery among nulliparous women (risk difference)

Figure 13. Randomized controlled trials of elective induction of labor versus expectant management: 5-minute Apgar score less than 7 (risk difference)

Figure 14. Randomized controlled trials of elective induction of labor versus expectant management: meconium-stained amniotic fluid (risk difference)

Figure 15. Randomized controlled trials of elective induction of labor versus expectant management: meconium aspiration syndrome (risk difference)

Figure 16. Observational studies of elective induction of labor versus spontaneous labor: 5-minute Apgar score less than 7 (risk difference)

Figure 17. Observational studies of elective induction of labor versus spontaneous labor: meconium-stained amniotic fluid (risk difference)

Figure 18. Observational studies of elective induction of labor versus spontaneous labor: NICU admissions (risk difference)

Figure 19. Cesarean deliveries (following induction) by parity: observational studies (risk difference)

Table 1 Studies of induction of labor reporting predictors of cesarean delivery: Study information

Article | Year of Publiction | Study Period | Location | Setting | Control Group | Sample size | | Induction Method | Study Quality | Applicability to KQ3
| | | | | | Control Group | Induced Labor
Abou el-Leil et al. ^1^ | 1993 | 1988-1999 | Kuwait | NS | - | - | 198 | Oxytocin, AROM, PGE_2_ gel | Poor | Poor
Ahner et al. ^2^ # | 1995 | NS | Austria | Academic Center | - | - | 64 | PGE_2_ gel | Poor | Poor
Alberico et al. ^3^ * | 1997 | 1992-1996 | Italy | Academic Center | - | - | 133 | PGE_2_ gel | Poor | Poor
Alchalabi et al. ^4^ | 2006 | NS | Jordan | Academic Center | - | - | 180 | PGE_2_ gel | Fair | Poor
Anderson ^5^ | 1965 | NS | United Kingdom | NS | - | - | 143 | Oxytocin, AROM | Fair | Poor
Arulkumaran et al. ^6^ and Gibb et al. ^7^ | 1985 | Jan 1982–Mar 1983 | Singapore | Academic Center | - | - | 1057 | Oxytocin, AROM | Fair | Poor
Ben-Haroush et al. ^8^ * | 2004 | Jan 1998–Dec 2000 | Israel | NS | SL | 574 | 135 | Oxytocin, PGE_2_ gel | Fair | Poor
Boyd et al. ^9^ | 1988 | 1978-1985 | Canada | Academic Center | SL | 5368 | 1455 | NS | Fair | Poor
Buist ^10^ * | 1999 | Mar 1997–Jun 1997 | New Zealand | NS | SL | 1375 | 438 | NS | Fair | Poor
Caughey et al. ^11^ | 2006 | 1986-2001 | United States | Academic Center | EM | 16,445 | 2932 | NS | Fair | Fair
Chan et al. ^12^ ‡ | 2004 | 1998-2000 | Hong Kong | Community Hospital | SL | 7920 | 706 | Oxytocin, AROM, PGE_2_ gel | Fair | Poor
Dhall et al. ^13^ * | 1987 | NS | India | Academic Center | - | - | 200 | Oxytocin, AROM | Poor | Poor
Dodd et al. ^14^ | 2006 | 2001-2004 | Australia | Academic Center | - | - | 620 | Misoprostol, PGE_2_ gel | Good | Poor
Ecker et al. ^15^ ^±^ | 2001 | 1998-1998 | United States | Academic Center | SL | 2222 | 1206 | NS | Poor | Poor
Edris et al. ^16^ ^±^ | 2006 | Apr 1998–Mar 2000 | Canada | Academic Center | - | - | 339 | Oxytocin, PGE_2_ gel | Poor | Fair
Ekman et al. ^17^ | 1983 | Feb 1980–Feb 1981 | Sweden or Denmark (Unclear) | NS | - | - | 54 | Oxytocin, PGE_2_ gel | Poor | Poor
Gabriel et al. ^18^ | 2003 | 1999-2001 | France | Academic Center | - | - | 179 | Oxytocin, Misoprostol, PGE_2_ gel | Poor | Poor
Garite et al. ^19^ | 1996 | Jul 1994–Jun 1995 | Mexico | Community Hospital | - | - | 160 | Oxtyocin, AROM, PGE_2_ gel | Poor | Poor
Goeschen and Pakzad ^20^ | 1980 | 1976-1978 | Germany | Academic Center | - | - | 453 | NS | Fair | Poor
Heffner et al. ^21^ | 2003 | 1998-1999 | United States | Academic Center | - | - | 4147 | NS | Fair | Fair
Heimstad et al. ^22^ ^‡^ | 2006 | 1990-2001 | Norway | Academic Center | - | - | 2500 | Oxytocin, AROM, PGE_2_ gel | Fair | Poor
Johnson et al. ^23^ | 2003 | 1997-1999 | United States | Community Hospital | SL | 4635 | 2647 | Oxytocin, Misoprostol, PGE_2_ gel | Fair | Fair
Morgan and Thurnau ^24^ | 1988 | 1986-1987 | United States | Academic Center | - | - | 49 | Oxytocin, AROM | Poor | Poor
Nooh et al. ^25^ | 2005 | May 2003–Jun 2003 | United Kingdom | Community Hospital | - | - | 95 | Oxytocin, PGE_2_ gel | Poor | Poor
Nuthalapaty et al. ^26^ | 2004 | 1997-1999 | United States | Academic Center | - | - | 509 | Oxytocin, AROM, extra-amniotic saline infusion | Fair | Fair
Ofinade ^27^ | 1970 | Jan 1967–Dec 1968 | Nigeria | Academic Center | - | - | 159 | Oxytocin, AROM | Poor | Poor
Orhue et al. ^28^ | 1984 | 1974-1981 | Nigeria | Academic Center | - | - | 931 | Oxytocin, AROM, ergonovine | Fair | Poor
Peregrine et al. ^29,^ ^30^ * | 2006 | Jun 2001–Nov 2003 | United Kingdom | Academic Center | - | - | 267 | Oxytocin, AROM, PGE_2_ gel | Good | Poor
Rizzo et al. ^31,^ ^32^ ^×^ | 2000 | NS | Italy | NS | - | - | 81 | PGE_2_ gel | Poor | Fair
Saunders et al. ^33^ | 1992 | NS | United Kingdom | Academic Center | - | - | 100 | Oxytocin, AROM, PGE_2_ gel | Poor | Poor
Schreyer et al. ^34^ * | 1991 | 1988-1989 | Israel | Academic Center | - | - | 65 | Oxytocin | Poor | Poor
Simon and Grobman ^35^ | 2005 | 2002-2003 | United States | Academic Center | - | - | 397 | Oxytocin, AROM, extra-amniotic saline infusion | Poor | Fair
Tan et al. ^36^ | 2006 | Jan 2003–Aug 2004 | Malaysia | Academic Center | - | - | 152 | Oxytocin, AROM, PGE_2_ gel | Fair | Poor
Ware and Raynor ^37^ | 2000 | NS | United States | NS | - | - | 77 | Oxytocin, Misoprostol | Fair | Poor
Wigton and Wolk ^38^ * | 1994 | 1989-1989 | United States | Community Hospital | - | - | 201 | Oxytocin, AROM | Poor | Fair
Xenakis et al. ^39^ * | 1997 | 1993-1995 | United States | NS | - | - | 597 | Oxytocin, AROM, PGE_2_ gel | Good | Fair

KQ=Key Question; NS=not specified; AROM=artificial rupture of membranes; PGE_2_=prostaglandin; SL=spontaneous labor; EM=expectant management

# Also reports predictors of vaginal delivery within 24 hours

× Also reports predictors of overall vaginal delivery

‡ Also reports predictors of spontaneous vaginal delivery in the setting of induction of labor

± Nulliparous women only

Table 2 Studies of induction of labor reporting predictors of induction success or failure: Study information

Article | Year of Publiction | Study Period | Location | Setting | Control Group | Sample size | | Induction Method | Measure of success or failure | Study Quality | Applicability to KQ3
| | | | | | Control Group | Induced Labor
Bueno et al. ^40,^ ^41^ | 2007 | 2002-2003 | Spain | Academic Center | - | - | 196 | Oxytocin, AROM, PGE_2_ gel | Overall vaginal delivery, Vaginal delivery within 24 hours | Poor | Poor
Pandis et al. ^42^ ^§^ | 2001 | NS | United Kingdom | NS | - | - | 240 | Oxytocin, PGE_2_ gel | Vaginal delivery within 24 hours | Fair | Poor
Wilson and Philpott ^43^ | 1976 | Mar 1974–Jul 1974 | Rhodesia | NS | - | - | 175 | Oxytocin, AROM | Overall vaginal delivery | Fair | Poor
Williams and Craft ^44^ ^‡^ | 1979 | 1972-1973 | United Kingdom | Academic Center | - | - | 1910 | Oxytocin, AROM | Rate of emergency Cesarean section | Poor | Poor
Williams et al. ^45^ | 1997 | Jun 1991–Dec 1993 | United States | NS | - | - | 415 | Oxytocin, PGE_2_ gel, hygroscopic dilation | Failure to progress to active labor within 12 hours, failed vaginal delivery | Good | Fair
Wing et al. ^46^ | 2002 | 1994-2000 | United States | Academic Center and Community Hospital | - | - | 1373 | Oxytocin, AROM, Misoprostol | Vaginal delivery within 24 hours | Fair | Fair

KQ=Key Question; AROM=artificial rupture of membranes; PGE_2_=prostaglandin NS=not specified

§ Also reported failure to deliver after 24 hours in the setting of induction of labor; NS=not specified

Table 3 Additional predictors of cesarean delivery among all women

Article | Predictor | Predictor | Predictor | Predictor
Ahner et al. ^2^ | Presence of Fetal Fibronectin (FFN): FFN+=10.0% FFN-=15.2%
Anderson ^5^ | Cervical status: “ripe” (otherwise undefined)=5.3% “unripe” (otherwise undefined)=8.2%
Chan et al. ^12^ | Number of PGE_2_ Doses: 0=19.0% 1–2=16.4% ≥3=48.1%
Gabriel et al. ^18^ | Cervical Length upon Arrival: <26 mm=20.6% ≥26 mm=40.2% | Bishop score </=5 AND cervix <26mm=21% Bishop score </=5 AND cervix >/=26mm=43% Bishop score >5 AND cervix <26mm=21%Bishop score >5 AND cervix >/=26mm=25%
Garite et al. ^19^ | Presence of FFN: FFN+=14.8% FFN-=26.9% (P=0.05)
Morgan and Thurnau ^24^ | Ultrasound Estimated Fetal Weight (EFW) (grams): EFW≥4000 =22.2% EFW<4000 =25.0% EFW ≥4500 =25.0% EFW<4500 =24.4% | Fetal-Pelvic Index (FPI) Status: FPI+=83.3% FPI-=5.4% | Colcher-Sussman x-ray Pelvimetry Result: Contract=100% Adequate=22.9%
Orhue et al. ^28^ | Cervical Dilation at 8 hours: <4 cm=38.4% 4–8 cm=15.4% >8 cm=0% | Length of latent period: <4 hours=5.1% 4–8 hours=10.3% >8 hours=69.5%
Peregrine et al. ^29,^ ^30^ | Fetal Position: Occipito-posterior=25.3% Not Occipito-posterior=31.2% (P=0.29)
Saunders et al. ^33^ | Fetal Occipital Position before Induction: Occipito-anterior=17.4% Occipito-transverse=22.5% Occipito-posterior=35.7%
Schreyer et al. ^34^ | Presence of Fetal Breathing Movements (FBM): FBM+=9.7% FBM-=0%
Tan et al. ^36^ | Cervical Length: >20 mm=30.0% ≤20 mm=12.9% (P=0.018) | EFW (grams): EFW<2500=28.6% EFW 2500–4000=22.2% EFW>4000=33.3% | Maternal Height: <150 cm=27.3% ≥150 cm=21.7% (P=0.59) | Race: Malaysian=22% (P=0.65)
Ware and Raynor ^37^ | Cervical Length: <30 mm=4.0% ≥30 mm=81.5% (P<0.001) | Pharmaceutical agent used for induction of labor: Oxytocin=14% Misoprostol=56% (P<0.005)
Wilailak et al. ^47^ | Patient Status: Private Patient=19.4% Non-private Patient=17.2%

Peregrine et al. ^29,^ ^30^ reported predictors of cesarean section only as odds ratios and P-values for maternal height, gestational age, amniotic fluid index, estimated fetal weight, transvaginal sonography cervical length, and Bishop score.

Rizzo et al. ^31,^ ^32^ reported predictors of cesarean section only as odds ratios for parity, amniotic fluid index, and number of doses of prostaglandin administered.

Tan et al. ^36^ also reported that for women who had cervical funneling, 14.3% delivered by cesarean section (P=0.18).

Table 4 Additional predictors of cesarean delivery among nulliparous women

Article | Predictor
Anderson ^5^ | Cervical status: “ripe” (otherwise undefined)=5.7%; “unripe” (otherwise undefined)=6.5%
Chan et al. ^12^ | Number of PGE_2_ doses: 0=31.6% 1–2=22.8% ≥3=58.8%
Dodd et al. ^14^ | Bishop score: 0–3=37%; 4–6=26%
Ecker et al. ^15^ | Maternal age (years): <25=15% 25–34=23% 35–39=31% ≥40=33%
Heffner et al. ^21^ | Gestational age (weeks): 36–38 =18%; 39–40 =23%
Nuthalapaty et al. ^26^ | Maternal weight (kilograms): 47 to < 72=15% 72 to < 85=20% 85 to < 103=30% 103 to 193=37%
Peregrine et al. ^29,^ ^30^ | Fetal Position: Occipito-posterior=39.1%; Not Occipito-posterior=48.6% (P=0.22)
Xenakis et al. ^39^ | Bishop score: 0–3=34%; >3=20%

Table 5 Additional predictors of cesarean delivery among multiparous women

Article | Predictor
Anderson ^5^ | Cervical status: “ripe” (otherwise undefined)=4.2%; “unripe” (otherwise undefined)=11.1%
Chan et al. ^12^ | Number of PGE_2_ doses: 0=5.5% 1–2=5.2% ≥3=30.0%
Dodd et al. ^14^ | Bishop score: 0–3=15%; 4–6=8%
Nuthalapaty et al. ^26^ | Maternal weight (kilograms): 47 to < 72=7% 72 to < 85=8% 85 to < 103=13% 103 to 193=9%
Peregrine et al. ^29,^ ^30^ | Fetal Position: Occipito-posterior=0%; Not Occipito-posterior=15.5% (P<0.05)
Xenakis et al. ^39^ | Bishop score: 0–3=23%; >3=13%

Table 6 Predictors of induction success reported among all women

Article | Success Measure | Predictor | Predictor | Predictor
Xenakis et al. ^39^ | Ability to achieve active labor | Bishop Score: 0–3=91% >3=99%
NICHHD ^48^ | Vaginal delivery within 12 hours | Parity: Nulliparous=2% Multiparous=14%
Ahner et al. ^2^ | Vaginal delivery within 24 hours | Presence of fetal fibronectin: FFN+=83% FFN-=43%
Bueno et al. ^40,^ ^41^ | Vaginal delivery within 24 hours | Parity: Nulliparous=51% Multiparous=83% | Bishop score: 0=35% 1–4=60% >4=81% | Cervical length: <16.5 mm=91% 16.5–27 mm=65% >27mm =48%
Dhall et al. ^13^ | Vaginal delivery within 24 hours | Parity: Nulliparous=69% Multiparous=76% | Bishop Score: 0–3=47% 4–5=68% ≥6=92% | Dhall score: 0–6=34% 7–8=72% ≥9=91%
Dodd et al. ^14^ | Vaginal delivery within 24 hours | Parity: Nulliparous=43% Multiparous=76% | Bishop score: 0–3=50% 4–6=66%
Egarter et al.^49^ | Vaginal delivery within 24 hours | Parity: Nulliparous=80% Multiparous=96%
Ekman et al. ^17^ | Vaginal delivery within 24 hours | Parity: Nulliparous=66% Multiparous=48%
Pandis et al. ^42^ | Vaginal delivery within 24 hours | Parity: Nulliparous=54% Multiparous=74%
Peregrine et al. ^29,^ ^30^ | Vaginal delivery within 24 hours | Parity: Nulliparous=34% Multiparous=65% | Fetal position: Non-occipito-posterior=43% occipito-posterior=50%
Wing et al. ^46^ | Vaginal delivery within 24 hours | Parity: Nulliparous=32% Multiparous=63%
Buist ^10^ | Spontaneous vaginal delivery | Parity: Nulliparous=49% Multiparous=74%
Chan et al. ^12^ | Spontaneous vaginal delivery | Parity: Nulliparous=38% Multiparous=81% | Number of doses of prostaglandin: 0=59% 1–2=57% ≥3=33%
Heimstad et al. ^22^ | Spontaneous vaginal delivery | Gestational age: 37 weeks=77% 38 weeks=73% 39 weeks=77% 40 weeks=74% 41 weeks=58% 42+ weeks=63%
Macer et al.^50^ | Spontaneous vaginal delivery | Use of epidural analgesia: Epidural=52% No epidural=85%
Saunders et al. ^33^ | Spontaneous vaginal delivery | Fetal position: occipito-anterior=57% occipito-transverse=63% occipito-posterior=64%
Alberico et al. ^3^ | Overall vaginal delivery | Parity: Nulliparous=76% Multiparous=95% | Bishop Score: <5=79% ≥5=85%
Ben-Haroush et al. ^33^ | Overall vaginal delivery | Parity: Nulliparous=37%
Boulvain et al. ^41^ | Overall vaginal delivery | Parity: Nulliparous=41% Multiparous=89% | Medications used: Oxtyocin=86% Misoprostol=44%
Dhall et al. ^13^ | Overall vaginal delivery | Parity: Nulliparous=81% Multiparous=81% | Bishop Score: <4=66% ≥4=86% | Dhall score: <7=54% ≥7=90%
Saunders et al. ^33^ | Overall vaginal delivery | Fetal position: occipito-anterior=83% occipito-transverse=78% occipito-posterior=64%
Schreyer et al. ^34^ | Overall vaginal delivery | Bishop Score: Bishop Score 3–5=91% Bishop Score 6–10=96% | Presence/absence of fetal breathing movements: FBM+=90% FBM-=100%
Wigton and Wolk ^38^ | Overall vaginal delivery | Parity: Nulliparous=76% Multiparous=100%
Wilson and Philpott ^43^ | Overall vaginal delivery | Parity: >4=35%

Note: Each predictor is reported as the percentage of women with induction success within the specific group; for e.g. in the study by Xenakis et al, 91% of women with a Bishop score 0–3 had successful induction of labor as compared with 99% of women with Bishop score >3.

FFN=fetal fibronectin

Bueno et al. ^40,^ ^41^ reported predictors of overall vaginal delivery only as odds ratios for parity, Bishop score, cervical length, gestational age, age, weight at delivery, biparietal diameter, and previous abortion.

Rizzo et al. ^31,^ ^32^ reported predictors of overall vaginal delivery only as odds ratios for parity, gestational age, weight at delivery, AFI, and number of doses of prostaglandin administered.

Table 7 Predictors of induction success reported among nulliparous women

Article | Success Measure | Predictor | Predictor | Predictor
Xenakis et al. ^39^ | Ability to achieve active labor | Bishop Score: 0–3=87% >3=99%
Bueno et al. ^40,^ ^41^ | Vaginal delivery within 24 hours | Bishop score: <5=45% ≥=73% | Cervical length: <16.5 mm=92% >16.5 mm=47% | Cervical length >16.5mm AND Bishop score<6=44% Cervical length >16.5mm AND Bishop score >6=88%
Dhall et al. ^13^ | Vaginal delivery within 24 hours | Bishop Score: <4=43% ≥4=76% | Dhall score: <7=43% ≥7=80%
Dodd et al. ^14^ | Vaginal delivery within 24 hours | Bishop Score: 0–3=33% 4–6=57%
Ekman et al. ^17^ | Vaginal delivery within 24 hours | Gestational Age: 40 weeks=67% ≥42 weeks=63%
Peregrine et al. ^29,^ ^30^ | Vaginal delivery within 24 hours | Fetal position: Non-occipito-posterior=30% Occipito-posterior=39%
Chan et al. ^12^ | Spontaneous vaginal delivery | Number of doses of prostaglandin: 0=38% 1–2=41% ≥3=18%
Alberico et al. ^3^ | Overall vaginal delivery | Bishop Score: < 5=71% ≥ 5=82%
Dhall et al. ^13^ | Overall vaginal delivery | Bishop Score: <4=71% ≥4=83% | Dhall score: <7=65% ≥7=88%

Bueno et al. ^40,^ ^41^ reported predictors of overall vaginal delivery only as odds ratios for parity, Bishop score, cervical length, gestational age, age, weight at delivery, biparietal diameter, and previous abortion.

Table 8 Predictors of induction success reported among multiparous women

Article | Success Measure | Predictor | Predictor
Xenakis et al. ^39^ | Ability to achieve active labor | Bishop Score: 0–3=95% >3=99%
Bueno et al. ^40,^ ^41^ | Vaginal delivery within 24 hours | Bishop score: 0=40% 1–3=78% >3=100% | Cervical length: <27 mm=100% >27 mm=70%
Dhall et al. ^13^ | Vaginal delivery within 24 hours | Bishop Score: < 4=53% ≥ 4=86% | Dhall score: <7=10% ≥7=89%
Dodd et al. ^14^ | Vaginal delivery within 24 hours | Bishop Score: 0–3=73% 4–6=80%
Ekman et al. ^17^ | Vaginal delivery within 24 hours | Gestational Age: ≤ 38 weeks=46% 40 weeks=27% ≥ 41 weeks=67%
Peregrine et al. ^29,^ ^30^ | Vaginal delivery within 24 hours | Fetal position: Non-occipito-posterior=61% Occipito-posterior=77%
Chan et al. ^12^ | Spontaneous vaginal delivery | Number of doses of prostaglandin: 0=81% 1–2=85% ≥3=60%
Alberico et al. ^3^ | Overall vaginal delivery | Bishop Score: < 5=97% ≥ 5=91%
Dhall et al. ^13^ | Overall vaginal delivery | Bishop Score: < 4=58% ≥ 4=91% | Dhall score: <7=10% ≥7=94%

Bueno et al. ^40,^ ^41^ reported predictors of overall vaginal delivery only as odds ratios for parity, Bishop score, cervical length, gestational age, age, weight at delivery, biparietal diameter, and previous abortion.

Table 9 Predictors of failure

Article | Failure Measure | Predictor | Predictor
Garite et al. ^19^ ^¦^ | Interval of PG administration to delivery >18hrs
Garite et al. ^19^ ^¦^ | Interval of PG administration to delivery >24hrs
Pandis et al. ^42^ | Failure to deliver after 24 hours | Bishop Score: < 5=44% ≥ 5=9% | Cervical length: 0–18mm=2% 19–24mm=21% 25–31mm=33% 32–50 mm=84%
Williams and Craft ^44^ | Emergency C-section only | Parity: Nulliparous=11% Multiparous=4%
Williams et al. ^45^ | Failure to progress to active labor within 12 hours | Parity: Nulliparous=54% Multiparous=45%
Williams et al. ^45^ | Failed vaginal delivery | Parity: Nulliparous=30% Multiparous=25%

¦ Odds ratios are given for entire group and nulliparous women separately on predictors of Bishop score>5 and fetal fibronectin+.

PG=prostaglandin

## References for Appendix Tables

1 Abou el-Leil LA, Nasrat AA, Fayed HM. Prostaglandin E2 vaginal pessaries in the grandmultipara with an unripe cervix, a comparison of different parity groups. Int J Gynaecol Obstet. Feb. 1993;40(2):119-122. [pmid: 8094680].
2 Ahner R, Egarter C, Kiss H, et al. Fetal fibronectin as a selection criterion for induction of term labor. Am J Obstet Gynecol. Nov. 1995;173(5):1513-1517. [pmid: 7503193].
3 Alberico S, Fadalti M, Grimaldi E, De Seta F, Mazza S, Guaschino S. Eligibility criteria for labor induction with prostaglandins. Clin Exp Obstet Gynecol. 1997;24(2):61-66. [pmid: 9342463].
4 Alchalabi HA, Obeidat BR, Jallad MF, Khader YS. Induction of labor and perinatal outcome: the impact of the amniotic fluid index. Eur J Obstet Gynecol Reprod Biol. Dec. 2006;129(2):124-127. [pmid: 16360261].
5 Anderson MM. The state of the cervix, and surgical induction of labour. J Obstet Gynaecol Br Commonw. Oct. 1965;72(5):711-716. [pmid: 5842319].
6 Arulkumaran S, Gibb DM, TambyRaja RL, Heng SH, Ratnam SS. Failed induction of labour. Aust N Z J Obstet Gynaecol. Aug. 1985;25(3):190-193. [pmid: 3866556].
7 Gibb DM, Arulkumaran S, Heng SH, Ratnam SS. Characteristics of induced labour. Asia Oceania J Obstet Gynaecol. Mar. 1985;11(1):27-31. [pmid: 4015518].
8 Ben-Haroush A, Glickman H, Yogev Y, Kaplan B, Feldberg D, Hod M. Induction of labor in pregnancies with suspected large-for-gestational-age fetuses and unfavorable cervix. Eur J Obstet Gynecol Reprod Biol. Oct 15. 2004;116(2):182-185. [pmid: 15358461].
9 Boyd ME, Usher RH, McLean FH, Kramer MS. Obstetric consequences of postmaturity. Am J Obstet Gynecol. Feb. 1988;158(2):334-338. [pmid: 3277431].
10 Buist R. Induction of labour: indications and obstetric outcomes in a tertiary referral hospital. N Z Med J. Jul 9. 1999;112(1091):251-253. [pmid: 10448982].
11 Caughey AB, Nicholson JM, Cheng YW, Lyell DJ, Washington AE. Induction of labor and cesarean delivery by gestational age. Am J Obstet Gynecol. Sep. 2006;195(3):700-705. [pmid: 16949399].
12 Chan LY, Fu L, Leung TN, Wong SF, Lau TK. Obstetric outcomes after cervical ripening by multiple doses of vaginal prostaglandin E2. Acta Obstet Gynecol Scand. Jan. 2004;83(1):70-74. [pmid: 14678088].
13 Dhall K, Mittal SC, Kumar A. Evaluation of preinduction scoring systems. Aust N Z J Obstet Gynaecol. Nov. 1987;27(4):309-311. [pmid: 3453668].
14 Dodd JM, Crowther CA, Robinson JS. Morning compared with evening induction of labor: a nested randomized controlled trial. A nested randomized controlled trial. Obstet Gynecol. Aug. 2006;108(2):350-360. [pmid: 16880306].
15 Ecker JL, Chen KT, Cohen AP, Riley LE, Lieberman ES. Increased risk of cesarean delivery with advancing maternal age: indications and associated factors in nulliparous women. Am J Obstet Gynecol. Oct. 2001;185(4):883-887. [pmid: 11641671].
16 Edris FE, von Dadelszen P, Ainsworth LM, Liston RM. Predictors of cesarean section following elective post-dates induction of labor in nullipara with uncomplicated singleton vertex pregnancies. Saudi Med J. Aug. 2006;27(8):1167-1172. [pmid: 16883446].
17 Ekman G, Perssen PH, Ulmsten U, Wingerup L. The impact on labor induction of intracervically applied PGE2-gel, related to gestational age in patients with an unripe cervix. Acta Obstet Gynecol Scand Suppl. 1983;113:173-175. [pmid: 6574676].
18 Gabriel R, Darnaud T, Chalot F, Gonzalez N, Leymarie F, Quereux C. Transvaginal sonography of the uterine cervix prior to labor induction. Ultrasound Obstet Gynecol. Mar. 2002;19(3):254-257. [pmid: 11896946].
19 Garite TJ, Casal D, Garcia-Alonso A, et al. Fetal fibronectin: a new tool for the prediction of successful induction of labor. Am J Obstet Gynecol. Dec. 1996;175(6):1516-1521. [pmid: 8987935].
20 Goeschen K, Pakzad S. Risks occurring in birth induction without considering cervix maturity. J Perinat Med. 1980;8(1):27-37. [pmid: 7365668].
21 Heffner LJ, Elkin E, Fretts RC. Impact of labor induction, gestational age, and maternal age on cesarean delivery rates. Obstet Gynecol. Aug. 2003;102(2):287-293. [pmid: 12907101].
22 Heimstad R, Romundstad PR, Eik-Nes SH, Salvesen KA. Outcomes of pregnancy beyond 37 weeks of gestation. Obstet Gynecol. Sep. 2006;108(3 Pt 1):500-508. [pmid: 16946207].
23 Johnson DP, Davis NR, Brown AJ. Risk of cesarean delivery after induction at term in nulliparous women with an unfavorable cervix. Am J Obstet Gynecol. Jun. 2003;188(6):1565-1569. discussion 1569–1572. [pmid: 12824994].
24 Morgan MA, Thurnau GR. Efficacy of the fetal-pelvic index in patients requiring labor induction. Am J Obstet Gynecol. Sep. 1988;159(3):621-625. [pmid: 3048100].
25 Nooh A, Baghdadi S, Raouf S. Induction of labour: how close to the evidence-based guidelines are we?. J Obstet Gynaecol. Jul. 2005;25(5):451-454. [pmid: 16183578].
26 Nuthalapaty FS, Rouse DJ, Owen J. The association of maternal weight with cesarean risk, labor duration, and cervical dilation rate during labor induction. Obstet Gynecol. Mar. 2004;103(3):452-456. [pmid: 14990405].
27 Onifade A. Induction of labour. West Afr Med J. Jun. 1970;19(3):105-108. [pmid: 5482328].
28 Orhue AA, Unuigbe JA, Ezimokhai M, Ojo VA. Outcome of induced labor in 931 term pregnancies. Obstet Gynecol. Jul. 1984;64(1):108-114. [pmid: 6738933].
29 Peregrine E, O'Brien P, Omar R, Jauniaux E. Clinical and ultrasound parameters to predict the risk of cesarean delivery after induction of labor. Obstet Gynecol. Feb. 2006;107(2 Pt 1):227-233. [pmid: 16449105].
30 Peregrine E, O'Brien P, Jauniaux E. Impact on delivery outcome of ultrasonographic fetal head position prior to induction of labor. Obstet Gynecol. Mar. 2007;109(3):618-625. [pmid: 17329512].
31 Rizzo N, Farina A, Santarsiero G, et al. Correlation among amniotic fluid index (AFI), cesarean section rate, and labor length in inducted pregnancies beyond 41 weeks' gestation with unfavorable cervix. Am J Perinatol. 2000;17(6):319-324. [pmid: 11144315].
32 Rizzo N, Farina A, Santarsiero G, et al. Amniotic fluid index and labor length of pregnancies induced beyond 41 weeks of gestation with unfavorable cervix. Gynecol Obstet Invest. 2000;49(4):244-248. [pmid: 10828707].
33 Saunders N, Amis S, Marsh M. The prognostic value of fetal ultrasonography before induction of labour. Br J Obstet Gynaecol. Nov. 1992;99(11):903-906. [pmid: 1450140].
34 Schreyer P, Bar-Natan N, Sherman DJ, Arieli S, Caspi E. Fetal breathing movements before oxytocin induction in prolonged pregnancies. Am J Obstet Gynecol. Sep. 1991;165(3):577-581. [pmid: 1892182].
35 Simon CE, Grobman WA. When has an induction failed?. Obstet Gynecol. Apr. 2005;105(4):705-709. [pmid: 15802394].
36 Tan PC, Suguna S, Vallikkannu N, Hassan J. Ultrasound and clinical predictors for Caesarean delivery after labour induction at term. Aust N Z J Obstet Gynaecol. Dec. 2006;46(6):505-509. [pmid: 17116055].
37 Ware V, Raynor BD. Transvaginal ultrasonographic cervical measurement as a predictor of successful labor induction. Am J Obstet Gynecol. May. 2000;182(5):1030-1032. [pmid: 10819818].
38 Wigton TR, Wolk BM. Elective and routine induction of labor. A retrospective analysis of 274 cases. J Reprod Med. Jan. 1994;39(1):21-26. [pmid: 8169911].
39 Xenakis EM, Piper JM, Conway DL, Langer O. Induction of labor in the nineties: conquering the unfavorable cervix. Obstet Gynecol. Aug. 1997;90(2):235-239. [pmid: 9241300].
40 Bueno B, San-Frutos L, Perez-Medina T, Barbancho C, Troyano J, Bajo J. The labor induction: integrated clinical and sonographic variables that predict the outcome. J Perinatol. Jan. 2007;27(1):4-8. [pmid: 17180126].
41 Bueno B, San-Frutos L, Salazar F, et al. Variables that predict the success of labor induction. Acta Obstet Gynecol Scand. Nov. 2005;84(11):1093-1097. [pmid: 16232178].
42 Pandis GK, Papageorghiou AT, Ramanathan VG, Thompson MO, Nicolaides KH. Preinduction sonographic measurement of cervical length in the prediction of successful induction of labor. Ultrasound Obstet Gynecol. Dec. 2001;18(6):623-628. [pmid: 11844202].
43 Wilson PD, Philpott RH. Induction of labour in Black patients. S Afr Med J. Mar 24. 1976;50(13):498-502. [pmid: 1265545].
44 Williams RM, Craft I. Caesarean section following modern induction of labour. Br J Clin Pract. Mar 1979;33(3):80–81, 84.
45 Williams MC, Krammer J, O'Brien WF. The value of the cervical score in predicting successful outcome of labor induction. Obstet Gynecol. Nov. 1997;90(5):784-789. [pmid: 9351765].
46 Wing DA, Tran S, Paul RH. Factors affecting the likelihood of successful induction after intravaginal misoprostol application for cervical ripening and labor induction. Am J Obstet Gynecol. Jun. 2002;186(6):1237-1240. discussion 1240–1233. [pmid: 12066104].
47 Wilailak S, Saropala N, Chaturachinda K. Elective induction of labor: Ramathibodi Hospital (Jan–Jun, 1990). J Med Assoc Thai. Jan. 1993;76(Suppl 1):44-47. [pmid: 8113655].
48 A clinical trial of induction of labor versus expectant management in postterm pregnancy. The National Institute of Child Health and Human Development Network of Maternal-Fetal Medicine Units. Am J Obstet Gynecol Mar 1994;170(3):716–723.