# Appendix B: Data Abstraction Forms

## Level 1. Title and abstract review form

Fundamentally, there are two types of articles we are looking for to address our Key Questions:

1 Elective IOL studies with outcomes on mothers and babies
2 Studies that examine predictors of IOL success.

Both types of studies, but particularly the latter, can be used to examine definitions of success.

1 What type of article is this?
  a Prospective RCT
  b Cohort/Case-control study
  c Review
  d Meta-analysis
  e Editorial
  f Letter
  g Case study
  h Clinical guideline
  i Can't tell
2 Is this a study of method induction (e.g. prostaglandins [misoprostol, cervidil, prepidil, PGE2, PGE1M], oxytocin, Foley bulb, laminaria, amniotomy, artificial rupture of membranes [AROM])?
  a Yes
  b No
  c Can't tell
3 Are there any other reasons that this article should be excluded?
  a No
  b Can't tell
  c Article primarily addresses postterm (>42 weeks gestational age) pregnancy
  d Article primarily addresses women with prior cesareans
  e Article primarily addresses multiple gestations
  f Article primarily addresses medical or obstetrical complications of pregnancy such as preeclampsia, diabetes mellitus and isoimmunization
  g Article primarily addresses fetal anomalies
  h Foreign language
  i Other (specify): ___________________________
4 Is the article about elective induction of labor? (Where elective induction of labor is defined as induction of labor without a medical indication prior to 42 weeks of gestation. A medical induction of induction of labor includes preeclampsia, diabetes mellitus, neonatal indications such as intrauterine growth restriction, oligohydramnios, nonreassuring fetal heart rate, fetal anomalies)
  a Yes - ANSWER QUESTION 5 ONLY
  b No - ANSWER QUESTION 6 ONLY
  c Can't tell - ANSWER QUESTION 5 ONLY

ANSWER ONLY QUESTION 5 IF THE ANSWER TO QUESTION 4 IS “YES” OR “CAN'T TELL”. DO NOT ANSWER QUESTION 6.

5 Which of the following outcomes do the results include?
  a Maternal outcomes (including cesarean delivery)
  b Neonatal outcomes
  c Neither (explain)
  d Can't tell

ANSWER ONLY QUESTION 6 IF THE ANSWER TO QUESTION 4 IS “NO”.

6 Do the results examine predictors of cesarean delivery? (Where such predictors might include maternal age, race/ethnicity, obesity/weight, parity, birthweight, gestational age, etc.)
  a Yes
  b No
  c Can't tell

## Level 2. Full text data abstraction form

1 Should this article be abstracted? Article #_____________________
  a Yes
  b No
2 Why should this article be excluded from full text abstraction (check all that apply)? (Please skip the rest of the form if the article is to be excluded)
  a Article is not about elective induction of labor nor predictors of success in the setting of induction of labor
  b While article is about elective induction of labor, does not examine mode of delivery or maternal or neonatal outcomes
  c Not a research study including cohort, case-control or RCT
  d Article primarily about method of induction
  e Article primarily addresses postterm (>42 weeks gestational age) pregnancy
  f Article primarily addresses multiple gestations
  g Article primarily addresses medical or obstetrical complications of pregnancy such as preeclampsia, diabetes mellitus and isoimmunization
  h Article primarily addresses fetal anomalies
  i Article primarily addresses women with prior cesareans
  j Foreign language article
  k Duplicate publication or linked to another publication (specify) _____
  l Data provided not usable (specify) _____________
  m Other reason (specify)
3 Does this article present data that overlaps with another article/publication?
  a Yes - please specify other article(s). ____________
  b No
4 What was the study design of the article?
  a Randomized, controlled trial
  b Prospective cohort study
  c Retrospective cohort study
  d Case-control study
5 What year was the article published? ________________
6 Over what years was the study conducted?
  a Began in:___________ Ended in:____________
7 What country was the study conducted in?
  a U.S.
  b Canada
  c Other (Specify): _______________________________
8 What was the primary location of the study?
  a Academic Center
  b Community Hospital
  c Both Academic and Community Hospital
  d Multi-center study
  e Not stated
9 Was this a study of elective induction of labor? (Where elective induction of labor is defined as induction of labor without a medical indication prior to 42 weeks of gestation. A medical induction of induction of labor includes preeclampsia, diabetes mellitus, neonatal indications such as intrauterine growth restriction, oligohydramnios, nonreassuring fetal heart rate, fetal anomalies)
  a Yes
  b No
10 What was the primary measure of success for induction of labor?
  a Not mentioned
  b Vaginal delivery
  c Spontaneous vaginal delivery (neither forceps nor vacuum)
  d Vaginal delivery within 24 hours
  e Vaginal delivery within 18 hours
  f Active labor within 24 hours
  g Active labor within 18 hours
  h Active labor within 12 hours
  i Other (Specify): ____________________________
11 What was the primary comparison group to IOL?
  a Expectant management
  b Spontaneous labor
  c No comparison group
12 What induction method was used?
  a Oxytocin
  b AROM (artificial rupture of membrane)
  c Misoprostil
  d PGE2 gel (prepidil)
  e Cervidil
  f Other method (specify)
13 Please report any additional information on the induction method that may be relevant in the text box below.
14 Which of the following exclusion criteria were used when selecting the population for the study? (Note: this applies only to the elective induction of labor studies)
  a Multiple gestation
  b Prior CS
  c Breech
  d > 42 weeks GA
  e < 37 weeks GA
  f Other (specify)
15 Which of the following inclusion criteria were used when selecting the population for the study? (Note: this applies to elective IOL studies only)
  a Multiparas
  b Nulliparas
  c Other (specify)
16 Please escribe any other issues with respect to the population studied in the text box below.

If this is a study of ELECTIVE IOL, then answer the outcomes questions; if this study only looked at predictors of success, then skip the outcomes questions and only report data for the table on predictors of CS.

What were the Maternal/Obstetric outcomes reported?

Maternal/Obstetric Outcomes for ALL patients (not stratified by parity)

| Spont Labor n | Spont Labor % | Spont Labor N | IOL n | IOL % | IOL N | P-value | RR | OR | 95% CI lower | 95% CI upper | aOR | 95% CI lower | 95% CI upper
Cesarean
Spontaneous Vaginal Del
Operative vaginal delivery
Chorio
Prolonged Labor
Prolonged 1^st^ stage of labor
Prolonged 2^nd^ stage of labor
Mean labor
Mean 1^st^ stage
Mean 2^nd^ stage
Median labor
Median 1^st^ stage
Median 2^nd^ stage
Mean EBL
3^rd^/4^th^ degree perineal laceration
Postpartum hemorrhage
Blood transfusion
Hysterectomy
Injury to organs - bowel/bladder
Wound complications
Endomyometritis

| Outcome | Spont Labor n | Spont Labor % | Spont Labor N | IOL n | IOL % | IOL N | P-value | RR | OR | 95% CI lower | 95% CI upper | aOR | 95% CI lower | 95% CI upper
Other maternal/obste outcome
Other
Other
Other
Other

Maternal/Obstetric Outcomes for NULLIPAROUS patients ONLY

| Spont Labor n | Spont Labor % | Spont Labor N | IOL n | IOL % | IOL N | P-value | RR | OR | 95% CI lower | 95% CI upper | aOR | 95% CI lower | 95% CI upper
Cesarean
Spontaneous Vaginal Del
Operative vaginal delivery
Chorio
Prolonged Labor
Prolonged 1^st^ stage of labor
Prolonged 2^nd^ stage of labor
Mean labor
Mean 1^st^ stage
Mean 2^nd^ stage
Median labor
Median 1^st^ stage
Median 2^nd^ stage
Mean EBL
3^rd^/4^th^ degree perineal laceration
Postpartum hemorrhage
Blood transfusion
Hysterectomy
Injury to organs - bowel/bladder
Wound complications
Endomyometritis

| Outcome | Spont Labor n | Spont Labor % | Spont Labor N | IOL n | IOL % | IOL N | P-value | RR | OR | 95% CI lower | 95% CI upper | aOR | 95% CI lower | 95% CI upper
Other maternal/obste outcome
Other
Other
Other
Other

Maternal/Obstetric Outcomes for MULTIPAROUS patients ONLY

| Spont Labor n | Spont Labor % | Spont Labor N | IOL n | IOL % | IOL N | P-value | RR | OR | 95% CI lower | 95% CI upper | aOR | 95% CI lower | 95% CI upper
Cesarean
Spontaneous Vaginal Del
Operative vaginal delivery
Chorio
Prolonged Labor
Prolonged 1^st^ stage of labor
Prolonged 2^nd^ stage of labor
Mean labor
Mean 1^st^ stage
Mean 2^nd^ stage
Median labor
Median 1^st^ stage
Median 2^nd^ stage
Mean EBL
3^rd^/4^th^ degree perineal laceration
Postpartum hemorrhage
Blood transfusion
Hysterectomy
Injury to organs - bowel/bladder
Wound complications
Endomyometritis

| Outcome | Spont Labor n | Spont Labor % | Spont Labor N | IOL n | IOL % | IOL N | P-value | RR | OR | 95% CI lower | 95% CI upper | aOR | 95% CI lower | 95% CI upper
Other maternal/obste outcome
Other
Other
Other
Other

What were the neonatal outcomes reported?

Neonatal outcomes for ALL patients (not stratified by parity)

| Spont Labor n | Spont Labor % | Spont Labor N | IOL n | IOL % | IOL N | P-value | RR | OR | 95% CI lower | 95% CI upper | aOR | 95% CI lower | 95% CI upper
Apgar score <7 at 5 minutes
UAph<7.0
UAph<7.1
UA base excess < -12
UA base excess < -11
Mean UApH
Mean base excess
Meconium
Meconium aspiration syndrome
“fetal distress” or fetal intolerance of labor
Respiratory distress syndrome
Transient tachypnea of the newborn
Suspected sepsis
Culture proven sepsis
Hypoxic-ischemic encephalopathy
LGA - large for gestational age
Birthweight > 4000 gms
Birthweight >4500 gms
Birthweight < 2500 gms
Neonatal seizures
Hypoglycemia
Neonatal jaundice
Neonatal polycythemia
Breastfeeding

| Outcome | Spont Labor n | Spont Labor % | Spont Labor N | IOL n | IOL % | IOL N | P-value | RR | OR | 95% CI lower | 95% CI upper | aOR | 95% CI lower | 95% CI upper
Other neonatal outcome
Other
Other
Other
Other

Neonatal outcomes for NULLIPAROUS patients only

| Spont Labor n | Spont Labor % | Spont Labor N | IOL n | IOL % | IOL N | P-value | RR | OR | 95% CI lower | 95% CI upper | aOR | 95% CI lower | 95% CI upper
Apgar score <7 at 5 minutes
UAph<7.0
UAph<7.1
UA base excess < -12
UA base excess < -11
Mean UApH
Mean base excess
Meconium
Meconium aspiration syndrome
“fetal distress” or fetal intolerance of labor
Respiratory distress syndrome
Transient tachypnea of the newborn
Suspected sepsis
Culture proven sepsis
Hypoxic-ischemic encephalopathy
LGA - large for gestational age
Birthweight > 4000 gms
Birthweight >4500 gms
Birthweight < 2500 gms
Neonatal seizures
Hypoglycemia
Neonatal jaundice
Neonatal polycythemia
Breastfeeding

| Outcome | Spont Labor n | Spont Labor % | Spont Labor N | IOL n | IOL % | IOL N | P-value | RR | OR | 95% CI lower | 95% CI upper | aOR | 95% CI lower | 95% CI upper
Other neonatal outcome
Other
Other
Other
Other

Neonatal outcomes for MULTIPAROUS patients only

| Spont Labor n | Spont Labor % | Spont Labor N | IOL n | IOL % | IOL N | P-value | RR | OR | 95% CI lower | 95% CI upper | aOR | 95% CI lower | 95% CI upper
Apgar score <7 at 5 minutes
UAph<7.0
UAph<7.1
UA base excess < -12
UA base excess < -11
Mean UApH
Mean base excess
Meconium
Meconium aspiration syndrome
“fetal distress” or fetal intolerance of labor
Respiratory distress syndrome
Transient tachypnea of the newborn
Suspected sepsis
Culture proven sepsis
Hypoxic-ischemic encephalopathy
LGA - large for gestational age
Birthweight > 4000 gms
Birthweight >4500 gms
Birthweight < 2500 gms
Neonatal seizures
Hypoglycemia
Neonatal jaundice
Neonatal polycythemia
Breastfeeding

| Outcome | Spont Labor n | Spont Labor % | Spont Labor N | IOL n | IOL % | IOL N | P-value | RR | OR | 95% CI lower | 95% CI upper | aOR | 95% CI lower | 95% CI upper
Other neonatal outcome
Other
Other
Other
Other

What were the predictors of cesarean delivery reported?

17 For which of the following outcomes were the predictors of delivery reported?
  a Overall vaginal delivery
  b Vaginal delivery within 24 hours
  c Other (specify)

Predictors of cesarean delivery in setting of IOL (ALL PATIENTS - NOT STRATIFIED BY PARITY)

| IOL n | IOL % | IOL N | P-value | RR | OR | 95% CI lower | 95% CI upper | aOR | 95% CI lower | 95% CI upper
Maternal age < 35
Maternal age ≥ 35
Maternal age < 20
Age 20–24
Age 25–29
Age 30–34
Age 35–39
Age ≥40
Asian
Black
White
Hispanic/Latina
Native American
Other (specify)_____________
Nulliparous
Multiparous
Medical Insurance
Private Insurance
Height < 5′0"
Height ≥ 5′0"
Underweight <BMI of 19
Normal weight BMI 20–24
Overweight BMI 25–29
Obese BMI >= 30
Bishop score <5
Bishop score >= 5
Cervical length < 2 cm
Cervical length >= 2 cm
Cervical length < 1.5 cm
Cervical length >= 1.5 cm
Cervical length < 1.0 cm
Cervical length >= 1.0 cm
Gestational age <41 weeks GA
≥ 41 weeks GA
<42 weeks GA
≥ 42 weeks GA
37 weeks GA
38 weeks GA
39 weeks GA
40 weeks GA
41 weeks GA
42 weeks GA
Preeclampsia
No preeclampsia
GDM/DM
NO GDM/DM
AFI <= 5
AFI >5 to <20
AFI >= 20
Other
Other
Other
Other
Other
Other
Other
Other
Other
Other

Predictors of cesarean delivery in setting of IOL (NULLIPAROUS PATIENTS ONLY)

| IOL n | IOL % | IOL N | P-value | RR | OR | 95% CI lower | 95% CI upper | aOR | 95% CI lower | 95% CI upper
Maternal age < 35
Maternal age ≥ 35
Maternal age < 20
Age 20–24
Age 25–29
Age 30–34
Age 35–39
Age ≥40
Asian
Black
White
Hispanic/Latina
Native American
Other (specify)_____________
Nulliparous
Multiparous
Medical Insurance
Private Insurance
Height < 5′0"
Height ≥ 5′0"
Underweight <BMI of 19
Normal weight BMI 20–24
Overweight BMI 25–29
Obese BMI >= 30
Bishop score <5
Bishop score >= 5
Cervical length < 2 cm
Cervical length >= 2 cm
Cervical length < 1.5 cm
Cervical length >= 1.5 cm
Cervical length < 1.0 cm
Cervical length >= 1.0 cm
Gestational age <41 weeks GA
≥ 41 weeks GA
<42 weeks GA
≥ 42 weeks GA
37 weeks GA
38 weeks GA
39 weeks GA
40 weeks GA
41 weeks GA
42 weeks GA
Preeclampsia
No preeclampsia
GDM/DM
NO GDM/DM
AFI <= 5
AFI >5 to <20
AFI >= 20
Other
Other
Other
Other
Other
Other
Other
Other
Other
Other

Predictors of cesarean delivery in setting of IOL (MULTIPAROUS PATIENTS ONLY)

| IOL n | IOL % | IOL N | P-value | RR | OR | 95% CI lower | 95% CI upper | aOR | 95% CI lower | 95% CI upper
Maternal age < 35
Maternal age ≥ 35
Maternal age < 20
Age 20–24
Age 25–29
Age 30–34
Age 35–39
Age ≥40
Asian
Black
White
Hispanic/Latina
Native American
Other (specify)_____________
Nulliparous
Multiparous
Medical Insurance
Private Insurance
Height < 5′0"
Height ≥ 5′0"
Underweight <BMI of 19
Normal weight BMI 20–24
Overweight BMI 25–29
Obese BMI >= 30
Bishop score <5
Bishop score >= 5
Cervical length < 2 cm
Cervical length >= 2 cm
Cervical length < 1.5 cm
Cervical length >= 1.5 cm
Cervical length < 1.0 cm
Cervical length >= 1.0 cm
Gestational age <41 weeks GA
≥ 41 weeks GA
<42 weeks GA
≥ 42 weeks GA
37 weeks GA
38 weeks GA
39 weeks GA
40 weeks GA
41 weeks GA
42 weeks GA
Preeclampsia
No preeclampsia
GDM/DM
NO GDM/DM
AFI <= 5
AFI >5 to <20
AFI >= 20
Other
Other
Other
Other
Other
Other
Other
Other
Other
Other

For which of the following outcomes were the predictors of delivery reported?

a Overall vaginal delivery
b Vaginal delivery within 24 hours
c Other (specify)

Predictors of cesarean delivery in setting of IOL (ALL PATIENTS - NOT STRATIFIED BY PARITY)

| IOL n | IOL % | IOL N | P-value | RR | OR | 95% CI lower | 95% CI upper | aOR | 95% CI lower | 95% CI upper
Maternal age < 35
Maternal age ≥ 35
Maternal age < 20
Age 20–24
Age 25–29
Age 30–34
Age 35–39
Age ≥40
Asian
Black
White
Hispanic/Latina
Native American
Other (specify)_____________
Nulliparous
Multiparous
Medical Insurance
Private Insurance
Height < 5′0"
Height ≥ 5′0"
Underweight <BMI of 19
Normal weight BMI 20–24
Overweight BMI 25–29
Obese BMI >= 30
Bishop score <5
Bishop score >= 5
Cervical length < 2 cm
Cervical length >= 2 cm
Cervical length < 1.5 cm
Cervical length >= 1.5 cm
Cervical length < 1.0 cm
Cervical length >= 1.0 cm
Gestational age <41 weeks GA
≥ 41 weeks GA
<42 weeks GA
≥ 42 weeks GA
37 weeks GA
38 weeks GA
39 weeks GA
40 weeks GA
41 weeks GA
42 weeks GA
Preeclampsia
No preeclampsia
GDM/DM
NO GDM/DM
AFI <= 5
AFI >5 to <20
AFI >= 20
Other
Other
Other
Other
Other
Other
Other
Other
Other
Other

Predictors of cesarean delivery in setting of IOL (NULLIPAROUS PATIENTS ONLY)

| IOL n | IOL % | IOL N | P-value | RR | OR | 95% CI lower | 95% CI upper | aOR | 95% CI lower | 95% CI upper
Maternal age < 35
Maternal age ≥ 35
Maternal age < 20
Age 20–24
Age 25–29
Age 30–34
Age 35–39
Age ≥40
Asian
Black
White
Hispanic/Latina
Native American
Other (specify)_____________
Nulliparous
Multiparous
Medical Insurance
Private Insurance
Height < 5′0"
Height ≥ 5′0"
Underweight <BMI of 19
Normal weight BMI 20–24
Overweight BMI 25–29
Obese BMI >= 30
Bishop score <5
Bishop score >= 5
Cervical length < 2 cm
Cervical length >= 2 cm
Cervical length < 1.5 cm
Cervical length >= 1.5 cm
Cervical length < 1.0 cm
Cervical length >= 1.0 cm
Gestational age <41 weeks GA
≥ 41 weeks GA
<42 weeks GA
≥ 42 weeks GA
37 weeks GA
38 weeks GA
39 weeks GA
40 weeks GA
41 weeks GA
42 weeks GA
Preeclampsia
No preeclampsia
GDM/DM
NO GDM/DM
AFI <= 5
AFI >5 to <20
AFI >= 20
Other
Other
Other
Other
Other
Other
Other
Other
Other
Other

Predictors of cesarean delivery in setting of IOL (MULTIPAROUS PATIENTS ONLY)

| IOL n | IOL % | IOL N | P-value | RR | OR | 95% CI lower | 95% CI upper | aOR | 95% CI lower | 95% CI upper
Maternal age < 35
Maternal age ≥ 35
Maternal age < 20
Age 20–24
Age 25–29
Age 30–34
Age 35–39
Age ≥40
Asian
Black
White
Hispanic/Latina
Native American
Other (specify)_____________
Nulliparous
Multiparous
Medical Insurance
Private Insurance
Height < 5′0"
Height ≥ 5′0"
Underweight <BMI of 19
Normal weight BMI 20–24
Overweight BMI 25–29
Obese BMI >= 30
Bishop score <5
Bishop score >= 5
Cervical length < 2 cm
Cervical length >= 2 cm
Cervical length < 1.5 cm
Cervical length >= 1.5 cm
Cervical length < 1.0 cm
Cervical length >= 1.0 cm
Gestational age <41 weeks GA
≥ 41 weeks GA
<42 weeks GA
≥ 42 weeks GA
37 weeks GA
38 weeks GA
39 weeks GA
40 weeks GA
41 weeks GA
42 weeks GA
Preeclampsia
No preeclampsia
GDM/DM
NO GDM/DM
AFI <= 5
AFI >5 to <20
AFI >= 20
Other
Other
Other
Other
Other
Other
Other
Other
Other
Other

Any other comments?

## Quality assessment and applicability forms

### I. Assessment of Quality of Individual Randomized Controlled Trials of Elective Induction of Labor

1) Was the comparison group expectant management? Yes No
2) Is there description of the method of randomization? Yes No
  2a) If yes, Is there a fatal flaw in the approach (such as lottery cards)? Yes No
  2b) Was randomization stratified by parity (or study includes only one parity group)? Yes No
3) Was there good balance achieved in parity, gestational age at randomization, maternal age, race/ethnicity, and insurance status/education, or less than a 20 percent difference between each arm? Yes (all) No (for any) Not reported
4) Was masking of outcome assessors attempted? Yes No Not reported
  4a) Was masking of outcome assessors accomplished? Yes No Not reported
5) Was loss to follow-up reported? Yes No
  5a) If yes, what was follow-up at different time periods?

Immediate Postpartum | <80% | 80–90% | 90–95% | >95%
4–8 wks Postpartum | <80% | 80–90% | 90–95% | >95% | N/A

6) How many total subjects in the study? <400 400–1000 >1000
  6a) Was a sample size calculation performed a priori? Yes No
  6b) If yes, was sample size achieved? Yes No N/A
7) Were statistical tests utilized? Yes No
  7a) Was the analysis conducted as intention-to-treat? Yes No
  7b) If there was any lack of balance in randomization, were multivariable analyses utilized to control for confounding variables? Yes No N/A
  7c) Were analyses stratified by parity (or study includes only one parity group)? Yes No

Overall Quality Good Fair Poor

### II. Assessment of Quality of Observational studies of Elective Induction of Labor

1) Was the comparison group expectant management? Yes No N/A
2) Was the study prospective? Yes No
3) Were the study groups comparable at baseline in terms of parity, maternal age, race/ethnicity, and insurance status/education as described/shown in a table?

Yes (all) | No (for any) | Not reported | N/A

4) Was loss to follow-up reported? Yes No N/A (retrospective study)
  4a) If yes, what was follow-up at different time periods?
    Immediate Postpartum | <80% | 0–90% | 0–95% | 95%
    4–8 wks Postpartum | <80% | 0–90% | 0–95% | 95% | N/A
5) How many total subjects in the study? <400 400–1000 >1000
  5a) Was a sample size calculation performed a priori? Yes No
  5b) If yes, was sample size achieved? Yes No N/A
6) Were statistical tests utilized? Yes No
  6a) Were multivariable analyses utilized to control for confounding variables? Yes No
  6b) Were analyses stratified by parity (or study includes only one parity group)? Yes No

Overall Quality Good Fair Poor

### III. Assessment of Applicability of Individual Studies of Induction of Labor

1) This study examined the following:
  a Mode of delivery/maternal outcomes (KQ1)
  b Neonatal outcomes (KQ2)
  c Factors associated with mode of delivery (KQ3)

[underlined: Key Questions 1 and 2]

2) Was the comparison group expectant management? Yes No N/A

(If No, then poor applicability for KQs 1 and 2, if yes then good)

[underlined: Key Question 3]

3) Was this a study of elective induction of labor? Yes No

(If No, not used for KQs 1 and 2 and baseline fair applicability for KQ 3 and if yes, then good applicability for KQ3)

[underlined: For All Key Questions]

4) Was any of the clinical care in the study provided before 1985? Yes No

(If the answer to #4 is yes, then applicability downgraded one step good to fair or fair to poor)

5) Was the clinical care provided in the U.S. ? Yes No

(If the answer to #5 is no, then applicability downgraded one step good to fair or fair to poor)

6) Were prostaglandins or other cervical ripening utilized in induction of labor? Yes No

(If the answer to #6 is no, then applicability downgraded one step good to fair or fair to poor)

Applicability KQ1 and 2 | Good | Fair | Poor
Applicability KQ3 | Good | Fair | Poor

7) Was there a stratified analysis of women delivered prior to 41 weeks of gestation or was the population all prior to 41 weeks of gestation in the induction group? Yes No

(If yes, then maintain applicability for KQ1 and 2, If no, then poor applicability to < 41 weeks)

Applicability to pregnancies prior to 41 weeks of gestation (for KQ1 and 2) Good Fair Poor