# Appendix A: Search Strategy

MEDLINE Search I

“Puerperal Disorders”[MeSH] OR “Pregnancy, Prolonged”[MeSH] OR “Pregnancy Complications”[MeSH] OR “Morbidity”[MeSH] OR “Infant, Newborn”[MeSH] OR “Fetal Diseases”[MeSH] OR “Puerperal Infection”[MeSH] OR “Pregnancy Outcome”[MeSH] OR “Cesarean Section”[MeSH] OR “Obstetric Labor Complications”[MeSH] AND “Labor, Induced”[MeSH]

Limits: English, Humans

# of citations as of 5/21/2007: 2597

MEDLINE Search II

#1 “Labor, Induced”[mesh] OR “induction of labor” OR “labor induction” OR (labor[ti] OR labour[ti] AND induc*[ti])
#2 trial OR study OR studies OR follow* OR “long term” OR outcome* OR risk OR mortality OR fatal* OR disabilit* OR (“Treatment Outcome”[MeSH] OR “Pregnancy Outcome”[MeSH] OR “Controlled Clinical Trials”[MeSH] OR “Epidemiologic Factors”[MeSH] OR “Cohort Studies”[MeSH] OR “Risk”[MeSH] OR “Retrospective Studies”[MeSH] OR “Prognosis”[MeSH] OR “Mortality”[MeSH] OR “Follow-Up Studies”[MeSH] OR “mortality”[Subheading] OR “Controlled Clinical Trial”[Publication Type])
#3 #1 and #2, limits: English, Humans

# of citations as of June 6, 2007 (total): 3207

# of citations as of June 6, 2007 (unique): 1110

MEDLINE Search III

#1 “Labor, Induced”[mesh] OR “induction of labor” OR “labor induction” OR (labor[ti] OR labour[ti] AND induc*[ti]) AND elective

# of citations as of June 6, 2007 (total): 272

# of citations as of June 6, 2007 (unique): 15

Total number of unique citations from MEDLINE search: 3722