# Appendixes

Appendix A: Search Strategy

Appendix B: Data Abstraction Forms

Appendix C: Additional Analyses for Systematic Review

Appendix D: List of Excluded Studies

Appendix E: Technical Expert Panel and Peer Reviewers