# Summary Tables

Summary Table 1. Level of Use of Interactive Consumer Health IT (KQ 1)

Author, Year Design, N | Condition and/or Population | Interactive Health IT | Findings: Technology Usage | Usage Comments
An, 2006^26^ Cohort, N=47 Experimental arm of RCT, N=257 | Smoking College students | Web-based self-monitoring and goal setting; discussion board; quiz with tailored feedback; weekly email reminders; Question of the Week; peer coach emails weekly if not completing tasks | Website use by study: Pilot: % subjects using site was 53%, 21% and 26% for weeks 1, 2, and 5, respectively RCT: mean 95% over 20 weeks (range, 89% to 98%) | Subject proportion usage
Bachofen, 1999^27^ Cohort study N=21 | Obsessive-compulsive disorder | IVR self-management; IVR calls after reading a 190-page manual on ERP (clinician-guided exposure and ritual prevention) | Subjects used system mean 67.2 +/- 38.3 days 22 days for self-assessment; 45 days for ERP | Limited-time intervention; Unclear inteneded use; Mean time used reported
Cathala, 2003^28^ Cohort, N=140 | Prostate cancer; post-op radical prostatectomy | Web-based access to hospital medical records, secure messaging with surgical team, monitoring PSA level, and answer questions | Website use over 6 months: 95% “regularly connected”, mean logons 8/subject (range: 1–22); Mean 2 PSA entries/subject; Mean 2 messages/subject | 58% subjects described as “senior executives”; Usage Estimate: 1.3 logins/subject/month
Cavan, 2003^29^ Cohort, N=6 | Type I Diabetes | Web-based monitoring blood glucose and insulin use; food diary; feedback with glucose level simulation; patient decision support for insulin dosing | Website use over 6 months: 1 of 6 subjects input 4 days' data on 3 occasions first month (study request). No input for several wks; Subjects input mean of 5 sets of data (range: 2–8) | Unable to estimate frequency
Cruz-Correia, 2007^30^ Randomized, cross-over study, N=21 | Asthma | Web-based self-monitoring of peak flow and symptoms; tailored action plan; decision support tool for patients and physician; Compared to paper-based monitoring | Website use during 4 week periods: variable monitoring, about half of scheduled monitoring conducted; paper tools more likely complete | Unable to estimate frequency
Delgado, 2003^31^ Cohort, N=6 | Congestive heart failure | Web-based self-monitoring of weight, BP, medication; secure messaging with providers; educational content | Website use over 3 months: Mean 73 logons/subject | Poor description of use over time; Usage Estimate: 22 logins/subject/month
Earnest, 2004^32^ Randomized trial, N=107 | Congestive heart failure | Web-based access to electronic records, secure messaging with clinical team; educational content | Website use over 1 year (N= 54): 80% used once or more, mean 8 hit-days/subject; Results suggest use associated with White, Non-Hispanic, more symptoms, more clinic visits (NS) | Usage Estimate: 0.7 logins/subject/month
Finkelstein, 1996^33^ Cohort, N=41 | Lung transplant | Web-based self-monitoring of symptoms, vital signs and automated spirometry readings; symptom diary; weekly transmission to clinicians | Monitoring over 1 year: 82% submitted weekly data; 8941 transmissions by 41 subjects, for mean of 4.5 records/week sent; Initial 6.2 records/wk, remained >3.9 records/wk for 43 weeks | Usage Estimate: 16 logins/subject/month
Glasgow, 2003^34^ Randomized trial, N=320 | Type II Diabetes | Web-based educational content, dietary goal setting (Basic); with glucose monitoring and feedback, online coach 2×/wk, Q & A forum (Self-Mgmt Condition); with online peer support monitored, e-news (Peer Support Condition) | Website use over 10 months: Highest in months 1–3, continued drop months 4–6 and 7–10; Mean logons/subject/month with Peer Support 18.7, with Self-Mgmt 16.7, with Basic 9.4 and 11.4; Use higher in Peer Support for months 4–6 (13.2) and 7–10 (6.7) | Usage Estimate: 18.7 logins/subject/month
Gustafson, 1994^35^ Randomized trial, N=204 | HIV/AIDS | CHESS: computerized information and problem-solving, Q & A, ask an expert, health profile, peer discussion group, personal stories, decision aids | Use over 3 to 6 months (N= 116): 116 subjects used 15,966 times; Mean 138 uses/subject; Mean time use 39 hrs/subject; 34% of use occurred 9 pm – 7 am; 73% of use was peer discussion, 17% was information and 4% was problem-solving; Use 13% more in women; Minorities used discussion slightly less and information slightly more | Usage Estimate: 23 logins/subject/month
Gustafson, 1998^36^ Cohort, N=38 | Breast cancer | CHESS: computerized information and problem-solving, Q & A, ask an expert, health profile, peer discussion group, personal stories, decision aids | Use over 10 weeks: Mean 6.8 uses/week/subject; 100% used discussion group, ask an expert, Q & A, health profile; 71% of uses for social support, 16% of uses for information | Usage Estimate: 27 logins/subject/month
Japuntich, 2006^37^ Randomized trial, N=284 | Smoking | CHESS: web-based information and problem-solving, discussion group, chat room, Q & A, ask an expert, mood self-management | Use over 12 wks (N=140): Use declined over period; Mean logins 33.6/subject ; Mean total time on 486.4 min; Support tools (discussion, chat) used most and information least; Gender, race, education not associated with use; older age correlated with greater use | Usage Estimate: 11.2 logins/subject/month
Jones, 1999^38^ Randomized trial, N=525 | Breast, cervical, prostate or laryngeal cancer | Computer touch-screen access to general (N=167) or personalized (n=93) information including electronic record, explanation of content, print-outs | Program use over 3 months: Mean time use was 12 minutes; 29% returned to use program; 11.8% with personalized information used after wk 3, vs. 2.6% with general information | Unclear inteneded use; Mean time use reported; Subject proportion usage
Jones, 2001^39^ Randomized trial, N=112 | Schizophrenia | Computer touch-screen access to general or personalized information including electronic record, explanation of content, feedback displays, print-outs | Program use: Median time for 5 sessions 69 min (range 34–143) | Limited-time intervention; Median time use reported
Kashem, 2006^40^ RCT N=36 | Congestive heart failure | Web-based self-monitoring weight, vitals, medications, graphic data feedback, patient-provider text messaging | Patient data entry: 1,253 Patient text messaging: 362 Provider non-tailored messages: 836 Provider tailored text messages: 416 Total Internet interactions: 2,867 | Transactions reported; unable to measure frequency
Leu, 2005^41^ Randomized trial, N=50 | Type I & II Diabetes | Wireless paging and messaging: automated reminders of subject's choice (e.g. check glucose, eat, take Rx, exercise), 2-way text messaging | Use over 3–6 months (N=25): 12,025 messages sent to subjects, with 1,676 responses; 114 additional messages sent from subjects, 16 needing action | Usage Estimate: < 1 message/subject/month
Lorig, 2006^42^ Randomized trial, N=958 | Heart disease, Type II diabetes, or chronic lung disease | Web-based self-management, with bulletin board, discussion group, educational information, weekly postings and moderated activities for 6 weeks, buddy support by email, email reminders to participate | Website use over 1 year (N=354): Mean logon 26.5 times/subject (range 0–177); 8 never logged on; | Usage Estimate: 17.7 logins/subject/month
Ma, 2006^43^ Cohort, N=12 | Type II Diabetes | Diabetes Information Profile (DIP): info tailoring and priority algorithms; Quiz Service: quiz tailoring and priority algorithms; Agenda Service: agenda algorithms. | Website use over 3 months: Median login 6 times/subject (range 2–15); total logins 82; 82 of 257 information items visited for 10 sec or more; 1 of 12 subjects made an agenda; of 5 subjects using quizzes, mean 61.8 questions conducted | Usage Estimate: 2 logins/subject/month
Mckay, 2001^44^ Randomized trial, N=78 | Type II Diabetes who were sedentary | Web-based self-management, goal physical activity setting, tailored and graphic feedback, online coaching, peer discussion group; Control condition basic website | Use over 8 weeks: Total logons 341 for full program vs. 105 for informational website; Mean logon/wk 1.1 vs. 0.3; Mean group posting 1.1/subject; Mean messg to coach 2.1/subject; Use declined from mean 2.7 logons/subject/wk first 2 weeks to 0.5 in last 2 weeks | Usage Estimate: 4.4 logins/subject/month
Nguyen, 2003^45^ Cohort, N=16 | Chronic obstructive pulmonary disease | Web-based self-management with exercise monitoring, goal setting and feedback, pulmonary function and symptom monitoring, weekly education, peer and professional chat, bulletin boards, email | First month registered most logins (330) compared to 104 in the final month | Unable to estimate frequency
Owen, 2005^46^ Cohort, N=62 | Breast cancer | Web-based self-guided training for coping skills, posted exercises every 2 weeks, bulletin board, discussion group, symptom management, educational information, email reminders | Use over 12 weeks: Mean 35.5 total logins/subject; Mean 9.5 bulletin posts/subject; Coping skills component highest use for 8 weeks then steep drop; Bulletin board had highest continuous use | Usage Estimate: 11.8 logins/subject/month
Piette, 1997^47^ Cohort, N=65 | Diabetes | Automated voice messaging to communicate messages, collect information, and identify concerning issues (promting a clinician telephone call) | AVM contact over 4 weeks: 3.3 out of 4 calls completed; 57% contacted all 4 wks, 23% contacted 3 of 4 wks, 15% contacted twice, 5% contacted once | Subject proportion usage
Pike, 2007^48^ Cohort, N=NR | Smoking | Recruitment to an interactive, tailored website | Wide variation in website use; 3 sites had higher use (20% or more subjects making 5 or more visits) and 3 had lower use (<10% make 5 or more visits); non-ITT quitting was 26% vs. 22.1% in high vs. low site use. | Subject proportion usage
Rasmussen, 2005^49^ Randomized trial, N=300 | Asthma | Web-based self-monitoring, input peak flow and symptoms, tailored action plans feedback, decision support for clinicians, email if treatment changes needed | Website use over 6 months: Mean use of self-management tool was 4 times in 2-week periods (range, 1–6) | Usage Estimate: 8 logins/subject/month
Reid, 2007^50^ Randomized trial, N=99 | Smokers with heart disease | Interactive voice response after discharge from hospital on day 3, 14 and 30. If subject wanted to quit or had confidence <7 (out of 10), nurse counselor called 3 times over 8 week period | IVR contact (N=50): Day 3, 35/50 (70%) Day 14, 36/50 (72%) Day 30, 34/50 (68%) | Subject proportion usage
Ross, 2004^51^ Randomized trial, N=107 | Congestive heart failure | Web-based access to electronic records, secure messaging with clinical team; educational content | Website use over 1 year (N=54): 43 subjects logged in 581 times; Use highest during month 1 to 3, thereafter 24% used it monthly; Subjects most frequently viewed clinical notes and lab results, and education guide was viewed least; 41 subjects sent 63 e-messages; Message categories: appointment 20%, refills 15%, Rx question 14%, tests 12%, feeling ill 8%, info 3% | Usage Estimate: 0.9 logins/subject/month
Ruland, 2003^52^ Randomized trial, N=52 | Cancer | Computerized touch-screen shared decision support for patients and clinicians, on patient symptoms, functional problems, and preferences, printed rank-order summary used for shared clinical decision-making | Use of decision tool: Median time 9 min to complete (range 0.5–49 minutes); 25% of subjects used <5 minutes | Limited-time intervention; Median time use reported
Shaw, 2007^53^ Randomized trial, N=231 | Breast cancer Underserved | CHESS: Web-based information, discussion group, ask an expert, and interactive services (tailored action plan, decision aids, health tracking | Use over 4 months, by category: Mean use discussion 506.2 min; Mean use information 35.5 min; Mean use ask an expert 28 min; Mean interactive service 27.9 min | Minutes used, not frequency
Smith, 2000^54^ Randomized trial, N=30 | Diabetes Rural women | Computer with web-based health and diabetes information. ‘health chat’ self-management training, monitored discussion group, ‘Mailbox’ private email, structured classroom, Q & A, bulletin board | Website use over 5 months: Mean use time 63.8 min/month; First month use 129 min, then mean time declined to 68, 78, 44, an 37 min for month 2 through 5; Highest use for discussion group, mean 111 times/subject total; Mailbox (email) 40 times/subject; Self-mgmt 38 times/subject | Minutes used, not frequency
Tsang, 2001^55^ Randomized cross-over study, N=20 | Diabetes | Computer diabetes monitoring with food diary and nutritional feedback, blood glucose monitoring, messaging to and from clinicians | Use over 6 months (N=19): Transmissions per week reported as >7/week by 15.8%, 5–6 by 10.5%, 3–4 by 21%, 1–2 by 36.8%, and <1 by 15.8% | Subject self-report
van den Brink, 2005^56^ Cohort, N=36 | Head and neck cancer | Web-based secure messaging, health and cancer information, support group forum, monitoring by questionnaire, e-mail alerts for concerning responses | Use over 6 weeks: Total sessions 982, with mean sessions/subject 273 (range 4–69); Sessions lasted mean 12 mins; 16% occurred after office hours; Use of functions: monitoring 100%, ask questions 64%, read messages 75%, contact subjects 8%, review information 61% | Usage Estimate: 5 logins/subject/month

Abbreviations

< X = less than X

> X = greater than X

≥ X or ≤ X = greater than or equal to X or less than or equal to X

BP = blood pressure

CHESS = Comprehensive Health Enhancement Support System

DIP = diabetes information profile

mgmt = management

min(s) = minute(s)

PSA = prostate-specific antigen

Q&A = question and answer

RCT = randomized controlled trial

Rx = precription

sec(s) = second(s)

TBD = to be determined

wk(s) = week(s)

Summary Table 2. Usability of Interactive Consumer Health IT (KQ 2)

| | | Usability Outcomes
Author, Year, Design, N | Condition | Intervention/Technology Type | Useful (technology elements) | Problematic technology elements | Ease of Use | Satisfaction
Andersson, 2002^94^ RCT, N=44 | Headaches | Therapist initiated telephone contact via the internet | Gradual introduction Attractive User involvement in development Familiar tools Controllability | Contrast, color, button size, graphics | Helpfulness Learn ability | Efficiency Global Usability
Anhoj, 2004^63^ Qualitative, N=231 | Asthma | Website with tailored feedback and support | One-click access to frequently used items | Distracting news, flashy graphics, opinion polls | NR | NR
Bond, 2006^64^ Qualitative Study, N=35 users; 52 surveyed | Diabetes | Tailored self-management instruction, chat/discussion, bulletin boards, advice, counseling, log of self-management activities, and information | Tailored program greatly increased usability | Size, graphics | NR | NR
Carroll, 2002^65^ Qualitative Study, N=14 | Type II Diabetes | Specifically usability testing; CV risk prevention; used in clinic; qualitative interviews comparing designs and interfaces. | Plain, simple backgrounds for display Using pie charts | Concern about clarity of information | NR | 86%
Cavan, 2003^29^ Cohort, N=16 | Type I Diabetes | Web-based, feedback, patient decision support | NR | Data entry screens hard to follow | NR | NR
Chen, 2006^66^ Qualitative Study, N=77 | Smoking (Cessation program) | Smoking cessation program (classroom), and Internet-assisted instruction program | Very easy to use | NR | Difficulty: 1.36 out of 7 (very low difficulty) | Very helpful in quitting smoking
Cleland, 2007^67^ Qualitative Study, N=12 | Asthma | Electronic peak flow meter linked to a mobile phone with an interactive screen to record current asthma symptoms transmitted to and stored in a server | Fast, easy to use, time saver | Problematic cable attachments and data head, sensitivity of Piko meter, absence of a good cell signal | Very easy to use | Staff agreed that technology was easy to use and wildly popular with pts
Crosbie, 2006^68^ Qualitative Study, N=20 | Stroke | Stroke rehabilitation, user moves arms and hands in a virtual environment and interacts with familiar objects | VE allowed pts with limited movement to experience sense of ‘presence’ | Virtual reality made some of the healthy users motion sick | Easy to use | Very satisfied
Cruz-Correia, 2007^30^ RCT, N=21 | Asthma | Web-based self-monitoring, tailored action plan; decision support | East to record data, view data, | User interface issues, difficult to interpret content | Useful | Like it
Delgado, 2003^31^ Cohort, N=6 | Congestive heart failure | Web-based, secure messaging, educational content | Reliable responses from clinic Good quality of care | NR | Easy to use | Useful
Feil, 2000^69^ Qualitative Study, N=160 | Type 2 Diabetes | D-Net intervention: peer social support and personalized dietary intervention | NR | Computer was initial barrier to program participants | NR | NR
Finkelstein, 1996^33^ Qualitative Study, N=41 | Post Lung Transplant patients | Electronic spirometer/diary (patient daily self-measurements of standard spirometry, vital signs, and symptoms recorded at home) | NR | Very few phone calls, only tech glitches were in the original developmental stages of device | All patients able to record daily entries | NR
Finkelstein, 1998^70^ Qualitative Study, N=17 | Asthma/underserved | Symptom diary and spirometry test | NR | NR | Not complicated at all, very easy to use | NR
Friedman, 1997^71^ Qualitative Study, N=516 | Elderly/Chronically III | TLC: carries out automated, telephone-based health care encounters with patients in their homes | NR | NR | Majority found it very easy to use | Satisfied, made more aware of disease/alleviated worries about disease
Gerbert, 2003^95^ Randomized Trial, N=52 | Smoking & Alcoholism (48% AA; 12%Latino; low income) | Brief motivational video risk assessment with tailored advice | Convenience (right amount of time;5.7 / 7); privacy(5.95/ 7 pts); confidential (5.9/7pts); honest (6.94/7 pts) | 71% would feel more comfortable with a “real” doctor. | 6.8 on 7 pt scale | 5.7 on 7pt scale
Glasgow, 2003^34^ Qualitative Study, N=320 | Diabetes Mellitus | Computer assessed, analyzed, and presented feedback on patients' dietary patterns, barriers to and support for dietary self-management, and tailored dietary fat reduction goal | NR | NR | NR | NR
Gomez, 2002a^72^ Qualitative, N=NR | HIV/AIDS | Web based self monitoring system for HIV/AIDS patient care | Graphics | NR | NR | NR
Gomez, 2002b^73^ Qualitative, N=NR | HIV/AIDS | Web based self monitoring system for HIV/AIDS patient care | Reliable | NR | Easy to use Easy to learn | Good efficiency
Gustafson, 2001^74^ Qualitative Study, NR | HIV/AIDS, breast cancer | Elderly, have/had cancer, not specific to one study!! | NR | NR | NR | NR
Holman, 1996^96^ Randomized, cross-over, N=6 | Diabetes | Hand held computer for self management and to make treatment recommendations | Convenient to use | NR | Easy to use | Enjoyed using the system Wanted to continue
Jones, 2001^39^ RCT, N=112 | Schizophrenia | Computer touch-screen, electronic record, feedback displays | Touch screen easy to use | Some displays confusing | Easy to use | NR
Kaufman, 2003^75^ Qualitative, N=25 | Diabetes | Videoconferencing, vitals upload and review, education, email | NR | Patient tutorial needs revision; creation of a field training program | NR | NR
Kenwright, 2004^97^ Cohort, N=27 | Phobia or Panic Disorder | FearFighter - Internet self-help system | | | “generally felt comfortable using the system” | (70% satisfied with an Internet Intervention)
Kerkenbush, 2003^76^ Qualitative Study, NR | DM | Track blood glucose levels, dietary intake, and activity level | NR | NR | Easy to use | NR
Kim, 2005^77^ Qualitative Study, N=42 | Diabetes Mellitus | Access a website via their mobile phone or Internet and input their blood glucose levels every day; patients were sent the optimal recommendations by both the mobile phone and the internet | NR | NR | Easy to use | Very satisfied
Kim, 2007^78^ Qualitative Study, N=33 | Diabetes Mellitus | Nurse short message service by mobile phone and internet on glycosylated hemoglobin (HbA1c) levels and adherence to diabetes control recommendations; patients input information and were sent weekly recommendations | NR | NR | NR | NR
Kosma, 2005^79^ Qualitative Study, N=25 | Physical Disability | Web-based physical activity motivational with and without discussion, weekly motivational messages | NR | NR | 4.5 out of 5 | Helpful: 3.4/5
Kressig 2002^98^ Cohort, N=34 | Physical activity for elderly | computer system for exercise promotion (questionnaire with tailored recommendations) | | Most problems had to do with survey issues, not computer. 22% questions were mouse related. | 4.6/5pt | 21.45/24pts on acceptability of recommendation
LaPlante-Levesque, 2006^80^ Qualitative Study, N=3 | Impaired hearing/hearing loss | Email communication between a new hearing aid user and the audiologist or from the audiologist to the client | All seemed ‘comfortable’ with the program-study is broken down into experience of each individual | NR | NR | NR
Leu, 2005^41^ RCT, N=50 | Type I & II Diabetes | Wireless messaging, automated reminders | Pager useful | NR | NR | Enjoyed using pager Wanted to continue (68%)
Liu, 2005^81^ Qualitative Study, N=274 | Type II Diabetes | POEM: Education management system: patient specific educational materials, medication data, and laboratory test results, as well as reminders with emails and short messages via cell phone | NR | NR | NR | NR
Lober, 2006^82^ Qualitative Study, N=38 | Elderly | Personal health records with areas for communication with health professional | Ability to print out PHR | Visibility, icon size, graphics | NR | NR
Ma, 2006^43^ Cohort, N=12 | Type II Diabetes | Information tailoring, question tailoring | System was useful System is relevant | None | Easy to use | Would recommend system to others
McDaniel, 2002^99^ Cohort, N=110 | Smoking; Low income women | Interactive smoking cessation software | | technology malfunctions; software errors | | 60.2 / 70pts; minority participants more satisfied
McKay, 2001^44^ RCT, N=78 | Type II Diabetes, sedentary | Web-based, tailored and graphic feedback, peer discussion | No difference between groups in helpfulness of the PA section or relevance of the program | NR | No difference between groups in ease of use | NR
McPherson, 2006^100^ Randomized Trial, N=101 | Children with Asthma | Multimedia educational program | | | | 35 / 37 felt is was a good way to learn about asthma; 31 / 37 felt they learned more from using the computer
Piette, 1997^47^ Cohort, N=65 | Diabetes | Voice messaging | No difficulty entering answers into touchtone system | NR | No difficulty understanding the messages | Calls very or somewhat helpful Wanted to continue
Ralston, 2004^83^ Qualitative Study, N=9 | Diabetes Mellitus | Living with diabetes program: web-based disease management module to support care | NR | NR | NR | NR
Reed, 2005^84^ Qualitative Study, N=NR | Diabetes Mellitus | Not specified, website review; www.diabetes-insight.info | Easy to navigate and comprehensive Few advertisements | NR | NR | NR
Ruland, 2003^52^ Randomized trial, N=52 | Cancer | Computerized touch-screen shared decision support and decision-making | Use of touch pad system without assistance System a useful tool | Not rated positively: Learning to use the computer To get it to do what I want Clear and understandable on how to operate Can become skillful using the computer | Questions easy to answer Do not find it overall easy to use | NR
Schäer, 2002^85^ Qualitative Study, N=600 | Bipolar Disorder | PDA; Patients encouraged to report most manic and depressive state not only in the presence of mood swings, information analyzed and sent to patient via email or paper | Experience with PDAs | PDA intimidating to novices at beginning | All expressed satisfaction with ease and use of IT | All expressed satisfaction with ease and use of IT
Sciamanna, 1999^101^ Qualitative Study, N(Pilot)=29, N(Study B)=503 | Smoking | Patients answer questions, these are analyzed and patient provided with tailored quit-smoking material, also physicians provided with information to help counsel patients | NR | NR | Easy to use | NR
Sciamanna, 2004^86^ Cohort, N=150 | Smoking & physical activity | Computer assessment with tailored printed feedback | NR | NR | Easy to use | NR
Sciamanna, 2005^102^ Quasi-experimental, N=121 | Osteoarthritis | Computer assessment with tailored feedback about OA and OA care | NR | NR | Easy to use | Most rated IT excellent or very good, no one rated as fair or poor
Shaw, 2000^87^ Qualitative Study, N=20 | Breast Cancer | CHESS | NR | NR | Found easy to use | NR
Skeels, 2006^88^ Cohort, N=30 | HIV+ | CARE+ Tablet PC counseling | NR | Tablet PC screen difficult to see Radio buttons Confusion on how to use tablet PC | NR | NR
Smaglik, 2008^89^ Qualitative Study, N=36 | HIV/AIDS | HIV CHESS support groups | NS | NS | NS | NS
Tsang, 2001^55^ Randomized cross-over study, N=19 | Diabetes | Hand-held electronic diary with touch screen | NR | Technical issues | 95% felt system was easy to use | NR
van den Brink, 2003^90^ Qualitative Study, N=NR | Head and Neck Cancer | Not specified-summary of electronic information system | NR | NR | NR | NR
van den Brink, 2005^56^ Cohort N=36 | Head & neck cancer | Electronic health information support system | NR | Technical issues | NR | NR
van't Riet, 2001^91^ Qualitative Study, N=14 families | Amblyopia | Interactive computer system that helps with communication between patients, their parents and caregiver | NR | NR | NR | NR
Wilkie, 2001^58^ Descriptive, N=41 | Cancer | The Symptom Report program was designed as an interactive, touch-screen method for assessment of pain and fatigue. | NR | NR | System was easy to use | NR
Yeh, 2006^92^ Qualitative Study, N=274 | Diabetes Mellitus | POEM: Education management system: patient specific educational materials, medication data, and laboratory test results, as well as reminders with emails and short messages via cell phone | NR | NR | NR | NR
Zimmerman, 2004^93^ Qualitative Study, N=52 | CABG/Elderly (≥65 yrs) | CABG patients access web for daily information on recovery, provider can observe patients' progress at home | NR | NR | NR | NR

Abbreviations

< X = less than X

≤ X or ≥ X = less than or equal to X or greater than or equal to X

> X = greater than X

BP = blood pressure

CABG = coronary artery bypass graft

CHESS = Comprehensive Health Enhancement Support System

CV = cardiovascular

DM = diabetes mellitus

HgBA1c = glycosylated hemoglobin

NR = not reported

NS = not significant

OA = osteoarthritis

PA = peer assessment

PDA = personal digital assistant

PHR = personal health records

RCT = randomized controlled trial

TBD = to be determined

VE = virtual entertainment

Summary Table 3. Barriers to Use of Interactive Consumer Health IT (KQ 3)

Author, Year, Design, N | Condition and/or Population | Interactive Computer Technology (ICT) | Barriers
Anhoj, 2004^63^ Qualitative, N=231 | Asthma | Website with tailored feedback and support | - Doctors reluctant due to time constraints; - Did not fit into patients' everyday lives; - Used inefficiently; - Contradictory information, caused disbelief and results with not follow the advice; - Access to the Internet; - The benefits are not immediate; - Lack of trust with virtual expert
Artinian, 2003^106^ RCT, N=18 | Congestive heart failure | Video cassette monitoring connected to telephone line | - 44% hated it; - Perception that they had to build their life around the monitor/reminder; - Nuisance and intrusive; - 44% had technical problems; - Difficult to get small pills; - Text on screen too small; color contrast difficult to read; needed longer message for clarity
Bond, 2006^64^ Qualitative Study, N=35 users; 52 surveyed | Diabetes | Tailored self-management instruction, chat/discussion, bulletin boards, advice, counseling, log of self-management activities, and information | - Lack of computer experience and lack of personal instruction; - Non-tailored device/program (in this case, larger text/icons and physical limitations such as double-clicking the mouse had to be implemented); - Lack of access to a computer (computers were given/installed for free in patient's homes in this study)
Carroll, 2002^65^ Qualitative Study, N=14 | Type II Diabetes | Specifically usability testing; CV risk prevention; used in clinic; qualitative interviews comparing designs and interfaces. | - Visibility; - Lack of computer skills
Cathala, 2003^28^ Cohort, N=140 | Prostate cancer; post-op radical prostatectomy | Web-based monitoring with messaging | - 11% had connection problems; - 14% had technical problems; - Physician email not reimbursed
Cavan, 2003^29^ Cohort, N=16 | Type I Diabetes | Web-based, feedback, patient decision support | - Took too much time; - Internet connection interruption caused loss of data
Chen, 2006^66^ Qualitative Study, N=77 | Smoking (Cessation program) | Smoking cessation program (classroom), and Internet-assisted instruction program | - Lack of computer skills; - Cost
Cleland, 2007^67^ Qualitative Study, N=12 | Asthma | Electronic peak flow meter linked to a mobile phone with an interactive screen to record current asthma symptoms transmitted to and stored in a server | - Lack of familiarization with mobile phone technology; - Failure of technology to work on several occasions; - Problems with cable attachments and data head (incomplete transfer of information); - Absence of a good cell signal (inhibited data transmission/sent reminders to patients to send data, if they had recorded it previously-frustrated some to receive redundant reminders); - Sensitivity of Piko meter (suggests in study that unusually high readings indicate that pts ‘spat rather than blew into the Piko meter’)
Crosbie, 2006^68^ Qualitative Study, N=20 | Stroke | Stroke rehabilitation, user moves arms and hands in a virtual environment and interacts with familiar objects | - Cost; - Side effects associated with technology (in the case of VE, healthy patients experience headaches, sweating, nausea, disorientation, and balance disturbance); - Delays
Cruz-Correia, 2007^30^ Randomized cross-over study, N=21 | Asthma | Web-based self-monitoring, tailored action plan; decision support | - Technical problems - 9/16 reported problems; Internet connection issues (9), system errors (3), peak flow meter batteries (5), meter technical problems (2); - Difficult data input for monitoring systems; - Poor graphic feedback
Delgado, 2003^31^ Cohort, N=6 | Congestive heart failure | Web-based, secure messaging, educational content | - Technical problems - system down for 24 hours during 3 months
Earnest, 2004^32^ Randomized trial, N=107 | Congestive heart failure | Web-based records, secure messaging, educational content | - Not comprehending medical jargon; - Watered down or “sugar-coated” information
Feil, 2000^69^ Qualitative Study, N=160 | Diabetes Mellitus | D-Net intervention: peer social support and personalized dietary intervention | - Cost of computer/internet; - Lack of computer/internet skills; - Computer anxiety
Finkelstein, 1996^33^ Qualitative Study, N=41 | Post Lung Transplant patients | Electronic spirometer/diary (patient daily self-measurements of standard spirometry, vital signs, and symptoms recorded at home) | - Lack of computer/internet skills; - Cost of computer/internet; - Failure to replace mouthpieces weekly
Finkelstein, 1998^70^ Qualitative Study, N=17 | Asthma/underserved | Symptom diary and spirometry test | - Lack of computer/internet skills; - Cost; - Limited personal instruction
Friedman, 1997^71^ Qualitative Study, N=516 | Elderly/Chronically Ill | TLC: carries out automated, telephone-based health care encounters with patients in their homes | - Lack of human interaction
Gerbert 2003^95^ Randomized Trial, N=52 | Smoking & Alcoholism | Brief motivational video risk assessment with tailored advice | - 71% would feel more comfortable with a “real” doctor.
Glasgow, 2003^34^ Qualitative Study, N=320 | Diabetes Mellitus | Computer assessed, analyzed, and presented feedback on patients' dietary patterns, barriers to and support for dietary self-management, and tailored dietary fat reduction goal | - Cost; - Level of commitment; - Lack of long-term weight loss intervention success
Gomez, 2002b^73^ Cross Over, N=NR | HIV/AIDS | Web based self monitoring system for HIV/AIDS patient care | - No battery checking software; - Low reliability of research system; - Required technical personnel at hospital for support during trial; - Required training users on when to call for technical support
Gustafson, 2001^74^ Qualitative Study, NR | HIV/AIDS, breast cancer | Elderly, have/had cancer, not specific to one study!! | - Cost; - Lack of internet/computer; - Lack of computer skills
Jones, 2001^39^ Randomized trial, N=112 | Schizophrenia | Computer touch-screen, electronic record, feedback displays | - Some preferred the nurse because of a “personal touch,” empathy, and talking rather than reading; - Bringing pts into the clinic for the touch screen computer was too costly for schizophrenia treatment
Kaufman, 2003b^75^ Qualitative Study, N=25 | Diabetes | IDEATel project; web-based diabetes diary (Diabetes Manager) that allows patients to track their own progress for five variables: BP, glucose, medications, exercise, and viewing Hgba1c; Videoconferencing, electronic transmission of glucose and blood pressure readings, secure email, web-based review of clinical data, access to web-based educational material | - Literacy and numeracy; - Visibility; - Psychomotor skills associated with keyboard/mouse use; - Lack of computer skills; - Numerous technical difficulties
Kenwright, 2004^97^ Cohort, N=27 | Phobia or Panic Disorder | FearFighter - Internet self-help system | - 3/10 would prefer face-to-face with doctor
Kerkenbush, 2003^76^ Qualitative Study, NR | DM | Track blood glucose levels, dietary intake, and activity level | - APNs have to evaluate patients to identify ideal candidates for PDAs (excluding people who have little PDA experience); - Cost; - Technological demands; - The fact that PDAs operate on batteries and sometimes when they run down completely the entire memory is lost
Kim, 2005^77^ Qualitative Study, N=42 | Diabetes Mellitus | Access a website via their mobile phone or Internet and input their blood glucose levels every day; patients were sent the optimal recommendations by both the mobile phone and the internet | - Lack of mobile phone technology skills; - Cost
Kim, 2007^78^ Qualitative Study, N=33 | Diabetes Mellitus | Nurse short message service by mobile phone and internet on glycosylated hemoglobin (HbA1c) levels and adherence to diabetes control recommendations; patients input information and were sent weekly recommendations | - Lack of mobile phone/internet skills; - Cost
Kosma, 2005^79^ Qualitative Study, N=25 | Physical Disability | Web-based physical activity motivational with and without discussion, weekly motivational messages | - Patient adherence/motivation; - Lack of computer/internet skills
Kressig 2002^98^ Cohort, N=34 | Physican activity for elderly | computer system for exercise promotion (questionnaire with tailored recommendations) | - Age directly related to increased need for assistance.
LaPlante-Levesque, 2006^80^ Qualitative Study, N=3 | Impaired hearing/hearing loss | Email communication between a new hearing aid user and the audiologist or from the audiologist to the client | - Cost; - Time
Leu, 2005^41^ Randomized trial, N=50 | Type I & II Diabetes | Wireless messaging, automated reminders | - 44% found messages annoying; - Anticipating messages; - Messages too overwhelming; - Pager didn't work in all locations; - Messages not programmable by patients; - Security issues, was this HIPAA compliant
Liu, 2005^81^ Qualitative Study, N=274 | Type II Diabetes | POEM: Education management system: patient specific educational materials, medication data, and laboratory test results, as well as reminders with emails and short messages via cell phone | - Cost; - Lack of computer/internet skills; - Lack of cell phone
Lober, 2006^82^ Qualitative Study, N=38 | Elderly | Personal health records with areas for communication with health professional | - Lack of computer/internet; - Lack of computer/internet skills; - Literacy and numeracy; - Legal restrictions to PHR
Ma, 2006^43^ Cohort, N=12 | Type II Diabetes | Information tailoring, question tailoring | - Redundancy of information or information they already knew; - Well controlled DM; - Lack of computer at home
McDaniel, 2002^99^ Cohort, N=110 | Smoking; Low income women | Interactive smoking cessation software | - Participants with less than a high school eduction were less satisfied as were those not seriously thinking about quitting; - Technology malfunctions and software errors
McKay, 2001^44^ Randomized trial, N=78 | Type II Diabetes who were sedentary | Web-based, tailored and graphic feedback, peer discussion | - Only 33% found the peer-to-peer support group helpful; - Low number of people in support group, not enough for critical mass
Ralston, 2004^83^ Qualitative Study, N=9 | Diabetes Mellitus | Living with diabetes program: web-based disease management module to support care | - Lack of computer/internet skills; - Lack of computer/internet; - Unmet expectations of the program; - program was Incompatible with daily activities
Reed, 2005^84^ Qualitative Study, N=NR | Diabetes Mellitus | Not specified, website review; www.diabetes-insight.info | - Lack of computer/internet
Schärer, 2002^85^ Qualitative Study, N=600 | Bipolar Disorder | PDA; Patients encouraged to report most manic and depressive state not only in the presence of mood swings, information analyzed and sent to patient via email or paper | - Cost; - Visibility (small font)
Sciamanna, 1999^101^ Qualitative Study, N(Pilot)=29, N(Study B)=503 | Smoking | Patients answer questions, these are analyzed and patient provided with tailored quit-smoking material, also physicians provided with information to help counsel patients | - Cost of internet/computer; - Lack of computer/internet skills; - Program requires personal responses from patient
Sciamanna, 2004^86^ Cohort, N=150 | Smoking | Tailored printed feedback (primary care setting) on smoking & physical activity for patients and physicians | - Lack of review/discussion of report by physician with patient
Shaw, 2000^87^ Qualitative Study, N=12 | Breast Cancer | CHESS support groups | - Lack of computer/internet skills; - Lack of interest
Skeels, 2006^88^ Qualitative Study, N=30 | HIV/AIDS | CARE+; Tablet PC Counseling Tool for HIV+; medication adherence and secondary HIV prevention; observation & semi-structured interview after use Specifically designed to test barriers & drivers with HIV+ pts | - Visibility; - Lack of human interaction/counseling; - Unable to ask clarifying questions of questionnaire
Smaglik, 2008^89^ Qualitative Study, N=36 | HIV/AIDS | HIV CHESS support groups | - Lack of computer/internet skills
Taylor, 2006^107^ RCT, N=114 | Sleep apnea | HealthBuddy; CPAP adherence | - Telephonic delay between patient and practitioner
Turnin, 1992^108^ RCT, N=105 | Diabetes | Internet expert system for diabetes - Diabeto | - Cost
van den Brink, 2003^90^ Qualitative Study, N=NR | Head and Neck Cancer | Not specified-summary of electronic information system | - Lack of computer/internet skills; - Lack of interest in site content
van den Brink, 2005^56^ Prospective Study, N=36 | Head and Neck Cancer | Patient-provider messaging; forum; monitoring; email alerts | - Technical difficulties; - Lack of computer/internet skills; - Program technology not integrated into most GPs tech system
van't Riet, 2001^91^ Qualitative Study, N=14 families | Amblyopia | Interactive computer system that helps with communication between patients, their parents and caregiver | - Lack of computer/internet; - Cost; - Lack of time
Wilkie, 2001^58^ Qualitative Study, N=41 | Cancer | Cancer symptom control; Symptom report questionnaire; interactive tailored education | - Lack of computer skills; - Not a comprehensive questionnaire, only about pain
Yeh, 2006^92^ Qualitative Study, N=274 | Diabetes Mellitus | POEM: Education management system: patient specific educational materials, medication data, and laboratory test results, as well as reminders with emails and short messages via cell phone | - Lack of computer/internet skills; - Cost; - Literacy
Zabinski, 2001^59^ Pilot study, N=4 | Eating Disorders | Women at risk of eating disorders; synchronous Internet relay chat; based on cognitive behavioral treatment; facilitated by a moderator | - Lack of body language/facial expression feedback; - Unable to control distractions in home environment; - Unable to control forwarding of messages
Zimmerman, 2004^93^ Qualitative Study, N=52 | CABG/Elderly (≥65 yrs) | CABG patients access web for daily information on recovery, provider can observe patients' progress at home | - Lack of computer/internet skills; - Literacy/numeracy

Abbreviations

< X = less than X

≤ X or ≥ X = less than or equal to X or greater than or equal to X

> X = greater than X

APN = advanced practice nurse

BP = blood pressure

CABG = coronary artery bypass graft

CHESS = Comprehensive Health Enhancement Support System

CPAP = continuous positive airway pressure

DM = diabetes mellitus

GP = general practitioner

HgBA1c = glycosylated hemoglobin

HIPAA = Health Insurance Portability and Accountability Act

NR = not reported

PDA = personal digital assistant

PHR = personal health records

RCT = randomized controlled trial

TBD = to be determined

VE = virtual entertainment

Summary Table 4. Drivers and Facilitators of the Use of Interactive Consumer Health IT (KQ 4)

Author, Year, Design, N | Condition and/ or Population | Interactive Computer Technology (ICT) | Drivers
Andersson, 2002^94^ RCT, N=44 | Headaches | Therapist initiated telephone contact via the internet | Gradual introduction Attractive User involvement in development Familiar tools Controllability
Anhoj, 2004^63^ Qualitative, N=231 | Asthma | Website with tailored feedback and support | - Trustworthy and reliable technology; - Perception that an electronic asthma diary helps manage the disease
Artinian, 2003^106^ RCT, N=18 | Congestive heart failure | Video cassette monitoring connected to telephone line | - Reminders
Bond, 2006^64^ Qualitative Study, N=35 users; 52 surveyed | Diabetes | Tailored self-management instruction, chat/discussion, bulletin boards, advice, counseling, log of self-management activities, and information | - One-on-one instruction; - Tailored program
Carroll, 2002^65^ Qualitative Study, N=14 | Type II Diabetes | Specifically usability testing; CV risk prevention; used in clinic; qualitative interviews comparing designs and interfaces. | - Patient enthusiasm in gaining knowledge; - Empowering patient adherence to behavioral changes
Cathala, 2003^28^ Cohort, N=140 | Prostate cancer; post-op radical prostatectomy | Web-based monitoring with messaging | - People who already have Internet access are more likely to accept and even want to try the Web technology
Cavan, 2003^29^ Cohort, N=16 | Type I Diabetes | Web-based, feedback, patient decision support | - Increased confidence; - Not in good control; - Planning a long journey; - Weather changes
Chen, 2006^66^ Qualitative Study, N=77 | Smoking (Cessation program) | Smoking cessation program (classroom), and Internet-assisted instruction program | - Quit smoking; - Ease of use
Cleland, 2007^67^ Qualitative Study, N=12 | Asthma | Electronic peak flow meter linked to a mobile phone with an interactive screen to record current asthma symptoms transmitted to and stored in a server | - Intervention that uses a technological staple of society (thus, most pts were familiar with cell phone tech, and reported no problems); - Digital Piko meter also was though to reduce error, therefore yielding a more satisfactory result for both pts and clinicians
Crosbie, 2006^68^ Qualitative Study, N=20 | Stroke | Stroke rehabilitation, user moves arms and hands in a virtual environment and interacts with familiar objects | - Site of stroke that limits arm movement in the real world that can be remedied by VE; - Low levels of interaction between pt and environment; - Ineffective traditional paralysis therapy techniques; - Very small percentage of time actually spent by pts practicing traditional therapy tasks
Delgado, 2003^31^ Cohort, N=6 | Congestive heart failure | Web-based, secure messaging, educational content | - Technology available at any time needed
Earnest, 2005^32^ Randomized trial, N=107 | Congestive heart failure | Web-based records, secure messaging, educational content | - Perceived more control; - Perceived better communication with doctor; - Perceived increased participation in care; - Perceived increase in efficiency of getting information
Feil, 2000^69^ Qualitative Study, N=160 | Diabetes Mellitus | D-Net intervention: peer social support and personalized dietary intervention | - Availability of access to intervention through home computer via the internet; - Internet/computer competence
Finkelstein, 1996^33^ Qualitative Study, N=41 | Post Lung Transplant patients | Electronic spirometer/diary (patient daily self-measurements of standard spirometry, vital signs, and symptoms recorded at home) | - Daily self-reporting by transplant pts is critical for early detection of disease/illness
Finkelstein, 1998^70^ Qualitative Study, N=17 | Asthma/underserved | Symptom diary and spirometry test | - Perceived sense of security; - Importance of knowing that results were reviewed after test
Friedman, 1997^71^ Qualitative Study, N=516 | Elderly/Chronically Ill | TLC: carries out automated, telephone-based health care encounters with patients in their homes | - Increased awareness of disease; - Relieves worries about the disease
Gerbert 2003^95^ Randomized Trial, N=52 | Smoking & Alcoholism | Brief motivational video risk assessment with tailored advice | - Convenience (right amount of time;5.7 / 7); - Privacy(5.95/ 7 pts); - Confidential (5.9/7pts); - Honest (6.94/7 pts); - Felt they learned something new(4.9/7pts
Glasgow, 2003^34^ Qualitative Study, N=320 | Diabetes Mellitus | Computer assessed, analyzed, and presented feedback on patients' dietary patterns, barriers to and support for dietary self-management, and tailored dietary fat reduction goal | - Empowerment of individual (goal setting); - Focus on behavioral changes vs. weight loss
Gomez 2002a^72^ NR, N=NR | HIV/AIDS | Web based self monitoring system for HIV/AIDS patient care | - Anonymity; - Access to experts / 2nd opinions; - Perceived greater control over their situation; - Perceived improved health
Gomez 2002b^73^ NR, N=NR | HIV/AIDS | Web based self monitoring system for HIV/AIDS patient care | - Perceived improved glycemic control; - Better communication with doctor,; - Good DM education
Gustafson, 2001^74^ Qualitative Study, NR | HIV/AIDS, breast cancer | Elderly, have/had cancer, not specific to one study!! | - Accessibility of internet by many; - Ability of internet to more information to those who didn't originally have access (underserved populations)
Holman, 1996^96^ Randomized, cross-over, N=6 | Diabetes | Hand held computer for self management and to make treatment recommendations | - No increased worry about DM; - Monitoring data feedback
Jan, 2007^111^ RCT, N=176 | Asthma | Education, monitoring, self-management advice | - Fun; - Reminders
Jones, 2001^39^ Randomized trial, N=112 | Schizophrenia | Computer touch-screen, electronic record, feedback displays | - Short
Kaufman, 2003^75^ *Qualitative, N=25 | Diabetes | Videoconferencing, vitals upload and review, education, email | - Field training program; - Tutorial
Kenwright, 2005^112^ Randomized trial, N=44 | Obsessive compulsive disorder | Live help-line support during office hours | - Proactive, brief support by phone
Kerkenbush^76^ 2003, Qualitative Study, NR | DM | Track blood glucose levels, dietary intake, and activity level | - Tracking data on their own empowers patients and allows healthcare providers to guide appropriate care recommendations
Kim, 2005^77^ Qualitative Study, N=42 | Diabetes Mellitus | Access a website via their mobile phone or Internet and input their blood glucose levels every day; patients were sent the optimal recommendations by both the mobile phone and the internet | - Cost and time effectiveness of mobile device
Kosma, 2005^79^ Qualitative Study, N=25 | Physical Disability | Web-based physical activity motivational with and without discussion, weekly motivational messages | - Increase health; - Increase physical activity; - Motivational
Kressig 2002^98^ Cohort, N=34 | Physican activity for elderly | computer system for exercise promotion (questionnaire with tailored recommendations) | - More computer experience related to shorter response times and less need for assistance
LaPlante-Levesque, 2006^80^ Qualitative Study, N=3 | Impaired hearing/hearing loss | Email communication between a new hearing aid user and the audiologist or from the audiologist to the client | - Enables people to give feedback on their hearing aids and allows manufacturers/audiologist make appropriate adjustments/recommendations
Leu, 2005^41^ Randomized trial, N=50 | Type I & II Diabetes | Wireless messaging, automated reminders | - Perceived pager helped their health care to be better; - Reminders useful when unusual life events occurred; - Monitoring treatment changes; - Personal accountability
Liu, 2005^81^ Qualitative Study, N=274 | Type II Diabetes | POEM: Education management system: patient specific educational materials, medication data, and laboratory test results, as well as reminders with emails and short messages via cell phone | - Ability to review medical information; - Appointment reminders; - Access to education materials
Lober, 2006^82^ Qualitative Study, N=38 | Elderly | Personal health records with areas for communication with health professional | - Empowering patients to keep track of PHR; - Reassurance that PHR will remain intact electronically
Ma, 2006^43^ Cohort, N=12 | Type II Diabetes | Information tailoring, question tailoring | - Tailored information; - Newly diagnosed patients found information more helpful
McDaniel, 2002^99^ Cohort, N=110 | Smoking; Low income women | Interactive smoking cessation software | - Minority participants were significantly more satisfied with the computer program as well as those with more than a high school education and those who were thinking about quitting in the next month
McKay, 2001^44^ Randomized trial, N=78 | Type II Diabetes who were sedentary | Web-based, tailored and graphic feedback, peer discussion | - Tailored action plan with personal feedback; - Personal coach; - Lesson: focus on keeping people engaged
Nguyen, 2005^113^ NR, N=23 | COPD | Web site with activities information | - Perceived increase access to information
Owen, 2005^46^ Cohort, N=62 | Breast cancer | Web-based self-guided trainings, bulletin board, discussion group, symptom management, educational information, email reminders | - Low perceived health status; - More severe depressive and anxious symptoms; - Newly or recently diagnosed
Piette, 1997^47^ Cohort, N=65 | Diabetes | Voice messaging | - Convenience; - Fewer messages for younger patients (<55 years old)
Ralston, 2008^83^ Qualitative Study, N=9 | Diabetes Mellitus | Living with diabetes program: web-based disease management module to support care | - Empowerment of patient; - Non-acute concerns uniquely valued; - Enhanced sense of security about health/health care; - Providing valuable feedback
Reed, 2005a^110^ Qualitative Study, N=NR | Diabetes Mellitus | Not specified, website review; www.diabetes-insight.info | - Accessibility of information
Reed, 2005b^84^ NR, NR | Diabetes | Website with static information, email support groups, video Web cast interviews, transcripts and articles | - Patient specific information about insulin therapies
Rodgers, 2005^84^ RCT, N=1705 | Smoking | Tailored text messages | - Use of cell phones with younger individuals; - Low cost; - Distracting activities
Schärer, 2002^114^ Qualitative Study, N=600 | Bipolar Disorder | PDA; Patients encouraged to report most manic and depressive state not only in the presence of mood swings, information analyzed and sent to patient via email or paper | - Discrete; - Not a ‘stigmatizing’ tool
Sciamanna, 1999^101^ Qualitative Study, N(Pilot)=29, N(Study B)=503 | Smoking | Patients answer questions, these are analyzed and patient provided with tailored quit-smoking material, also physicians provided with information to help counsel patients | - Tailored quit-smoking materials; - Easy/fun to use
Sciamanna, 2004^86^ Cohort, N=150 | Smoking | Tailored printed feedback (primary care setting) on smoking & physical activity for patients and physicians | - Tailored printed feedback
Sciamanna, 2005^102^ Quasi-experimental, N=121 | Osteoarthritis | Web-tailored feedback and recommendations based on guidelines for osteoarthritis care | - Better care from doctors; - Try/recommend website to others
Shaw, 2000^87^ Qualitative Study, N=12 | Breast Cancer | CHESS support groups | - Anonymity within the support group fostered equalized participation
Skeels, 2006^88^ Qualitative Study, N=30 | HIV/AIDS | CARE+; Tablet PC Counseling Tool for HIV+; medication adherence and secondary HIV prevention; observation & semi-structured interview after use Specifically designed to test barriers & drivers with HIV+ pts | - Computer as “objective” and “non-judgmental”; - Privacy; - Accessibility and convenience
Smaglik, 2008^89^ Qualitative Study, N=36 | HIV/AIDS | HIV CHESS support groups | - Availability of support group via the internet; - Anonymity; - Availability of information; - Access to professionals who answer e-mails
Turnin, 1992^108^ RCT, N=105 | Diabetes | Internet expert system for diabetes - Diabeto | - 24 hour home access; - Free of charge
van den Brink, 2003^90^ Qualitative Study, N=NR | Head and Neck Cancer | Not specified-summary of electronic information system | - Accessibility and availability of information
van der Brink, 2005^56^ Prospective Study, N=36 | Head and Neck Cancer | Patient-provider messaging; forum; monitoring; email alerts | - Sense of security; - Enable communication between healthcare providers and patients
van't Riet, 2001^91^ Qualitative Study, N=14 families | Amblyopia | Interactive computer system that helps with communication between patients, their parents and caregiver | - Ability to access information and support from home
Wilkie, 2001^58^ Qualitative Study, N=41 | Cancer | Cancer symptom control; Symptom report questionnaire; interactive tailored education | - Enabling communication; - Beneficial for the novice patient
Yeh, 2006^92^ Qualitative Study, N=274 | Diabetes Mellitus | POEM: Education management system: patient specific educational materials, medication data, and laboratory test results, as well as reminders with emails and short messages via cell phone | - Ability to review medical information; - Appointment reminders; - Access to education materials
Zabinski, 2001^59^ Pilot study, N=4 | Eating Disorders | Women at risk of eating disorders; synchronous Internet relay chat; based on cognitive behavioral treatment; facilitated by a moderator | - Chat room forum; - Low cost
Zimmerman, 2004^93^ Qualitative Study, N=52 | CABG/Elderly (≥65 yrs) | CABG patients access web for daily information on recovery, provider can observe patients' progress at home | - Empowerment of patients to manage symptoms

Abbreviations

CABG = coronary artery bypass graft

CHESS = Comprehensive Health Enhancement Support System

COPD = chronic obstructive pulmonary disease

CV = cardiovascular

DM = diabetes mellitus

NR = not reported

PDA = personal digital assistant

PHR = personal health records

RCT = randomized controlled trial

TBD = to be determined

VE = virtual entertainment

Summary Table 5. Studies of Effectiveness of Interactive Consumer Health IT (KQ 5)

Author, Year Design, N | Patients | Intervention(s) | Comparison Group(s) | Duration, Setting | Outcomes | Quality Rating
Andrade, 2005^117^ RCT, N=64 | HIV/AIDS, initial Rx and failed Rx, good and poor memory; 42% female, 88% African American | Rx reminder device; reports to clinician; monthly counseling; auto- adherence monitor | monthly counseling; auto- adherence monitor | 24 week; Baltimore; (1999-2002) | Rx adherence 80% v 65% (NS) but in memory impaired subgroup 77% v 57% (p=.001); CD4 301 v 250 (NS); HV RNA decrease 1 log 72% v 41% (p=0.02); undetectable HIV RNA 34% v 38% (NS) | Fair
Araki, 2006^118^ RCT, N=36 | Alcoholic factory workers (GGTP high on screen); age 44 yrs | tailored email counseling | tailored face to face counseling; no counselling | 2 mos, 2 sessions; Tokyo | alcohol consumption and GGTP decreased, knowledge and attitude scores increased significantly in face to face group; nonsignificant or no change in email group or controls | Fair
Artinian, 2003^106^ RCT, N=18 | Heart Failure, 1 of 18 female, age ~ 68 yrs; LVEF<40, 61% African American | daily monitoring; reminding, daily clinician review and adjustment; (videocassette size device with meds and phone connection) | digital scale; BP monitor, logs, incentive pmts, educ booklet, HF clinic visits, pharmacist review meds | 3 mos, Virginia | both groups improved self-care, medication adherence, quality of life; neither changed 6 min walk, NYHA class; technical problems: ‘most pts did not follow our instructions”; 4/9 hated it, 5/9 loved it | Fair
Barnason, 2003^119^ RCT, N=18 | post CABG HF 24 Males 71 yrs (65–85 yrs) LVEF<40 NYHA I, II | daily monitoring Sx, standardized advice acc to Sx,reviewed by RN, education, encouragement; no human co-intervention (Health Buddy); telephone attachment with 4 buttons (Health Buddy) | 17 predischarge education re CABG, CAD RFs, exercise | 3, Midwestern hospitals larger study of 180 CABG patients | SELF EFFICACY 43.2 50.1 50.8 vs 43 45.7 47.4 CV RF MOD salt, exercise, stress adherence greater in TX; others not; MOS SF36 overall improvement across all scales, but baseline differences cloud the picture | Fair
Barrera, 2002^120^ RCT, N=160 | DM 2, 75 males; 59 yrs no internet access, has phone, speak English (of 650 sent letters) | www personal self mgmt coach (with data monitoring and review) vs www social support vs www coach plus support vs education only | none | 3, primary care Eugene Oregon | DM Support Scale CTRL 0.10 (1.14) CCH 0.90 (1.46) SS 1.39 (1.44) SS+CCH 1.20 (1.49) ISEL items CTRL -0.08 (0.52) CCH 0.08 (0.68) SS 0.45 (0.82) SS + CCH 0.19 (0.74) | Fair
Block, 2004^122^ RCT, N=481 | Midlife, low income women; 48.4% African American; 75% overwt | CDROM + reminder calls; CDROM alone | stress management CDROM | 2 mos; California | fruit & vegetable intake increase 1.32/day (p=0.016) v 1.2/day (p=0.52) v 0.71/day in controls; greater effect in less educated; stress reduction CDROM also increased fruit & vegetable intake | Fair
Chan, 2003^144^ Case series, N=10 | Asthma children; 50% F, ~ 7 Y, | web based daily PEF, Sx; education, video monitor 2×/wk by case mgr; case mgr email or phone re PEF, Sx, technique, mgmt plan | paper based daily monitor PEF, Sx, office based education at 2, 6, 12, 24 weeks | 6 mos, Hawaii | inhaler technique and peak flows increased in both groups | Good
Cho, 2006^123^ RCT, N=120 | DM2 53 yrs (62%) MHbA1c 7.6 BMI 23 webaccess, > 30 years old, no HF, ESLD, Ckd, insulin pump, prior webprogram | >2× per week monitoring BG, weight; EHR (lab, Hx) access; feedback; daily review by clinic, MD message biweekly; weekly reminder to logon, w/ quarterly clinic visit | education diet, self management; glucometer, paper record quarterly visit, recommendation to monitor at least 3× a week | 30 mo Taiwan | HBA1c 6.7 v 7.5 HFI .47 v .78 (fluctuation index) ~20% 2–3 logins/mo ~50% >3 logins/week NS trend to lower HbA1c in 80% + adherence to monitoring 1586 recommendations by staff to patients (45.3 per person), regimen modificaiton least frequent | Good
Christensen, 2004^124^ RCT, N=525 | Depressed adults, 71% female, age ~36 yrs | weekly contact, web based education vs. web based cognitive behavioral therapy with assessments | weekly contact about lifestyle, health habits | 6 weeks, Canberra | depression symptoms and depression literacy improved with both interventions compared to untreated controls; | Fair
Cruz-Correia, 2007^30^ RCT, crossover, N=19 | asthma 29 yrs (16–65) no bad comorbidity, have internet none doing self-monitoring | monitoring, graphic feedback, tailored reminding, education vs paper diary, paper action plan | none | NR Asthma clinic Porto, Portugal | Technical/Usability connection problems (9), system errors (3), wording (2), peakflow meter (5); problems w/ paper (5) Time to complete same www vs ppr HIT Satisfaction high overall satisfaction with both ppr and www; small preference for www viewing data Health Behavior: higher monitoring adherence with paper (clearest effect in study) | Fair
Delgado, 2003^31^ Case series, N=16 | CHF, 10 males 53.3 yrs (±12.5) NYHA 7II, 9III CHF and internet access and >6 months life expectancy | www daily monitoring, display, education, daily communication | none | 3, University HF clinic Toronto | HIT Satisfaction high mean scores on ease of use etc HIT Use one 24 hr breakdown Morb/Util 2 hospitalized QOL 59.75 to 49.87 p=0.09 relationships, working around home, side effects improved | Fair
Ewald, 2006^147^ Case Series, N=49 | Hypertensive adults, 43% female, age ~58 | BP monitor twice daily, physician-patient communication, medication reminding | none | 9 weeks, Germany | greater BP reduction correlated with more frequent BP monitoring. No controls | Fair
Finkelstein, 1996^33^ Case series, N=NR | lung transplant | monitoring | none | NR | HIT Use | Good
Franklin, 2006^125^ RCT, N=92 | DM 1 49 males 12.7, 14.1, 12.6 yrs (Conv Ins, Conv Ins + INT, Int Ins +INT, respectively) (range=8–18 yrs) Diagnosis >1 yr No social problems, learning difficulties, or needle phobias | daily scheduled individualized text message reminders; text message education; cellphone | none | Tayside, UK | HbA1c: no change w/ INT; Self Efficacy DM: 56.0 vs 62.1; self rpt adherence: 70.4 vs 77.2; DM Knowledge Score: no change w/ INT; DM Social Support more from team, not from family/friends DKA no change Hypoglyc req assist no change BMI: no change Visits: not compared HIT Satisfaction: 80% ‘it helped’ 97% like frequency of msg 90% would keep using | Fair
Gerbert, 2003^95^ Case series, N=52 | smokers, problem drinkers, 51% women, 77% nonwhite | 1.5 – 3 min tailored advice OR 3–5 min motivational intervention | pamphlets | immediate | favorable views of video doctor, but 72% would prefer real doctor; intention to quit smoking or reduce drinking after viewing | Fair
Glasgow, 2000^148^ Case Series, (RCT for components), N=320 | DM 2 59 yrs 43.5 % male | Single use dietary goal setting intervention with touch screen in office computer asst goal setting (all groups); followup phone calls; 3 ring binder of community resources | none | 3 and 6, Primary care Denver, CO Eugene, OR | HbA1c, weight, chol, lipid ration all no change self efficacy no change diet behaviors improved | Fair
Glasgow, 2003^34^ Case series (RCT for components), N=320 | DM 2 59 years DM for 8 years 83% minimal www exp independent, English, phone, | TSM: professional coach online 2×/wk, online resources, Q&A, optional diet data entry and display; PS: online peer support forum, newsletters, | PC in home, periodic online assessment with automated dietary change goals, DM self mgmt website, DM information | 12, Primary care Denver, CO Eugene, OR | Behaviors diet better, DM care better, exercise not Biological chol better, HbA1c not: 7.44–7.55, Psychosocial DM support better CES MDD better HIT use drops off in 3 mo, higher in peer support group | Fair
Green, 2008^127^ RCT, N=778 | HTN 48% male age 59.1 yrs 25% some post bacc; 90% retired or employed, 87% white, 7% smoke Inclusion: BP > 140, on Rx, no DM or KD, use PC, email, web access | biweekly pharmacist adjustment, BP monitoring, webaccess EHR | training in BP monitoring and web EHR (I1), or HTN education and web EHR (CTRL) | 12 mo HMO in Seattle, WA | SBP C, I1, I2:146.5, 144.2, I2: 139.1; DBP 86, 84.9, 82.7; BP CNTRL 0.29, 0.34, 0.51; BMI 32.5, 32.5, 31.6; phone calls C/I1/I2: 4, 3.8, 7.5; visits specialist less C2, primary care, urgent care, ED, ‘not different’ professional initiated email threads C/I1/I2: 4.6, 7.4, 22.3; patient initiated email threads 1.8, 2.7, 4.2; ASA use C/I1/I2 0.53; HTN Rxs 1.69, 1.94, 2.16 HRQoL Gen 66.7, 66.7, 66.6; Phys 88.1, 77.7,, 81.0; Emot 71.5, 72.1, 71.7 | Fair
Guendelman, 2002^128^ RCT, N=134 | Asthma 73% mod or severe 12 yrs 57 male 10 white, 90% public asst | home phone device daily monitoring (sx, activity, med use, peak flow), feedback, information, no change in regimen between visits | asthma diary | inner city hospital clinic | Missed school last 6 week CTRL .44 – .22 INT .52 – .15 Peakflow red CTRL 20/32 26/52 INT 22/36 – 19/57 Activity limit CTRL .72 – .47 INT .67 – .32 cough/wheeze, sleep trouble no different UTIL, fewer urgent calls, no other diff HRBINT, more adherent to medications and to monitoring (.89 v .65) | Fair
Gustafson, 1999^129^ RCT, N=107 | HIV/AIDS 90% male | information (FAQ, library, resource guide, dictionary); expert consultation, peer support forum, stories, assessment, decision aids, action plan PC | 97 | 3 to 6 months implementation with 2–3 month follow-up (total 5 to 9 months) Madison, Milwaukee | QoL improved on social support and participation in care, but not other scales; Utilization: fewer hospitalzations and hospital days, more phone calls to clinic among intervention patients | Fair
Jones, 2001^39^ Cohort, N=112 | Schizophrenia > 65 yrs, recent education uncertain Dx, acutely ill, persistent defaulter | 5 session personalised computer education1-3-1 hybrid education | 5 session psychiatric nurse education | community psychiatric clinic in Glasgow | NS higher satisfaction with nurse sessions in all categories; Psych outcomes improved in patients completing sessions in all three groups, NS difference by group | Fair
Joseph, 2007^130^ RCT, N=314 | Symptomatic Asthma 46% male 15.2 years urban, 98% African American, high school, 49% medicaid | 4 sessions tailored webbased asthma education; referral coordinator interaction based on input | 4 sessions timed access to generic asthma website; referral coordinator avoids interaction | 6 mo INT 12 mo follow-up school computers in Detroit | SX/FXN fewer days/nites, Sx fewer days missed school, restr activity UTIL fewer hospitals, trend to fewer ED visits and more MD visits, more obtained controller Rx, HRB trend greater control and adherence, greater rescue med availability, QOL no change | Fair
Kenwright, 2004^97^ Cohort, N=27 | Panic disorder and phobias, 40% female, ~37 years | Self help CBT online | Self help CBT in office | 16 weeks, London | both groups improved on phobia and work and social adjustment scales | Fair
Kim, 2006a^131^ RCT, N=167 | DM2 55 yrs 53% male over 21, FBS under 240, A1c under 10, no complications, no insulin | general information, assessment tool, screening instrument, exercise test individualized physical activity prescription, five stage-matched interventions, a question-and-answer board, weekly nurse phone feedback, update, revision; TTM info available on web | general information, assessment tool, screening instrument, exercise test individualized physical activity prescription, five stage-matched interventions, a question-and-answer board, weekly nurse phone feedback, update, revision; TTM info available in print, (C1) standard DM information (C2) | 12 weeks University clinic in South Korea | HbA1c 7.00 – 7.4 (INT), 7.51 - 7.0 (PRINT), 7.87 – 8.3 (UC); FBS 162 - 147, 154 - 138, 157 – 161; Activity 17 – 27 mets/week, 15 – 28 mets/week, 14 – 15 mets/week | Fair
Kim, 2007^115^ RCT, N=51 | DM2, 47 yrs, 57% female | monitor and view CBG, Rx doses, events; weekly RN review, adjustment, education, reinforcment. | 1 or 2 office based specialty visits | 12 weeks University clinic in South Korea | improved HbA1c (8.1 to 6.9 vs 7.6 to 7.7 in controls, improved postprandial glucose | Fair
Kwon, 2004^132^ RCT, N=110 | DM2 54 years 67% males A1c 7.3, BMI 24, webaccess, over 30, no HF or ESLD, Ckd, insulin pump, prior webprogram | 3× per week monitoring BG, weight, etc; EHR (lab, Hx) access; feedback; daily review by MD; MD, RN, dietician recommendations; weekly reminder to logon, with quarterly clinic visit | monthly clinic visit, same recommendation to monitor at least 3× a week | 12 weeks in Taiwan | HBA1c 7.59 – 6.94 INT; 7.19 – 7.62 CTRL HDL increased INT; BG monitor 72 INT, 38 CTRL / 12 weeks; 23/50 got reminded to login (7 days w/o); Login 42±32/ 12 weeks | Fair
La Porta, 2007a^153^ Cross sectional, N=2525 | Cancer 24% male more often learned of service online all ages, IM users | instant messaging with cancer information specialist | telephone cancer information service | NR | IM users a little more knowledge increase, new information received, discussed or plan to discuss with doctor | N/A
LaFramboise, 2003^133^ RCT, N=103 | Heart Failure | monitoring, review by RN, tailored advice, education, encouragement; telephone advice if needed; with OR without home visit | telephone care OR home visit | 2 mo | self efficacy increased with home visits and HIT, not phone care; 6 min walk test, HRQoL, and depression improved in all groups | Fair
Leu, 2005^41^ RCT, N=50 | DM1/2 51 yrs uncontrolled DM1, DM2 (A1c 8–9) | automated text pager/email reminders about BG, Rx, eat, exercise, appointments, labs; clinician replies to requests | could page investigator | ~ 5 mo UW clinics in Seattle | HbA1c CTRL 8.5 - 7.9 INT 8.5 - 8.2 BP > 130 CTRL 17 - 16 of 21 INT 16 - 8 of 21 ATT minimal differences INT liked pager | Fair
Levetan, 2002^134^ RCT, N=128 | Diabetic adults, 67.% female, age ~58 yrs, 86% African American | computer generated goals poster, wallet card, monthly postcards, a phone call, and report to physician | usual diabetes care | 6 mo, Washington DC | HbA1c 8.85 -> 7.78 INTRV HbA1c 8.39 -> 7.78 CTRL; At 6 mo no difference in weight, BP, or lipids | Fair
Lorig, 2006^42^ RCT, N=958 | Chronic disease (heart, lung, DM2) 29% male 57.5 yr 15+ yrs of education, 88% white INCL: internet, e-mail EXCL: cancer | peer moderated web-based education: (diet, exercise, meds, communication, cognitive behavioral training, self-management), forums, reference book Chronic Disease Self-Management Program (CDSMP) 3/wk × 6 wk | usual care | 12 mo | Health; no diff global health, illness intrusiveness, disability; better health distress, pain, dyspnea, (fatigue); no diff self-efficacy HRB; no diff aerobics, stress mgmt, MD comm; better stretch UTIL; no diff MD, ED, hospital visits | Fair
McDaniel, 2002^99^ Cross-sectional, N=100 | Smokers, low income women, age ~42 yrs, 23% African American | interactive video with tailored advice | none | 1 week followup | 79% reported at least one, 50% two or more behavioral changes such as cutting down, discuss with family, etc.; overall decrease in favorable attitudes toward smoking | Fair
McKay, 2001^44^ RCT, N=68 | DM2, sedentary 47% male 52.3% yrs 50% bacc deg, 62% employed EXCL <40 | personalized goal setting, feedback, strategies, online monitoring, forum online coach biweekly prompts 8 week | generic internet information | 8 weeks US, Canada | USE higher in INT v CTRL, fell sharply EXINT had no effect; both groups increased walking & vigorous exercise | Fair
McPherson, 2006^100^ RCT, N=101 | Asthmatic children, age 7–14 yrs | CDROM interactive asthma and self management education, role playing, tailored goal setting | asthma booklet | 6 mo, United Kingdom | At 1 mo: greater asthma knowledge, no difference in flow rates; At 6 mo: fewer courses of steroids and school absences, but not only a trend in intention to treat analysis | Fair
Noel, 2004^135^ RCT, N=104 | CHF, COPD, DM frail, elderly veterans 3% female, ~71 yrs | monitoring signs and symptoms, messaging, clinician advice and case management | home health care and case menagment | 6 mo, Connecticut | fewer hospital days and urgent care, lower HbA1c with telecare; no change in cogntion or quality of life; | Fair
Owen, 2005^46^ RCT, crossover, N=62 | breast cancer 100% female 52 yrs | self guided coping skills trainig, email reminders, library, peer forum, resources, art/poetry | | academic center in Southeast US | no difference in HRQOL, psychological well being, physical fxn; subgroup analysis: worst at baseline showed benefit | Fair
Pike, 2007^48^ RCT, N=6451 | 30% male 41 yrs 21 ciggarettes/day 6 prior attempts to quit, smokers visiting American Cancer Society website, frequent internet users | 5 independent smoking cessation sites | internet accessible booklets | 4 mo US | 54% follow-up (3500) 7 day prev 23.6% abstinence all sites, v 22.3% CTRLS less than 5 slips 11% both | Fair
Rasmussen, 2005^49^ RCT, N=300 | Asthma 25% mod, 25% severe, 5% mild 101 male 30 yrs | daily monitoring (web or touch tone) peak flow, action plan; CDSS for MD; MD email or phone adjustment; 1 mo steroids for severe | CTRL-1 patient given peak flow meter, action plan, instruction Rx adjustment CTRL-2 told to contact GP with spirometer results; | 6 mo in Denmark | Sx improved: 64 INT .40 C1 .35 C2 Asthma QoL improved: .33, .18, .19 FEV1 .32, .13, .09 HAVE PLAN .88, .66, .06 ADHERE .32–.87, .25–.79, .36–.54 VISITS .037, .021, .013 per mo; ED/Hosp 2, 1, 1 | Fair
Reid, 2007^50^ RCT, N=100 | Smoking CAD 54 yrs 61% males 91% 12+ years education, 80% ACS, 80% 1st smoke in 30 min from awake adults, recent ACS, PCI, card cath | pre discharge smoking cessation then IVR at 3, 14, 30 days, then nurse phone counseling 3 × 20 min on quit request | pre discharge smoking cessation only | 12 mos hospital in Ottawa | 7day abstinence 23 INT, 17 CTRL (NS) | Fair
Robertson, 2006^149^ Case series, N=144 | MDD 54% male webaccess, willingness, cognitive intact | weekly then biweekly then monthly monitoring w/feedback, education, online CBT, e-consultation, med list, information, strategies, clinician review, automated or case manager reminding | none | 12 mo Perth, AU | adherence higher with case manager than with automated reminding' depresssion severity reduced in 72 completing 8 weeks | Fair
Rodgers, 2005^114^ RCT, N=1705 | Smokers 42% male 25 yrs over 15, have mobilephone | set quit date, regular, personalised (person but not state specific) text messages providing smoking cessation advice, support, and distraction; quit buddy, quit quiz, quit messages on request | txt message thanks every 2 weeks, incentive to continue to follow-up measurements leading to higher complete participation rate | 6 mo New Zealand | self report quit: 239 v 109 at 6 weeks;cotinue quit 17/83 v 6/42 | Good
Rogers, 2001^136^ RCT, N=121 | Hypertension, 50% female, age ~61 yrs | BP monitoring 3×/wk; fax weekly reports to patient, physician, physician adjustment by phone and/or visit | usual care | 8 weeks, Syracuse, NY | SBP, DBP, mean BP improved at 6 mo; adjusted odds ratio for control of BP 2.6 – 2.8; marked benefit in African Americans (10% subgroup); more treatment adjustments in intervention group | Good
Ross, 2004^51^ RCT, N=107 | Heart failure 56 yrs 77% males NYHA II, over 18, webuser, not health proffessional | webaccess to EHR labs, notes; email to providers | | HF clinic in Colorado | No difference self efficacy, health status, Improved adherence, UTIL more ED visits, no diff hospitals (22 v 21) visits (325 v 324) or deaths (6 v 6); INT 287 calls, 63 msgs; CTRL 267 msgs | Good
Sciamanna, 2005^102^ RCT, N=121 | osteoarthritis in the knee 48 yrs 23% male 89% white, 25% 4+years, college 65% regular webuser 88% surgery and md visit for knee surgery limited by OA | webbased assessment w/recommendations for care | same, but measured satisfaction before assmt | specialty website | no difference in satisfaction with prior care after using site and receiving ~8 suggestions | Fair
Shaw, 2007^53^ Cross-sectional, N=231 | Breast cancer 52 yrs 100% female < 250% poverty, not homeless, literate | information (FAQ, library, resource guide, dictionary); expert consultation, peer support forum, stories, assessment, decision aids, action plan, PC, CHESS training | none | 4 mo Detroit, MI/Madison, WI | perceived information competence correlated with information and interactive services use, not with communicaiton expert | Fair
Shegog, 2001^138^ RCT, N=71 | Asthmatic children, 8–13 yrs, 35% female, 59% nonwhite | CDROM interactive asthma and self management education, role playing | not described | 3 sessions, 3 weeks, Houston | Some knowledge measures higher in intervention group, self-efficacy possibly higher in intervention group | Fair
Southard, 2003^139^ RCT, N=104 | CAD or CHF 62 yrs 96% white 50% retired 25% college degree | weekly monitoring surgery and signs, feedback, case manager and dietician led education, risk factor managementt, online forum; phone and mail incentive gifts for participation | usual care | 6 mo | wt loss (3#) INT v 0 CTRL, both improved activity, BP, chol, HDL, LDL, depression, fat intake | Fair
Strecher, 2006^116^ RCT, N=3971 | smokers 44% male 37 yrs 23 cigarettes/day smoke 1st in 30 min of awakening with set date, email, purchased patch | tailored webbased smoking education, newsletters, supportive messages by email, and support person, tailored account to initial questionnaire | generic web based smoking intervention, not tailored to initial questionnaire, no newsletters, no support person | 12 weeks UK | 10 week abstinence strongest moderators: tobacco related illness, children in household, alcohol consumption;also no adult smoker and less severe smoking | Fair
Taylor, 2006^107^ RCT, N=114 | 45 yrs 88% male OSA, new Dx, no prior CPAP | monitoring symptoms, CPAP use; education; contact from sleep medicine clinic by phone if high risk | | stratified age, severity, 30 days specialty clinic Walter Reed | no difference days CPAP use, hours CPAP use functional status, satisfaction | Fair
Turnin, 1992^108^ RCT crossover, N=105 | Diabetic adults, 42% female, age ~45 yrs, ~ 70% on IDDM | monitoring, dietary analysis, expert system advice, email, education | crossover condition not described | 12 mo, Toulouse, FR | DM knowledge increased proportional to system use; most diet behaviors improved,body weight was unchanged; HbA1c improved 11.0 -> 9.9 in the second subgroup. | Fair
Winzelberg, 2003^141^ RCT, N=72 | breast cancer 36% some grad school 80% white not suicidal, in CA, English speaking | Web-based MH professional actively moderated structured breast cancer social support group, personal journal, others' stories | wait list control | 12 weeks Palo Alto | INT improved CES-D (MDD), PCLC (PTSD), PSS (stress) | Fair
Yon, 2007^152^ Case series, N=176 | obesity 13% male BMI 25–39, over 18 yrs, web access not pregnant, moving, major illness, unable to meet weekly | PDA dietary monitoring, part of 24 week weight loss program, weekly email encouragement monitoring | historical controls using paper based monitoring, weekly encouragement | 24 weeks Vermont | no difference in wt loss, monitoring, diet compliance; PDA less complaint with exercise goals; actual data not given; weight loss correlated with monitoring, attendance, adherence to diet, exercise | Fair
Zimmerman, 2004^93^ RCT, N=45 | CABG | daily monitoring symptoms, daily review and scripted response | predischarge teaching, followup phone calls at 2, 4, and 6 weeks | 6 weeks, | no significant difference in physical functioning or symptom scores | Fair

Abbreviations

ASA = aspirin

BG = blood glucose

BP = blood pressure

CBT = computer based test

CDSS = clinical decision support system

CHESS = Comprehensive Health Enhancement Support System

CHF = chronic heart failure

chol = cholesterol

COPD = chronic obstructive pulmonary disease

CTRL = control

DBP = diastolic blood pressure

diff = difference

DM = Diabetes Mellitus

Dx = diagnosis

ED = emergency department

EHR = electronic health records

ESLD = end stage liver disease

EXCL = exclusion

f/u = follow-up

fxn = function

HbA1c = glycosylated hemoglobin

HF = heart failure

hosps = hospitals

HTN = hypertension

INCL = inclusion

INT = intervention

KD = kidney disease

M = male

MD = doctor

MDD = Major Depressive Disorder

mgmt = management

mo(s) = month(s)

msg = message

OA = osteoarthritis

OSA = sleep apnea

PDA = personal digital assistant

QoL = quality of life

Rx = prescription

SPB = systolic blood pressure

sx = symptoms

txt = text

UTIL = utilized

wk(s) = week(s)

wt = weight

yr=year(s)

Summary Table 6. Specific Findings for Populations of Interest

Author, Year, Design, N | Population description | Condition | Interactive Computer Technology (ICT) | Findings
African Americans
Artinian, 2003^106^ RCT, N= 18 | 65 % Black (11 pts) 35% White (6 pts) | Congestive heart failure | video cassette (Med - Monitor) that sat in a cradle connected to a telephone line | Majority (56%) loved it Lifestyle change seen in 67% BP more stable by remembering meds; need less nitroglycerine Improved self care behaviors and QOL Some technical difficulties reported
Brennen, 2001^157^ RCT, N= 140 | 12% African American 86% Caucasian | CABG | Computerized, internet-based information and support system that provides extension and enhancement of traditional nursing services | For one week snapshot: Group 1 used the HeartCare system a total of 451 times, an average of 64 accesses per day
Gerbert, 2003^95^ RCT, N=52 | 48% African American; 12%Latino; low income | Smoking & Alcoholism | Brief motivational video risk assessment with tailored advice | Convenience (right amount of time;5.7 / 7); privacy(5.95/ 7 pts); confidential (5.9/7pts); honest (6.94/7 pts); ease of use (6.8 /7 pts); satisfaction (5.7 /7pts) 71% would feel more comfortable with a “real” doctor.
Guendelman, 2002^128^ RCT, N= 134 | Gp 1: 79% African American 8% Caucasian Gp 2: 74% African American 12% Caucasian | Asthma | Interactive communication device with question and response tasks. Questions provided by the nurse to the patient for their respones | Reduction in the number of urgent calls (p= 0.05), ED visits (p= 0.21), hospitalizations, (0.96) Reduction in limitation of activity (p=0.03) Decrease in the number of people having trouble sleeping, (p= 0.83) Reduction in number of subjects that missed school
Joseph, 2007^130^ RCT, N= 314 | >98% students were African American | Asthma | Web based program focusing on controller medication adherence, rescue inhaler availability, smoking cessation/reduction. | Decrease in symptom days, symptom nights, school days missed/30 days, Decreased days of restricted activity Decrease in days having to change plans Decreased Hospitalizations (p= 0.01) and ED visits/12 months, p= (0.08) Positive behavior in medication adherence (p= 0.09) and rescue inhaler activity (p=0.01) Trend towards better quality of life
La Porta, 2007a^153^ Survey, N= 2485 | 11% African American 75% Caucasian 6% Hispanic | Cancer and Smoking | Cancer Information Service and LiveHelp provide cancer patients and family members with real time information and advice | 73% reported their knowledge had increased after using the service 95% said they were very satisfied or satisfied 88% said service met or exceeded expectations 67% said they felt more confident in their ability to seek cancer information following the service 60% of those who used the service for themselves (not a family member) and were dx w/cancer, felt more confident in their ability to actively participate in treatment decisions Of those actively smoking at time of using service, at survey completion: 14% had quit, 35% had cut back, 45% plan to quit or cut back in future
La Porta, 2007b^158^ Survey, N= 2485 | 11% African American 75% Caucasian 6% Hispanic | Cancer and Smoking | Cancer Information Service (CIS)and LiveHelp provide cancer patients and family members with real time information and advice | Live help group was more likely to gain cancer-related knowledge compared to CIS telephone group (P<0.001) 61% in Live help grp and 59% in CIS grp were very satisfied, 39% in Live help and 35% in CIS grp were satisfied 38% in Live Help and 29% in CIS said the system exceeded expections, 56% in Live Help and 59% in CIS said system met expectations
Meigs, 2003^159^ RCT, N= 598 | Grp 1 vs Grp 2 Black: 19.2% vs 18.9% White: 71% vs 71.1% Other: 9.8% vs 10.0% | Type 2 Diabetes | web based decision support tool, displaying interactive patient specific clinical data, treatment advice, and links to other web based care resources | Positive change seen in all glycemic control outcomes except Mean HbA1c (% Hb) Positive change seen in all cholesterol control outcomes Positive change seen in all BP control outcomes except the Mean systolic BP (mmHg) Increase in the number of subjects having at least one eye examination by an eye care professional and one foot exam in the last 12 months
Nguyen, 2005*^113^ Between group, N= 23 | 6% African-American (1) 13% White (13) 6% Native American (1) 6% Other (1) | Chronic Obstructive Pulmonary disease | web site to help individuals with COPD by logging onto website at least 3 times/week, 2 weekly chat sessions, online bulletin board and email support, individualized exercise plans | No significant differences in physiologic outcomes.
Piette, 1997*^47^ Prospective study, N= 65 | 9.2% Black 61.5% White 18.5% Hispanic 10.8% Asian/Pacific Islander | Diabetes | AVM system using specialised computer technology to telephone patients, communicate messages, and collect information | AVM system with multiple phone line with half time nurse will cost 10% of the human calling system Program cost for second year is 2% of human calling system (assuming progam paid for itself in first yr) Almost all of the subjects reported that AVM was useful and would like to receive AVM. Almost all had no difficulty responding to the system 37.5% – 85.6% listened to 2 + preventive messages 72.2–90.9 % thought AVM would make them more satisfied with VA care
Sciamanna, 2004*^86^ Cohort, N= 150 | 4.1% Black (6) 83.1% White (123) 11.4% Hispanic (17) 1.4% Other (2) | chronic illness | computer assessment on smoking and physical activity with tailored printed feedback | 12% of patients asked for help using computer; 81.1% patients felt computer easy to use Satisfaction with provider visit significantly related to having a chronic conditon, being a nonsmoker, and having a provider who reviewed the report with the patient
Sciamanna, 2005^102^ Quasi experimental, N= 121 | 6.6% Black 86.8% White 2.5% American Indian 3.3% Hispanic 5% Other | osteoarthritis of the knee | computer assessment on OA, satisfaction with care; computer personalized feedback about OA quality of care and treatment recommendations | website ratings-23.1% excellent, 52.9% very good, 24% good; 97.5 % said website was easy to use Majority thought that Website could help get better care, help understand and manage osteoarthritis and help talk to doctor
Shaw, 2007*^53^ RCT, N= 231 | 35.9% African American (83) 62.3% Caucasian (144) 1.7% Other minorities | Metastatic Breast Cancer | CHESS: Web-based information, discussion group, ask an expert, and interactive services (tailored action plan, decision aids, health tracking | Positive change in information competence Use of all four components of ICT Use over 4 months by category Mean use discussion 506.2 min Mean use information 35.5 min Mean use ask an expert 28 min Mean interactive service 27.9 min
Taylor, 2006^107^ RCT, N= 114 | UC vs Exp 40% vs 42% African American 60% vs 49% Caucasian 0% vs 5% Hispanic 0% vs 5% Asian | Obstructive sleep apnea | OSAS library with customized information; Daily questions on sleep and CPAP use, responses monitored and categorized into low/medium/high risk, sleep specialist call patient after 3 days of high-risk responses | 83% found HealthBuddy very easy to use; 2 out of 3 reported it a positive experience; 83% had no difficulty using it; 75% wer likely or very likely to continue using it. 69% satisfied with Health Buddy, 71% satisfied with communication with clinicians; Mean hours of CPAP use (hrs): Usual care 4.22, Exp 4.29, p=.87 CPAP mean proportion (hrs):UC 50.1%, exp 46.9%, p=.61; Functional status, Usual care 2.27, exp group 2.03, p=.76
Winzelberg, 2002^141^ RCT, N= 72 | 4% African American 80% Caucasian 4% Asian 6% Hispanic/Latina 6% Other | Breast cancer | 12 week, structured, web based support group moderated by a mental health professional | Group experience evaluation (% reporting a lot or a great deal) getting support and encouragement: 65 helping others: 56 learning that problems are not unique: 56 develop new friendships: 63 get advice: 55 express true feelings: 65 model self after group participants: 30 confront difficult probs. and fears: 44 discuss sexual concerns: 44
Rural
Estabrooks, 2005^146^ RCT, N= 422 | Urban as well as rural | Type 2 Diabetes | Computer CD-ROM with Goal setting, Tailored action plan, assessments of dietary intake and physical activity, hard copy of pts personal action plan | Decreased fat consumtion increased veggie and fruit consumption Increased moderate/vigorous activity
Ferrer-Roca, 2004^60^ Case series, N= 172 (Gp 1 (DM): 12 Gp 2 (website review only): 160) | Rural Islanders | Diabetes | Website with patient and doctor interfaces for inputting data and sending advice | Out of those who entered the trial to test the system 86% would recommend the site Majority (71%) thought the system was easy 33% did not find the system useful and efficient 50% had difficulties in accessing the system Ambiguous results on HIT satisfaction Out of those who reveiwed the website 40% would recommend the site Majority (92%) thought the system was easy 12%did not find the system useful and efficient 88% had difficulties in accessing the system
Gustafson, 1998*^36^ Cohort, N=38 | 28[76%] of 27 potentially eligible urban vs. 10 [71%] of 14 rural | Breast Cancer | CHESS: computerized information and problem-solving, Q & A, ask an expert, health profile, peer discussion group, personal stories, decision aids | Use over 10 weeks: Mean 6.8 uses/week/subject 100% used discussion group, ask an expert, Q & A, health profile 71% of uses for social support, 16% of uses for information
Gustafson, 2001^74^ RCT, N = 295 | Urban, small city and rural areas | Breat cancer | Computer based patient support system providing information, decision-making and emotional support | Increased participation and level of comfort Increased confidence in doctors Increased information competence Decreased unmet information need (5 month Follow up) Increased partici[ation and behavioral involvement Better quality of life
Hill, 2006^156^ RCT, N= 120 | Ranch, Farm or Small town (Rural- lived 25 miles outside an urbanized area (a city of 12,500 or more),having to travel almost 57 miles one way) | Diabetes, Rheumatoid conditions, heart disease, cancer, multiple sclerosis | Online, asynchronous, peer-led support group and health teaching units using WebCT | Trend toward increasing self esteem, (p=0.016) Increase in feeling of empowerment, (p=0.016) Increased seld efficacy (p=0.107) Decreased feelings of depression, loneliness and stress (p= 0.342, 0.206, 0.343 respt) High levels of social support, (p=0.038)
Kaufman, 2003*^75^ usability cognitive walkthrough and field observation, N= 14 NYC, 11 upstate (but really 2 case studies) | rural upstate NY and hispanic NYC | Diabetes Mellitus | videoconferencing, BP & BG uploading and review, education, email | Usability issues system barriers- problematic widgets, small fonts, bad spacing, complext tasks, screen transitions, system stability Cognitive/Skill barriers-mouse-keyboard skill, mental model, literacy, numeracy. Also anxiety, self-efficacy, motivation
Shaw, 2007*^53^ RCT, N= 231 | Detroit cohort: unknown. Wisconsin cohort: rural. | Metastatic Breast Cancer | CHESS: Web-based information, discussion group, ask an expert, and interactive services (tailored action plan, decision aids, health tracking | Positive change in information competence Use of all four components of ICT Use over 4 months by category Mean use discussion 506.2 min Mean use information 35.5 min Mean use ask an expert 28 min Mean interactive service 27.9 min
Smith, 2000^54^ RCT, N= 30 | Rural-at least 25 miles away from 6 major cities of Montana | Diabetes | web based computer intervention on general health and info on diabetes with Conversation area, mailbox, health chat area and resource rack | Time spent using the HIT decreasing over study period Psychosocial adjustment to illness scale lower in the computer group as compared to the non computer group Raw mean scores of quality of life and support lower in the computer group
Woodruff, 2001^151^ pre post cohort study, N= 26 | Rural alternative schools | Smoking | chat room, facilitated by tobacco counselor, using Active World | 38.9% self reported not smoking
Underserved
Finkelstein, 1996^33^ Qualitative Study, N=41 | Reside in low-income inner city area, 2/3 had never used a computer, almost 50% had never used a computer or an ATM, >50% born outside US and English was their 2nd language, age range was on older side (most >40 yrs, and 1/3 >50 yrs), | Asthma/underserved | Symptom diary and spirometry test | Not complicated at all, very easy to use
Lober, 2006*^82^ N=38 | Low-income elderly and disabled, mean age 69 years (range 49–92 years), 82% Female, 18% Male, many had chronic diseases | Many chronic illnesses | Personal health records with areas for communication with health professional | Empowering patients to keep track of PHR, reassurance that if a natural disaster hits, their PHR will remain intact since they are not paper-form; - 93% of providers found the Personal Health Information System useful when treating patients
McDaniel, 2002^99^ Cohort, N=110 | 35% did NOT have HS diploma | Smoking | Interactive smoking cessation software | Technology malfunctions; software errors; 60.2 / 70pts; minority participants more satisfied
Sciamanna 2004*^86^ Cohort N= 150 | Public health clinics 1 provider at 10 clinic sites; | 63.3% had some chronic illness | computer assessment on smoking and physical activity with tailored printed feedback | 12% of patients asked for help using computer; 81.1% patients felt computer easy to use Satisfaction with provider visit significantly related to having a chronic conditon, being a nonsmoker, and having a provider who reviewed the report with the patient
Elderly
Barnason, 2003^119^ RCT w/ repeated measures, N= 35 | Age range 65 –85 years | Coronary Artery disease | Health buddy:small device attached to patient's telephone. Provides asssessment, strategies, education, and positive reinforcement | Significantly higher self efficacy scores, adjusted physical functioning mean scores, adjusted general health functioning mean scores, mental health functioning and validity functioning in intervention group, Significant time effect [F(1,29)=11.25, P <.002] on the role emotional functioning and pain subscale [F(1,29)=11.25, P <.002] Fewer subjects reported the use of salt when cooking and eating at 4 weeks, 6 weeks, and 3 months postoperatively. Significantly higher exercise adherence (t = 3.09, P < .01) and stress control
Baranson, 2006^120^ randomized, experitmental two-group repeated measures design, N= 50 | Average age- 73.3 years | Coronary Artery disease | Health Buddy-12 weeks of a desktop telehealth device with daily interventions with recovery assessment, strategies to manage problems, education and positive reinforcement | Improvement seen in physical and mental health outcomes at 6 wks and 3 months after bypass (Physical- F=9.42, p<0.01; Mental- F= 7.97, p< 0.01) Decreased number of emergency room visits in the intervention grp (p= 0.15) More number of non routine provider visits in the intervention grp (Mean =2.8) as compared to the conrol (mean=2.61) Nursing visit average higher in the experimental group as compared to control group
Feil, 2000^69^ Qualitative Study, N=160 | Ages 40–75 years | Type 2 Diabetes | D-Net intervention: peer social support and personalized dietary intervention | Computer was initial barrier to program participants
Gustafson, 1998*^36^ Cohort, N=38 | Mean age- 71.8, SD 6.06 | Breast Cancer | CHESS: computerized information and problem-solving, Q & A, ask an expert, health profile, peer discussion group, personal stories, decision aids | Use over 10 weeks: Mean 6.8 uses/week/subject 100% used discussion group, ask an expert, Q & A, health profile 71% of uses for social support, 16% of uses for information
Holbrook, 2007^162^ Randomised trial (no control), N= 98 | ≥ 65 years | Not specified | Decision board, decision booklet with audiotape, or interactive computer program with either pie graphs or pictograms | Higher post intervention scores on the Atrial Fibrillation Information Questionnaire (p<0.01) 96% of participants felt that the information in the decision aids helped them make their treatment decision Mean difference scores by format and graphic presentation similar in corresponding groups
Jones, 1999^38^ RCT, N= 525 | >60 examined as variable | Cancer | Personalized computer based information i.e. Cancer information tailored by data in EHR vs not tailored vs printed booklets | NS change depression and cancer adjustment scores; 84% improved anxiety scores, especially PINF (tailores), especially but also BKLT (booklets); subgroups examined Physician assessed ‘above avg knowledge’ 35% GINF(non tailored), 25% PINF, 20% BKLT. [note that in general, docs assessed pt knowledge below average] 12 min (1–44) 1st use; 71% no repeat use: 20/169 PINF, 4/155 GINF 80% would prefer 10 min w/ professional (71% PINF, 80% GINF, 90% BKLT); overall 40% satisfied; satisfaction with information higher in PINF
Kaufman, 2003*^75^ usability cognitive walkthrough and field observation, N= 14 NYC, 11 upstate (but really 2 case studies) | Age-69.6±6 (NYC); 73.7±8 upstate | Diabetes Mellitus | videoconferencing, BP & BG uploading and review, education, email | Usability issues system barriers- problematic widgets, small fonts, bad spacing, complext tasks, screen transitions, system stability Cognitive/Skill barriers-mouse-keyboard skill, mental model, literacy, numeracy. Also anxiety, self-efficacy, motivation
Kressig, 2002^98^ Cohort, N=34 | ≥60 years | Physical activity for elderly | computer system for exercise promotion (questionnaire with tailored recommendations) | Most problems had to do with survey issues, not computer. 22% questions were mouse related. Ease of use 4.6/5 pts; 21.45/24pts on acceptability of recommendation.
Lee, 2007^62^ Quasi-experimental, N= 274 | Elderly examined as subgroup | Type 2 DM | Web-based system for managing patients' care of their diabetes | Significant reduction in fasting blood glucose levels (p= 0.001), total cholesterol levels p=0.012 and HbA1c % (p=0.001) Subjects in “College or University” logged into system more often than those in “Illiterate” or “Elementary school/Junior high school” (P=0.007 and P=0.012, respectively) Subjects in the age category of <29 years logged than those in 50–59, 60–69, and 70–79 (P=0.011, P=0.000, P=0.000, respectively) Those in the age category of 40–49 years logged more often than those in the age category of 60–69 and 70–79 (P=0.012 and P=0.040, respectively)
Lober, 2006*^82^ N=38 | Low-income elderly and disabled, mean age 69 years (range 49–92 years), 82% Female, 18% Male, many had chronic diseases | Many chronic illnesses | Personal health records with areas for communication with health professional | Empowering patients to keep track of PHR, reassurance that if a natural disaster hits, their PHR will remain intact since they are not paper-form; - 93% of providers found the Personal Health Information System useful when treating patients
Nguyen, 2003^45^ Non randomized trial, N= 16 | Mean age = 69.1 (grp 2) range- 55–82 | Dyspnoea | nurse facilitated and peer supported internet based dyspnoea self management program | FEV1/FVC: 41 +/- 7%; Improvements noted for Dyspnoea (effect size=0.86) Endurance exercie 0.27 for the overall sample Improvement in self efficacy for managing dyspnoea = 0.94 First month registered most logins (330) compared to 104 in the final month
Nguyen, 2005*^113^ Between groups, N= 23 | Age- 69.1 +/- 7.0 (55–82) | Chronic Obstructive Pulmonary disease | web site to help individuals with COPD by logging onto website at least 3 times/week, 2 weekly chat sessions, online bulletin board and email support, individualized exercise plans | No significant differences in physiologic outcomes.
Piette, 1997*^47^ Prospective study, N= 65 | 9.2% Black 61.5% White 18.5% Hispanic 10.8% Asian/Pacific Islander | Diabetes | AVM system using specialised computer technology to telephone patients, communicate messages, and collect information | AVM system with multiple phone line with half time nurse will cost 10% of the human calling system Program cost for second year is 2% of human calling system (assuming progam paid for itself in first yr) Almost all of the subjects reported that AVM was useful and would like to receive AVM. Almost all had no difficulty responding to the system 37.5% – 85.6% listened to 2 + preventive messages 72.2–90.9 % thought AVM would make them more satisfied with VA care

* Study appears in more than one category on this table