# References

1 Keselman A, Logan R, Smith CA, Leroy G, Zeng-Treitler Q. Developing Informatics Tools and Strategies for Consumer-centered Health Communication. JAMIA. 2008;15:473-483. [pmid: 18436895].
2 US Dept of Heath and Human Services. http://www.hhs.gov/healthit/. Accessed July 10, 2008.
3 Committee on Quality Health Care in America. Crossing the quality chasm: a new health system for the 21st century. Washington D.C.: Institute of Medicine; 2001.
4 New Health Partnerships. Supporting Self Management. http://www.newhealthpartnerships.org/ProvidersPeopleInCirclePrint.aspx?id=78&linkidentifier=id&itemid=78. Accessed July 10, 2008.
5 Hoffman C, Rice D, Sung HY. Persons with chronic conditions. Their prevalence and costs. JAMA. 1996;276:1473-1479. [pmid: 8903258].
6 Wagner EH. Meeting the needs of chronically ill people. . BMJ. 2001;323(945–6).
7 Bodenheimer T, Lorig K, Holman H, Grumbach K. Patient self-management of chronic disease in primary care. JAMA. 2002;288(19):2469-2475. [pmid: 12435261].
8 Bodenheimer T, Wagner EH, Grumbach K. Improving primary care for patients with chronic illness: the chronic care model, Part 2. JAMA. 2002;288(15):1909-1914. [pmid: 12377092].
9 Robert Wood Johnson Foundation. Improving chronic illness care. http://www.improvingchroniccare.org. Accessed July 5, 2008.
10 Coleman MT, Newton KS. Supporting self-management in patients with chronic illness. Am Fam Physician. 2005;72(8):1503-1510. [pmid: 16273817].
11 Lorig KR, Ritter P, Stewart AL, et al. Chronic disease self-management program: 2-year health status and health care utilization outcomes. Med Care. 2001;39(11):1217-1223. [pmid: 11606875].
12 Renders CM, Valk GD, Griffin SJ, Wagner EH, Eijk Van JT, Assendelft WJ. Interventions to improve the management of diabetes in primary care, outpatient, and community settings: a systematic review. Diabetes Care. 2001;24(10):1821-1833. [pmid: 11574449].
13 Whitlock WL, Brown A, Moore K, et al. Telemedicine improved diabetic management. Mil Med. 2000;165(8):579-584. [pmid: 10957848].
14 Demeris G, Eysenbach G. Internet use in disease management for home care patients: a call for papers. J Med Internet Res. 2002;4(2):E6. [pmid: 12554553].
15 Eysenbach G, Powell J, Kuss O, Sa ER. Empirical studies assessing the quality of health information for consumers on the world wide web: a systematic review. JAMA. 2002;287(20):2691-2700. [pmid: 12020305].
16 Ratzan L. Making sense of the Web: a metaphorical approach. Information Research. 2000;6(1).
17 Madden M, Fox S. Riding the Waves of “Web 2.0”: More than a buzzword, but still not easily defined: Pew Internet Project; October 5, 2006.
18 Harris RP, Hefland M, Woolf SH, et al. Methods Work Group, Third US Preventive Services Task Force. Current methods of the US Preventive Services Task Force: a review of the process. Am J Prev Med. 2001;20(3 Suppl):21-35.
19 Khan K, ter Riet G, Popay J, Nixon J, Kleijnen J. Undertaking Systematic Reviews of Research on Effectiveness: Stage II: Conducting the Review. York: University of York; 2001.
20 Verhagen AP, de Vet HC, de Bie RA, et al. The delphi list a criteria list for quality assessment of randomized clinical trials for conducting systematic reviews developed by delphi consensus. J Clin Epidemiol. 1998;51(12):1235-1241. [pmid: 10086815].
21 Critical Appraisal Skills Programme. 10 questions to help you make sense of qualitative research: Milton Keynes Primary Care Trust; 2002.
22 Popay J, Baldwin S, Arai L, et al. Methods Briefing 22: Narrative Synthesis in Systematic Reviews. Manchester, England: Cathie Marsh Centre for Census and Survey Research; 2006.
23 Denyer D, Tranfield D, van Aken JE. Developing Design Propositions through Research Synthesis. Organization Studies. 2008;29(3):393-413.
24 Tranfield DR, Denyer D, Smart P. Towards a methodology for developing evidence-informed management knowledge by means of systematic review. British Journal of Management. 2003;14:207-222.
25 Task Force on Community Preventive Services. Guide to Community Preventive Services: What works to promote health? New York: Center for Disease Control; 2005.
26 An LC, Perry CL, Lein EB, et al. Strategies for increasing adherence to an online smoking cessation intervention for college students. Nicotine Tob Res. 2006;8(Suppl 1):S7-12. [pmid: 17491165].
27 Bachofen M, Nakagawa A, Marks IM, et al. Home self-assessment and self-treatment of obsessive-compulsive disorder using a manual and a computer-conducted telephone interview: replication of a UK-US study. J Clin Psychiatry. 1999;60(8):545-549. [pmid: 10485637].
28 Cathala N, Brillat F, Mombet A, et al. Patient followup after radical prostatectomy by Internet medical file. J Urol. 2003;170(6 Pt 1):2284-2287. [pmid: 14634397].
29 Cavan DA, Everett J, Plougmann S, Hejlesen OK. Use of the Internet to optimize self-management of type 1 diabetes: preliminary experience with DiasNet. J Telemed Telecare. 2003;9(Suppl 1):S50-52. [pmid: 12952722].
30 Cruz-Correia R, Fonseca J, Lima L, et al. Web-based or paper-based self-management tools for asthma—patients' opinions and quality of data in a randomized crossover study. Stud Health Technol Inform. 2007;127:178-189. [pmid: 17901611].
31 Delgado DH, Costigan J, Wu R, Ross HJ. An interactive Internet site for the management of patients with congestive heart failure. Can J Cardiol. 2003;19(12):1381-1385. [pmid: 14631472].
32 Earnest MA, Ross SE, Wittevrongel L, Moore LA, Lin CT. Use of a patient-accessible electronic medical record in a practice for congestive heart failure: patient and physician experiences. JAMIA. 2004;11(5):410-417. [pmid: 15187074].
33 Finkelstein SM, Snyder M, Edin-Stibbe C, et al. Monitoring progress after lung transplantation from home-patient adherence. J Med Eng Technol. 1996;20(6):203-210. [pmid: 9029392].
34 Glasgow RE, Boles SM, McKay HG, Feil EG, Barrera M Jr. The D-Net diabetes self-management program: long-term implementation, outcomes, and generalization results. Prev Med. 2003;36(4):410-419. [pmid: 12649049].
35 Gustafson DH, Hawkins RP, Boberg EW, Bricker E, Pingree S, Chan CL. The use and impact of a computer-based support system for people living with AIDS and HIV infection. Proc Annu Symp Comput Appl Med Care. 1994:604–608.
36 Gustafson DH, McTavish F, Hawkins R, et al. Computer support for elderly women with breast cancer. JAMA. 1998;280(15):1305. [pmid: 9794300].
37 Japuntich SJ, Zehner ME, Smith SS, et al. Smoking cessation via the internet: a randomized clinical trial of an internet intervention as adjuvant treatment in a smoking cessation intervention. Nicotine Tob Res. 2006;8(Suppl 1):S59-67. [pmid: 17491172].
38 Jones R, Pearson J, McGregor S, et al. Randomised trial of personalised computer based information for cancer patients. BMJ. 1999;319(7219):1241-1247. [pmid: 10550090].
39 Jones RB, Atkinson JM, Coia DA, et al. Randomised trial of personalised computer based information for patients with schizophrenia.[erratum appears in BMJ 2001 May 5;322(7294):1103]. BMJ. 2001;322(7290):835-840. [pmid: 11290639].
40 Kashem A, Droogan MT, Santamore WP, et al. Web-based Internet telemedicine management of patients with heart failure. Telemed J E Health. 2006;12(4):439-447. [pmid: 16942416].
41 Leu MG, Norris TE, Hummel J, Isaac M, Brogan MW. A randomized, controlled trial of an automated wireless messaging system for diabetes. Diabetes Technol Ther. 2005;7(5):710-718. discussion 719–720. [pmid: 16241873].
42 Lorig KR, Ritter PL, Laurent DD, Plant K. Internet-based chronic disease self-management: a randomized trial. Med Care. 2006;44(11):964-971. [pmid: 17063127].
43 Ma C, Warren J, Phillips P, Stanek J. Empowering patients with essential information and communication support in the context of diabetes. Int J Med Inf. 2006;75(8):577-596.
44 McKay HG, King D, Eakin EG, Seeley JR, Glasgow RE. The diabetes network internet-based physical activity intervention: a randomized pilot study. Diabetes Care. 2001;24(8):1328-1334. [pmid: 11473065].
45 Nguyen HQ, Carrieri-Kohlman V, Rankin SA, Slaughter R, Stulbarg MS. Pilot study of an online dyspnea self-management program for COPD. AMIA Annu Symp Proc. 2003;Annual Symposium Proceedings/AMIA Symposium.:951.
46 Owen JE, Klapow JC, Roth DL, et al. Randomized pilot of a self-guided internet coping group for women with early-stage breast cancer. Ann Behav Med. 2005;30(1):54-64. [pmid: 16097906].
47 Piette JD, Mah CA. The feasibility of automated voice messaging as an adjunct to diabetes outpatient care. Diabetes Care. 1997;20(1):15-21. [pmid: 9028687].
48 Pike KJ, Rabius V, McAlister A, Geiger A. American Cancer Society's QuitLink: randomized trial of Internet assistance. Nicotine Tob Res. 2007;9(3):415-420. [pmid: 17365773].
49 Rasmussen LM, Phanareth K, Nolte H, Backer V. Internet-based monitoring of asthma: a long-term, randomized clinical study of 300 asthmatic subjects. J Allergy Clin Immunol. 2005;115(6):1137-1142. [pmid: 15940125].
50 Reid RD, Pipe AL, Quinlan B, Oda J. Interactive voice response telephony to promote smoking cessation in patients with heart disease: a pilot study. Patient Educ Couns. 2007;66(3):319-326. [pmid: 17336026].
51 Ross SE, Moore LA, Earnest MA, Wittevrongel L, Lin CT. Providing a web-based online medical record with electronic communication capabilities to patients with congestive heart failure: randomized trial. J Med Internet Res. 2004;6(2):e12. [pmid: 15249261].
52 Ruland CM, White T, Stevens M, Fanciullo G, Khilani SM. Effects of a computerized system to support shared decision making in symptom management of cancer patients: preliminary results. JAMIA. 2003;10(6):573-579. [pmid: 12925545].
53 Shaw BR, Han JY, Baker T, et al. How women with breast cancer learn using interactive cancer communication systems. Health Educ Res. 2007;22(1):108-119. [pmid: 16829544].
54 Smith L, Weinert C. Telecommunication support for rural women with diabetes. Diabetes Educ. 2000;26(4):645-655. [pmid: 11140073].
55 Tsang MW, Mok M, Kam G, et al. Improvement in diabetes control with a monitoring system based on a hand-held, touch-screen electronic diary. J Telemed Telecare. 2001;7(1):47-50. [pmid: 11265938].
56 van den Brink JL, Moorman PW, de Boer MF, Pruyn JFA, Verwoerd CDA, van Bemmel JH. Involving the patient: a prospective study on use, appreciation and effectiveness of an information system in head and neck cancer care. Int J Med Inf. 2005;74(10):839-849.
57 Nakagawa A, Marks IM, Park JM, et al. Self-treatment of obsessive-compulsive disorder guided by manual and computer-conducted telephone interview. J Telemed Telecare. 2000;6(1):22-26. [pmid: 10824386].
58 Wilkie DJ, Huang HY, Berry DL, et al. Cancer symptom control: feasibility of a tailored, interactive computerized program for patients. Fam Community Health. 2001;24(3):48-62. [pmid: 11563944].
59 Zabinski MF, Wilfley DE, Pung MA, Winzelberg AJ, Eldredge K, Taylor CB. An interactive internet-based intervention for women at risk of eating disorders: a pilot study. Int J Eat Disord. 2001;30(2):129-137. [pmid: 11449446].
60 Ferrer-Roca O, Franco Burbano K, Cardenas A, Pulido P, Diaz-Cardama A. Web-based diabetes control. J Telemed Telecare. 2004b;10(5):277-281. [pmid: 15494085].
61 Zrebiec JF, Jacobson AM. What attracts patients with diabetes to an internet support group? A 21-month longitudinal website study. Diabet Med. 2001;18(2):154-158. [pmid: 11251681].
62 Lee TI, Yeh YT, Liu CT, Chen PL. Development and evaluation of a patient-oriented education system for diabetes management. Int J Med Inf. 2007;76(9):655-663.
63 Anhoj J, Nielsen L. Quantitative and qualitative usage data of an Internet-based asthma monitoring tool. J Med Internet Res. 2004;6(3):e23. [pmid: 15471749].
64 Bond GE. Lessons learned from the implementation of a Web-based nursing intervention. Cin Comput Inform Nurs. 2006;24(2):66-74.
65 Carroll C, Marsden P, Soden P, Naylor E, New J, Dornan T. Involving users in the design and usability evaluation of a clinical decision support system. Comput Methods Programs Biomed. 2002;69(2):123-135. [pmid: 12100792].
66 Chen H, Yeh M, Chao Y. Comparing effects of auricular acupressure with and without an Internet-assisted program on smoking cessation and self-efficacy of adolescents. J Altern Complement Med. 2006;12(2):147-152. [pmid: 16566674].
67 Cleland J, Caldow J, Ryan D. A qualitative study of the attitudes of patients and staff to the use of mobile phone technology for recording and gathering asthma data. J Telemed Telecare. 2007;13(2):85-89. [pmid: 17359572].
68 Crosbie JH, Lennon S, McNeill MDJ, McDonough SM. Virtual reality in the rehabilitation of the upper limb after stroke: the user's perspective. Cyberpsychol Behav. 2006;9(2):137-141. [pmid: 16640466].
69 Feil EG, Glasgow RE, Boles S, McKay HG. Who participates in Internet-based self-management programs? A study among novice computer users in a primary care setting. Diabetes Educ. 2000;26(5):806-811. [pmid: 11140008].
70 Finkelstein J, Hripcsak G, Cabrera MR. Patients' acceptance of Internet-based home asthma telemonitoring. Proc AMIA Symp. 1998;Annual Symposium.:336–340.
71 Friedman RH, Stollerman JE, Mahoney DM, Rozenblyum L. The virtual visit: using telecommunications technology to take care of patients. JAMIA. 1997;4(6):413-425. [pmid: 9391929].
72 Gomez EJ, Caceres C, Lopez D, Del Pozo F. A web-based self-monitoring system for people living with HIV/AIDS. Comput Methods Programs Biomed. 2002a;69(1):75-86. [pmid: 12088595].
73 Gomez EJ, Hernando ME, Garcia A, et al. Telemedicine as a tool for intensive management of diabetes: the DIABTel experience. Comput Methods Programs Biomed. 2002b;69(2):163-177. [pmid: 12100795].
74 Gustafson DH, Hawkins R, Pingree S, et al. Effect of computer support on younger women with breast cancer. J Gen Intern Med. 2001;16(7):435-445. [pmid: 11520380].
75 Kaufman DR, Patel VL, Hilliman C, et al. Usability in the real world: assessing medical information technologies in patients' homes. J Biomed Inform. 2003b;36(12):45-60. [pmid: 14552846].
76 Kerkenbush NL, Lasome CEM. The emerging role of electronic diaries in the management of diabetes mellitus. AACN Clin Issues. 2003;14(3):371-378. [pmid: 12909805].
77 Kim H, Yoo Y, Shim H. Effects of an Internet-based intervention on plasma glucose levels in patients with type 2 diabetes. J Nurs Care Qual. 2005;20(4):335-340. [pmid: 16177585].
78 Kim HS, Jeong HS. A nurse short message service by cellular phone in type-2 diabetic patients for six months. J Clin Nurs. 2007;16(6):1082-1087. [pmid: 17518883].
79 Kosma M, Cardinal BJ, McCubbin JA. A pilot study of a web-based physical activity motivational program for adults with physical disabilities. Disabil Rehabil. 2005;27(23):1435-1442. [pmid: 16418058].
80 Laplante-Levesque A, Pichora-Fuller KM, Gagne J. Providing an internet-based audiological counselling programme to new hearing aid users: a qualitative study. Int J Audiol. 2006;45(12):697-706. [pmid: 17132558].
81 Liu C, Yeh Y, Lee T, Li Y. Observations on online services for diabetes management. Diabetes Care. 2005;28(11):2807-2808. [pmid: 16249564].
82 Lober WB, Zierler B, Herbaugh A, et al. Barriers to the use of a personal health record by an elderly population. AMIA Annu Symp Proc. 2006;Annual Symposium Proceedings/AMIA Symposium.:514–518.
83 Ralston JD, Revere D, Robins LS, Goldberg HI. Patients' experience with a diabetes support programme based on an interactive electronic medical record: qualitative study. BMJ. 2004;328(7449):1159. [pmid: 15142919].
84 Reed K, Lehmann ED. Website review: diabetes insight—www.diabetes-insight.info. Diabetes Technol Ther. 2005b;7(3):573-580. [pmid: 15929693].
85 Schärer LO, Hartweg V, Valerius G, et al. Life charts on a palmtop computer: first results of a feasibility study with an electronic diary for bipolar patients. Bipolar Disord. 2002;4(Suppl 1):107-108. [pmid: 12479693].
86 Sciamanna CN, Novak SP, Houston TK, Gramling R, Marcus BH. Visit satisfaction and tailored health behavior communications in primary care. Am J Prev Med. 2004;26(5):426-430. [pmid: 15165659].
87 Shaw BR, McTavish F, Hawkins R, Gustafson DH, Pingree S. Experiences of women with breast cancer: exchanging social support over the CHESS computer network. J Health Commun. 2000;5(2):135-159. [pmid: 11010346].
88 Skeels MM, Kurth A, Clausen M, Severynen A, Garcia-Smith H. CARE+ user study: usability and attitudes towards a tablet pc computer counseling tool for HIV+ men and women. AMIA Annu Symp Proc. 2006;Annual Symposium Proceedings/AMIA Symposium.:729–733.
89 Smaglik P, Hawkins RP, Pingree S, Gustafson DH, Boberg E, Bricker E. The quality of interactive computer use among HIV-infected individuals. J Health Commun. 1998;3(1):53-68. [pmid: 10947374].
90 van den Brink JL, Moorman PW, de Boer MF, van Bemmel JH, Pruyn JFA, Verwoerd CDA. An information system to support the care for head and neck cancer patients. Support Care Cancer. 2003;11(7):452-459. [pmid: 12707835].
91 van't Riet A, Berg M, Hiddema F, Sol K. Meeting patients' needs with patient information systems: potential benefits of qualitative research methods. Int J Med Inf. 2001;64(1):1-14.
92 Yeh YT, Chiu YT, Liu CT, Wu SJ, Lee TI. Development and evaluation of an integrated patient-oriented education management system for diabetes. Stud Health Technol Inform. 2006;122:172-175. [pmid: 17102242].
93 Zimmerman L, Barnason S, Nieveen J, Schmaderer M. Symptom management intervention in elderly coronary artery bypass graft patients. Outcomes Manag. 2004;8(1):5-12. [pmid: 14740578].
94 Andersson NB, Hanson E, Magnusson L. Views of family carers and older people of information technology. Br J Nurs. 2002;11(12):827-831. [pmid: 12131833].
95 Gerbert B, Berg-Smith S, Mancuso M, et al. Using innovative video doctor technology in primary care to deliver brief smoking and alcohol intervention. Health Promot Pract. 2003;4(3):249-261. [pmid: 14610995].
96 Holman RR, Smale AD, Pemberton E, Riefflin A, Nealon JL. Randomized controlled pilot trial of a hand-held patient-oriented, insulin regimen optimizer. Med Inform (Lond). 1996;21(4):317-326. [pmid: 9179835].
97 Kenwright M, Marks IM. Computer-aided self-help for phobia/panic via internet at home: a pilot study. Br J Psychiatry. 2004;184:448-449. [pmid: 15123511].
98 Kressig RW, Echt KV. Exercise prescribing: computer application in older adults. Gerontologist. 2002;42(2):273-277. [pmid: 11914468].
99 McDaniel AM, Hutchison S, Casper GR, Ford RT, Stratton R, Rembusch M. Usability testing and outcomes of an interactive computer program to promote smoking cessation in low income women. Proc AMIA Symp. 2002;Annual Symposium.:509–513.
100 McPherson AC, Glazebrook C, Forster D, James C, Smyth A. A randomized, controlled trial of an interactive educational computer package for children with asthma. Pediatrics. 2006;117(4):1046-1054. [pmid: 16585298].
101 Sciamanna CN, Ford DE, Flynn JA, Langford C. An evidence-based interactive computer program to assist physicians in counseling smokers to quit. MD Comput. 1999;16(5):54-60. [pmid: 10570612].
102 Sciamanna CN, Harrold LR, Manocchia M, Walker NJ, Mui S. The effect of web-based, personalized, osteoarthritis quality improvement feedback on patient satisfaction with osteoarthritis care. Am J Med Qual. 2005;20(3):127-137. [pmid: 15951518].
103 Kaufman DR, Starren J, Patel VL, et al. A cognitive framework for understanding barriers to the productive use of a diabetes home telemedicine system. AMIA Annu Symp Proc. 2003a;Annual Symposium Proceedings/AMIA Symposium.:356–360.
104 Nielsen J. Usability Engineering. San Francisco, CA: Morgan Kaufmann Publishers; 1993.
105 Kirakowski J, Claridge N. The Website Analysis and Measurement Inventory: WAMMI. http://www.wammi.com/. Accessed 24 Jun, 2008.
106 Artinian NT, Harden JK, Kronenberg MW, et al. Pilot study of a Web-based compliance monitoring device for patients with congestive heart failure. Heart Lung. 2003;32(4):226-233. [pmid: 12891162].
107 Taylor Y, Eliasson A, Andrada T, Kristo D, Howard R. The role of telemedicine in CPAP compliance for patients with obstructive sleep apnea syndrome. Sleep Breath. 2006;10(3):132-138. [pmid: 16565867].
108 Turnin MC, Beddok RH, Clottes JP, et al. Telematic expert system Diabeto. New tool for diet self-monitoring for diabetic patients. Diabetes Care. 1992;15(2):204-212. [pmid: 1547677].
109 Sciamanna CN, Gifford DR, Smith RJ. Design and acceptability of patient-oriented computerized diabetes care reminders for use at the point of care. Med Inform Internet Med. 2004;29(2):157-168. [pmid: 15370995].
110 Reed K, Lehmann ED. Diabetes website review: Diabetes website reviewv. Diabetes Technol Ther. 2005a;7(5):741-754. [pmid: 16241878].
111 Jan RL, Wang JY, Huang MC, Tseng SM, Su HJ, Liu LF. An internet-based interactive telemonitoring system for improving childhood asthma outcomes in Taiwan. Telemed J E Health. 2007;13(3):257-268. [pmid: 17603828].
112 Kenwright M, Marks I, Graham C, Franses A, Mataix-Cols D. Brief scheduled phone support from a clinician to enhance computer-aided self-help for obsessive-compulsive disorder: randomized controlled trial. J Clin Psychol. 2005;61(12):1499-1508. [pmid: 16173084].
113 Nguyen HQ, Carrieri-Kohlman V, Rankin SH, Slaughter R, Stulbarg MS. Is Internet-based support for dyspnea self-management in patients with chronic obstructive pulmonary disease possible? Results of a pilot study. Heart Lung. 2005;34(1):51-62. [pmid: 15647734].
114 Rodgers A, Corbett T, Bramley D, et al. Do u smoke after txt? Results of a randomised trial of smoking cessation using mobile phone text messaging. Tob Control. 2005;14(4):255-261. [pmid: 16046689].
115 Kim H. A randomized controlled trial of a nurse short-message service by cellular phone for people with diabetes. Int J Nurs Stud. 2007;44(5):687-692. [pmid: 16618486].
116 Strecher VJ, Shiffman S, West R. Moderators and mediators of a web-based computer-tailored smoking cessation program among nicotine patch users. Nicotine Tob Res. 2006;8(Suppl 1):S95-101. [pmid: 17491176].
117 Andrade ASA, McGruder HF, Wu AW, et al. A programmable prompting device improves adherence to highly active antiretroviral therapy in HIV-infected subjects with memory impairment. Clin Infect Dis. 2005;41(6):875-882. [pmid: 16107989].
118 Araki I, Hashimoto H, Kono K, Matsuki H, Yano E. Controlled trial of worksite health education through face-to-face counseling vs. e-mail on drinking behavior modification. J Occup Health. 2006;48(4):239-245. [pmid: 16902267].
119 Barnason S, Zimmerman L, Nieveen J, Schmaderer M, Carranza B, Reilly S. Impact of a home communication intervention for coronary artery bypass graft patients with ischemic heart failure on self-efficacy, coronary disease risk factor modification, and functioning. Heart Lung. 2003;32(3):147-158. [pmid: 12827099].
120 Barnason S, Zimmerman L, Nieveen J, Hertzog M. Impact of a telehealth intervention to augment home health care on functional and recovery outcomes of elderly patients undergoing coronary artery bypass grafting. Heart Lung. 2006;35(4):225-233. [pmid: 16863894].
121 Barrera M Jr., Glasgow RE, McKay HG, Boles SM, Feil EG. Do Internet-based support interventions change perceptions of social support?: An experimental trial of approaches for supporting diabetes self-management. Am J Community Psychol. 2002;30(5):637-654. [pmid: 12188054].
122 Block G, Wakimoto P, Metz D, et al. A randomized trial of the Little by Little CD-ROM: demonstrated effectiveness in increasing fruit and vegetable intake in a low-income population. Prev Chronic Dis. 2004;1(3):A08.
123 Cho JH, Chang SA, Kwon HS, et al. Long-term effect of the Internet-based glucose monitoring system on HbA1c reduction and glucose stability: a 30-month follow-up study for diabetes management with a ubiquitous medical care system. Diabetes Care. 2006;29(12):2625-2631. [pmid: 17130195].
124 Christensen H, Griffiths KM, Jorm AF. Delivering interventions for depression by using the internet: randomised controlled trial. BMJ. 2004;328(7434):265. [pmid: 14742346].
125 Franklin VL, Waller A, Pagliari C, Greene SA. A randomized controlled trial of Sweet Talk, a text-messaging system to support young people with diabetes. Diabet Med. 2006;23(12):1332-1338. [pmid: 17116184].
126 Frenn M, Malin S, Brown RL, et al. Changing the tide: an Internet/video exercise and low-fat diet intervention with middle-school students. Applied nursing research : ANR. 2005;18(1):13-21. [pmid: 15812731].
127 Green B, et al. Effectiveness of Home Blood Pressure Monitoring, Web Communication, and Pharmacist Care on Hypertension Control. JAMA. 2008;299(24):2857-2867. [pmid: 18577730].
128 Guendelman S, Meade K, Benson M, Chen YQ, Samuels S. Improving asthma outcomes and self-management behaviors of inner-city children: a randomized trial of the Health Buddy interactive device and an asthma diary. Arch Pediatr Adolesc Med. 2002;156(2):114-120. [pmid: 11814370].
129 Gustafson DH, Hawkins R, Boberg E, et al. Impact of a patient-centered, computer-based health information/support system. Am J Prev Med. 1999;16(1):1-9. [pmid: 9894548].
130 Joseph CLM, Peterson E, Havstad S, et al. A web-based, tailored asthma management program for urban African-American high school students. Am J Respir Crit Care Med. 2007;175(9):888-895. [pmid: 17290041].
131 Kim C, Kang D. Utility of a Web-based intervention for individuals with type 2 diabetes: the impact on physical activity levels and glycemic control. Cin Comput Inform Nurs. 2006a;24(6):337-345.
132 Kwon HS, Cho JH, Kim HS, et al. Establishment of blood glucose monitoring system using the internet. Diabetes Care. 2004;27(2):478-483. [pmid: 14747232].
133 LaFramboise LM, Todero CM, Zimmerman L, Agrawal S. Comparison of Health Buddy with traditional approaches to heart failure management. Fam Community Health. 2003;26(4):275-288. [pmid: 14528134].
134 Levetan CS, Dawn KR, Robbins DC, Ratner RE. Impact of computer-generated personalized goals on HbA(1c). Diabetes Care. 2002;25(1):2-8. [pmid: 11772893].
135 Noel HC, Vogel DC, Erdos JJ, Cornwall D, Levin F. Home telehealth reduces healthcare costs. Telemed J E Health. 2004;10(2):170-183. [pmid: 15319047].
136 Rogers MAM, Small D, Buchan DA, et al. Home monitoring service improves mean arterial pressure in patients with essential hypertension: a randomized, controlled trial. Ann Intern Med. 2001;134(11):1024–1032, I1042.
137 Safren SA, Hendriksen ES, Desousa N, Boswell SL, Mayer KH. Use of an on-line pager system to increase adherence to antiretroviral medications. AIDS Care. 2003;15(6):787-793. [pmid: 14617500].
138 Shegog R, Bartholomew LK, Parcel GS, Sockrider MM, Masse L, Abramson SL. Impact of a computer-assisted education program on factors related to asthma self-management behavior. JAMIA. 2001;8(1):49-61. [pmid: 11141512].
139 Southard BH, Southard DR, Nuckolls J. Clinical trial of an Internet-based case management system for secondary prevention of heart disease. J Cardiopulm Rehabil. 2003;23(5):341-348. [pmid: 14512778].
140 Stuart GW, Laraia MT, Ornstein SM, Nietert PJ. An interactive voice response system to enhance antidepressant medication compliance. Top Health Inf Manage. 2003;24(1):15-20. [pmid: 12674391].
141 Winzelberg AJ, Classen C, Alpers GW, et al. Evaluation of an internet support group for women with primary breast cancer. Cancer. 2003;97(5):1164-1173. [pmid: 12599221].
142 Albisser AM, Harris RI, Albisser JB, Sperlich M. The impact of initiatives in education, self-management training, and computer-assisted self-care on outcomes in diabetes disease management. Diabetes Technol Ther. 2001;3(4):571-579. [pmid: 11911169].
143 Andersson G, Bergstrom J, Hollandare F, Carlbring P, Kaldo V, Ekselius L. Internet-based self-help for depression: randomised controlled trial. Br J Psychiatry. 2005;187:456-461. [pmid: 16260822].
144 Chan DS, Callahan CW, Sheets SJ, Moreno CN, Malone FJ. An Internet-based store-and-forward video home telehealth system for improving asthma outcomes in children. Am J Health-Syst Pharm. 2003;60(19):1976-1981. [pmid: 14531243].
145 Durso SC, Wendel I, Letzt AM, Lefkowitz J, Kaseman DF, Seifert RF. Older adults using cellular telephones for diabetes management: a pilot study. Medsurg Nurs. 2003;12(5):313-317. [pmid: 14608688].
146 Estabrooks PA, Nelson CC, Xu S, et al. The frequency and behavioral outcomes of goal choices in the self-management of diabetes. Diabetes Educ. 2005;31(3):391-400. [pmid: 15919639].
147 Ewald S, vor dem Esche J, Uen S, Neikes F, Vetter H, Mengden T. Relationship between the frequency of blood pressure self-measurement and blood pressure reduction with antihypertensive therapy : results of the OLMETEL (OLMEsartan TELemonitoring blood pressure) study. Clin Drug Invest. 2006;26(8):439-446.
148 Glasgow RE, Toobert DJ. Brief, computer-assisted diabetes dietary self-management counseling: effects on behavior, physiologic outcomes, and quality of life. Med Care. 2000;38(11):1062-1073. [pmid: 11078048].
149 Robertson L, Smith M, Castle D, Tannenbaum D. Using the Internet to enhance the treatment of depression. Australas. 2006;14(4):413-417.
150 Safren S. Internet paging system helps improve adherence. Counseling is combined with reminders. Aids Alert. 2002;17(9):118-119. [pmid: 12236200].
151 Woodruff SI, Edwards CC, Conway TL, Elliott SP. Pilot test of an Internet virtual world chat room for rural teen smokers. J Adolesc Health. 2001;29(4):239-243. [pmid: 11587907].
152 Yon BA, Johnson RK, Harvey-Berino J, Gold BC, Howard AB. Personal digital assistants are comparable to traditional diaries for dietary self-monitoring during a weight loss program. J Behav Med. 2007;30(2):165-175. [pmid: 17216341].
153 La Porta M, Hagood H, Kornfeld J, Treiman K. Evaluating the NCI's Cancer Information Service Contact Centers: meeting and exceeding the expectations of the public. J Cancer Educ. 2007a;22(1 Suppl):S18-25.
154 Stead WW, Haynes RB, Fuller S, et al. Designing medical informatics research and library—resource projects to increase what is learned. JAMIA. 1994;1(1):28-33. [pmid: 7719785].
155 Bell KM. Report to the Office of the National Coordinator for Health Information Technology on Defining Key Health Information Technology Terms Washington, DC: The National Alliance for Health Information Technology; April 28, 2008.
156 Hill W, Weinert C, Cudney S. Influence of a computer intervention on the psychological status of chronically ill rural women: preliminary results. Nurs Res. 2006;55(1):34-42. [pmid: 16439927].
157 Brennan PF, Moore SM, Bjornsdottir G, Jones J, Visovsky C, Rogers M. HeartCare: an Internet-based information and support system for patient home recovery after coronary artery bypass graft (CABG) surgery. J Adv Nurs. 2001;35(5):699-708. [pmid: 11529972].
158 La Porta M, Hagood H, Patt J, Hodorowski JK, Treiman K. The NCI's Cancer Information Service: meeting the public's cancer information needs via the internet. J Cancer Educ. 2007b;22(1 Suppl):S26-34.
159 Meigs JB, Cagliero E, Dubey A, et al. A controlled trial of web-based diabetes disease management: the MGH diabetes primary care improvement project. Diabetes Care. 2003;26(3):750-757. [pmid: 12610033].
160 Joseph AM. Care Coordination and Telehealth Technology in Promoting Self-Management Among Chronically Ill Patients. Telemed J E Health. 2006;12(2):156-159. [pmid: 16620170].
161 Gustafson DH, Hawkins RP, Boberg EW, et al. CHESS: ten years of research and development in consumer health informatics for broad populations, including the underserved. Medinfo. 2001;10(Pt 2):1459-1563.
162 Holbrook A, Labiris R, Goldsmith CH, Ota K, Harb S, Sebaldt RJ. Influence of decision aids on patient preferences for anticoagulant therapy: a randomized trial. Cmaj. 2007;176(11):1583-1587. [pmid: 17515584].
163 Critical Appraisal Skills Programme (CASP): 10 Questions to Help You Make Sense of Qualitative Research: National CASP Collaboration for Qualitative Methodologies; 2002.
164 Stead WW. Matching the level of evaluation to a project's stage of development. JAMIA. 1996;3(1):92-94. [pmid: 8750393].
165 Demiris G, Finkelstein SM, Speedie SM. Considerations for the design of a Web-based clinical monitoring and educational system for elderly patients. JAMIA. 2001;8(5):468-472. [pmid: 11522767].
166 Berwick DM. Continuous improvement as an ideal in health care. N Engl J Med. 1989;320(1):53-56. [pmid: 2909878].