# Acknowledgments

The research team would like to express our regard and appreciation for the efforts of Andrew Hamilton, MLS, for database searching; Kimberly Peterson, M.S., and Lakshmi Harinath, M.D., MPH, for data abstraction assistance; Roger Chou, M.D., for oversight and guidance; Janna Kimel and Alia Broman for program support; and everyone else who shared support and ideas throughout the development of this report. We would also like to offer special thanks to Teresa Zayas Cabán, Ph.D., of the Agency for Healthcare Research and Quality for her contributions as our Task Order Officer.