# Conclusions

The findings from our evidence review on the barriers and drivers to the use of interactive consumer health IT by the elderly, chronically ill, and underserved were derived from our summarization of papers that met our inclusion criteria and quality standards (Appendix H *). These papers were reviewed according to each of our key questions on the level of use of the technology, the usability and usefulness of the technology, the barriers and drivers to the use of the technology, and the outcomes from the use of the technology. We found that it was important to characterize and specify the technology components, intended use, care protocols, content and system environment in order to interpret evidence from disparate technologies, populations, and implementations. The barriers to consumers' use of interactive consumer health IT were heavily influenced by unreliable and difficult to use technology. This was partially due to many of the studies using early stage system prototypes, as is typical for a relatively new field. Few of the studies we reviewed were specifically designed to compare the elderly, chronically ill, or underserved to the general population. But in general, we did find that several types of interactive consumer health IT were usable and effective in many settings and with all of our populations of interest. We saw that convenience and ease-of-use were important drivers of system use, especially if the interventions could be delivered on technologies users already had and interacted with on a daily basis. It was critical that data entry not be cumbersome and that the intervention fit into the user's daily routine. Perceived benefit, system trust, anonymity for sensitive health conditions, and rapid clinician feedback were also important factors influencing the successful use of interactive consumer health IT.

* Appendixes and Evidence Tables cited in this report are available electronically at http://www.ahrq.gov/clinic/tp/hitbartp.htm

The most important and consistent finding regarding the effectiveness of these technology interventions was that it was important that the systems provide a complete feedback loop that included some assessment of current patient status, interpretation of this status information in light of established treatment goals or plans, and communication back the patient with tailored recommendations or advice. Interactive consumer health IT that provided only one or a subset of these functions were less consistently effective.

The systems described in the studies we examined depended on active engagement of patients and involvement of health professionals, supported by the specific technology interventions. Questions remain as to (a) the optimal frequency of use of the system by the patient, which is likely to be condition specific; (b) the optimal frequency of use or degree of involvement by the health professionals; (c) whether their success depends on repeated modification of the patient's treatment regimen or simply ongoing assistance with applying a static treatment plan. Perhaps most challenging, these systems shift the locus of care away from traditional physician office visits and many of them involve the participation of a multidisciplinary health care team; it is difficult to support these activities financially under current episode-based, fee-for-service health care reimbursement mechanisms.